# Appendixes

Appendix A Exact Search Strings

Appendix B Evidence Tables

Appendix C Quality Assessment – Systematic Reviews

Appendix D Quality Assessment – RCTs

Appendix E Quality Assessment – Observational Studies

Appendix F Peer Reviewers

Appendix G Excluded Studies