# Acronyms and Abbreviations

3MS: Modified Mini-Mental State Examination
AA: Arachidonic acid
AACD: Aging-associated cognitive decline
AAMI: Age-associated memory impairment
ABI: Ankle-brachial index
ACE: Angiotensin 1 converting enzyme
ACTIVE: Advanced Cognitive Training for Independent and Vital Elderly trial
AD: Alzheimer’s disease
ADAPT: Alzheimer’s Disease Anti-inflammatory Prevention Trial
ADAS-Cog: Alzheimer Disease Assessment Scale-Cognitive subscale
ADEPT: Adult Development and Enrichment Project;
ADL(s): Activities of daily living
AHRQ: Agency for Healthcare Research and Quality
aMCI: Amnestic mild cognitive impairment
ApoE: Apolipoprotein E protein
APOE: Apolipoprotein E gene
APOE e4: Epsilon 4 allele of the apolipoprotein E gene
APP: Amyloid precursor protein
ARIC: Atherosclerosis Risk in Communities study
ASA: Acetylsalicylate (aspirin)
AVLT: Auditory Verbal Learning Test
BDI: Beck Depression Inventory
BMI: Body mass index
BNT: Boston Naming Test
BP: Blood pressure
BSRT: Babcock Story Recall Test
BVRT: Benton Visual Retention Test
CAD: Coronary artery disease
CASI: Cognitive Abilities Screening Instrument
CDR: Clinical Dementia Rating
CDR-SB: Clinical Dementia Rating-sum of boxes
CEE: Conjugated equine estrogen
CERAD: Consortium to Establish a Registry for Alzheimer’s Disease
CES-D: Center for Epidemiologic Studies Depression scale
CHD: Coronary heart disease
CHF: Congestive heart failure
CI: Confidence interval
CIND: Cognitive impairment not demented
CNS: Central nervous system
COPD: Chronic obstructive pulmonary disease
COWA: Controlled Oral Word Association test
CRP: C-reactive protein
CSI-D: Community Screening Interview for Dementia
CVA: Cerebrovascular accident
CVD: Cardiovascular disease
CVLT: California Verbal Learning Test
DBP: Diastolic blood pressure
DCT: Digit Cancellation Test
DHA: Docosahexaenoic acid
DHEA: Dehydroepiandosterone
DHP-CCB: Dihydropyridine-calcium channel blockers;
DM: Diabetes mellitus
DSM: Diagnostic and Statistical Manual of Mental Disorders
DSST: Digit Symbol Substitution Test
DWR: Delayed word recall
EPA: Eicosapentaenoic acid
EPC: Evidence-based Practice Center
FTT: Finger Tapping Test
GDS: Geriatric Depression Scale
GEE: Generalized estimated equations
GRADE: Grading of Recommendations Assessment, Development and Evaluation
GWAS: Genome-wide association studies
HDL: High density lipoprotein
HDL-C: High density lipoprotein cholesterol
HDRS: Hamilton Depression Rating Scale
HDDS: Hasegawa Dementia Screening Scale
HFFQ: Harvard Food Frequency Questionnaire
HMG-CoA: 3-hydroxy-3-methylglutaryl-coenzyme A
HMO: Health maintenance organization
HR: Hazard ratio
HRT: Hormone replacement therapy
HTN: Hypertension
IADL: Instrumental activities of daily living
IL-1B: Interleukin-1beta
IL-6: Interleukin-6
IQ: Intelligence quotient
JNC VII: Seventh Report of the Joint National Committee on Prevention, Detection, Evaluation, and Treatment of High Blood Pressure
LDL: Low density lipoprotein
MAC: Memory assessment clinics
MCD: Mild cognitive disorder
MCI: Mild cognitive impairment
MDD: Major depressive disorder
MeSH: Medical Subject Heading
MI: Myocardial infarction
MMSE: Mini-Mental State Examination
MNC: Mild neurocognitive disorder
MPA: Medroxyprogesterone acetate
mTICS: modified Telephone interview for cognitive status
MUFA(s): Monounsaturated fatty acid
NCEP-ATPIII: National Cholesterol Education Program 3^rd^ Adult Treatment Panel Guideline
NIH: National Institutes of Health
NIMH: National Institutes of Mental Health
NINCDS-ADRDA: National Institute of Neurological and Communicative Diseases and Stroke-Alzheimer’s Disease and Related Disorders Association
NS: Not statistically significant
NSAID(s): Non-steroidal anti-inflammatory drug(s)
NYU: New York University
OMAR: Office of Medical Applications of Research
OR: Odds ratio
PMA: Primary Mental Abilities
PUFA(s): Polyunsaturated fatty acid(s)
PVD: Peripheral vascular disease
RCT: Randomized controlled trial
RERI: Relative excess risk from interaction
RR: Relative risk
RVLT: Rey Auditory Verbal Learning Test
SBP: Systolic blood pressure
SCOPE: Study on Cognition and Prognosis in the Elderly
SD: Standard deviation
SDMT: Symbol Digit Modalities Test
SE: Standard error
SERM: Selective estrogen receptor modulator
SES: Socioeconomic status
SF-36: Medical Outcomes Study 36-Item Short Form Health Survey
SFA(s): Saturated fatty acid(s)
SHEP: Systolic Hypertension in the Elderly Program
SNP: Single-nucleotide polymorphism
SPMSQ: Short Portable Mental Status Questionnaire
STAI: State Trait Anxiety Inventory
Syst-Eur: Systolic Hypertension in Europe trial
TBI: Traumatic brain injury
TEP: Technical expert panel
TFAM: Transcription factor A, mitochondrial
TIA: Transient ischemic attack
TICS: Telephone Interview for Cognitive Status
TICS-m: Telephone Interview for Cognitive Status (modified version)
TNK1: Tyrosine kinase, non-receptor 1
Trails A/B: Trail Making Test Part A/B
Trails B: Trail Making Test Part B
VA: United States Department of Veterans Affairs
VAD: Vascular Alzheimer’s disease
VRT: Visual Reproduction Test (immediate and delayed recall) from the Wechsler Memory Scale
WAIS: Wechsler Adult Intelligence Scale
WAIS-R: Wechsler Adult Intelligence Scale-Revised
WF: Word Fluency Test
WMD: Weighted mean difference
WMS: Wechsler Memory Scale
WMS-R: Wechsler Memory Scale-Revised