# References and Included Studies

(Note that this set of references is different from those in Appendix D and the numbers are different.)

1 Kanis JA. Assessment of fracture risk and its application to screening for postmenopausal osteoporosis: synopsis of a WHO report. WHO Study Group. Osteoporos Int. Nov. 1994;4(6):368-81. [pmid: 7696835].
2 Kanis JA, McCloskey EV, Johansson H, et al. A reference standard for the description of osteoporosis. Bone. Mar. 2008;42(3):467-75. [pmid: 18180210].
3 Kanis JA, Melton LJ 3rd, Christiansen C, et al. The diagnosis of osteoporosis. J Bone Miner Res. Aug. 1994;9(8):1137-41. [pmid: 7976495].
4 Kanis JA, Gluer CC. An update on the diagnosis and assessment of osteoporosis with densitometry. Committee of Scientific Advisors, International Osteoporosis Foundation. Osteoporos Int. 2000;11(3):192-202. [pmid: 10824234].
5 Di Stefano M, Veneto G, Malservisi S, et al. Lactose malabsorption and intolerance and peak bone mass. Gastroenterology. Jun. 2002;122(7):1793-9. [pmid: 12055586].
6 Looker AC, Wahner HW, Dunn WL, et al. Updated data on proximal femur bone mineral levels of US adults. Osteoporos Int. 1998;8(5):468-89. [pmid: 9850356].
7 Ahmad M, Flatz G. Prevalence of primary adult lactose malabsorption in Pakistan. Hum Hered. 1984;34(2):69-75. [pmid: 6745955].
8 Beyerlein L, Pohl D, Delco F, et al. Correlation between symptoms developed after the oral ingestion of 50 g lactose and results of hydrogen breath testing for lactose intolerance. Aliment Pharmacol Ther. Apr. 2008;27(8):659-65. [pmid: 18221409].
9 Bolin TD, Morrison RM, Steel JE, et al. Lactose intolerance in Australia. Med J Aust. Jun 27. 1970;1(26):1289-92. [pmid: 5449513].
10 Bujanover Y, Katz A, Peled Y, et al. Lactose malabsorption in Israeli children. Isr J Med Sci. Jan. 1985;21(1):32-5. [pmid: 3972555].
11 Burgio GR, Flatz G, Barbera C, et al. Prevalence of primary adult lactose malabsorption and awareness of milk intolerance in Italy. Am J Clin Nutr. Jan. 1984;39(1):100-4. [pmid: 6691285].
12 Farup PG, Monsbakken KW, Vandvik PO. Lactose malabsorption in a population with irritable bowel syndrome: prevalence and symptoms. A case-control study. Scand J Gastroenterol. Jul. 2004;39(7):645-9. [pmid: 15370685].
13 Garza C, Scrimshaw NS. Relationship of lactose intolerance to milk intolerance in young children. Am J Clin Nutr. Feb. 1976;29(2):192-6. [pmid: 946382].
14 Hermans MM, Brummer RJ, Ruijgers AM, et al. The relationship between lactose tolerance test results and symptoms of lactose intolerance. Am J Gastroenterol. Jun. 1997;92(6):981-4. [pmid: 9177514].
15 Ladas SD, Katsiyiannaki-Latoufi E, Raptis SA. Lactose maldigestion and milk intolerance in healthy Greek schoolchildren. Am J Clin Nutr. Mar. 1991;53(3):676-80. [pmid: 2000821].
16 Leis R, Tojo R, Pavon P, et al. Prevalence of lactose malabsorption in Galicia. J Pediatr Gastroenterol Nutr. Sep. 1997;25(3):296-300. [pmid: 9285380].
17 Maggi R, Sayagues B, Fernandez A, et al. Lactose malabsorption and intolerance in Uruguayan population by breath hydrogen test (H2). J Pediatr Gastroenterol Nutr. May–Jun. 1987;6(3):373-6. [pmid: 3501460].
18 Newcomer AD, McGill DB. Disaccharidase activity in the small intestine: prevalence of lactase deficiency in 100 healthy subjects. Gastroenterology. Dec. 1967;53(6):881-9. [pmid: 6064999].
19 Rosado JL, Gonzalez C, Valencia ME, et al. Lactose maldigestion and milk intolerance: a study in rural and urban Mexico using physiological doses of milk. J Nutr. Jul. 1994;124(7):1052-9. [pmid: 8027855].
20 Seakins JM, Elliott RB, Quested CM, et al. Lactose malabsorption in Polynesian and white children in the south west Pacific studied by breath hydrogen technique. Br Med J (Clin Res Ed). Oct 10. 1987;295(6603):876-8.
21 Segal I, Gagjee PP, Essop AR, et al. Lactase deficiency in the South African black population. Am J Clin Nutr. Dec. 1983;38(6):901-5. [pmid: 6650448].
22 Socha J, Ksiazyk J, Flatz G, et al. Prevalence of primary adult lactose malabsorption in Poland. Ann Hum Biol. Jul–Aug. 1984;11(4):311-6. [pmid: 6465837].
23 Ting CW, Hwang B, Wu TC. Developmental changes of lactose malabsorption in normal Chinese children: a study using breath hydrogen test with a physiological dose of lactose. J Pediatr Gastroenterol Nutr. Nov–Dec. 1988;7(6):848-51. [pmid: 3199271].
24 Vernia P, Marinaro V, Argnani F, et al. Self-reported milk intolerance in irritable bowel syndrome: what should we believe?. Clin Nutr. Oct. 2004;23(5):996-1000. [pmid: 15380888].
25 Wang YG, Yan YS, Xu JJ, et al. Prevalence of primary adult lactose malabsorption in three populations of northern China. Hum Genet. 1984;67(1):103-6. [pmid: 6235167].
26 Woteki CE, Weser E, Young EA. Lactose malabsorption in Mexican-American adults. Am J Clin Nutr. Apr. 1977;30(4):470-5. [pmid: 851073].
27 Woteki CE, Weser E, Young EA. Lactose malabsorption in Mexican-American children. Am J Clin Nutr. Jan. 1976;29(1):19-24. [pmid: 946157].
28 Yang Y, He M, Cui H, et al. The prevalence of lactase deficiency and lactose intolerance in Chinese children of different ages. Chin Med J (Engl). Dec. 2000;113(12):1129-32. [pmid: 11776151].
29 Enattah N, Pekkarinen T, Valimaki MJ, et al. Genetically defined adult-type hypolactasia and self-reported lactose intolerance as risk factors of osteoporosis in Finnish postmenopausal women. Eur J Clin Nutr. Oct. 2005;59(10):1105-11. [pmid: 16015262].
30 Johnson JD, Simoons FJ, Hurwitz R, et al. Lactose malabsorption among adult Indians of the Great Basin and American Southwest. Am J Clin Nutr. Mar. 1978;31(3):381-7. [pmid: 580162].
31 Johnson RC, Cole RE, Ahern FM, et al. Reported lactose tolerance of members of various racial/ethnic groups in Hawaii and Asia. Behav Genet. Jul. 1980;10(4):377-85. [pmid: 6894234].
32 Kokkonen J, Tikkanen S, Savilahti E. Residual intestinal disease after milk allergy in infancy. J Pediatr Gastroenterol Nutr. Feb. 2001;32(2):156-61. [pmid: 11321385].
33 Paajanen L, Korpela R, Tuure T, et al. Cow milk is not responsible for most gastrointestinal immune-like syndromes--evidence from a population-based study. Am J Clin Nutr. Dec. 2005;82(6):1327-35. [pmid: 16332667].
34 Saberi-Firoozi M, Khademolhosseini F, Mehrabani D, et al. Subjective lactose intolerance in apparently healthy adults in southern Iran: Is it related to irritable bowel syndrome?. Indian J Med Sci. Nov. 2007;61(11):591-7. [pmid: 18025745].
35 Nicklas TA, Qu H, Hughes SO, et al. Prevalence of self-reported lactose intolerance in a multi-ethnic sample of adults. Nutrition Today. 2009;44(5):222-7.
36 Barr RG, Levine MD, Watkins JB. Recurrent abdominal pain of childhood due to lactose intolerance. N Engl J Med. Jun 28. 1979;300(26):1449-52. [pmid: 449886].
37 Bayoumi RA, Flatz SD, Kuhnau W, et al. Beja and Nilotes: nomadic pastoralist groups in the Sudan with opposite distributions of the adult lactase phenotypes. Am J Phys Anthropol. Jun. 1982;58(2):173-8. [pmid: 6810704].
38 Bayoumi RA, Saha N, Salih AS, et al. Distribution of the lactase phenotypes in the population of the Democratic Republic of the Sudan. Hum Genet. 1981;57(3):279-81. [pmid: 6788676].
39 Carroccio A, Montalto G, Cavera G, et al. Lactose intolerance and self-reported milk intolerance: relationship with lactose maldigestion and nutrient intake. Lactase Deficiency Study Group. J Am Coll Nutr. Dec. 1998;17(6):631-6. [pmid: 9853544].
40 Czeizel A, Flatz G, Flatz SD. Prevalence of primary adult lactose malabsorption in Hungary. Hum Genet. 1983;64(4):398-401. [pmid: 6618492].
41 Debrot KF. Lactose absorption and consumption in Curacao schoolchildren. Am J Clin Nutr. Oct. 1990;52(4):682-4. [pmid: 2403060].
42 Newcomer AD, McGill DB. Irritable bowel syndrome. Role of lactase deficiency. Mayo Clin Proc. May. 1983;58(5):339-41. [pmid: 6843184].
43 Ramirez FC, Lee K, Graham DY. All lactase preparations are not the same: results of a prospective, randomized, placebo-controlled trial. Am J Gastroenterol. Apr. 1994;89(4):566-70. [pmid: 8147360].
44 Rao DR, Bello H, Warren AP, et al. Prevalence of lactose maldigestion. Influence and interaction of age, race, and sex. Dig Dis Sci. Jul. 1994;39(7):1519-24. [pmid: 8026265].
45 Schirru E, Corona V, Usai-Satta P, et al. Decline of lactase activity and c/t-13910 variant in Sardinian childhood. J Pediatr Gastroenterol Nutr. Oct. 2007;45(4):503-6. [pmid: 18030226].
46 Tadesse K, Yuen RC, Leung DT. Late-onset hypolactasia in Hong Kong school children. Ann Trop Paediatr. 1991;11(3):289-92. [pmid: 1719930].
47 Tolliver BA, Herrera JL, DiPalma JA. Evaluation of patients who meet clinical criteria for irritable bowel syndrome. Am J Gastroenterol. Feb. 1994;89(2):176-8. [pmid: 8304298].
48 Webster RB, DiPalma JA, Gremse DA. Lactose maldigestion and recurrent abdominal pain in children. Dig Dis Sci. Jul. 1995;40(7):1506-10. [pmid: 7628274].
49 Scrimshaw NS, Murray EB. The acceptability of milk and milk products in populations with a high prevalence of lactose intolerance. Am J Clin Nutr. Oct. 1988;48(4 Suppl):1079-159. [pmid: 3140651].
50 Ferguson A, MacDonald DM, Brydon WG. Prevalence of lactase deficiency in British adults. Gut. Feb. 1984;25(2):163-7. [pmid: 6693044].
51 Lebenthal E, Rossi TM, Nord KS, et al. Recurrent abdominal pain and lactose absorption in children. Pediatrics. Jun. 1981;67(6):828-32. [pmid: 7195004].
52 Pfefferkorn MD, Fitzgerald JF, Croffie JM, et al. Lactase deficiency: not more common in pediatric patients with inflammatory bowel disease than in patients with chronic abdominal pain. J Pediatr Gastroenterol Nutr. Sep. 2002;35(3):339-43. [pmid: 12352524].
53 Welsh JD. Isolated lactase deficiency in humans: report on 100 patients. Medicine (Baltimore). Jul. 1970;49(4):257-77. [pmid: 5426744].
54 Swallow DM. Genetics of lactase persistence and lactose intolerance. Annu Rev Genet. 2003;37:197-219. [pmid: 14616060].
55 Almon R, Engfeldt P, Tysk C, et al. Prevalence and trends in adult-type hypolactasia in different age cohorts in Central Sweden diagnosed by genotyping for the adult-type hypolactasia-linked LCT -13910C > T mutation. Scand J Gastroenterol. Feb. 2007;42(2):165-70. [pmid: 17327935].
56 Anthoni S, Elg P, Haahtela T, et al. Should milk-specific IgE antibodies be measured in adults in primary care?. Scand J Prim Health Care. 2008;26(4):197-202. [pmid: 18609255].
57 Enattah N, Valimaki VV, Valimaki MJ, et al. Molecularly defined lactose malabsorption, peak bone mass and bone turnover rate in young finnish men. Calcif Tissue Int. Dec. 2004;75(6):488-93. [pmid: 15365657].
58 Gugatschka M, Hoeller A, Fahrleitner-Pammer A, et al. Calcium supply, bone mineral density and genetically defined lactose maldigestion in a cohort of elderly men. J Endocrinol Invest. Jan. 2007;30(1):46-51. [pmid: 17318022].
59 Lehtimaki T, Hemminki J, Rontu R, et al. The effects of adult-type hypolactasia on body height growth and dietary calcium intake from childhood into young adulthood: a 21-year follow-up study--the Cardiovascular Risk in Young Finns Study. Pediatrics. Oct. 2006;118(4):1553-9. [pmid: 17015546].
60 Piepoli A, Schirru E, Mastrorilli A, et al. Genotyping of the lactase-phlorizin hydrolase c/t-13910 polymorphism by means of a new rapid denaturing high-performance liquid chromatography-based assay in healthy subjects and colorectal cancer patients. J Biomol Screen. Aug. 2007;12(5):733-9. [pmid: 17478481].
61 Rasinpera H, Savilahti E, Enattah NS, et al. A genetic test which can be used to diagnose adult-type hypolactasia in children. Gut. Nov. 2004;53(11):1571-6. [pmid: 15479673].
62 Woo J, Lau W, Xu L, et al. Milk supplementation and bone health in young adult chinese women. J Womens Health (Larchmt). Jun. 2007;16(5):692-702. [pmid: 17627404].
63 Baran D, Sorensen A, Grimes J, et al. Dietary modification with dairy products for preventing vertebral bone loss in premenopausal women: a three-year prospective study. J Clin Endocrinol Metab. Jan. 1990;70(1):264-70. [pmid: 2294135].
64 Buchowski MS, Semenya J, Johnson AO. Dietary calcium intake in lactose maldigesting intolerant and tolerant African-American women. J Am Coll Nutr. Feb. 2002;21(1):47-54. [pmid: 11838887].
65 Enattah NS, Sulkava R, Halonen P, et al. Genetic variant of lactase-persistent C/T-13910 is associated with bone fractures in very old age. J Am Geriatr Soc. Jan. 2005;53(1):79-82. [pmid: 15667380].
66 Gugatschka M, Dobnig H, Fahrleitner-Pammer A, et al. Molecularly-defined lactose malabsorption, milk consumption and anthropometric differences in adult males. QJM. Dec. 2005;98(12):857-63. [pmid: 16299058].
67 Kull M, Kallikorm R, Lember M. Impact of molecularly defined hypolactasia, self-perceived milk intolerance and milk consumption on bone mineral density in a population sample in Northern Europe. Scand J Gastroenterol. 2009;44(4):415-21. [pmid: 19039706].
68 Obermayer-Pietsch BM, Bonelli CM, Walter DE, et al. Genetic predisposition for adult lactose intolerance and relation to diet, bone density, and bone fractures. J Bone Miner Res. Jan. 2004;19(1):42-7. [pmid: 14753735].
69 Obermayer-Pietsch BM, Gugatschka M, Reitter S, et al. Adult-type hypolactasia and calcium availability: decreased calcium intake or impaired calcium absorption?. Osteoporos Int. Apr. 2007;18(4):445-51. [pmid: 17103297].
70 Laaksonen MM, Mikkila V, Rasanen L, et al. Genetic lactase non-persistence, consumption of milk products and intakes of milk nutrients in Finns from childhood to young adulthood. Br J Nutr. Jul. 2009;102(1):8-17. [pmid: 19138442].
71 Goulding A, Taylor RW, Keil D, et al. Lactose malabsorption and rate of bone loss in older women. Age Ageing. Mar. 1999;28(2):175-80. [pmid: 10350415].
72 Horowitz M, Wishart J, Mundy L, et al. Lactose and calcium absorption in postmenopausal osteoporosis. Arch Intern Med. Mar. 1987;147(3):534-6. [pmid: 3827431].
73 Larson NI, Neumark-Sztainer D, Harnack L, et al. Calcium and dairy intake: Longitudinal trends during the transition to young adulthood and correlates of calcium intake. J Nutr Educ Behav. Jul–Aug. 2009;41(4):254-60. [pmid: 19508930].
74 Bohmer CJ, Tuynman HA. The effect of a lactose-restricted diet in patients with a positive lactose tolerance test, earlier diagnosed as irritable bowel syndrome: a 5‐year follow-up study. Eur J Gastroenterol Hepatol. Aug. 2001;13(8):941-4. [pmid: 11507359].
75 Vernia P, Ricciardi MR, Frandina C, et al. Lactose malabsorption and irritable bowel syndrome. Effect of a long-term lactose-free diet. Ital J Gastroenterol. Apr. 1995;27(3):117-21. [pmid: 7548919].
76 Black RE, Williams SM, Jones IE, et al. Children who avoid drinking cow milk have low dietary calcium intakes and poor bone health. Am J Clin Nutr. Sep. 2002;76(3):675-80. [pmid: 12198017].
77 Kelsey JL, Browner WS, Seeley DG, et al. Risk factors for fractures of the distal forearm and proximal humerus. The Study of Osteoporotic Fractures Research Group. Am J Epidemiol. Mar 1. 1992;135(5):477-89. [pmid: 1570814].
78 Nieves JW, Grisso JA, Kelsey JL. A case-control study of hip fracture: evaluation of selected dietary variables and teenage physical activity. Osteoporos Int. May. 1992;2(3):122-7. [pmid: 1627898].
79 Wyshak G, Frisch RE, Albright TE, et al. Nonalcoholic carbonated beverage consumption and bone fractures among women former college athletes. J Orthop Res. 1989;7(1):91-9. [pmid: 2908917].
80 Cumming RG, Klineberg RJ. Case-control study of risk factors for hip fractures in the elderly. Am J Epidemiol. Mar 1. 1994;139(5):493-503. [pmid: 8154473].
81 Tavani A, Negri E, La Vecchia C. Calcium, dairy products, and the risk of hip fracture in women in northern Italy. Epidemiology. Sep. 1995;6(5):554-7. [pmid: 8562636].
82 Johnell O, Gullberg B, Kanis JA, et al. Risk factors for hip fracture in European women: the MEDOS Study. Mediterranean Osteoporosis Study. J Bone Miner Res. Nov. 1995;10(11):1802-15. [pmid: 8592959].
83 Fujiwara S, Kasagi F, Yamada M, et al. Risk factors for hip fracture in a Japanese cohort. J Bone Miner Res. Jul. 1997;12(7):998-1004. [pmid: 9199997].
84 Feskanich D, Willett WC, Stampfer MJ, et al. Milk, dietary calcium, and bone fractures in women: a 12-year prospective study. Am J Public Health. Jun. 1997;87(6):992-7. [pmid: 9224182].
85 Turner LW, Wang MQ, Fu Q. Risk factors for hip fracture among southern older women. South Med J. Jun. 1998;91(6):533-40. [pmid: 9634114].
86 Kalkwarf HJ, Khoury JC, Lanphear BP. Milk intake during childhood and adolescence, adult bone density, and osteoporotic fractures in US women. Am J Clin Nutr. Jan. 2003;77(1):257-65. [pmid: 12499350].
87 Johansson H, Oden A, Johnell O, et al. Optimization of BMD measurements to identify high risk groups for treatment--a test analysis. J Bone Miner Res. Jun. 2004;19(6):906-13. [pmid: 15190881].
88 Kanis JA, Johansson H, Oden A, et al. A meta-analysis of milk intake and fracture risk: low utility for case finding. Osteoporos Int. Jul. 2005;16(7):799-804. [pmid: 15502959].
89 Goulding A, Rockell JE, Black RE, et al. Children who avoid drinking cow’s milk are at increased risk for prepubertal bone fractures. J Am Diet Assoc. Feb. 2004;104(2):250-3. [pmid: 14760576].
90 Appleby P, Roddam A, Allen N, et al. Comparative fracture risk in vegetarians and nonvegetarians in EPIC-Oxford. Eur J Clin Nutr. Dec. 2007;61(12):1400-6. [pmid: 17299475].
91 Gugatschka M, Hoeller A, Fahrleitner-Pammer A, et al. Calcium supply, bone mineral density and genetically defined lactose maldigestion in a cohort of elderly men. J Endocrinol Invest. Jan. 2007;30(1):46-51. [pmid: 17318022].
92 Kudlacek S, Freudenthaler O, Weissboeck H, et al. Lactose intolerance: a risk factor for reduced bone mineral density and vertebral fractures?. J Gastroenterol. 2002;37(12):1014-9. [pmid: 12522532].
93 Chiu JF, Lan SJ, Yang CY, et al. Long-term vegetarian diet and bone mineral density in postmenopausal Taiwanese women. Calcif Tissue Int. Mar. 1997;60(3):245-9. [pmid: 9069160].
94 Birge SJ Jr, Keutmann HT, Cuatrecasas P, et al. Osteoporosis, intestinal lactase deficiency and low dietary calcium intake. N Engl J Med. Feb 23. 1967;276(8):445-8. [pmid: 6071242].
95 Parsons TJ, van Dusseldorp M, van der Vliet M, et al. Reduced bone mass in Dutch adolescents fed a macrobiotic diet in early life. J Bone Miner Res. Sep. 1997;12(9):1486-94. [pmid: 9286766].
96 Du XQ, Greenfield H, Fraser DR, et al. Milk consumption and bone mineral content in Chinese adolescent girls. Bone. Mar. 2002;30(3):521-8. [pmid: 11882468].
97 Rockell JE, Williams SM, Taylor RW, et al. Two-year changes in bone and body composition in young children with a history of prolonged milk avoidance. Osteoporos Int. Sep. 2005;16(9):1016-23. [pmid: 15565350].
98 Stallings VA, Oddleifson NW, Negrini BY, et al. Bone mineral content and dietary calcium intake in children prescribed a low-lactose diet. J Pediatr Gastroenterol Nutr. May. 1994;18(4):440-5. [pmid: 8071779].
99 Matlik L, Savaiano D, McCabe G, et al. Perceived milk intolerance is related to bone mineral content in 10- to 13‐year-old female adolescents. Pediatrics. Sep. 2007;120(3):e669-77. [pmid: 17766507].
100 Segal E, Dvorkin L, Lavy A, et al. Bone density in axial and appendicular skeleton in patients with lactose intolerance: influence of calcium intake and vitamin D status. J Am Coll Nutr. Jun. 2003;22(3):201-7. [pmid: 12805246].
101 Lau EM, Lynn H, Chan YH, et al. Benefits of milk powder supplementation on bone accretion in Chinese children. Osteoporos Int. Aug. 2004;15(8):654-8. [pmid: 15095035].
102 Gibbons MJ, Gilchrist NL, Frampton C, et al. The effects of a high calcium dairy food on bone health in pre‐pubertal children in New Zealand. Asia Pac J Clin Nutr. 2004;13(4):341-7. [pmid: 15563438].
103 Chan GM, Hoffman K, McMurry M. Effects of dairy products on bone and body composition in pubertal girls. J Pediatr. Apr. 1995;126(4):551-6. [pmid: 7699532].
104 Cadogan J, Eastell R, Jones N, et al. Milk intake and bone mineral acquisition in adolescent girls: randomised, controlled intervention trial. BMJ. Nov 15. 1997;315(7118):1255-60. [pmid: 9390050].
105 Bonjour JP, Carrie AL, Ferrari S, et al. Calcium-enriched foods and bone mass growth in prepubertal girls: a randomized, double-blind, placebo-controlled trial. J Clin Invest. Mar 15. 1997;99(6):1287-94. [pmid: 9077538].
106 Chevalley T, Bonjour JP, Ferrari S, et al. Skeletal site selectivity in the effects of calcium supplementation on areal bone mineral density gain: a randomized, double-blind, placebo-controlled trial in prepubertal boys. J Clin Endocrinol Metab. Jun. 2005;90(6):3342-9. [pmid: 15755866].
107 Cheng S, Lyytikainen A, Kroger H, et al. Effects of calcium, dairy product, and vitamin D supplementation on bone mass accrual and body composition in 10–12-y-old girls: a 2-y randomized trial. Am J Clin Nutr. Nov. 2005;82(5):1115-26. quiz 47–8. [pmid: 16280447].
108 Montalto M, Nucera G, Santoro L, et al. Effect of exogenous beta-galactosidase in patients with lactose malabsorption and intolerance: a crossover double-blind placebo-controlled study. Eur J Clin Nutr. Apr. 2005;59(4):489-93. [pmid: 15674309].
109 Gremse DA, Greer AS, Vacik J, et al. Abdominal pain associated with lactose ingestion in children with lactose intolerance. Clin Pediatr (Phila). May. 2003;42(4):341-5. [pmid: 12800728].
110 Suarez FL, Adshead J, Furne JK, et al. Lactose maldigestion is not an impediment to the intake of 1500 mg calcium daily as dairy products. Am J Clin Nutr. Nov. 1998;68(5):1118-22. [pmid: 9808231].
111 Suarez FL, Savaiano D, Arbisi P, et al. Tolerance to the daily ingestion of two cups of milk by individuals claiming lactose intolerance. Am J Clin Nutr. May. 1997;65(5):1502-6. [pmid: 9129483].
112 Vesa TH, Korpela RA, Sahi T. Tolerance to small amounts of lactose in lactose maldigesters. Am J Clin Nutr. Aug. 1996;64(2):197-201. [pmid: 8694020].
113 Suarez FL, Savaiano DA, Levitt MD. A comparison of symptoms after the consumption of milk or lactose‐hydrolyzed milk by people with self-reported severe lactose intolerance. N Engl J Med. Jul 6. 1995;333(1):1-4. [pmid: 7776987].
114 Johnson AO, Semenya JG, Buchowski MS, et al. Correlation of lactose maldigestion, lactose intolerance, and milk intolerance. Am J Clin Nutr. Mar. 1993;57(3):399-401. [pmid: 8438774].
115 Brand JC, Holt S. Relative effectiveness of milks with reduced amounts of lactose in alleviating milk intolerance. Am J Clin Nutr. Jul. 1991;54(1):148-51. [pmid: 2058576].
116 Rorick MH, Scrimshaw NS. Comparative tolerance of elderly from differing ethnic backgrounds to lactose-containing and lactose-free dairy drinks: a double-blind study. J Gerontol. Mar. 1979;34(2):191-6. [pmid: 374454].
117 Lin MY, Yen CL, Chen SH. Management of lactose maldigestion by consuming milk containing lactobacilli. Dig Dis Sci. Jan. 1998;43(1):133-7. [pmid: 9508514].
118 Hertzler SR, Savaiano DA. Colonic adaptation to daily lactose feeding in lactose maldigesters reduces lactose intolerance. Am J Clin Nutr. Aug. 1996;64(2):232-6. [pmid: 8694025].
119 Hertzler SR, Huynh BC, Savaiano DA. How much lactose is low lactose?. J Am Diet Assoc. Mar. 1996;96(3):243-6. [pmid: 8613657].
120 Newcomer AD, McGill DB, Thomas PJ, et al. Tolerance to lactose among lactase-deficient American Indians. Gastroenterology. Jan. 1978;74(1):44-6. [pmid: 336450].
121 Xenos K, Kyroudis S, Anagnostidis A, et al. Treatment of lactose intolerance with exogenous beta-D-galactosidase in pellet form. Eur J Drug Metab Pharmacokinet. Apr–Jun. 1998;23(2):350-5. [pmid: 9725505].
122 Cavalli-Sforza LT, Strata A. Double-blind study on the tolerance of four types of milk in lactose malabsorbers and absorbers. Hum Nutr Clin Nutr. Jan. 1987;41(1):19-30. [pmid: 3570859].
123 Nielsen OH, Schiotz PO, Rasmussen SN, et al. Calcium absorption and acceptance of low-lactose milk among children with primary lactase deficiency. J Pediatr Gastroenterol Nutr. Mar. 1984;3(2):219-23. [pmid: 6368790].
124 Rask Pedersen E, Jensen BH, Jensen HJ, et al. Lactose malabsorption and tolerance of lactose-hydrolyzed milk. A double-blind controlled crossover study. Scand J Gastroenterol. Oct. 1982;17(7):861-4. [pmid: 6818684].
125 Reasoner J, Maculan TP, Rand AG, et al. Clinical studies with low-lactose milk. Am J Clin Nutr. Jan. 1981;34(1):54-60. [pmid: 6893787].
126 Haverberg L, Kwon PH, Scrimshaw NS. Comparative tolerance of adolescents of differing ethic backgrounds to lactose-containing and lactose-free dairy drinks. I. Initial experience with a double-blind procedure. Am J Clin Nutr. Jan. 1980;33(1):17-21. [pmid: 7188826].
127 Kwon PH Jr, Rorick MH, Scrimshaw NS. Comparative tolerance of adolescents of differing ethnic backgrounds to lactose-containing and lactose-free dairy drinks. II. Improvement of a double-blind test. Am J Clin Nutr. Jan. 1980;33(1):22-6. [pmid: 7188827].
128 Cheng AH, Brunser O, Espinoza J, et al. Long-term acceptance of low-lactose milk. Am J Clin Nutr. Oct. 1979;32(10):1989-93. [pmid: 114042].
129 Lisker R, Aguilar L. Double blind study of milk lactose intolerance. Gastroenterology. Jun. 1978;74(6):1283-5. [pmid: 348553].
130 Jones DV, Latham MC, Kosikowski FV, et al. Symptom response to lactose-reduced milk in lactose-intolerant adults. Am J Clin Nutr. Jun. 1976;29(6):633-8. [pmid: 946937].
131 Stephenson LS, Latham MC. Lactose intolerance and milk consumption: the relation of tolerance to symptoms. Am J Clin Nutr. Mar. 1974;27(3):296-303. [pmid: 4405996].
132 Vesa TH, Lember M, Korpela R. Milk fat does not affect the symptoms of lactose intolerance. Eur J Clin Nutr. Sep. 1997;51(9):633-6. [pmid: 9306091].
133 Rosado JL, Solomons NW, Lisker R, et al. Enzyme replacement therapy for primary adult lactase deficiency. Effective reduction of lactose malabsorption and milk intolerance by direct addition of beta-galactosidase to milk at mealtime. Gastroenterology. Nov. 1984;87(5):1072-82. [pmid: 6434367].
134 Lybeck Sorensen K, Vergara Meersohn M, Sonne J, et al. A new type of low-lactose milk. Tolerance by lactose malabsorbers and evaluation of protein nutritional value. Scand J Gastroenterol. Nov. 1983;18(8):1063-8. [pmid: 6424228].
135 Paige DM, Bayless TM, Huang SS, et al. Lactose hydrolyzed milk. Am J Clin Nutr. Aug. 1975;28(8):818-22. [pmid: 1173737].
136 Lin MY, Dipalma JA, Martini MC, et al. Comparative effects of exogenous lactase (beta-galactosidase) preparations on in vivo lactose digestion. Dig Dis Sci. Nov. 1993;38(11):2022-7. [pmid: 8223076].
137 Unger M, Scrimshaw NS. Comparative tolerance of adolescents of differing ethnic backgrounds to alctose‐containing and lactose-free dairy drinks. I. Initial experience with a double-blind procedure. Nutr Res. 1981;1(3):227-33.
138 Jarvinen RM, Loukaskorpi M, Uusitupa MI. Tolerance of symptomatic lactose malabsorbers to lactose in milk chocolate. Eur J Clin Nutr. May. 2003;57(5):701-5. [pmid: 12771971].
139 Mustapha A, Jiang T, Savaiano DA. Improvement of lactose digestion by humans following ingestion of unfermented acidophilus milk: influence of bile sensitivity, lactose transport, and acid tolerance of Lactobacillus acidophilus. J Dairy Sci. Aug. 1997;80(8):1537-45. [pmid: 9276791].
140 Jiang T, Mustapha A, Savaiano DA. Improvement of lactose digestion in humans by ingestion of unfermented milk containing Bifidobacterium longum. J Dairy Sci. May. 1996;79(5):750-7. [pmid: 8792277].
141 Vesa TH, Marteau P, Zidi S, et al. Digestion and tolerance of lactose from yoghurt and different semi-solid fermented dairy products containing Lactobacillus acidophilus and bifidobacteria in lactose maldigesters--is bacterial lactase important?. Eur J Clin Nutr. Nov. 1996;50(11):730-3. [pmid: 8933119].
142 Lerebours E, N’Djitoyap Ndam C, Lavoine A, et al. Yogurt and fermented-then-pasteurized milk: effects of short-term and long-term ingestion on lactose absorption and mucosal lactase activity in lactase-deficient subjects. Am J Clin Nutr. May. 1989;49(5):823-7. [pmid: 2497632].
143 Martini MC, Smith DE, Savaiano DA. Lactose digestion from flavored and frozen yogurts, ice milk, and ice cream by lactase-deficient persons. Am J Clin Nutr. Oct. 1987;46(4):636-40. [pmid: 3116836].
144 Newcomer AD, Park HS, O’Brien PC, et al. Response of patients with irritable bowel syndrome and lactase deficiency using unfermented acidophilus milk. Am J Clin Nutr. Aug. 1983;38(2):257-63. [pmid: 6410897].
145 Savaiano DA, AbouElAnouar A, Smith DE, et al. Lactose malabsorption from yogurt, pasteurized yogurt, sweet acidophilus milk, and cultured milk in lactase-deficient individuals. Am J Clin Nutr. Dec. 1984;40(6):1219-23. [pmid: 6439026].
146 Briet F, Pochart P, Marteau P, et al. Improved clinical tolerance to chronic lactose ingestion in subjects with lactose intolerance: a placebo effect?. Gut. Nov. 1997;41(5):632-5. [pmid: 9414969].
147 Cappello G, Marzio L. Rifaximin in patients with lactose intolerance. Dig Liver Dis. May. 2005;37(5):316-9. [pmid: 15843080].
148 Jacobs DR Jr, Gross MD, Tapsell LC. Food synergy: an operational concept for understanding nutrition. Am J Clin Nutr. May. 2009;89(5):1543S-8S. [pmid: 19279083].
149 Jacobs DR Jr, Tapsell LC. Food, not nutrients, is the fundamental unit in nutrition. Nutr Rev. Oct. 2007;65(10):439-50. [pmid: 17972438].
150 Jacobs DR Jr, Steffen LM. Nutrients, foods, and dietary patterns as exposures in research: a framework for food synergy. Am J Clin Nutr. Sep. 2003;78(3 Suppl):508S-13S. [pmid: 12936941].
151 Perman JA, Modler S, Olson AC. Role of pH in production of hydrogen from carbohydrates by colonic bacterial flora. Studies in vivo and in vitro. J Clin Invest. Mar. 1981;67(3):643-50. [pmid: 7193687].
152 Stata Corporation. Stata base reference manual. Release 10. College Station, TX. Stata Corporation. 2007.
153 SAS Institute. SAS version 9.1.3. Chicago, Ill. SAS Institute Inc. 2008. 6 CD-ROMs.
154 Review Manager (RevMan) [computer program]. Version 5.0. Copenhagen. The Nordic Cochrane Centre, The Cochrane Collaboration. 2008.
155 Landau DA, Goldberg A, Levi Z, et al. The prevalence of gastrointestinal diseases in Israeli adolescents and its association with body mass index, gender, and Jewish ethnicity. J Clin Gastroenterol. Sep. 2008;42(8):903-9. [pmid: 18645527].
156 Montes RG, Saavedra JM, Perman JA. Relationship between methane production and breath hydrogen excretion in lactose-malabsorbing individuals. Dig Dis Sci. Mar. 1993;38(3):445-8. [pmid: 8444074].
157 Bolin TD, Davis AE. Lactose intolerance in Australian-born Chinese. Australas Ann Med. Feb. 1970;19(1):40-1. [pmid: 5505520].
158 Anthoni SR, Rasinpera HA, Kotamies AJ, et al. Molecularly defined adult-type hypolactasia among working age people with reference to milk consumption and gastrointestinal symptoms. World J Gastroenterol. Feb 28. 2007;13(8):1230-5. [pmid: 17451204].
159 Infante D, Tormo R. Risk of inadequate bone mineralization in diseases involving long-term suppression of dairy products. J Pediatr Gastroenterol Nutr. Mar. 2000;30(3):310-3. [pmid: 10749417].
160 Vatanparast H, Baxter-Jones A, Faulkner RA, et al. Positive effects of vegetable and fruit consumption and calcium intake on bone mineral accrual in boys during growth from childhood to adolescence: the University of Saskatchewan Pediatric Bone Mineral Accrual Study. Am J Clin Nutr. Sep. 2005;82(3):700-6. [pmid: 16155286].
161 Laaksonen MM, Impivaara O, Sievanen H, et al. Associations of genetic lactase non-persistence and sex with bone loss in young adulthood. Bone. May. 2009;44(5):1003-9. [pmid: 19168163].
162 Alhava EM, Jussila J, Karjalainen P, et al. Lactose malabsorption and bone mineral content. Acta Med Scand. 1977;201(4):281-3. [pmid: 576770].
163 Shaw CK. An epidemiologic study of osteoporosis in Taiwan. Ann Epidemiol. May. 1993;3(3):264-71. [pmid: 8275199].
164 Wheadon M, Goulding A, Barbezat GO, et al. Lactose malabsorption and calcium intake as risk factors for osteoporosis in elderly New Zealand women. N Z Med J. Oct 9. 1991;104(921):417-9. [pmid: 1923091].
165 Vigorita VJ, Lane M, Suda MK, et al. Differences between lactase deficient and non-lactase deficient women with spinal osteoporosis. Clin Orthop Relat Res. Feb. 1987;(215):248-53. [pmid: 3100122].
166 Honkanen R, Pulkkinen P, Jarvinen R, et al. Does lactose intolerance predispose to low bone density? A population‐based study of perimenopausal Finnish women. Bone. Jul. 1996;19(1):23-8. [pmid: 8830983].
167 Honkanen R, Kroger H, Alhava E, et al. Lactose intolerance associated with fractures of weight-bearing bones in Finnish women aged 38–57 years. Bone. Dec. 1997;21(6):473-7. [pmid: 9430235].
168 Finkenstedt G, Skrabal F, Gasser RW, et al. Lactose absorption, milk consumption, and fasting blood glucose concentrations in women with idiopathic osteoporosis. Br Med J (Clin Res Ed). Jan 18. 1986;292(6514):161-2.
169 Corazza GR, Benati G, Di Sario A, et al. Lactose intolerance and bone mass in postmenopausal Italian women. Br J Nutr. Mar. 1995;73(3):479-87. [pmid: 7766570].
170 Harma M, Alhava E. Is lactose malabsorption a risk factor in fractures of the elderly?. Ann Chir Gynaecol. 1988;77(5–6):180-3. [pmid: 3267105].
171 Lau EM, Kwok T, Woo J, et al. Bone mineral density in Chinese elderly female vegetarians, vegans, lacto‐vegetarians and omnivores. Eur J Clin Nutr. Jan. 1998;52(1):60-4. [pmid: 9481534].
172 Bauer DC, Browner WS, Cauley JA, et al. Factors associated with appendicular bone mass in older women. The Study of Osteoporotic Fractures Research Group. Ann Intern Med. May 1. 1993;118(9):657-65. [pmid: 8460853].
173 Soroko S, Holbrook TL, Edelstein S, et al. Lifetime milk consumption and bone mineral density in older women. Am J Public Health. Aug. 1994;84(8):1319-22. [pmid: 8059895].
174 Looker AC, Harris TB, Madans JH, et al. Dietary calcium and hip fracture risk: the NHANES I Epidemiologic Follow-Up Study. Osteoporos Int. Jul. 1993;3(4):177-84. [pmid: 8338972].
175 Parker TJ, Woolner JT, Prevost AT, et al. Irritable bowel syndrome: is the search for lactose intolerance justified?. Eur J Gastroenterol Hepatol. Mar. 2001;13(3):219-25. [pmid: 11293439].
176 Bohmer CJ, Tuynman HA. The clinical relevance of lactose malabsorption in irritable bowel syndrome. Eur J Gastroenterol Hepatol. Oct. 1996;8(10):1013-6. [pmid: 8930569].
177 Lisker R, Solomons NW, Perez Briceno R, et al. Lactase and placebo in the management of the irritable bowel syndrome: a double-blind, cross-over study. Am J Gastroenterol. Jul. 1989;84(7):756-62. [pmid: 2500848].
178 Unger M, Scrimshaw NS. Comparative tolerance of adults of differing ethnic backgrounds to lactose-free and lactose-containing dairy drinks. Nutr Res. 1981;1:227-33.
179 Chung M. United States. Agency for Healthcare Research and Quality., Tufts-New England Medical Center. Evidence-based Practice Center. Vitamin D and calcium : a systematic review of health outcomes. Rockville, MD. Agency for Healthcare Research and Quality. 2009.