# Executive Summary

## Introduction

Milk and milk products contain high concentrations of the disaccharide lactose (galactose and glucose linked by a beta-galactoside bond). Intestinal absorption of lactose requires that the disaccharide be hydrolyzed to its component monosaccharides, both of which are rapidly transported across the small bowel mucosa. A brush border beta-galactosidase, lactase, carries out this hydrolysis. While infants virtually always have high concentrations of lactase, sometime after weaning a genetically programmed reduction in lactase synthesis results in very low lactase activity in some adult subjects, a situation known as lactase nonpersistence.

Lactase nonpersistence results in incomplete digestion of an ingested load of lactose; hence lactose is malabsorbed and reaches the colon. If sufficient lactose enters the colon, the subject may experience symptoms of abdominal pain, bloating, excess flatulence, and diarrhea, a condition known as lactose intolerance (LI). Diseases of the small bowel mucosa (infection, celiac disease) may also be associated with low brush border lactase, with resultant lactose malabsorption (LM) and LI.

The terminology involved in lactose absorption/intolerance is as follows:

a. Lactase nonpersistence (or lactase insufficiency) – indicates that brush border lactase activity is only a small fraction of the infantile level, a condition documented by analysis of brush border biopsies. Recently it has been shown that a genotype (C/C) of the lactase promoter gene is responsible for lactase nonpersistence, and demonstration of this genotype can be used as indirect evidence of lactase nonpersistence.
b. Lactose malabsorption – indicates that a sizable fraction of a dosage of lactose is not absorbed in the small bowel and thus is delivered to the colon. Since such malabsorption is virtually always a result of low levels of lactase, there is a nearly a one to one relationship of lactase nonpersistence (or deficiency) and LM. LM is objectively demonstrated via measurements of hydrogen H_2_ breath or blood glucose concentrations following ingestion of a lactose load.
c. Lactose intolerance – indicates that malabsorbed lactose produces symptoms (diarrhea, abdominal discomfort, flatulence, or bloating). It should be stressed that this symptomatic response to LM is linked to the quantity of lactose malabsorbed (as well as other variables), i.e., ingestion of limited quantities of lactose does not cause recognizable symptoms in lactose malabsorbers, while very large doses commonly induce appreciable LI symptoms. As a result, the prevalence of lactase nonpersistence or LM could far exceed the prevalence of LI symptoms in population groups ingesting modest quantities of lactose.

A public health problem may arise when large numbers of individuals diagnose themselves as being lactose intolerant. However, these self-identified lactose intolerant individuals may actually be lactase persisters. Some of these lactase persisters (and even lactase nonpersisters) may mistakenly ascribe the symptoms of undiagnosed irritable bowel syndrome (IBS) or other intestinal disorders to LI. Given that the relatively nonspecific abdominal symptoms caused by IBS and LM are extremely susceptible to the placebo effect, reliable demonstration of LI requires double-blind methodology.

The problem may become intergenerational when self-diagnosed lactose intolerant parents place their children on lactose restricted diets (even in the absence of symptoms) or use enzymatic replacement in the belief that the condition is hereditary. Children and adults with LI may avoid dietary milk intake to reduce symptoms of intolerance. Since the avoidance of milk and milk containing products can result in a dietary calcium intake that is below recommended levels of 1,000 milligrams (mg) per day for men and women and 1,300 mg for adolescents, osteoporosis and associated fractures secondary to inadequate dietary calcium is the perceived major potential health problem associated with real or assumed LI.

Current dietary recommendations suggest consuming 3 cups/day of fat-free or low-fat milk or equivalent milk products. This amount is equivalent to about 50 grams of lactose, which we defined to be the threshold of minimum tolerance. We defined LI to be present when ingestion of 50 grams of lactose (or less) as a single dose by a lactose malabsorbing subject induces gastrointestinal symptoms not observed when the subject ingests an indistinguishable placebo.

Because ingesting smaller portions over the course of the day may minimize potential problems with larger acute lactose loads, the above definition of lactose intolerance may miss lactose malabsorbers who ingest smaller dosages of lactose. The prevalence of clinically important lactose intolerance requires demonstration that the quantity of lactose that subjects actually ingest (or wish to ingest) causes symptoms in placebo-controlled experiments.

Treatment to reduce lactose exposure, while maintaining calcium intake from dairy products, consists of a lactose restricted diet or the use of milk in which the lactose has been pre-hydrolyzed via treatment with lactase supplements. Lactase supplements taken at the time of milk ingestion also are commercially available.

This report was commissioned as background material for a National Institutes of Health (NIH) and Office of Medical Applications of Research (OMAR) Consensus Development Conference on Lactose Intolerance and Health to address the following key questions:

### Key Questions Addressed in this Report

1. What is the prevalence of lactose intolerance? How does this differ by race, ethnicity, and age?
2. What are the health outcomes of dairy exclusion diets?
  - In true lactase nonpersisters
  - In undiagnosed or self-identified lactose intolerant individuals.
  - How does this differ by age and ethnicity?
  - Health outcomes to include: Bone health – osteoporosis, fracture, bone density, bone mass; and gastrointestinal symptoms – abdominal pain, diarrhea, nausea, flatulence, bloating.
3. What amount of daily lactose intake is tolerable in subjects with diagnosed lactose intolerance?
  - How does this differ by age and ethnicity?
  - What are the diagnostic standards used?
4. What strategies are effective in managing individuals with diagnosed lactose intolerance?
  - Commercially-available lactase
  - Prebiotics and probiotics
  - Incremental lactose loads for colonic adaptation
  - Other dietary strategies
5. What are the future research needs for understanding and managing lactose intolerance?

## Methods

We searched several databases including MEDLINE® via PubMed® and via Ovid, the Cochrane Library of randomized controlled clinical trials, BIOSIS Previews®, Biological Abstracts®, Global Health, Food Science and Technology Abstracts®, and Commonwealth Agricultural Bureau International databases, to find studies published in English between 1967 and November 2009. We included observations that examined prevalence, symptoms, and outcomes of LI in different age, gender, racial, and ethnic groups. We excluded populations with other gastrointestinal disorders, including individuals diagnosed with IBS, inflammatory or infectious bowel diseases, or milk allergies. We excluded children younger than 4 years of age.

We synthesized the results using the exact definitions the authors used for LI and LM. We defined LI to be present when ingestion of 50 grams of lactose (or less) as a single dose by a lactose malabsorbing subject induces gastrointestinal symptoms not observed when the subject ingests an indistinguishable placebo. Since the symptomatic response to lactose likely increases with increasing dosages, this definition is also intimately related to the dose of lactose administered.

For question 2 we operationalized dairy exclusion diets by including studies that compared outcomes among populations reporting, or randomized, to consume diets very low in or free from lactose. We included the following populations: general, vegans, lactase nonpersisters, diagnosed or self-identified lactose intolerant or lactose malabsorber. For bone health outcomes we analyzed bone fractures and osteoporosis, bone mineral content (BMC), and bone mineral density (BMD). For gastrointestinal outcomes we assessed gastrointestinal symptoms at different categories of lactose intake. Dietary recall may be unreliable, and our search identified few studies meeting these criteria. Therefore, we included studies that examined the association between individuals classified as lactose intolerant, lactose malabsorbers, or lactase deficient and health outcomes even if they did not specifically state the amount of lactose/dairy consumed. We included these studies because evidence suggested that these populations were likely to consume diets low in lactose. We provide quantitative estimation of lactose intake expressed in differences between consumed and recommended dietary calcium. We included randomized controlled trials (RCTs) that evaluated the effect of lactose free diets on outcomes to assess if lactose intake resulted in improved bone health. We excluded the studies of patients with milk allergies, irritable bowel syndrome, chronic diarrhea, gastroenteritis, or other diagnosed gastrointestinal diseases.

Osteoporosis was defined according to World Health Organization criteria1–3 as a BMD 2.5 standard deviation or more below the young average value in women and men.4 Osteopenia was defined as a BMD 1–2.5 standard deviation below the population average.5

We used reference data on femur bone mineral content and density of noninstitutionalized adults in the United States from the third National Health and Nutrition Examination Survey that collected dual energy x-ray absorptiometry in a nationally representative sample of 14,646 men and women 20 years of age and older.6

For Key Question 3 we included double-blind RCTs and analyzed the tolerable dose of lactose given in single or multiple doses. Findings from these studies (and for question 4) provided information regarding the short-term gastrointestinal outcomes among subjects diagnosed with LI or LM.

For Key Question 4 we included randomized double blind controlled trials of probiotics, enzyme replacement therapies with lactase from nonhuman sources, administration of lactose reduced milk, and regimes of increases in dietary lactose load. We evaluated the efficacy of therapeutic agents and strategies in alleviating symptoms among individuals with diagnosed lactose malabsorption.

We judged level of evidence using modified GRADE criteria. Inconsistency in direction or magnitude of the association or inconsistent adjustment for known confounding factors reduced level of evidence. We also determined low level of evidence and confidence when data came from a single study. We judged moderate level of evidence for statistically heterogeneous results from several small RCTs because further research is likely to have an important impact on our confidence in the estimate of effect and may change the estimate.

## Results

### Key Question 1: What is the prevalence of lactose intolerance? How does this differ by race, ethnicity, and age?

A total of 54 articles met inclusion criteria, including 15 articles from the United States. Studies did not directly assess LI in a blinded lactose challenge but instead assessed unblinded subjective LI symptoms, an inability to fully absorb lactose (lactose malabsorption), or lactase nonpersistence. The data available tended to be from highly selected populations and was not likely representative of the overall U.S. population. We report results according to the following conditions: lactose intolerance, lactose malabsorption, or lactase nonpersistence. Within these conditions we further describe findings according to assessment method and populations studied.

#### Lactose intolerance

Symptoms following blinded lactose challenge. We identified no studies that reported on the prevalence of LI based on our “gold-standard” definition; i.e., gastrointestinal symptoms that are more prevalent and severe after ingestion of 50 grams of lactose (or less) as a single dose by a lactose malabsorbing subject that are not observed when the subject ingests an indistinguishable placebo.

Symptoms following nonblinded lactose challenge. We identified 21 studies that reported LI-related symptoms (abdominal pain, bloating, excess flatulence, and diarrhea) following a nonblinded lactose challenge.7–28 Few assessed U.S. populations. No studies were published in the last 30 years. There were four older U.S. convenience sample studies13,18,26,27 that reported results on different subpopulations. One study of healthy Caucasian volunteers with no history of milk intolerance reported that symptoms were rare and confined primarily to those with biopsy determined hypolactasia.18 In another study on healthy adults,26 Hispanics were 43 percent more likely to report symptoms following a lactose challenge compared to white non-Hispanics.26 Similarly, in healthy children27 the rate of symptoms was twice as high among Hispanic children (41 percent versus 20 percent in non-Hispanic). The fourth U.S. study included African American (n=69) and Caucasian (n=30) children between the ages of 4 and 9 years old. The overall frequency of symptoms following a challenge was quite low in young children, but the rate increased with age and was higher in African American children compared to Caucasian children.13 Age up to adulthood was a consistent predictor of LI-related symptoms. Racial and ethnic variation was present, but the variation in symptoms reported following a challenge did not seem as extreme as the racial and ethnic variation seen in lactose malabsorption and prevalence of lactase nonpersistence.

Symptoms without lactose challenge. We identified seven studies reporting baseline self-reported symptoms in 6,161 people.29–35 There was only one U.S. population-based study.35 This study included only self-reported LI with no additional confirmation of the diagnosis. Overall, U.S. estimated prevalence of self-reported LI was 12 percent from this study, with estimates of 8 percent in European Americans, 10 percent in Hispanic Americans, and 20 percent in African Americans. The rest of the self-reported studies’ results provide little evidence to address our research questions about population prevalence and the impact of age and ethnicity. Overall, the prevalence of self-reported symptoms was typically lower than the prevalence of symptoms following a lactose challenge.

#### Lactose malabsorption

Determined by hydrogen breath test following lactose challenge. We identified 31 studies evaluating participants from a wide range of ages and ethnicities that reported LM prevalence as defined by subjects with a positive hydrogen breath test.7,8,11,12,14–17,20–25,28,30,32,36–48 None of the U.S. studies were representative population-based studies. All U.S. studies focused on reporting results in populations of patients with gastrointestinal (GI) symptoms at baseline,36,42,47,48 with the exception of one three decade old study of American Indians30 and one convenience sample of adults from the Army, senior centers, nursing homes, and a university.44

Within the U.S. studies of patients with GI symptoms at baseline, the prevalence of LM in Caucasian adult populations ranged from 6 to 24 percent.42,44,47 Some data suggested high levels of LM among American Indians, but this effect was substantially attenuated among those with American Indian and Caucasian mixed ancestry.30 One study showed that the prevalence of LM may be greater than 70 percent in African Americans, around 50 percent in Hispanic Americans, and even higher for Asian Americans.49 Age is an important contributor to the rate of LM, since nearly every population group identified showed low rates of LM in the youngest age groups, particularly those less than 6 years of age.16,17,23,28,39,45,46 In populations with high adult rates of LM, rates peaked between 10 and 16 years of age.

#### Lactase nonpersisters (adult-type hypolactasia)

Biopsy identification. We identified five studies that reported on the prevalence of lactase persistence as diagnosed by biopsy assays.18,50–53 These estimates ranged from 6 percent to 34 percent among Caucasians, to 75 percent among nonwhites; however, there was little to no correlation with symptoms of LI. It is difficult to generalize these findings to create population estimates or understand their clinical relevance.

Genetic Test Association. The most commonly reported genetic mutation for adult-type hypolactasia is the single nucleotide polymorphism (SNP) of the lactase (LCT) gene. The C allele is the globally most prevalent allele, while the less common T allele is dominantly associated with lactase persistence.54 Nine studies were identified that reported genotype frequencies for LCT -13910C>T SNP mutation, indicating a genetic predisposition for hypolactasia, or lactose nonpersistence.29,45,55–61 None of these studies were of U.S. populations. There were no obvious differences in genotype by age group.55,56 In North European studies, Caucasians had frequencies between 10–20 percent for the homozygous C/C genotype.29,55–57,59,61

### Key Question 2: What are the health outcomes of dairy exclusion diets?

We identified 55 publications of observational studies of 223,336 subjects that reported symptoms or bone health outcomes in relation to lactose intake. The absence of specific documentation of the amount of lactose consumed over long periods of time hampered synthesis, so indirect associations between bone outcomes and proxy variables for lower lactose consumption were assessed. We also found seven RCTs of 1,207 children on low lactose diets (less than 50 percent of the recommended calcium intake), and two RCTs of adult women (34–73 percent of recommended calcium intake) 62,63 that provide direct evidence of lactose intake on bone health. African American women were enrolled in one study.64 We identified no studies that specifically addressed gastrointestinal symptoms after long-term (>1 month) dairy exclusion diets. In evidence presented for key questions 3 and 4 we report on short-term gastrointestinal symptoms after blinded administration of lactose free diets or differing doses of lactose intake among subjects diagnosed with LI or LM. We included indirect evidence of the effect of dairy exclusion diets on health outcomes in populations that are presumed to have low dairy intake (e.g., vegans, individuals with LI/LM or lactase nonpersistence), even if the studies did not report on the amount of dairy consumed.

Lactose and calcium. Children and adults with self-reported symptoms of milk intolerance and diagnosed LM reported (or were assumed to be consuming) lactose free or low lactose diets. Limited evidence suggest that adults with C/C genotype may report reduced milk intake.59,65–67 The association was more consistent for women.68,69 Young adults with C/C genotype reported not drinking milk two times more often than those with TT genotype.70 The association may diminish with aging.71,72

Dietary calcium intake was 47 percent of that recommended in children and 30 percent in women who followed a vegan diet. Among those with LI, children consumed 45 percent and women 37 percent of the recommended dietary calcium. During the transition to young adulthood, adolescents with LI had decreased dairy calcium intake.73 Among those with LM, adults consume 44 percent and women 50 percent of the recommended dietary calcium. Daily calcium intake was 32 percent of that recommended in women with LM and LI. Young adults with C/C genotype had lower than recommended calcium intake when compared to those with TT genotype.70 Women with C/C genetic polymorphism consumed 48 percent of the recommended dairy calcium from all sources and 34 percent from milk. Men with C/C genetic polymorphism consumed 58 percent of the recommended dairy calcium from all sources and 1.3 percent from milk. Children with C/C genetic polymorphism consumed 80 percent of the recommended dietary calcium.

We evaluated GI symptoms and bone health in vegans (lactose free), in healthy adults with low lactose intake and an unknown proportion of subjects with undiagnosed LI, and in populations with lactase deficiency, LI, or LM who followed low lactose diet.

Association between GI symptoms and dairy exclusion diets. We identified no studies that addressed the long-term impact (>1 month) of dairy exclusion diets on GI symptoms in the general population, vegans, or those diagnosed with LI or LM. Limited evidence suggested that long-term lactose free diet resulted in improved symptoms in patients with IBS and lactose malabsorption.74 A degree of clinical improvement, however, was not associated with severity of clinical symptoms during hydrogen diagnostic tests in patients with IBS and no history of milk intolerance.75 Therefore, severity of clinical symptoms during hydrogen diagnostic tests could not predict favorable responses to long-term lactose free diets. Postmenopausal Austrian women with TT genotype (lactase persistence) had lower odds of aversion to milk consumption than women with C/C genotype.68,69 Among children who avoided milk, those diagnosed with lactose intolerance had much greater odds of milk related symptoms.76

In key questions 3 and 4 we report short-term GI outcomes from blinded RCTs among subjects with diagnosed LI or controls fed short-term diets containing varying doses of lactose or lactose free diets.

Association between lactose intake and metabolism and bone fractures. We found low levels of evidence from observational studies that low milk consumers had fractures more frequently than populations with higher milk consumption. Inconsistency in magnitude of the association and lack of consistent adjustment for all known confounding factors lowered the level of evidence.76–88 The magnitude varied depending on definitions of exposure. Studies did not analyze all levels of exposure, including milk and dairy calcium intake, genetic polymorphism, perceived milk intolerance, and positive tests for lactose maldigestion. We found low levels of evidence from two industry sponsored studies that children who avoid milk intake for more than 4 months had increased risk of bone fractures.76,89

A single study found that odds of the annual incidence of distal forearm fracture in prepubertal children with a history of long-term milk avoidance more than doubled.76 Another study reported that the age-adjusted odds of history of any fracture were more than three times higher among children with lactose free diets compared to the general population.89 We found low levels of inconsistent evidence from three studies of 44,552 adults (not stratified by gender) that those with low lifetime or childhood milk intake had increased odds of any or osteoporotic fracture.80 Evidence from nine studies of 111,485 adult women suggested an increase in risk of fracture in association with low dairy intake. The magnitude of the association varied across the studies. Variability in definitions of lactose intake and types of fracture may contribute to inconsistency in the results of the studies. While all nine studies found increased odds of fracture in women with lower dairy intake; only five reported a significant association.77–79,81,82,84–87 We found no significant association between any osteoporotic or hip fracture and low milk intake among male participants in large well designed observational studies.83,88 One large cohort reported that vegans had increased relative risk of fractures compared to the general population.90

Genetic predisposition. We found no studies that examined the association of low versus regular lactose diet and bone outcomes in those with genetic diagnosis, probably because of high prevalence of low lactose diet in this population However, we found studies that compared bone outcomes in subjects with C/C genotype (true lactase nonpersisters) and TT genotype (lactase persisters). The association between a single nucleotide polymorphism of the LCT gene at chromosome 2q21–22 (associated with lactase deficiency and reduced lactose intake) and fractures in adults was examined in five publications.29,65,68,69,91 Evidence of the association between bone fracture and lactase deficiency from three studies of 895 postmenopausal women were inconsistent in direction and effect size.29,68,69 One population-based study “Vantaa 85+” of 601 Finnish elderly found that those with C/C genotype (lactase deficient) had more than a threefold increase in crude odds of hip and nearly a twofold increase in crude odds of wrist fracture when compared to TT genotype (lactase persistent and reporting lower odds of milk aversion).65 The Austrian Study Group on Normative Values on Bone Metabolism did not find a significant association between genetic polymorphism and bone fracture in elderly men.91

Lactose intolerance: One study reported that children who avoided drinking cow’s milk because of perceived milk intolerance did not have higher rates of fracture compared to milk avoiders who did not report symptoms of intolerance.89 Finnish postmenopausal women with lactose intolerance (and presumed lower lactose intake) did not have greater risk of any, vertebral, or nonvertebral fracture when compared to healthy women.29 Austrian men and women with self-reported symptoms of LI (and presumed lower lactose intake) during the hydrogen breath test had a 96 percent increase in crude odds of any fracture.92 Estonian men and women with self-reported milk intolerance had increased crude odds of osteoporotic fracture.67

Association between lactose intake and osteopenia, osteoporosis, bone mineral density, and bone mineral content. Low level evidence indicates that adults with lactose free or low lactose diets had osteopenia more often than controls.5,93,94 Postmenopausal Taiwanese women consuming lactose free diets had a twofold increase in adjusted odds of femoral neck osteopenia compared to nonvegan vegetarians.93 Italian adults with symptoms of LI and positive hydrogen test (assumed to consume low lactose diets) had a large increase in crude odds of osteopenia.5 Women with different lactase genetic polymorphism (assumed to vary in lactose intake according to lactase gene presence) had the same odds of osteoporosis.29,69

Four studies demonstrated that children from Europe,95 Asia,96 or New Zealand76,97 with lactose free or low lactose diets had reduced BMC and BMD.76,95–97

Genetic polymorphism. We found low levels evidence that women with C/C genotype (lactase nonpersistent who consumed 48 percent of recommended calcium) had lower BMD compared to TT (lactase persistent) genotype.68,69 Bone outcomes did not differ by genotype in either gender.57,67

Lactose intolerance. We found low levels of evidence that children and adults with self-reported milk intolerance (reduced dairy intake with 45 percent of recommended calcium intake) had reduced BMC and BMD. Children98 and adolescent girls99 from the United States with lactose intolerance had an inconsistent reduction in BMC. Adults with self-reported milk intolerance had consistent reduction in BMD5,67,100 and BMC.5

Role of diet: bone health outcomes by intake of dairy and calcium. We found moderate level RCT evidence that increased lactose intake resulted in improved BMC of the lumbar spine and femoral neck in prepubertal children with low baseline milk intake (less than 50 percent of recommended calcium intake). Lactose effects were causal and direct but the effect sized varied across studies and lowered the level of evidence. Dairy intervention with 1,794 or 1,067 mg of calcium per day compared to 400–879 mg of calcium per day for 12 months resulted in a significant increase in total body BMC in boys and girls from Hong Kong.101 One RCT that included pre-pubertal children with very low baseline milk intake reported significant increases in total body BMC after dairy administration that provided 1,200 mg of calcium per day.102 The effect, however, was not significant at 18 months of followup.102 The U.S.103 and British104 RCTs that included only girls consuming half of the recommended daily calcium did not demonstrate significant improvement in total body BMC. Study design, population, race/ethnicity, gender, and baseline milk intake could explain inconsistency between studies in lumbar spine BMC. Lumbar spine BMC was increased in three RCTs,101,102,105 while two trials did not report significant changes.106,107 Children from Hong Kong with very low baseline calcium intake had the greatest increase in lumbar spine BMC.101 Dairy intervention increased lumbar spine BMC in girls105 but not in boys.106 The improvement in bone mineral density was less evident. Dairy interventions did not increase BMD in girls in two RCTs that reported absolute levels of the outcome.103,105 Dairy interventions increased BMD from baseline in one RCT of Finnish girls,107 while British girls104 and children from New Zealand102 or Hong Kong101 did not have significant changes in BMD. Dairy intervention did not result in a significant increase in total spine BMD at 6 months in young women.62 In one small RCT (n=59) of premenopausal U.S. women, dairy intervention reduced age-related decline over a 3-year period in vertebral BMD.63 Observational studies reported that children with very low milk intake had reduced BMD when compared to the reference population.76,96,97 Long term milk avoiders had lower BMC.76,95–97

### Key Question 3: What amount of daily lactose intake is tolerable in subjects with diagnosed lactose intolerance?

Twenty-eight randomized crossover trials were included. Half of the trials included lactose digesting controls. The vast majority of studies of LI were small (<30 subjects) with trial populations ranging between six and 150 subjects. Women constituted 55 percent of the subjects, and the mean age was 37 years (20 studies reporting). Seven trials included children or adolescents, four exclusively. Among the 20 studies reporting race or ethnicity, 33 percent of the subjects were white, 30 percent Hispanic, 20 percent black, and ten percent Asian. Studies did not report outcomes stratified by these baseline factors. In 11 studies abdominal symptoms compatible with malabsorption of lactose prior to study entry were not required for participation. Lactose malabsorption was diagnosed following lactose tolerance tests by the hydrogen breath test in 13 of the studies,108–120 and blood glucose test in 11 studies.121–131 Diagnosis based on urinary galactose concentration was reported in one study132 and biochemical method of diagnosis was not reported in three trials.133–135 Half of the trials included lactose digesting controls.110–113,116,120,122,125–129,133,135

While subjects were routinely tested for LM, only a few studies then tested the intolerant subjects in blinded fashion with increasing doses of lactose administered throughout the day to determine the daily tolerable dosage of lactose. Most studies utilized a single dose of lactose and a lactose-free control administered in water or milk without food, frequently in not totally blinded fashion (i.e., the taste of low lactose milk differs from milk). The statistical rating of symptoms may not indicate clinical significance. The probability that a given dose of lactose induces more symptoms than the control treatment has been assessed by standard statistical tests of the differences between group means. No attention has been paid to the possibility of outliers. Results were heterogeneous in terms of patient populations, interventions, assessment methods, and outcome definitions, thus precluding pooling. Most studies used hydrogen H_2_ breath testing to identify lactose malabsorbers which can incorrectly classify subjects. The problem is compounded because studies do not clearly distinguish between individuals with and without symptoms, suggestive of LI individuals who undergo the testing.

The one study that investigated symptoms when lactose was ingested for 1 week with each of the three meals showed that up to 70 grams of lactose/day could be tolerated without appreciable symptoms.118 Studies testing the tolerance of lactose malabsorbing subjects to a single dose of lactose yielded discordant results. Several studies indicated that subjects with “lactose intolerance” can ingest from 10–15 grams of lactose (comparable to approximately one cup of milk), particularly if taken with food, with no or minor symptoms.113,116,119,120,126,127,130,131,134,135 When the dosage of lactose was increased to 18–25 grams, once again, the finding of intolerance varied between studies. Five trials reported that intolerance becomes more prominent, with single doses of 20 grams or greater usually yielding appreciable symptoms.119,127,129,130,134 Lactose may be better tolerated when ingested with other nutrients versus administration of an aqueous solution of lactose or milk as a single test dose without other nutrients. When taken with other nutrients, symptoms appear to be minimal with daily lactose dosages of less than 20 grams (1. 7 cups of milk), while many subjects experience severe symptoms with dosages of 50 grams. In contrast, when lactose/milk is administered as a single test dose without other nutrients, dosages of 12 grams may be symptomatic. Two trials demonstrated that if 20–24 grams of lactose is distributed throughout the day and given with meals, many lactose malabsorbers will tolerate this dosage.111,132 Studies with comparable lactose doses reporting high frequency of appreciable intolerance symptoms supplied lactose in a single dose without food.124,133,134 No studies determined if lactose malabsorbers of differing ethnicities have differing tolerance to lactose. Likewise, there was no data on the relationship of age or sex to the quantity of lactose that can be tolerated by lactose intolerant subjects.

### Key Question 4: What strategies are effective in managing individuals with diagnosed lactose intolerance?

For individuals wishing to consume milk and milk products that exceed the amount of lactose that they are able to tolerate, we examined the strategy of consuming lactose reduced/hydrolyzed formulations. A total of 37 unique randomized studies (26 on lactase/lactose hydrolyzed milk supplements and lactose reduced milk, eight on probiotics, two on incremental lactose dose for colonic adaptation, and one on other agents) met inclusion criteria. The quality of the studies was low, with almost no study reporting adequate allocation concealment. Generally, studies had small sample sizes, and reporting of symptoms was variable or not reported: composite scores of four to five symptoms or individual symptoms such as abdominal pain, diarrhea, bloating, and flatulence were reported, either as means or proportion.

Lactase/lactose hydrolyzed milk. The 26 articles represented 28 unique trials. There was one study representing two trials that tested lactase supplements Lactodigest, DairyEase, and Lactaid,136 while the remaining 25 studies reported on lactose reduced or hydrolyzed milk by adding a lactase enzyme such as beta-galactosidase to the milk. Studies enrolled between six and 150 subjects. Women constituted 56 percent of the subjects (n=23 studies). The mean age of subjects was 37 years of age with a range between 10 and 77 (n=19 studies). Six trials included children or adolescents.109,114,123,126,127,135 One trial enrolled elderly subjects (mean age 77 years).116 Within the 19 studies reporting race or ethnicity, 40 percent of the subjects were white, 30 percent Hispanic, 20 percent black, and 9 percent Asian.109–116,123,126–130,133–135,137 Sixteen studies utilized commercial lactase products or hydrolyzed milk,108–111,113–115,121–125,128,130,133,135 two used milk products with lactose removed by ultrafiltration or chromatographically,112,134 and three assessed nonlactose solutions.116,126,127

Unclear or unreported methods of lactose removal were noted in two trials.129,132 Subjects in 18 studies reported abdominal symptoms compatible with malabsorption of lactose prior to study entry.108–114,121,123–125,128,130,132,134,136–138 Abdominal symptoms were not required for study participation (based solely on biochemical diagnosis) or subjects were not reported to experience symptoms following ingestion of lactose in ten studies.115,116,122,126,127,129,130,133,135,136 LM was diagnosed following lactose tolerance tests by the hydrogen H_2_ breath test in 11 of the studies108–116,136 and blood glucose test in 13 studies.121–130,137,138 Diagnosis based on urinary galactose concentration was reported in one study132 and biochemical method of diagnosis was not reported in three trials.133–135 Over half the trials included lactose digesting controls.110–113,116,122,125–129,133,135,137 Among the 18 studies that enrolled symptomatic subjects at baseline, 13 utilized lactose doses greater than 12 grams, comparable to one cup of milk.108,110,111,114,121,123–125,128,130,132,134,136,137 Hydrolyzed lactose doses typically ranged from 0–2 grams per dose. In most of the studies, the lactose dose was consumed in a single serving. In six trials, the lactose dose was administered over multiple intervals per day for at least part of the study.110,111,122,125,128,132

We found insufficient evidence that lactose reduced solution/milk, with lactose content of 0–2 grams, reduced symptoms of lactose intolerance. Seven studies, representing nine comparisons that enrolled individuals who had symptoms compatible with LI reported inconsistent results that lactose reduced preparations decreased overall symptom scores compared to controls. None of the four studies reported a significant improvement in overall symptoms compared to control preparations of up to 12 grams of lactose. However, as noted in key question 3, doses of 12 grams of lactose or less are well tolerated and produce minimal to no symptoms. When compared to controls given greater than 12 grams of lactose, only two out of five trials reported statistically significant reductions in overall symptoms with lactose reduced/hydrolyzed milk. Results for individual symptoms of abdominal pain, diarrhea, flatulence, and bloating were also inconsistent.

When we examined all included studies, regardless of symptom history, we found insufficient information from 16 (19 comparisons), mostly low quality, trials regarding the effect of hydrolyzed milk, lactase, or non-lactose preparations in reducing GI symptoms compared to lactose controls. Because these studies enrolled subjects with and without a prior history of GI symptoms compatible with LI (and did not provide results stratified by prior symptom history) they have very low applicability to the question to be addressed. Some studies did report substantial reductions (improvement from moderate and severe to mild or none, or an absolute reduction of at least 50 percent) in abdominal pain/cramping109,112,123,125,134 and diarrhea136 with use of lactose reduced solution/milk, with lactose content of 0–2 grams, compared to a lactose dose of 12 grams or more. However, even in studies where symptoms were reduced statistically significant reductions were not consistently observed among all symptoms reported, or only a subset of symptoms were reported. For example, the overall symptom score was significantly reduced by 60 percent with 591 milliliters (ml) of lactose reduced milk containing 7.5 grams of lactose compared to a similar amount of milk with 30 grams of lactose130 and by 13 percent with low lactose skim milk with 0.8–6.5 grams of lactose compared to skim milk with 6.1–49 grams of lactose,122 but the subjects in both studies were not symptomatic at enrollment, and improvement in individual symptoms was not provided. Mean and total symptom scores were also reduced, from 3.7 to 0.36 with 70 percent hydrolyzed milk compared to placebo with 20 grams of lactose,108 but subjects were also not symptomatic at enrollment, and improvement in individual symptoms was not provided. One study reported a score of 46 for skim milk with 11.3 grams of lactose, which was reduced to a score of 17 with low lactose milk with 3.2 grams of lactose, but the difference was not statistically significant.134 Similar reductions were seen in summed scores for abdominal pain from 43 with milk containing 25 grams of lactose to 1 with lactose hydrolyzed milk containing 1.25 grams of lactose123 and a mean score for abdominal pain from 7.5 with milk containing 12 grams of lactose to 4.1 with milk containing lactase,109 both in children. Again, neither study required subjects to be symptomatic at baseline. One study showed a statistically significant reduction in abdominal pain from moderate to none or mild with low lactose milk containing 2.9 grams of lactose compared to skim milk containing 28.5 grams of lactose.125 One trial found a significantly greater percentage of subjects reporting abdominal pain and bloating compared to the 0.5 gram and 1.5 gram doses, respectively.112 Compared to placebo, use of lactase supplement Lactodigest, DairyEase, or Lactaid in doses of two to four capsules/tablets when taken with 400 ml of 2 percent milk containing 20 grams of lactose reduced overall symptom scores in subjects not symptomatic at enrollment. However, more relevant to the clinical question of treatment for individuals with symptoms compatible with LI who desire to consume lactose beyond the “minimally tolerable dose,” these products did not reduce symptoms when administered with a dose of 50 grams of lactose in subjects who had symptoms compatible with LI.136 Generally, studies had small sample sizes and reporting of symptoms was variable: composite scores of four to five symptoms or individual symptoms such as abdominal pain, diarrhea, bloating, and flatulence were reported, either as means or proportion, making pooling estimates difficult.

Prebiotics and probiotics. Trials were generally small, enrolling between nine and 28 subjects. Among the five studies reporting gender, women constituted 34 percent of the subjects.139–143 Two studies enrolled only male subjects.142,143 Subjects were typically young to middle-aged adults (between 18 and 45 years old), and only one study enrolled subjects older than 60 years of age.144 Half of the studies reported race or ethnicity. White subjects comprised two trials,140,141 one study evaluated black African immigrants to France142 and one trial was conducted in Taiwan.117 Five of the studies were conducted in the United States,139,140,143–145 and two in France.141,142 Five trials assessed probiotic test products, prepared by adding strains of lactobacillus acidophilus, lactobacillus bulgaricus, or bifidobacterium longum to milk prior to consumption.117,139,140,144,145 Four studies evaluated yogurt products.141–143,145 Lactose malabsorption was diagnosed by the hydrogen breath test in all studies.

We found insufficient evidence to determine the effectiveness of yogurt or probiotics to improve LI symptoms. The inclusion criteria were variable; the type, source, and concentration of yogurt and probiotics studied were variable; and no two studies studied the same agent. Results either did not show a difference in symptom score or reported clinically insignificant differences, mostly in symptoms of flatulence. Symptoms of abdominal pain, diarrhea, or overall score were not improved, which may be more clinically relevant to the patients and their providers. Only one study noted that the enrolled subjects reported symptoms compatible with malabsorption of lactose prior to study entry144 and reported a symptom score of 40 in groups given milk or acidophilus milk. In the remaining studies, study entry was based solely on hydrogen H_2_ breath tests, and subjects were not reported to experience symptoms following ingestion of lactose. Lactose doses in the control tests were between 10 and 20 grams. Overall symptom score was reduced from 12.5 with 2 percent milk containing 20 grams of lactose to 2.8 with the same milk formulation but with added lactobacillus at 10^9^ cfu/ml117 and from fairly strong to mild with 400 ml of bulgofilus milk (Ofilus bacteria+L. bulgaircus) compared to control (10 grams lactulose in 250 ml water), both with 18 grams of lactose.141 Reductions in other symptoms, such as abdominal pain and diarrhea, were either not reported, not significantly different, or of lower clinical significance or relevance. The inclusion criteria were variable, the type, source, and concentration of yogurt and probiotics studied were variable, and no two studies studied the same agent.

Other strategies. We identified three small short-term studies.118,146,147 We found insufficient evidence that incremental doses of lactose reduce LI symptoms. We found one cross-over study evaluating 10 days of incremental doses of lactose versus dextrose for colonic adaptation among 20 subjects with LM diagnosed on hydrogen breath tests.118 Most subjects had mild symptoms, even with high doses of lactose consumption. Flatulence but not abdominal pain and diarrhea were reduced. The second study evaluated colonic adaptation to lactose by comparing symptoms among 46 adults with lactose malabsorption that were fed either 34 grams of lactose or sucrose in a double blind fashion for 13 days.146 The overall clinical score and individual mean scores for pain, flatulence, bloating, and borborygmi also improved, but the improvement seen in lactose and sucrose groups was similar, suggesting a placebo response. One additional study of 40 subjects with malabsorption on breath hydrogen testing evaluated rifaximin compared to lactose free diets and placebo.147 Rifaximin and lactose free diets resulted in similar reductions in abdominal pain, diarrhea, bloating, and distension compared to their respective baseline values. There were no data directly comparing rifaximin to placebo or lactose-free diets.

## Summary and Discussion

Our evidence synthesis reached the following major conclusions: (1) Reliable estimates of prevalence rates for LI in the United States are not currently available, though there is some evidence that the magnitude of LI will be very low in young children and remain low into adulthood for most populations of Northern European descent. For African American, Hispanic, Asian, and American Indian populations the rates of LI will likely be higher in late childhood and adulthood. (2) Evidence regarding the effect of dairy exclusion diets on long-term GI and bone health outcomes is relatively sparse in quantity and low in quality. Evidence does not strongly indicate that dairy-free diets are independently associated with poor long-term bone health outcomes, and there is no direct information on long-term GI outcomes among individuals consuming dairy-free diets. However, results from genetic association tests consistently reported decreased consumption of milk in adults with the C/C genotype compared to those with at least one T allele, suggesting that individuals with lactase nonpersistence avoid milk, presumably to reduce dairy induced GI symptoms. (3) The majority of individuals diagnosed with LI can likely tolerate up to 12 grams (equivalent to 1 cup of milk) at a given sitting with minimal to no symptoms, especially if consumed with other foods. (4) Treatment with lactose reduced milk products may result in clinically important improvements in selected GI symptoms in selected individuals diagnosed with LI or LM, but there is very little high quality data on the effect of incremental lactose loads.

Our findings have important research and clinical implications. With regard to LI prevalence estimates, most of the identified research assessed subjective symptoms in an unblinded fashion or an inability of individuals to fully absorb lactose irrespective of symptoms or lactase nonpersistence. Available data tended to be from highly selected populations and not likely representative of the overall U.S. population. Additional genetic association studies may provide a useful method to assess LI in epidemiologic studies. Dietary history assessing dairy consumption and symptoms linked to results from testing for the lactase gene might obviate the need for blinding of lactose intake.

Our findings that there is not a strong or consistent association on bone health with dairy intake is supported by a previous evidence report that concluded that the majority of findings concerning vitamin D, calcium, or a combination of both nutrients on the different health outcomes (including bone health) were inconsistent. Because the major long-term health concern of dairy exclusion diets is the potential for intake of calcium below recommended dietary levels, future research is required to clarify whether populations that consume dairy-free diets have adverse bone health outcomes, particularly fractures. We found that dairy interventions in healthy children with low baseline milk intakes may result in short but not long-term improvement of bone mineral content and density. Adults with lactose free or low lactose diet may have increased risk of bone fractures. Low and inconsistent evidence suggested that adults with milk intolerance and malabsorption had greater odds of fractures and worse bone outcomes. Adult women with low childhood and lifetime milk intake, lactose malabsorption, and C/C genotype had greater risk of osteoporosis and fractures. However, studies did not find significant association with lactose metabolism and bone health in men. There was little data on African Americans. Additional information would be important because African Americans have a higher prevalence of LI and likely lower consumption of dairy products, yet they have lower rates of bone health outcomes of interest for this report. Children with low baseline calcium consumption may benefit from increased lactose intake. It is not clear if increased milk consumption in healthy adult women with low childhood and lifetime milk intake, LM, or C/C genotype reduces the risk of osteoporosis and fractures.

Our findings can aid patients and practitioners in clinical management of individuals diagnosed with lactose intolerance. The preponderance of evidence indicates individuals diagnosed with LI can be informed that they can ingest 12 grams of lactose (1 cup of milk) as a single dose (particularly if taken with food) with no or minor symptoms. Therefore, most individuals (either self or clinically diagnosed) can consume a sufficient amount of dairy products each day to meet minimum recommendations without incurring GI symptoms. However, as the dose is increased above 12 grams, these individuals can be informed that intolerance becomes more prominent, with single doses of 24 grams usually yielding appreciable symptoms. There is some evidence that if 24 grams of lactose are distributed throughout the day, many lactose malabsorbers will tolerate this dosage. Lactose in a dose of 50 grams induces symptoms in the vast majority of subjects. No studies assessed if lactose malabsorbers of differing ethnicities have differing tolerance to lactose. There was no data on the relationship of age or sex to the quantity of lactose that can be tolerated.

Advice regarding additional management strategies is hampered from the lack of study uniformity in design and methodology. We caution that the criterion of being symptomatic at baseline was found in only a few studies. This makes comparison of symptoms at the end of trial difficult across studies. Most studies had an 8-hour recording period, and it is difficult to generalize these findings to individuals with chronic relapsing remitting problems with a constellation of symptoms. While it seems logical that consuming lactose reduced products (i.e. to less than 12 grams of lactose) would reduce or prevent LI symptoms, the evidence was insufficient that products, as tested, provide this effect.

### Key Question 5: What are the future research needs for understanding and managing lactose intolerance?

We recommend that future prevalence studies be derived from population-based samples that include adequate distributions across ages and ethnic variation in order to assess the effects of these factors. Efforts are needed to account for possible placebo effects in the reporting of symptoms. The best mechanisms available for accounting for placebo effects would be to conduct blinded challenges with and without lactose and to assign the difference in reported symptoms as the true prevalence due to the lactose challenge. Double blind placebo controlled RCTs of individuals examining the effect of treatment strategies that enroll subjects with clearly documented LI are needed. Standardized, validated outcome reports are needed. Additional work on what constitutes a meaningful challenge dose should also be conducted. We recommend that research on lactose intolerance take into account the prevalence of symptoms that might be expected following doses of lactose that would be consumed during a normal diet (e.g., 1 cup or 12 grams) as compared to extreme doses of lactose that are comparable to getting a full day’s worth of calcium from a one-time consumption of milk (50 gram load at a single sitting).

We recommend that future research investigate the association between lactose and dietary calcium intake and patient outcomes in patients with lactose intolerance lactose free diet compared to age, gender, and race/ethnicity matched controls. We recommend that the sources of dietary calcium from nondairy products and from nutritional supplements be examined separately and in interaction with other dietary patterns (food synergy).148–150 Bone health in treated patients with LI is unknown. Length and doses of dairy products, probiotics, and plant calcium sources, as well as patient adherence to the recommended treatment regimes may modify the association and should be examined in future research. We recommend that future studies examine intermediate outcomes such as improvement in bone density and mineral content but, more importantly, clinical outcomes such as the incidence of osteoporosis and fractures. We recommend that other health outcomes include obesity, diabetes, cardiovascular diseases, and cancer in treated and untreated lactose intolerant patients in comparison with the general population.

Additional studies are required to accurately diagnose the overlapping symptoms of LI from other GI disorders (especially IBS), determine the health consequences of low lactose diets, and identify methods to improve patient and provider information about the diagnosis and management of LI versus other GI symptom based conditions (especially functional bowel or celiac disease) versus LM.

It is not clear to what extent restriction in intake of milk is from symptoms of LI versus reasons unrelated to symptoms, such as taste, caloric intake, or cultural factors. To the extent that milk avoidance is unrelated to LI, lactose reduced milk is not going to enhance ingestion. Thus, we believe a crucial question is to determine to what extent symptoms of LI limit the ingestion of milk or milk related products. Information on this could be obtained by studies in which lactose malabsorbers to avoid milk are provided with lactose containing and lactose hydrolyzed diets to determine if ingestion of milk and milk related products is increased by reduction of lactose content. To the extent that milk intake is reduced due to lactose intolerance symptoms, the next important question to answer is if there are long-term health consequences of limiting lactose intake.