# Discussion

## Summary and Discussion

Our evidence synthesis has the following major conclusions: (1) Reliable estimates of U.S. prevalence rates for LI are not currently available, though there is some evidence that the magnitude of LI will be very low in young children and remain low into adult ages for most populations of Northern European descent. For African American, Hispanic, Asian, and American Indian populations the rates of LI will likely be higher in late childhood and adulthood. (2) Evidence regarding the effect of dairy exclusion diets on long-term GI and bone health outcomes is relatively sparse in quantity and low in quality. The evidence does not strongly indicate that dairy free diets are independently associated with poor long-term bone health outcomes, and there is no direct information on long-term GI outcomes among individuals consuming dairy free diets. However, results from genetic association tests consistently reported decreased consumption of milk in adults with the C/C genotype compared to those with at least one T allele, suggesting that individuals with lactase nonpersistence avoid milk presumably to reduce dairy induced GI symptoms. (3) The majority of symptomatic individuals diagnosed with LI can likely tolerate up to 12 grams (equivalent of 1 cup of milk) at a given setting with minimal to no symptoms, especially if consumed with other foods. (4) Although reduced lactose consumption is logical and a biologically plausible treatment plan, evidence was insufficient to determine if lactose reduced milk products result in clinically important improvements in GI symptoms in individuals diagnosed with LI who wish to consume doses of lactose that exceed 12 grams per serving. There was also insufficient evidence on the effects of other treatment options, including probiotics and incremental lactose loads.

Our findings have important research and clinical implications. With regard to LI prevalence estimates, most of the identified research assessed subjective symptoms in an unblinded fashion, an inability of individuals to fully absorb lactose, irrespective of symptoms or lactase nonpersistence. Data available tended to be from highly selected populations and not likely representative of the overall U.S. population. Racial and ethnic variation was clearly present, but the variation in symptoms reported following a challenge does not seem as extreme as the racial and ethnic variation seen in lactose malabsorption and prevalence of hypolactasia. This is likely due in part to the fact the GI symptoms are commonly caused by factors unrelated to LI, so the effects due to lactose are likely attenuated by symptoms caused by nonlactose factors. Also, many people who malabsorb lactose do not report symptoms. Additional genetic association studies may provide a useful method to assess LI in epidemiologic studies. Dietary history assessing dairy consumption and symptoms linked to results from testing for the lactase gene might obviate the need for blinding of lactose intake.

Dietary lactose intake and supplemental calcium consumption were recorded in a few observational studies. We found inconsistent increased risk of bone fracture in populations with documented or assumed low lactose intake. Poor documentation of dietary intake may contribute to inconsistency in results of observational studies. A recently published systematic review of the association between vitamin D and dietary calcium also found that inconsistent dietary analysis hampered synthesis of evidence.179 The authors could not find consistent evidence that increased dietary or supplemental vitamin D and calcium intake improves bone health. Because the major long-term health concern of dairy exclusion diets beyond GI symptoms is the potential for intake of calcium below recommended dietary levels, future research is needed to accurately assess long-term bone health outcomes in populations that consume dairy free diets. We found that dairy interventions in healthy children with low baseline milk intake may result in short but not long-term improvement of bone mineral content and density. Adults with lactose free or low lactose diet may have increased risk of bone fractures. Low and inconsistent evidence suggested that adults with milk intolerance and malabsorption had greater odds of fractures and worse bone outcomes. Adult women with low childhood and lifetime milk intake, LM, and C/C genotype had greater risk of osteoporosis and fractures. However, studies did not find significant association with lactose metabolism and bone health in men. There was little data on African Americans. Additional information would be important because African Americans have a higher prevalence of LI, likely lower consumption of dairy products, yet have lower rates of bone health outcomes of interest for this report. Children with low baseline calcium consumption may benefit from increased lactose intake. It is not clear if increased milk consumption in healthy adult women with low childhood and lifetime milk intake, LM, or C/C genotype reduces the risk of osteoporosis and fractures.

Our findings can aid patients and practitioners in clinical management of individuals diagnosed with LI. The preponderance of evidence indicates individuals diagnosed with LI can be informed that they can ingest 12 grams of lactose (one cup of milk) as a single dose (particularly if taken with food) with no or minor symptoms. Therefore, most individuals diagnosed (either self or clinically), can consume a sufficient amount of dairy products each day to meet minimum recommendations without incurring GI symptoms. However, as the dose is increased above 12 grams, these individuals can be informed that intolerance becomes more prominent, with single doses of 24 grams usually yielding appreciable symptoms. There is some evidence that if 24 grams of lactose is distributed throughout the day, many lactose malabsorbers will tolerate this dosage. Lactose in a dose of 50 grams induces symptoms in the vast majority of subjects. No studies assessed if lactose malabsorbers of differing ethnicities have differing tolerance to lactose. There was no data on the relationship of age or sex to the quantity of lactose that can be tolerated.

Advice regarding additional management strategies is hampered from the lack of study uniformity in design and methodology. For individuals with LI who wish to consume more than 12 grams of lactose at an individual sitting, there is insufficient evidence of clinically relevant reductions in overall symptoms and abdominal pain and diarrhea with consumption of lactose reduced milk (to content of 0–2 grams). However, we caution that the criterion of being symptomatic at baseline was found only in a few studies, and not all of the enrolled subjects may have actually been lactose intolerant. This greatly reduces the applicability of these studies to the clinical management of individuals with LI as well and limits the comparison of findings across studies. Most studies had an 8-hour recording period, and it is difficult to generalize these findings to individuals with chronic relapsing remitting problems with a constellation of symptoms. Individuals can be informed that while some studies indicated that treatments provided a statistical benefit, symptomatic improvement generally went from none to mild or slight, and the clinical significance for many individuals may be low. There is little information on the effect of these interventions on diarrhea and abdominal pain.

## Key Question 5: What are the future research needs for understanding and managing lactose intolerance?

### Key Question 1

In order to accurately assess the population prevalence of lactose, future studies will need to be derived from population based samples that include adequate distributions across ages and ethnic variation in order to map the effects of these important factors. Effort will also need to be made to account for possible placebo effects in reporting symptoms. The best mechanisms available for accounting for placebo effects would be to conduct blinded challenges with and without lactose and to assign the difference in reported symptoms and the true prevalence due to the lactose challenge. Additional work on what constitutes a meaningful challenge dose should also be conducted. For the research to be clinically meaningful, research on LI should take into account the prevalence of symptoms that might be expected following doses of lactose that would be consumed during a normal diet as compared to extreme doses of lactose that are comparable to getting a recommended daily intake of calcium from a one-time consumption of milk.

### Key Question 2

We were unable to identify long-term studies that assess the impact of dairy exclusion diets on GI symptoms, especially if blinding individuals to dairy exclusion. Studies evaluating individuals diagnosed with IBS and gluten intolerance are needed. Future research should investigate the association between dietary calcium and patient outcomes in patients with LI and lactose free diets. The target populations for investigational research should include children, elderly, gender and ethnic subgroups, and patients with genetic polymorphism. The sources of dietary calcium from nondairy products and from nutritional supplements should be examined separately and in interaction with other dietary patterns (food synergy).148–150 Despite the widespread perception that low intake of dairy products and associated low vitamin D and calcium intake can lead to poor health outcomes, bone health in patients with LI is unknown. Length and doses of dairy products, probiotics, and plant calcium sources, as well as patient adherence to the recommended treatment regimes, may modify the association and should be examined in future research. Future research should prioritize patient outcomes, including bone fractures and intermediate outcomes of bone density and mineral content. Other health outcomes, including obesity, diabetes, cardiovascular diseases, and cancer, should be examined in treated and untreated lactose intolerant patients in comparison with the general population. In children with LI, incidence of infection and allergic diseases should be evaluated in long-term observational studies and in randomized controlled clinical trials of available treatment options.

### Key Question 3

Future research needs to examine if lactose malabsorbers of differing ethnicities have differing tolerance to lactose. Additionally, blinded RCTs should enroll and provide outcomes among subjects according to age and gender to determine if the quantity of lactose that can be tolerated by lactose intolerant subjects varies by these characteristics. Reporting of outcomes in a standardized validated fashion and determining clinically significant as well as statistically significant differences are needed.

### Key Question 4

Few studies have tested the hypotheses that incremental lactose loads for colonic adaptation is beneficial. Furthermore, studies that have examined different products to prevent LM used a wide variety of patients, interventions, comparisons, and outcomes. Pooling results is difficult, and determining generalized estimates of clinically relevant effect sizes was generally not feasible. Future research is needed employing standardized interventions with blinded controls and reported validated outcomes in a standardized fashion.

In summary, while probiotics, lactose reduced milks, and lactase supplements hold great promise and high public acceptance, evidence of efficacy and effectiveness in specific populations is lacking. Rigorous scientific data to support their use is lacking, and there is also a dearth of information on their safety. Probiotics are generally considered effective and safe. Using the approach, “they can’t hurt and may help” is potentially erroneous as safety and efficacy, particularly long-term use, are not known.

The connection between bench and bedside application needs to be made. A large body of literature exists on physiological and experimental measurement of LM, but few studies evaluate the symptomatic response of agents. Also, the correlation between measurement of hydrogen breath excretion, colonic bacterial fermentation, and lactase activity and other physiological measurements with symptomatic improvement needs to be studied and reported.

Need for blinded randomized clinical studies. LI is well recognized by the medical and lay community and is often blamed for being the cause of diarrhea, abdominal pain, bloating, and flatulence. Patients self diagnose the condition and drastically reduce or stop their intake of lactose or use supplements to help digest lactose. This has the variable effect of reducing or alleviating symptoms. However, given the subjective nature of symptoms and the large placebo effect of any dietary manipulation, it is unclear if the response is a ‘placebo effect’ or due to use of supplements. The literature on efficacy of hydrolyzed milk, probiotics, and supplements to help digest lactose is fraught with this problem. Rigorous double blinded placebo controlled studies are required to demonstrate efficacy, and larger long-term studies demonstrating effectiveness are needed. There also needs to be rigorous long-term safety data of these agents. Outcomes reported in a standardized validated fashion and that determine clinically significant as well as statistically significant differences are needed.

Appendixes and evidence tables cited in this report are available at http://www.ahrq.gov/downloads/pub/evidence/pdf/lactoseint/lactint.pdf.