# Evidence Tables

Appendix Table D1 Observational studies of lactose intolerance or malabsorption in association with patient outcomes

Study | Subjects | Diagnosis and Control for Bias | Comments
Alhava, 1977^1^ Country: Finland Population: Adults Source: The Outpatient Clinic in the University of Central Hospital, Kuopio Study design: Cross-sectional | Inclusion: Adults with documented positive lactose intolerance test and healthy controls Exclusion: General malabsorption, rheumatoid arthritis, other diseases that affect bone metabolism Excluded: NS Inclusion age: >19 Followup: None Mean age: 21–72 for men and 19–71 for women | Diagnosis of LI: Lactose malabsorption as positive glucose test, max rise <1.3 mmol/l Diet: Self reported Diet assessment: NS Control for bias: None | Test: Blood glucose test Race: NS Ethnicity: NS
Birge, 1967^2^ Country: USA Population: Adults 50 years or over Source: Patients referred to the National Institute of Arthritis and Metabolic Diseases Study design: Cross-sectional | Inclusion: Confirmed diagnosis of osteoporosis, healthy volunteers without osteoporosis Exclusion: History of steroid therapy, malabsopriton, endocrinopathy, cancer, renal disease or lithiasis or other causes of demineralization Excluded: NR Inclusion age: >50 Followup: None Mean age: NS | Diagnosis of LI: Positive lactose tolerance test; Patients who had less than a 50% mg/dl rise in blood glucose were lactase deficient Diet: Self reported Diet assessment: Interviews conducted by a registered dietician and PI Control for bias: None | Test: Oral lactose tolerance tests, glucose tolerance test, jejunal biopsy with impaired lactase activity Race: NS Ethnicity: NS
Buchowski, 2002^3^ Country: USA Population: Premenopausal lactose maldigesting African American women Source: Recruited in Meharry Medical College Study design: Cross-sectional | Inclusion: Premenopausal (self-reported frequency of menstruation in the preceding three-month period ) African American women with a rise in breath hydrogen concentration of greater than 0.90 mol/L (20 ppm) after ingestion of 25 g of lactose Exclusion: NR Excluded: Seven women were excluded from final analyses; two withdrew from the study, and five women did not complete dietary records Inclusion age: Adults Followup: None Mean age: 34.1–37.1 | Diagnosis of LI: Lactose maldigestion – positive hydrogen breath testing. Lactose intolerance self reported symptoms were scored, women with scores of at least 3 on this scale after ingesting lactose-containing milk were classified as lactose intolerant. Women who scored 2 or less after drinking lactose containing milk were classified as lactose tolerant Diet: Regular diet Diet assessment: Seven-day dietary record Control for bias: Matching by age, adjustment for BMI | Test: The occurrence and severity of symptoms were self- rated by the subjects after ingesting 250 mL of lactose containing or lactose-free milk (Suarez et al.) Subjects reported occurrence and severity of abdominal fullness or cramps, flatulence, and diarrhea on a 0–5 scale as follows: 0 no symptoms, 1 trivial, 2 mild, 3 moderate, 4 strong, and 5 severe. Race: African-American Ethnicity: NR
Corazza, 1995^4^ Country: Italy Population: Postmenopausal women Source: Clinic based Study design: Cross-sectional | Inclusion: 83 consecutive postmenopausal women with suspected osteoporosis, Caucasian, residents in the Bologna area Exclusion: Ovariectomy, estrogen replacement therapy, Ca supplementation, gastrointestinal diseases, recent treatment with antibiotics or drugs which could modify the intestinal flora, diseases known to influence Ca and bone metabolism Excluded: 25 Inclusion age: Adults Followup: NA Mean age: 57±7 | Diagnosis of LI: Self reported relationship between the onset of abdominal symptoms, such as flatulence, abdominal pain, diarrhea and the intake of milk, ice cream, cheese and yoghurt and positive Hydrogen breath testing Diet: Self reported Diet assessment: Dietary diary for three consecutive days evaluated by the nutritionist blinded to the details of the study Control for bias: None | Test: Positive hydrogen breath test Race: Caucasian Ethnicity: Caucasian
Di Stefano, 2002^5^ Country: Italy Population: Adults Source: Work place Study design: Cross-sectional | Inclusion: 103 healthy subjects (59 women, 44 men), members of medical or paramedical staff of our hospital, or were students Exclusion: NR Excluded: NR Inclusion age: Adults Followup: NA Mean age: 28± 2 | Diagnosis of LI: Lactose malabsorption was defined as positive hydrogen breath test Diet: Self reported Diet assessment: Dietary diary for 3 nonconsecutive days evaluated by blinded to the study details researcher Control for bias: None | Test: Self reported symptoms during the test and the 24-hour period after the test. Bloating, abdominal pain or cramps, diarrhea, and flatulence were ranked as follows: 0 absence of symptoms, 1 trivial symptoms, 2 mild symptoms, 3 moderate symptoms, 4 strong symptoms, and 5 severe symptoms Race: Caucasian Ethnicity: NS
Du, 2002^6^ Country: China Population: Adolescent Girls Source: Population based Study design: Cross-sectional | Inclusion: A random sample of 649 girls, ages 12–14 years from a sample of 1,277 girls selected in 13 middle schools in the Beijing area using cluster sampling procedure by means of a socioeconomic strata Exclusion: Evidence of liver, kidney, or other disorders that may have caused abnormal bone metabolism Excluded: NR Inclusion age: 12–14 years Followup: NA Mean age: 12.9±0.6 | Diagnosis of LI: Feeling uncomfortable after drinking milk including symptoms such as stomach upset, cramps, bloating, and diarrhea, or any minor abnormal feeling Diet: Self reported Diet assessment: Habitual food and nutrient intakes over the past year were estimated by use of a specially designed and validated semi quantitative food frequency questionnaire Control for bias: Adjustment | Test: Not addressed Race: Caucasian Ethnicity: Asian
Enattah, 2004^7^ Country: Finland Population: Young men Source: Population based cohort The Cardiovascular Risk in Young Finns Study Study design: Cross-sectional | Inclusion: Participants in a study examining the role of genes, hormones, and lifestyle factors: 234 young men, ages 18.3 to 20.6 years, 184 men were recruits of the Finnish Army, and 50 were men of similar age who had postponed their military service for reasons not related to health Exclusion: Not reported Excluded: NR Inclusion age: 18.3–20.6 Followup: NA Mean age: 19.4–19.7 | Diagnosis of LI: Adult-type hypolactasia, caused by the lactase-phlorizin hydrolase C/C-13910 genotype Diet: Self reported Diet assessment: Calcium intake was calculated on the basis of the supply from dairy products only Control for bias: Adjustment | Test: lactase-phlorizin hydrolase C/T-13910 polymorphism Race: Caucasian Ethnicity: NS
Enattah, 2005^8^ Country: Finland Population: Postmenopausal women Source: Population based cohort The Cardiovascular Risk in Young Finns Study Study design: Cross-sectional | Inclusion: A random subset of the control group participating in an ongoing RCT of an educational program for the prevention of fractures. RCT study population was 2,181 postmenopausal women, ages 60–70 years living in Southern Finland, they were initially recruited from the population register between 1996 and 2000;.52 women 69–85 years old, participants in trials of drug treatment of osteoporosis, were included for genotyping if they had vertebral fracture or osteoporosis according to the WHO criteria of BMD (a T-score <-2.5) at either the lumbar spine or the femoral neck Exclusion: Metabolic bone disease other than postmenopausal osteoporosis, use of bone-active agents (any previous use of bisphosphonates, concomitant use of oral glucocorticoids, or hormone replacement therapy use less than 6 months before the study), diseases that affect bone turnover, history of gastrointestinal mucosal disorders (erosive gastritis, gastric ulcer or esophagitis), history of a prior thromboembolic disease, liver or kidney disease, insulin-treated diabetes, history of uterus or breast cancer, or uncontrolled hypertension. Control group was 59 healthy women of the same age Excluded: 2 women who did not answer the question about self perceived LI Inclusion age: >60 Followup: NA Mean age: 62–78 | Diagnosis of LI: Adult-type hypolactasia, caused by the lactase-phlorizin hydrolase C/C-13910 genotype Diet: Self reported Diet assessment: Calcium intake was calculated from dairy products only. The questionnaire was not validated. Control for bias: Adjustment | Test: lactase-phlorizin hydrolase C/T-13910 polymorphism and self reported LI Race: Caucasian Ethnicity: NS
Enattah, 2005^9^ Country: Finland Population: Elderly Source: Population based cohort The Cardiovascular Risk in Young Finns Study Study design: Prospective cohort | Inclusion: Vantaa 85+ population-based study of all subjects born before April 1, 1906, who were living in the city of Vantaa, Finland, on April 1, 1991; included 483 people older than 85 years of age (106 men and 377 women). Exclusion: NR Excluded: The data on milk product intake was available on 399 of 483 subjects Inclusion age: 85 - 98 Followup: 8 years Mean age: 89 | Diagnosis of LI: Adult-type hypolactasia, caused by the lactase-phlorizin hydrolase C/C-13910 genotype Diet: Self reported Diet assessment: The data on consumption of milk was based on interviews of the participants Control for bias: Adjustment | Test: lactase-phlorizin hydrolase C/T-13910 polymorphism Race: Caucasian Ethnicity: NS
Finkenstedt, 1986^10^ Country: Austria Population: Women Source: NS Study design: Case-control | Inclusion: Cases- women with "idiopathic" osteoporosis confirmed by the presence of reduced bone mineral density in plain x-ray films and either a femoral trabecular index <5 in 4 degree or the presence of spontaneous fractures of vertebrae or long bones, or both. Controls: 33 women without osteoporosis (Singh index >4) of the same ethnic origin matched for age Exclusion: Endocrine disorders, liver and renal disease, postgastrectomy states, malabsorption syndromes, rheumatoid arthritis, osteomalacia, and malignancy and patients receiving corticosteroids. Patients and controls were not taking drugs that influenced calcium or bone metabolism Excluded: NR Inclusion age: Adults Followup: NA Mean age: 54–56 | Diagnosis of LI: Lactose malabsorption as a rise in glucose concentration of <20 mg/100 ml) after the ingestion of 50 g lactose dissolved in water Diet: Self reported Diet assessment: A questionnaire about mean daily or weekly ingestion of dairy products and about tolerance to milk in childhood and later life. The daily calcium intake derived from milk and dairy products was calculated according to standard nutritional tables Control for bias: Matching | Test: Self reported symptoms related to milk intolerance and diagnosis of lactose intolerance Race: Caucasian Ethnicity: Caucasian
Goulding, 1999^11^ Country: New Zealand Population: Middle age and older women Source: Population based Study design: Prospective | Inclusion: Healthy Caucasian women ages 40–79 years Exclusion: Medications affecting bones, history of gastro-intestinal surgery, radiotherapy, hip replacement, malapsorption syndromes, hyperthyroidism, hyperparathyroidism Excluded: NR Inclusion age: 40–79 Followup: 1 year Mean age: NR | Diagnosis of LI: Lactose malabsorption: Positive hydrogen test, >10ppmH2 above baseline 60–180 min after lactose load Diet: Self reported Diet assessment: Food frequency questionnaire and 4-day diet records Control for bias: Adjustment | Test: breath hydrogen after a 50 g oral lactose tolerance test Race: Caucasian Ethnicity: NR
Gugatschka, 2005^12^ Country: Austria Population: Adult males Source: Population based and out-patient in the Division of Endocrinology and Nuclear Medicine Study design: Cross-sectional | Inclusion: Participants in the population- based study by the Austrian Study Group on Normative Values on Bone Metabolism and out-patients who had examination of bone metabolism and nutritional and constitutional factors, response rate 56% Exclusion: Liver or kidney disease, primary hyperparathyroidism, long-term use of corticosteroids, other possible causes of secondary osteoporosis, consumption of bone-active medication, alcoholism Excluded: Breath hydrogen test was performed in 52 women (22%) Inclusion age: Adults Followup: NA Mean age: 56±12 | Diagnosis of LI: Lactose malabsorption was diagnosed when the difference between breath hydrogen concentration at baseline and maximum exceeded 20 parts per million according to international standards (ppm). Diet: Self reported Diet assessment: Calcium intake from dairy and other food products and self perceived lactose intolerance (nonmilk drinkers) were obtained using a questionnaire Control for bias: None | Test: Self reported symptoms related to milk intolerance and diagnosis of lactose intolerance Race: Caucasian Ethnicity: Caucasian
Gugatschka, 2007^13^ Country: Austria Population: Elderly male Source: Population based and out-patient in the Division of Endocrinology and Nuclear Medicine Study design: Cross-sectional | Inclusion: Participants in the population- based study by the Austrian Study Group on Normative Values on Bone Metabolism and out-patients who had examination of bone metabolism and nutritional and constitutional factors, response rate 56% Exclusion: Liver or kidney disease, primary hyperparathyroidism, long-term use of corticosteroids, other possible causes of secondary osteoporosis, consumption of bone-active medication, alcoholism Excluded: Breath hydrogen test was performed in 52 women (22%) Inclusion age: Elderly Followup: NA Mean age: 61±9 | Diagnosis of LI: Lactose malabsorption was diagnosed when the difference between breath hydrogen concentration at baseline and maximum exceeded 20 parts per million according to international standards (ppm). Diet: Self reported Diet assessment: Standardized calcium questionnaire Control for bias: None | Test: Self reported symptoms related to milk intolerance and diagnosis of lactose intolerance Race: Caucasian Ethnicity: Caucasian
Harma, 1988^14^ Country: Finland Population: Elderly women Source: Hospital based Study design: Case-control | Inclusion: Cases: 18 women with spinal fragility fractures and 28 women with hip fractures within one week after the fracture. Healthy controls: 35 female of the same ethnic background hospitalized for cataract surgery or other minor operations Exclusion: Institutionalized patients, previous gastric surgery, hepatic or renal failure, metabolic bone diseases, drugs altering bone metabolism Excluded: NR Inclusion age: 38–84 with spinal fractures, 64–93 with hip fractures, and 45–86 healthy controls) Followup: NA Mean age: 67–78 years | Diagnosis of LI: Lactose malabsorpion as positive blood glucose test (<1.3mmol/L) Diet: Self reported Diet assessment: Interview to assess daily milk consumption Control for bias: Matching | Test: Blood glucose test Race: Caucasian Ethnicity: Caucasian
Honkanen, 1997^15^ Country: Finland Population: Perimenopausal women Source: Population based Study design: Cross-sectional | Inclusion: A random population sample of 11,619 women of the 13,100 respondents who also responded to the fracture and health disorder questions. A random stratified sample of 3,222 of these 13,100 women underwent bone densitometry. Exclusion: Not reported Excluded: NR Inclusion age: NR Followup: None Mean age: 52.4± 2.9 | Diagnosis of LI: Positive lactose tolerance test Diet: Self reported Diet assessment: Dairy calcium intake was computed as the sum intake from fluid milk products (l20 mg/dL) and cheese (87 mg/slice) in 1989. The validity of the dairy calcium intake inquiry was tested against a 4 day food record of total nutritional calcium intake 76 women, resulting in a correlation of 0.50 Control for bias: Adjustment | Test: Lactose tolerance test and abdominal symptoms during the test Race: Caucasian Ethnicity: NS
Honkanen, 1996^16^ Country: Finland Population: Perimenopausal women Source: Population based Study design: Cross-sectional | Inclusion: A random population sample of 2,025 women 48–59 years old, who underwent spinal and femoral BMD measurement with dual x-ray absorptiometry in Kuopio, Finland, during 1989–1991 Exclusion: Not reported Excluded: NS Inclusion age: 47–56 Followup: None Mean age: 54±9 | Diagnosis of LI: Positive lactose tolerance test (serial blood glucose determinations after a 50 g oral dose of lactose). Diet: Self reported Diet assessment: Dairy calcium intake was estimated with two questions: (1) “How many deciliters of milk products (such as milk, buttermilk, processed sour milk, and yogurt) do you use daily on average?” and (2) “How many slices of cheese do you use daily on average?” Dairy calcium intake was computed as the sum of calcium derived from fluid milk products (120 mg/dL) and cheese (87 mglslice) based on the NUTRICA, a PC-program for nutritional data developed by the Social Insurance Institution of Finland. The validity of the questionnaire was tested against a 4-day food record completed by 76 women (39 LI and 37 control women) in 1990. Control for bias: Adjustment | Test: Lactose tolerance test and abdominal symptoms during the test Race: Caucasian Ethnicity: NS
Horowitz, 1987^17^ Country: Austria Population: Postmenopausal women Source: Clinic based Study design: Cross-sectional | Inclusion: 48 randomly selected untreated women with postmenopausal osteoporosis from 50 to 83 years Exclusion: Recent fractures Excluded: NR Inclusion age: 50–83 Followup: NA Mean age: 65 | Diagnosis of LI: Lactose malabsorpion as positive hydrogen breath test, LI- self reported symptoms during and after the test Diet: Self reported Diet assessment: Questionnaire to record milk intake before the diagnosis of osteoporosis and the presence of symptoms of LI Control for bias: None | Test: Breath hydrogen and interview by blinded to the results of the test researchers to assess symptoms of LI Race: NR Ethnicity: NR
Infante, 2000^18^ Country: Spain Population: Children and adolescents Source: Clinic based Study design: Cross-sectional | Inclusion: Thirty children followed dietary advice to exclude dairy for at least 2 years: 10 patients with late-onset, genetically induced lactose intolerance (breath hydrogen test >20 ppm), 3 patients with short bowel syndrome, 7 with cow's milk protein allergy and l0 with hypercholesterolemia (cholesterol >200 mg/dl and low-density lipoprotein cholesterol >130 mg/dl).14 patients received special formulas for children (lactose-free cow's milk formula, highly hydrolyzed cow's milk protein formula, soy protein isolate formula), 4 patients received liquid soy beverages, 6 patients received skim milk (1% fat), and 6 patients had exclusion of dairy products. Exclusion: NR Excluded: NR Inclusion age: 2–14 years Followup: NA Mean age: 7 | Diagnosis of LI: Medical diagnosis Diet: Advised Diet assessment: Questionnaire commenting dairy food (or substitute)o consumption for a total of 7 days during a 4-week period Control for bias: None | Test: NS Race: NS Ethnicity: NS
Kanis, 2005^19^ Country: UK Population: Adults Source: Population based Study design: Meta-analysis of individual patient data | Inclusion: Meta-analysis of the original data from 6 prospective cohorts that recruited randomly selected from the populations in Europe, Australia, and Canada 39,563 men and women. The collaborative study to identify clinical risk factors for fracture included the European Vertebral Osteoporosis Study (EVOS/EPOS study), the Canadian Multicentre Osteoporosis Study (CaMos), the Dubbo Osteoporosis Epidemiology Study (DOES), the Rotterdam Study, the Sheffield Study and a cohort from Gothenburg. Exclusion: Invalidated data on milk consumption Excluded: NR Inclusion age: Adults Followup: Total 3.8 years, 151,957 person years for 39,563 subjects Mean age: Varied in the studies, the ranges 21–103 | Diagnosis of LI: Reference category of low milk intake <1 glass of milk/day (~250 mg calcium/day). A threshold of <500 mg of calcium was used two studies (Rotterdam and DOES) assuming that ~50% of calcium intake is in the form of milk. Diet: Self reported Diet assessment: Validated food frequency questionnaire or dietary intake questionnaire Control for bias: Adjustment | Test: Not addressed Race: NS Ethnicity: NS
Kudlacek, 2002^20^ Country: Austria Population: Adults Source: Clinical based screening Study design: Cross-sectional | Inclusion: Healthy individuals who were referred for confirmation of suspected osteoporosis or for osteoporosis screening and estimation of risk for fracture; male female ratio, 1:4 Exclusion: Secondary osteoporosis, medical treatment, e.g., receiving hormone replacement therapy, fluorides, calcitonin, or vitamin D, other gastrointestinal diseases, e.g., celiac disease or chronic inflammatory bowel disease, a history of fracture due to severe trauma. Excluded: NR Inclusion age: NR Followup: NA Mean age: 58.2± 11.5 | Diagnosis of LI: Lactose intolerance was diagnosed with a positive hydrogen breath test. Lactose malabsorbers moderate, 20ppm <DH2 < 59ppm or was severe (DH2 >60ppm). Clinical symptoms were categorized as moderate (group 1) or severe (group 2). Symptoms during the test were scored with a self-reported questionnaire. Group 0 reported no symptoms; group 1 experienced abdominal discomfort (moderate symptoms); and group 2, severe diarrhea with abdominal cramps (severe symptoms). Diet: Self reported Diet assessment: Questionnaire to categorize as lactose exclusion (denied milk consumption), low lactose diet (1 glass per day ~ 200ml milk; 240mg calcium/day) no restrictions with regard to milk (>400ml milk; 480mg calcium/day). Control for bias: None | Test: Hydrogen breath test, self reported symptoms Race: Caucasian Ethnicity: Caucasian
Kull, 2009^21^ Country: Estonia Population: Adults Source: Health care based: registers of general practitioners in the region Study design: Cross-sectional | Inclusion: Randomly selected from the registers healthy subjects, response rate 66% (200 F, 167 M) Exclusion: NR Inclusion age: >20 Followup: NA Mean age: 25–70 | Diagnosis of LI: Adult-type hypolactasia was diagnosed by direct sequencing of the LCT gene Diet: Self reported Diet assessment: Questionnaire about milk and dairy product consumption, self- perceived milk tolerance Control for bias: None | Test: Self-reported milk intolerance and direct sequencing of the LCT gene Race: Caucasian Ethnicity: Caucasian
Lehtimaki, 2006^22^ Country: Finland Population: children and adolescents Source: Population based cohort The Cardiovascular Risk in Young Finns Study Study design: Prospective cohort | Inclusion: A random sample from the national population register, from 5 university cities in Finland and the rural municipalities in their vicinity Exclusion: Not reported Excluded: 2,265 from original 3,596 participants had genotyping exam Inclusion age: 3–18 years Followup: 21 years Mean age: 10 | Diagnosis of LI: Adult-type hypolactasia, caused by the lactase-phlorizin hydrolase C/C-13910 genotype Diet: Self reported Diet assessment: Dietary questionnaires, detailed dietary interviews, and a 48-hour dietary recall Control for bias: Stratification by sex and onset of LI | Test: Lactase-phlorizin hydrolase C/T-13910 polymorphism Race: Caucasian Ethnicity: NS
Matlik, 2007^23^ Country: USA Population: 10–13 year old female adolescents Source: Participants in a sub study of the multiple-site project Adequate Calcium Today Study design: Cross-sectional study was a sub study of the Adequate Calcium Today (ACT) project, a school- randomized intervention project conducted at sites in 6 states | Inclusion: Middle schools that had larger proportions of Asian or Hispanic students than the state average and were located within a 1-hour distance from the designated dual-energy x-ray absorptiometry (DXA) measurement site (1 site in each state). Girls were eligible if they were at least 75% Asian, Hispanic, or non-Hispanic white, as self- reported by their biological parents Exclusion: Estimated daily food calcium intakes that were 100 mg/day or 2,500 mg/day were considered improbable, and individuals with such values were excluded from any analyses using food calcium intake. Excluded: A total of 39 (13.5%) of 289 subjects were excluded Inclusion age: 10–13 years Followup: None Mean age: 11. | Diagnosis of LI: Lactose maldigestion diagnosed with hydrogen breath testing (breath hydrogen levels of >20 ppm), perceived milk intolerance diagnosed with questionnaires Diet: Self reported diet Diet assessment: Calcium-specific, semi quantitative, food frequency questionnaire developed for and evaluated with Asian, Hispanic, and non-Hispanic white youths Control for bias: Adjustment | Test: Perceived milk intolerance was diagnosed with questionnaire included 3 statements derived from focus group discussions with a sample of adolescents representing the same age group and race/ethnic groups as the ACT participants.30 The statements were as follows: (1) “I am allergic to milk,” (2) “I get a stomachache after drinking milk,” and (3) “I have been told that milk will make my stomach hurt after I drink it.” Responses were “strongly disagree” (scored as 1) to “strongly agree” (scored as 5) or “do not know” (scored as missing). A PMI score was calculated as a mean of the responses. The frequency of responses separated distinctly above 2; therefore, a score of 2 was defined to be indicative of PMI Race: Among 230 girls :65 Asian, 76 Hispanic, and 89 non- Hispanic white
Obermayer-Pietsch, 2007^24^ Country: Austria Population: Postmenopausal women Source: Participants in a genetic screening study for osteoporosis Study design: Prospective followup of the previously published study | Inclusion: Unrelated postmenopausal women who live independently Exclusion: Liver or kidney disease, primary hyperparathyroidism or other causes of bone disease Excluded: 60 Inclusion age: Adults Followup: 61±9months Mean age: 65±9 | Diagnosis of LI: Hydrogen breath test and glucose blood test, symptoms Diet: Self reported Diet assessment: Detailed food-frequency questionnaire on dietary calcium intake in milligrams per day Control for bias: None | Test: LCT genotypes TT, TC, and CC Race: NR Ethnicity: NR
Obermayer-Pietsch, 2004^25^ Country: Austria Population: Postmenopausal women Source: Participants in a genetic screening study for osteoporosis Study design: Cross-sectional study | Inclusion: Unrelated postmenopausal women Exclusion: Liver or kidney disease, primary hyperparathyroidism, other causes of secondary bone disease, consumption of bone active medication Excluded: 92 Inclusion age: Adults Followup: None Mean age: 62 ± 9 | Diagnosis of LI: Recorded by the general practitioner during the standardized interview, self reported dislike of milk taste, and aversion to milk consumption Diet: Self reported Diet assessment: Detailed food-frequency questionnaire on dietary calcium intake in milligrams per day Control for bias: Adjustment | Test: LCT genotypes TT, TC, and CC Race: NR Ethnicity: NR
Segal, 2003^26^ Country: Israel Population: Adults Source: Clinic based Study design: Cross-sectional | Inclusion: Seventy-eight consecutive patients 20 to 78 years of age, with clinical signs of LI referred to gastroenterologists or recruited from the Gastroenterology Unit Exclusion: Ontogenesiimperfect; chronic renal failure; hypocalciuric hypercalcemia; history of recent malignancy Excluded: 12 Inclusion age: 20–78 Followup: NA Mean age: 66 patients, 49 women (18 premenopausal, 31 postmenopausal), 17 men | Diagnosis of LI: Positive breath test in addition to clinical symptoms (concentration of H2 in the expired air increased by more than 20 ppm above baseline) Diet: Self reported Diet assessment: Calcium intake from dairy and other sources was evaluated using a semi-quantitative food frequency questionnaire adapted from W. Willet Control for bias: Matching by age and gender | Test: Clinical diagnosis was confirmed in all patients by positive breath test. Race: NS Ethnicity: NS
Stallings, 1994^27^ Country: USA Population: Prepubertal children Source: Children's Hospital of Philadelphia Study design: Cross sectional controlled comparison | Inclusion: Prepubertal children 6–12 years with LI diagnosed with standard breath hydrogen test within the previous 3 years, without symptoms related to LI at the time of the study. Healthy children participating in the Fels Longitudinal Study Exclusion: Significant illnesses that could affect growth or bone development including inflammatory bowel syndrome, renal failure, cardiac disease, sarcoidosis. Consume Ca++ supplement and/or>16oz milk products Excluded: One girl without suitable control Inclusion age: 6–12 years Followup: None Mean age: 9.6±1.9 | Diagnosis of LI: LI diagnosed by standard breath hydrogen test Diet: prescribed low lactose diet Diet assessment: Food frequency questionnaire of 7 days over 6 week period to evaluate adherence to prescribed diet Control for bias: Matching, Adjustment for body size | Test: Breath hydrogen test Race: NR Ethnicity: NR.
Vigorita, 1987^28^ Country: USA Population: Postmenopausal women Source: NS Study design: Cross-sectional | Inclusion: Postmenopausal women with the osteoporotic spinal compression fracture syndrome Exclusion: Concurrent malabsorption syndromes, endocrinopathies, marrow tumor, or prior therapy Excluded: 3 women with normal and 6 women with abnormal lactose tolerance test were excluded from bone biopsy analyses Inclusion age: >53 Followup: None Mean age: 66.3–70.3 | Diagnosis of LI: Positive lactose tolerance test; Patients who had less than a 30% mg/dl rise in blood glucose were termed lactase deficient Diet: Self reported Diet assessment: Interviews conducted by a registered dietician using a questionnaire based on dietary preference, 24-hour recall, and weekly intake Control for bias: None | Test: Oral lactose tolerance tests Race: Caucasian Ethnicity: All Whites, not Hispanic
Wheadon, 1991^29^ Country: New Zealand Population: Elderly New Zealand women with hip fractures Source: NS Study design: Case-control | Inclusion: Cases-women <75 years of age with hip fractures 6 months-2 years before the study diagnosed with type II osteoporosis. Controls: 16 healthy age- matched women who had never had a fracture and 50 healthy young volunteers (17–30 years old) Exclusion: Previous surgery of gastro-intestinal tract, baseline reasons for malabsorption Excluded: NR Inclusion age: Cases-<75 years old, age matched controls, healthy controls 17–30 years Followup: NA Mean age: 66±10 | Diagnosis of LI: Lactose malabsorption- breath hydrogen after a 50 g oral lactose tolerance test of >10ppm above baseline Diet: Self reported Diet assessment: Dietary calcium was estimated from a food frequency questionnaire Control for bias: Age matched controls | Test: breath hydrogen after a 50 g oral lactose tolerance test Race: Caucasian Ethnicity: 1 women from India
Studies of low lactose diet that did not address lactose intolerance status
Appleby, 2007^30^ Country: UK Population: Vegetarians; adults Source: The Oxford cohort of the European Prospective Investigation into Cancer and Nutrition (EPIC-Oxford) Study design: Prospective cohort | Inclusion: The Oxford cohort of the European Prospective Investigation into Cancer and Nutrition (EPIC-Oxford) general practice surgeries recruited 57,450 adults from the residential areas and several general practice surgeries in the UK Exclusion: NR Excluded: 240 participants who did not answer the question about fractures, 1,360 who reported any type of fracture before recruitment or a fracture of the digits or ribs, and 660 whose nutrient intake data were considered to be unreliable (>20% of food frequencies missing or daily energy intakes less than 800 kcal or more than 4,000 kcal for men or less than 500 kcal or more than 3,500 kcal for women). Inclusion age: NR Followup: 6 years Mean age: 46.6 | Diagnosis of LI: Not addressed Diet: Self reported Diet assessment: Food frequency questionnaire Control for bias: Adjustment | Test: Not addressed Race: NR Ethnicity: NR
Bauer, 1993^31^ Country: USA Population: Older women Source: The Study of Osteoporotic Fractures Research Group Study design: Cross-sectional | Inclusion: 9,704 ambulatory, nonblack women, ages 65 years or older Exclusion: Blacks or unable to walk without the assistance of another person or who had bilateral hip replacements Excluded: NR Inclusion age: >65 Followup: NA Mean age: 71.1 | Diagnosis of LI: Not addressed Diet: Self reported Diet assessment: Checklist-interview method developed from the HANES-II survey to asses dietary Ca++ (correlation of 0.76 with calcium intake assessed by a 7-day diet diary) and milk intake Control for bias: Adjustment | Test: Not addressed Race: Caucasian Ethnicity: Whites Calcium intake from milk as a teenager, between ages 18 and 50, and after age 50 years, adjusted for current calcium intake, was associated with increased bone mass: women who drank milk at every meal, between ages 18 and 50, had 3.1% higher bone mass compared with those who rarely or never drank milk
Black, 2002^32^ Country: New Zealand Population: Prepubertal children with a history of long- term milk avoidance Source: Population based Study design: Cross-sectional | Inclusion: Caucasian children ages 3–10 years with a history of prolonged milk avoidance for more than 4 months Exclusion: Gait disorders, current bone fractures, or medical diagnoses affecting bone (e.g., diabetes or malabsorptive syndromes) Excluded: None Inclusion age: Children Followup: NA Mean age: 5.9±1.9 (female) and 6.4±2.3 (male) | Diagnosis of LI: Not diagnosed Diet: Self reported prolonged milk avoidance Diet assessment: Validated food-frequency questionnaire; current calcium intakes were estimated both by the same FFQ used at baseline and by 4-day diet records (4DDRs), which we collected just before the followup clinic appointment to avoid post interview bias. Control for bias: None | Test: Self reported symptoms related to milk avoidance Race: Caucasian Ethnicity: NR Sex-specific, age-adjusted Z scores were derived from a reference population of 100 boys and 100 girls without history of fracture or milk avoidance living in Dunedin
Chiu, 1997^33^ Country: Taiwan Population: Postmenopausal Taiwanese women Source: 10 temples in Tai-nan and Kaoshiung, two of the largest counties in southern Taiwan. Study design: Cross-sectional | Inclusion: 258 postmenopausal Buddhist nuns and female religious followers of Buddhism in southern Taiwan Exclusion: Disease or therapy known to affect bone metabolism Excluded: NR Inclusion age: 40–87 Followup: NA Mean age: 60.8 ± 9.2 | Diagnosis of LI: Not addressed Diet: Vegan diet Diet assessment: Questionnaire interview to identify type of vegetarian practiced (strict vegan, lacto vegetarian, or omnivore who ate vegan diet only periodically). Long- term vegan vegetarians were defined in this study as those who had adhered to a strict vegan vegetarian diet for at least 15 years. Dietary assessment included a 24-hour recall and food frequency questionnaire Control for bias: Adjustment | Test: Not addressed Race: Asian Ethnicity: Asian
Cumming, 1994^34^ Country: Australia Population: Elderly women and men Source: Population-based control Study design: Case-control | Inclusion: Cases-patients with acute hip fracture older than 65 years of age were recruited in 12 hospitals. Controls were selected in a defined region in Sydney, Australia, using an area probability sampling method, with additional sampling from nursing homes Exclusion: NR Excluded: Exposure data was not available for 42% of cases because of impaired cognitive function and difficulties collecting proxy responses Inclusion age: >75 Followup: NA Mean age: NR | Diagnosis of LI: Not addressed Diet: Self reported Diet assessment: Interview administered questionnaire, proxy responders. To assess recall bias, all participants were asked what cases hip fractures in old age. Dairy intake was categorized in units, 1 unit of dairy products was equal 1 glass of milk+0.5 servings of chees+0.5 (milk on cereal) Control for bias: Adjustment | Test: Not addressed Race: NR Ethnicity: NR
Feskanich, 1997^35^ Country: USA Population: Middle aged women Source: The Nurses’ Health Study Study design: Prospective cohort | Inclusion: 77,761 women, ages 34–59 years in 1980, who had never used calcium supplements were selected from the original cohort of 121,701 female registered nurses in 11 states who were 30 to 55 years of age when they returned an initial questionnaire in 1976 Exclusion: Implausibly low or high daily food intake or failure to report frequency of milk consumption (6%); a previous hip or forearm fracture or a diagnosis of coronary heart disease, stroke, cancer, or osteoporosis (6%); and reported use of calcium supplements in 1982 (9%). Excluded: 0.21 Inclusion age: 34–59 Followup: 12 years Mean age: 45.8–46.4 | Diagnosis of LI: Not addressed Diet: Self reported Diet assessment: Food-frequency questionnaire to collect four dairy items were added: cream or whipped cream, sour cream, sherbet or ice milk, and cream cheese. In validation studies the questionnaire was compared with multiple weeks of diet records, correlations were 0.81 for skim or low-fat milk, 0.62 for whole milk, and 0.57 for dietary calcium. In a reproducibility study that compared the frequency of milk consumption during their teenage years (ages 13 to 18) with data from a second administration 8 years later, the correlation was 0.71. Control for bias: Adjustment | Test: Not addressed Race: Caucasian Ethnicity: 98% of the cohort is White
Fujiwara, 1997^36^ Country: Japan Population: Adults Source: The Adult Health Study Study design: Prospective cohort | Inclusion: 4,869 residents in Hiroshima and Nagasaki ages 32 years who responded to the mail questionnaire survey conducted in 1979–1981. Exclusion: Incident hip fractures due to traffic accidents Excluded: 285 who lacked measurements of height and weight and 11 who were diagnosed as having hip fracture in the 1978–1980 examination were excluded Inclusion age: >32 Followup: 18 Mean age: 58.5 ± 12.2 | Diagnosis of LI: Not addressed Diet: Self reported Diet assessment: Questionnaire survey about food frequency Control for bias: Adjustment | Test: Not addressed Race: Asian Ethnicity: Asian
Goulding, 2004^37^ Country: New Zealand Population: Prepubertal children with a history of long- term milk avoidance Source: Population based Study design: Prospective followup of the previously published study | Inclusion: Caucasian children ages 3–10 years with a history of prolonged milk avoidance for more than 4 months Exclusion: Gait disorders, current bone fractures, or medical diagnoses affecting bone (e.g., diabetes or malabsorptive syndromes) Excluded: 4 Inclusion age: Children Followup: 2 years Mean age: 3–10 years | Diagnosis of LI: Not diagnosed Diet: Self reported prolonged milk avoidance Diet assessment: Validated food-frequency questionnaire; current calcium intakes were estimated both by the same FFQ used at baseline and by 4-day diet records (4DDRs), which we collected just before the followup clinic appointment to avoid post interview bias. Control for bias: None | Test: Self reported symptoms related to milk avoidance Race: Caucasian Ethnicity: NR Data from the Dunedin Multidisciplinary Health and Development Study (a birth cohort >1,000 children born in 1972/1973) was used to provide comparative fracture incidence in the general community
Johansson, 2004^38^ Country: UK Population: Elderly women Source: population based Study design: Placebo arm in RCT, prospective | Inclusion: 2,113 women >75 years of age randomly selected from Sheffield, UK, and adjacent regions who were randomized to placebo group in RCT of Ca++ supplement. 35,000 were invited, 5,873 responded (response rate 17%) Exclusion: Bone active agents, known malabsorption states, lack of compliance because of a poor mental state or concurrent illnesses, serum creatinine >0.3 mM, leukopenia (white cell count, <2 109/liter), hyper- or hypocalcemia, and elevated transaminases (greater than twice the upper reference limit). Excluded: 683 women randomized to placebo group Inclusion age: >75 Followup: 6 years Mean age: NR | Diagnosis of LI: Not addressed Diet: Self reported Diet assessment: Questionnaire to record milk intake Control for bias: Adjustment | Test: Not addressed Race: NR Ethnicity: NR
Johnell, 1995^39^ Country: Sweden Population: Women Source: The MEDOS Study. Mediterranean Osteoporosis Study Study design: Case-control | Inclusion: Cases: 2,086 women ages 50 years or more with hip fracture (interviewed within 14 days of fracture) in 14 centers from Portugal, Spain, France, Italy, Greece, and Turkey. Controls: 3,532 women ages 50 years or more selected from the neighborhood or population registers Exclusion: Poor mental health, concurrent illness Excluded: 80% of cases and 84% of controls were intervwied Inclusion age: >50 Followup: NA Mean age: 77.7–78.1 | Diagnosis of LI: Not addressed Diet: Self reported Diet assessment: Cases and controls were interviewed using a structured questionnaire on consumption of milk. Ca++ from milk in the recent past, young adulthood and childhood was assessed with 5 point scale (0–4: never, sometimes, 1–2 glasses/day, 3–4 glasses/day, >5 glasses/day) An overall score was calculated from three measurements with max 12 points. The median score was 6~ lifetime 1–2 glasses of milk/day or 240–480mg Ca++/day Control for bias: Adjustment | Test: Not addressed Race: NR Ethnicity: NR
Kalkwarf, 2003^40^ Country: USA Population: Adults Source: Population based Study design: Cross-sectional | Inclusion: The third National Health and Nutrition Examination Survey of 3,251 non- Hispanic, white women age ≥20 not institutionalized in 1988 and 1994 using a stratified, multistage probability design to select a nationally representative sample Exclusion: Unacceptable bone measurements Excluded: Exclusion of fractures associated with severe trauma did not affect the results Inclusion age: Adults Followup: NA Mean age: 35±8 | Diagnosis of LI: Not defined Diet: Self reported Diet assessment: Milk intake during childhood was examined during the household interview with the questionnaire targeted 5 distinct age periods: childhood (5–12 years), adolescence (13–17 years), young adulthood (18–35 years), middle adulthood (36–65 years), and later adulthood (> 65 years). Subjects were asked to recall how often they consumed any type of milk, responses were collapsed into 4 categories: >1/day, 1/day, 1–6/week, and <1/week. Current milk intake was derived from the food-frequency questionnaire with the same categories as the historical milk intake information. Calcium intake was estimated from the 24-hour recall conducted during the MEC visit. The 24-hour recall was conducted with the use of an automated, interactive dietary data-collection system that was developed by the University of Minnesota Nutrition Coordinating Center. Food composition data were based on the US Department of Agriculture data files specific for that time period Control for bias: Adjustment | Test: Not addressed Race: Caucasian Ethnicity: Non-Hispanic, white Among women ages 20–49 years, bone mineral content was 5.6% lower in those who consumed <1 serving of milk/week (low intake) than in those who consumed >1 serving/day (high intake) during childhood (P < 0.01). Low milk intake during adolescence was associated with a 3% reduction in hip bone mineral content and bone mineral density (P <0.02). Among women ages ≥50 years, there was a nonlinear association between milk intake during childhood and adolescence and hip bone mineral content and bone mineral density (P < 0.04).
Kelsey, 1992^41^ Country: USA Population: Older women Source: The Study of Osteoporotic Fractures Research Group Study design: Cross-sectional | Inclusion: 9,704 ambulatory, nonblack women, ages 65 years or older Exclusion: Blacks or unable to walk without the assistance of another person or who had bilateral hip replacements Excluded: NR Inclusion age: >65 Followup: NA Mean age: 71.1 | Diagnosis of LI: Not addressed Diet: Self reported Diet assessment: Checklist-interview method developed from the HANES-II survey to asses dietary Ca++ (correlation of 0.76 with calcium intake assessed by a 7-day diet diary) and milk intake Control for bias: Adjustment | Test: Not addressed Race: Caucasian Ethnicity: Whites
Lau, 1998^42^ Country: Hong Kong Population: Elderly Chinese vegetarian women Source: Population based Study design: Cross-sectional | Inclusion: 76 vegetarian for over 30 years noninstitutionalized Buddhist women (ages 70±89 years). 250 Chinese omnivorous women, participants in a previous dietary survey, served as controls Exclusion: NR Excluded: NR Inclusion age: 70–89 Followup: NA Mean age: 79.1±5.2 | Diagnosis of LI: Not addressed Diet: Vegan diet Diet assessment: The 24 hour recall method administered by a single trained interviewer. Control for bias: None | Test: Not addressed Race: Asian Ethnicity: Asian
Looker, 1993^43^ Country: USA Population: Men and posmenopausal women Source: the NHANES I Epidemiologic Follow-Up Study cohort Study design: Prospective cohort | Inclusion: Nationally representative sample of the United States population: 4,342 white men and postmenopausal women ages 50–74 years at baseline (1971–1975) were observed through 1987 for up to 16 years of followup Exclusion: African American Excluded: NR Inclusion age: >50 Followup: 16 years Mean age: NR | Diagnosis of LI: Not addressed Diet: Self reported Diet assessment: 24-hour recall and qualitative food frequency questionnaire to obtain weekly frequency of dairy food consumption. Daily calcium intake was categorized: 0–405, 406–654, 655–1,003 and >1,004 for men; 0–300, 301–501, 502–776, and ≥777 for all women; 0–292, 293–500, 501–755 and >756 for late menopausal women. Daily Ca++ intake was also categorized by selected cutoff points: <400 rag/day versus >600, > 800 or >1,000 rag/day. The food frequency questionnaire assessed weekly frequency, of milk and cheese consumption in the previous 3 months. Ca++ intake index combined both measurement. Control for bias: Adjustment | Test: Not addressed Race: Caucasian Ethnicity: Whites
Nieves, 1992^44^ Country: USA Population: Middle aged women Source: Clinic based Study design: Case-control | Inclusion: Cases: 161 white women admitted to one of 30 participating hospitals with radiologically confirmed diagnosis of a first hip fracture. Controls included 168 white women from general and orthopedic surgical services frequency-matched to cases by age group and hospital. The response rate was 61% in the case group and 56% in the controls; respondents were similar to nonrespondents with respect to age and city Exclusion: Previous hip fracture or hip replacement; cognitive impairment, death prior to interview, severe language and hearing impairments or medical instability Excluded: 143 potential cases and 44 potential controls with proxy responses Inclusion age: >45 Followup: NA Mean age: 50–103 | Diagnosis of LI: Not addressed Diet: Self reported Diet assessment: Standardized questionnaire to all cases and controls to assess frequency of consumption of milk, cheese and dark green leafy vegetables was used to estimate calcium intake during the teen years Control for bias: Matching by age and hospital, adjustment for BMI, education, smoking, HRT, chronic disease | Test: Not addressed Race: Caucasian Ethnicity: Whites
Parsons, 1997^45^ Country: The Netherlands Population: Adolescents Source: Macrobiotic families connected with the Human Nutrition Department, Wageningen University Study design: Cross-sectional | Inclusion: 195 adolescents (103 girls, 92 boys) ages 9–15 years who followed a macrobiotic diet in childhood (43 girls, 50 boys) and 102 (60 girls, 42 boys) control subjects; response rates of the families 50% Exclusion: Poor health, taking medications that can affect bone health Excluded: 10 families failed to keep appointments Inclusion age: >9 Followup: NA Mean age: 11.6–12.5 | Diagnosis of LI: Not addressed Diet: Macrobiotic children reported following a macrobiotic diet from birth onward for a period of 6.2 6 2.9 (mean 6 SD) years, in most cases subsequently adopting a vegetarian-type diet Diet assessment: Previously validated food frequency questionnaire with added questions to asses non dairy sources of Ca++ Control for bias: Adjustment | Test: Not addressed Race: Caucasian Ethnicity: NR
Rockell, 2005^46^ Country: New Zealand Population: Prepubertal children with a history of long- term milk avoidance Source: Population based Study design: Prospective followup of the previously published study | Inclusion: Caucasian children ages 3–10 years with a history of prolonged milk avoidance for more than 4 months Exclusion: Gait disorders, current bone fractures, or medical diagnoses affecting bone (e.g., diabetes or malabsorptive syndromes) Excluded: 4 Inclusion age: Children Followup: 2 years Mean age: 8.1±2 | Diagnosis of LI: Not diagnosed Diet: Self reported prolonged milk avoidance Diet assessment: Validated food-frequency questionnaire; current calcium intakes were estimated both by the same FFQ used at baseline and by 4-day diet records (4DDRs), which we collected just before the followup clinic appointment to avoid post interview bias. Control for bias: None | Test: Self reported symptoms related to milk avoidance Race: Caucasian Ethnicity: NR Sex-specific, age-adjusted Z scores were derived from a reference population of 100 boys and 100 girls without history of fracture or milk avoidance living in Dunedin
Shaw, 1993^47^ Country: Taiwan Population: Adults Source: Population based Study design: Cross-sectional | Inclusion: 404 healthy volunteers (266 women and 138 men, ages 15 to 83 years) living in Lin-Kou Township Exclusion: History of hip fracture, spine disorders, adrenal gland disorders Excluded: NR Inclusion age: 15–83 Followup: NA Mean age: NR | Diagnosis of LI: Not addressed Diet: Self reported Diet assessment: Interview with a trained technician, food frequency questionnaire of 16 calcium-rich items common for Taiwan Control for bias: None | Test: Not addressed Race: Asian Ethnicity: Asian
Soroko, 1994^48^ Country: USA Population: Older women Source: community based cohort of older women in California Study design: Cross-sectional | Inclusion: 624 postmenopausal White women Exclusion: No data on milk consumption history and had bone mineral density measurements Excluded: 43 Inclusion age: >60 Followup: NA Mean age: 70.6 | Diagnosis of LI: Not addressed Diet: Self reported Diet assessment: Standardized interview with food-frequency questionnaire to assess current dietary calcium intake and calcium supplementation history. Participants also quantified their daily milk consumption during adolescence (12 to 19 years of age), midlife (20 to 50 years of age), and older adulthood (after 50 years of age) as (1) “rarely or never“ (classified as none), (2) “about every week, but not every day“ (low), (3) “1 to 2 glasses per day, about every day“ (medium), or (4) “3 or more glasses per day, about every meal“ (high). Childhood milk intake was not queried because of expected poor recall. Control for bias: Adjustment | Test: Not addressed Race: Caucasian Ethnicity: Whites Higher milk consumption in adulthood was independently and significantly associated with higher bone mineral density levels at the mid radius, spine, total hip, intertrochanter, and trochanter. Higher teenage milk intake was associated with significantly higher bone mineral density at the spine and mid radius. Milk intake was not associated with bone mineral density of the ultradistal wrist. Analyses stratified by calcium supplementation revealed similar patterns
Tavani, 1995^49^ Country: Italy Population: Postmenopausal women Source: 4 largest teaching and general hospitals in Milan Study design: Case-control | Inclusion: Cases: 241 postmenopausal women (median age 64 years, range 45–74 years) admitted to hospital for fracture of the hip. Controls- 719 controls hospitalized patients for acute, non-neoplastic, nontraumatic, nondigestive, non-hormone-related diseases Exclusion: Long-term modifications in diet Excluded: NR Inclusion age: 45–74 Followup: NA Mean age: 64 | Diagnosis of LI: Not addressed Diet: Self reported Diet assessment: Trained interviewers used a structured questionnaire to collect data on frequency of 29 food items before the onset of the disease including major sources of calcium Control for bias: Adjustment | Test: Not addressed Race: NR Ethnicity: NR
Turner, 1998^50^ Country: USA Population: Older women Source: The Third National Health and Nutritional Examination Survey, Phase 1 Study design: Cross-sectional | Inclusion: National sample of 953 southern women ages 50 years and older Exclusion: NR Excluded: NR Inclusion age: >50 Followup: NA Mean age: 68.8 ±11.5 | Diagnosis of LI: Not addressed Diet: Self reported Diet assessment: Food-frequency questionnaire Control for bias: Adjustment | Test: Not addressed Race: 58% Caucasian, 27.6 African American, 14.7% Asian
Vatanparast, 2005^51^ Country: Canada Population: children and adolescents Source: Population based Study design: Prospective cohort | Inclusion: Participants in the University of Saskatchewan Pediatric Bone Mineral Accrual Study (PBMAS)-population-based sample of children in Saskatoon.7-year longitudinal data from 85 boys and 67 girls are analyzed Exclusion: History of chronic disease or chronic medication use, medical conditions, allergies, or medication use known to influence bone metabolism or calcium balance Excluded: NR Inclusion age: 8–20 years Followup: 7 years Mean age: 11.8±0.9 for girls; 13.5±1 for boys | Diagnosis of LI: Not addressed Diet: Self reported Diet assessment: Dietary intake was assessed by serial 24-hour recalls Control for bias: Adjustment | Test: Not addressed Race: Caucasian Ethnicity: Caucasian For every additional 1 mg calcium consumed by boys, 0.017 g BMC was accrued
Wyshak, 1989^52^ Country: USA Population: Women Source: University based Study design: Cross-sectional | Inclusion: 5,398 alumnae listed as currently alive by the alumnae offices of 8 colleges and two universities, response rate 71% Exclusion: NR Excluded: NR Inclusion age: >21 Followup: NA Mean age: 51.3 ±0.2 | Diagnosis of LI: Not addressed Diet: Self reported Diet assessment: Questionnaire to asses any dietary restrictions including low milk intake Control for bias: Adjustment | Test: Not addressed Race: NR Ethnicity: NR

NS - not specified, NA - not applicable, NR - not reported

Appendix Table D2 Association between low dairy Ca++ intake and bone fractures

Study | Comparison | Outcome | Estimate | Mean (95% CI)
Goulding, 2004^37^ Country: New Zealand Prepubertal children with a history of long-term milk avoidance Ca++ intake difference in comparison groups: NR/NR | Calcium intake below 300 mg/day vs. >300mg/day | History of fracture | Crude OR | 1.26 (0.34; 4.65)
Looker, 1993^43^ Country: USA Men and postmenopausal women Ca++ intake difference in comparison groups: NR/Y | Selected calcium cut points (mg~day) <400 vs. >1,000 in men | History of fracture | Adjusted for alcohol use, smoking, physical activity, BMI, and postmenopausal hormone use in the total sample of women in addition to age RR | 0.51 (0.20; 1.10)
Looker, 1993^43^ Country: USA Men and postmenopausal women Ca++ intake difference in comparison groups: NR/Y | Selected calcium cut points (mg~day) <400 vs. >1,000 in women | History of fracture | Adjusted for alcohol use, smoking, physical activity, BMI, and postmenopausal hormone use in the total sample of women in addition to age RR | 0.91 (0.50; 1.60)
Looker, 1993^43^ Country: USA Men and postmenopausal women Ca++ intake difference in comparison groups: NR/Y | Selected calcium cut points (mg~day) <400 vs., >1,000 in late menopausal women | History of fracture | Adjusted for alcohol use, smoking, physical activity, BMI, and postmenopausal hormone use in the total sample of women in addition to age RR | 0.73 (0.30; 1.60)
Tavani, 1995^49^ Country: Italy Postmenopausal women Ca++ intake difference in comparison groups: NR/NR | Ca++ intake >1,026mg/day vs. <443mg/day | Hip fracture | Adjusted for age, education, smoking status, total alcohol consumption, and estrogen replacement therapy OR | 1.20 (0.80; 2.00)

Appendix Table D3 Association between lactose intake and genetic polymorphism or self reported lactose intolerance

Study | Comparison | Outcome | Results
Lehtimaki, 2006^22^ Country: Finland Children and adolescents | T/T vs. C/C | Lactose-free or low lactose diet | Statistically insignificant after adjustment for baseline dietary calcium intake, pubertal stage, age, and study area
Lehtimaki, 2006^22^ Country: Finland Children and adolescents | C/T vs. C/C | Lactose-free or low lactose diet | Statistically insignificant after adjustment for baseline dietary calcium intake, pubertal stage, age, and study area
Lehtimaki, 2006^22^ Country: Finland Children and adolescents | T/T vs. C/T | Lactose-free or low lactose diet | Statistically insignificant after adjustment for baseline dietary calcium intake, pubertal stage, age, and study area
Lehtimaki, 2006^22^ Country: Finland Children and adolescents | T/T vs. C/C in women | Lactose-free or low lactose diet | products were significantly lower for subjects with the C/C-13910 genotype than the other genotypes over the study years 1980, 1986, and 2001.
Lehtimaki, 2006^22^ Country: Finland Children and adolescents | C/T vs. C/C in women | Lactose-free or low lactose diet | products were significantly lower for subjects with the C/C-13910 genotype than the other genotypes over the study years 1980, 1986, and 2001.
Lehtimaki, 2006^22^ Country: Finland Children and adolescents | T/T vs./C/T in women | Lactose-free or low lactose diet | products were significantly lower for subjects with the C/C-13910 genotype than the other genotypes over the study years 1980, 1986, and 2001.
Lehtimaki, 2006^22^ Country: Finland Children and adolescents | T/T vs. C/C in men | Lactose-free or low lactose diet | genotype differences in the intake of calcium over the study years, but the consumption of milk and milk products was significantly lower for subjects with the C/C-13910 genotype over the study years from 1980 to 2001 For male subjects >10 years of age, the consumption of milk and dairy products was significantly lower for subjects with the C/C-13910 genotype over the study years from 1980 to 2001.
Lehtimaki, 2006^22^ Country: Finland Children and adolescents | C/T vs. C/C in men | Lactose-free or low lactose diet
Lehtimaki, 2006^22^ Country: Finland Children and adolescents | T/T vs/C/T in men | Lactose-free or low lactose diet
| | | Estimate | Mean (95%CI)
Enattah, 2005^9^ Country: Finland Elderly | T/T or T/C vs. C/C | Use of milk products | OR | 2.06 (1.38; 3.06)
Country: Austria Adult males | T/T vs. C/C | | | 3.79 (1.02; 14.15)
Country: Austria Adult males | C/T vs. C/C | | | 1.84 (0.84; 4.03)
Country: Austria Adult males | T/T vs. C/T | | | 2.07 (0.57; 7.44)
Kull, 2009^21^ Country: Estonia Adults | T/T vs. C/C | Milk consumption (dL/day) | Mean Difference | 1.00 (0.34; 1.66)
Kull, 2009^21^ Country: Estonia Adults | C/T vs. C/C | Milk consumption (dL/day) | Mean Difference | 0.80 (0.21; 1.39)
Kull, 2009^21^ Country: Estonia Adults | T/T vs. C/T | Milk consumption (dL/day) | Mean Difference | 0.20 (−0.51; 0.91)
Kull, 2009^21^ Country: Estonia Adults | Hypolactasia vs. normolactasia | Milk consumption (dL/day) | Mean Difference | −0.80 (−1.32; −0.28)
Kull, 2009^21^ Country: Estonia Adults | Self reported LI vs. none | Milk consumption (dL/day) | Mean Difference | −1.40 (−2.12; −0.68)

Appendix Table D4 Association between low lactose diets, lactose intolerance or malabsorption, and clinical symptoms

Study | Comparison | Outcome | Crude odds Ratio (95% CI)
Dietary preferences as a lifestyle choice
Black, 2002^32^ Country: New Zealand Prepubertal children with a history of long-term milk avoidance Ca++ intake difference in comparison groups: NR/NR | Bad taste of milk vs. not | Presence of milk related symptoms | 0.05 (0.01; 0.24)
Black, 2002^32^ Country: New Zealand Prepubertal children with a history of long-term milk avoidance Ca++ intake difference in comparison groups: NR/NR | Lifestyle choice: The family consumed soymilk or goat milk rather than cow milk vs. not | Presence of milk related symptoms | 0.22 (0.04; 1.21)
Black, 2002^32^ Country: New Zealand Prepubertal children with a history of long-term milk avoidance Ca++ intake difference in comparison groups: NR/NR | Subjects whose family member avoided cow milk consumption vs. not | Presence of milk related symptoms | 1.26 (0.33; 4.84)
Genetic polymorphism
Obermayer-Pietsch, 2004^25^ Country: Austria Postmenopausal women Ca++ intake difference in comparison groups: 0.55/Y | TT vs. CC | Dislike of milk taste | 0.83 (0.25; 2.73)
Obermayer-Pietsch, 2004^25^ Country: Austria Postmenopausal women Ca++ intake difference in comparison groups: 0.55/Y | TT vs. CC | Frequency of aversion to milk consumption | 0.26 (0.09; 0.70)
Obermayer-Pietsch, 2004^25^ Country: Austria Postmenopausal women Ca++ intake difference in comparison groups: 0.55/Y | TT vs. CC | Dislike of milk taste | 1.54 (0.58; 4.11)
Obermayer-Pietsch, 2004^25^ Country: Austria Postmenopausal women Ca++ intake difference in comparison groups: 0.55/Y | TT vs. CC | Frequency of aversion to milk consumption | 0.14 (0.05; 0.39)
Obermayer-Pietsch, 2004^25^ Country: Austria Postmenopausal women Ca++ intake difference in comparison groups: 0.55/Y | TT vs. CC | Dislike of milk taste | 0.54 (0.20; 1.43)
Obermayer-Pietsch, 2004^25^ Country: Austria Postmenopausal women Ca++ intake difference in comparison groups: 0.55/Y | TT vs. CC | Frequency of aversion to milk consumption | 1.80 (0.56; 5.81)
Obermayer-Pietsch, 2007^24^ Country: Austria Postmenopausal women Ca++ intake difference in comparison groups: 349/Y | TT vs. CC | Dislike of milk taste | 0.18 (0.05; 0.63)
Obermayer-Pietsch, 2007^24^ Country: Austria Postmenopausal women Ca++ intake difference in comparison groups: 349/Y | TT vs. CC | Aversion to milk consumption | 0.05 (0.01; 0.40)
Enattah, 2004^7^ Country: Finland Young men Ca++ intake difference in comparison groups:/ | TT or C/T vs. CC | Self reported lactose intolerance | 0.39 (0.09; 1.65)
Gugatschka, 2005^12^ Country: Austria Adult males Ca++ intake difference in comparison groups: 5/N | T/T vs. C/C | Self-reported lactose intolerance | 1.49 (0.09;2 4.47)
Gugatschka, 2005^12^ Country: Austria Adult males Ca++ intake difference in comparison groups: 5/N | C/T vs. C/C | Self-reported lactose intolerance | 2.03(0.22;18.59)
Gugatschka, 2005^12^ Country: Austria Adult males Ca++ intake difference in comparison groups: 5/N | T/T vs. C/T | Self-reported lactose intolerance | 0.73(0.08;6.74)
Gugatschka, 2007^13^ Country: Austria Elderly male Ca++ intake difference in comparison groups: −7/N | T/T vs. C/C | Self reported Lactose intolerance | 1.35 (0.08; 22.12)
Gugatschka, 2007^13^ Country: Austria Elderly male Ca++ intake difference in comparison groups: −7/N | C/T vs. C/C | Self reported Lactose intolerance | 1.48 (0.15; 14.48)
Gugatschka, 2007^13^ Country: Austria Elderly male Ca++ intake difference in comparison groups: −7/N | T/T vs. C/T | Self reported Lactose intolerance | 0.91 (0.09; 9.00)
Black, 2002^32^ Country: New Zealand Prepubertal children with a history of long-term milk avoidance Ca++ intake difference in comparison groups: NR/NR | Lactose intolerance vs. none | Presence of milk related symptoms | 190.09 (9.92; 3642.28)
Black, 2002^32^ Country: New Zealand Prepubertal children with a history of long-term milk avoidance Ca++ intake difference in comparison groups: NR/NR | Consulted a health professional vs. not | Presence of milk related symptoms | 13.50 (3.40; 53.68)
Objectively detected lactose malabsorption
Goulding, 1999^11^ Country: New Zealand Middle age and older women Ca++ intake difference in comparison groups: NR/NR | Malabsorbers vs. absorbers | Symptoms of gastrointestinal discomfort associated with milk intake | 2.06 (0.04; 106.52)
Kudlacek, 2002^20^ Country: Austria Adults Ca++ intake difference in comparison groups: NR/NR | Moderate lactose malabsorption vs. absorbers | Moderate symptoms (diarrhea, abdominal cramps) during the H2 breath test | 1.34 (0.59; 3.01)
Kudlacek, 2002^20^ Country: Austria Adults Ca++ intake difference in comparison groups: NR/NR | Moderate lactose malabsorption vs. absorbers | Severe symptoms (diarrhea, abdominal cramps) during the H2 breath test | 3.58 (1.43; 9.00)
Kudlacek, 2002^20^ Country: Austria Adults Ca++ intake difference in comparison groups: NR/NR | Severe lactose malabsorption vs. absorbers | Moderate symptoms (diarrhea, abdominal cramps) during the H2 breath test | 1.66 (0.86; 3.19)
Kudlacek, 2002^20^ Country: Austria Adults Ca++ intake difference in comparison groups: NR/NR | Severe lactose malabsorption vs. absorbers | Severe symptoms (diarrhea, abdominal cramps) during the H2 breath test | 6.22 (2.87; 13.51)
Di Stefano, 2002^5^ Country: Italy Adults Ca++ intake difference in comparison groups: −54/Y | Lactose malabsorption vs. absorbers | Symptoms of LI | 107.98 (6.34; 1838.99)
Horowitz, 2987^17^ Country: Austria Postmenopausal women Ca++ intake difference in comparison groups:/ | Malabsorbers vs. absorbers | History of milk intolerance | 1.50 (0.31; 7.19)
Rockell, 2005^46^ Country: New Zealand Prepubertal children with a history of long-term milk avoidance Ca++ intake difference in comparison groups: NR/NR | Baseline vs. 2 years of followup | Any symptoms related to milk intake were the reason for avoidance | 3.30 (1.33; 8.19)
Rockell, 2005^46^ Country: New Zealand Prepubertal children with a history of long-term milk avoidance Ca++ intake difference in comparison groups: NR/NR | Baseline vs. 2 years of followup | No milk intake whatsoever | 8.95 (3.00;2 6.71)

Appendix Table D5 Gains in osteodensitometric values in prepubertal boys consuming low lactose diet (74% of the recommended daily Ca++ intake) after interventions with dairy foods (1,607 vs. 747mg/day of Ca++)53

Outcome | Outcome Mean ±STD in Active Group | Outcome Mean ± STD in Control Group | Mean Difference (95% CI)
12 months | Gain in BMD
Radial metaphysis | 14.6±19.2 | 11.2±16.7 | 3.4 (−1.237; 8.037)
Radial diaphysis | 25.6±22.2 | 22.3±19.6 | 3.3 (−2.096; 8.696)
Femoral neck | 22±31.9 | 22.7±30 | −0.7 (−8.674; 7.274)
Femoral trochanter | 25±31.3 | 20.5±27.5 | 4.5 (−3.092; 12.092)
Femoral diaphysis | 76.3±31.7 | 64.3±33 | 12 (3.675; 20.325)
Lumbar spine (L2–L4) | 25.9±18 | 28.1±18.5 | −2.2 (−6.897; 2.497)
12 months | Gain in BMC (mg/year)
Radial metaphysis | 79±62 | 71±56 | 8 (−7.219; 23.219)
Radial diaphysis | 93±58 | 87±46 | 6 (−7.5; 19.5)
Femoral neck | 159±187 | 164±222 | −5 (−57.752; 47.752)
Femoral trochanter | 472±198 | 495±211 | −23 (−75.635; 29.635)
Femoral diaphysis | 4,460±2234 | 4,011±2119 | 449 (−111.669; 1009.669)
Lumbar spine (L2–L4) | 1,971±804 | 1,994±814 | −23 (−231.214; 185.214)
Mean of 5 appendicular skeletal sites | 1,064±470 | 969±449 | 95 (−23.35; 213.35)

Bold - statistically significant difference at 95% confidence level

Appendix Table D6 Association between lactose intake and metabolism and bone mineral density (BMD, g/cm^2^)

Study Difference in Daily Ca++ Intake in Comparison Groups | Comparison | Outcome | Estimate | Mean Difference (95% CI)
Lactose free diet
Country: Hong Kong Elderly Chinese vegetarian women Ca++ intake difference in comparison groups: −94/Y | vs. lactovegetarians | BMD spine (L1±L4) | | 0.04 (−0.02; 0.10)
Country: Hong Kong Elderly Chinese vegetarian women Ca++ intake difference in comparison groups: −94/Y | vs. lactovegetarians | BMD femoral neck | | 0.02 (−0.02; 0.06)
Country: Hong Kong Elderly Chinese vegetarian women Ca++ intake difference in comparison groups: −94/Y | vs. lactovegetarians | BMD intertrochanteric area | | 0.00 (−0.06; 0.06)
Country: Hong Kong Elderly Chinese vegetarian women Ca++ intake difference in comparison groups: −94/Y | vs. lactovegetarians | BMD ward triangle | | 0.00 (−0.04; 0.04)
Country: New Zealand Prepubertal children with a history of long-term milk avoidance Ca++ intake difference in comparison groups: 182/Y | baseline | Total body BMD | | 0.04 (0.03; 0.05)
Country: New Zealand Prepubertal children with a history of long-term milk avoidance Ca++ intake difference in comparison groups: 182/Y | baseline | 33% radius BMD | | 0.06 (0.05; 0.07)
Country: New Zealand Prepubertal children with a history of long-term milk avoidance Ca++ intake difference in comparison groups: 182/Y | baseline | Lumbar spine (L2–4) BMD | | 0.05 (0.03; 0.07)
Country: New Zealand Prepubertal children with a history of long-term milk avoidance Ca++ intake difference in comparison groups: 182/Y | baseline | Femoral neck BMD | | 0.11 (0.07; 0.15)
Country: New Zealand Prepubertal children with a history of long-term milk avoidance Ca++ intake difference in comparison groups: 182/Y | baseline | Hip trochanter BMD | | 0.10 (0.07; 0.12)
Country: New Zealand Prepubertal children with a history of long-term milk avoidance Ca++ intake difference in comparison groups: 182/Y | baseline | UD radius, z score | | −0.35 (−0.61; 0.21)
Country: New Zealand Prepubertal children with a history of long-term milk avoidance Ca++ intake difference in comparison groups: 182/Y | baseline | 33% radius, z score | | 0.38 (−0.10; 0.67)
Country: New Zealand Prepubertal children with a history of long-term milk avoidance Ca++ intake difference in comparison groups: 182/Y | baseline | Lumbar spine (L2–4), z score | | −0.22 (−0.39; −0.05)
Country: New Zealand Prepubertal children with a history of long-term milk avoidance Ca++ intake difference in comparison groups: 182/Y | baseline | Femoral neck, z score | | 0.86 (0.20; 1.51)
Country: New Zealand Prepubertal children with a history of long-term milk avoidance Ca++ intake difference in comparison groups: 182/Y | baseline | Hip trochanter, z score | | 0.69 (0.23; 1.15)
Country: New Zealand Prepubertal children with a history of long-term milk avoidance Ca++ intake difference in comparison groups: 182/Y | baseline | Total body, z score | | −0.28 (−0.40; −0.12)
Country: New Zealand Prepubertal children with a history of long-term milk avoidance Ca++ intake difference in comparison groups: NR/NR | avoiders vs. reference healthy children | Total-body BMD | | 0.13 (−0.17; 0.43)
Country: New Zealand Prepubertal children with a history of long-term milk avoidance Ca++ intake difference in comparison groups: NR/NR | avoiders vs. reference healthy children | Femoral neck BMD | | −1.11 (−2.00; −0.22)
Country: Taiwan Postmenopausal Taiwanese women Ca++ intake difference in comparison groups: NR/NR | practice vs. nonlong-term vegan and nonvegan vegetarians | Lumbar spine BMD | continuous variable), vigorous physical activity (three categories), calcium, protein, and nonprotein kcal (as continuous variables) | −0.03 (−0.08; 0.01)
Country: Taiwan Postmenopausal Taiwanese women Ca++ intake difference in comparison groups: NR/NR | practice vs. nonlong-term vegan and nonvegan vegetarians | Femoral neck BMD | continuous variable), vigorous physical activity (three categories), calcium, protein, and nonprotein kcal (as continuous variables) | −0.05 (−0.08; −0.02)
Country: Estonia Adults Ca++ intake difference in comparison groups: NR/NR | vs. high (>4dL/day) | Femoral BMD (total) | | −0.05 (−0.10; −0.01)
Country: Estonia Adults Ca++ intake difference in comparison groups: NR/NR | vs. high (>4dL/day) | Spinal BMD (L1– L4) g/cm^2^ | | −0.08 (−0.14; −0.01)
Du, 2002^6^ Country: China Ca++ intake difference in comparison groups: NR/NR | No milk consumers vs. low milk group (<22±18 g/day) | BMD (g/cm^2^); distal one-third radius | Crude | −0.03 (−0.04; −0.01)
Du, 2002^6^ Country: China Ca++ intake difference in comparison groups: NR/NR | No milk consumers vs. low milk group (<22±18 g/day) | Distal one-third ulna | Crude | −0.02 (−0.03; 0.00)
Du, 2002^6^ Country: China Ca++ intake difference in comparison groups: NR/NR | No milk consumers vs. low milk group (<22±18 g/day) | Distal one-tenth radius | Crude | −0.03 (−0.04; −0.01)
Du, 2002^6^ Country: China Ca++ intake difference in comparison groups: NR/NR | No milk consumers vs. low milk group (<22±18 g/day) | Distal one-tenth ulna | Crude | −0.02 (−0.04; 0.00)
Du, 2002^6^ Country: China Ca++ intake difference in comparison groups: NR/NR | group (>128±165 g/day) | Distal one-third radius | Crude | −0.04 (−0.05; −0.02)
Du, 2002^6^ Country: China Ca++ intake difference in comparison groups: NR/NR | group (>128±165 g/day) | Distal one-third ulna | Crude | −0.02 (−0.03; 0.00)
Du, 2002^6^ Country: China Ca++ intake difference in comparison groups: NR/NR | group (>128±165 g/day) | Distal one-tenth radius | Crude | −0.04 (−0.05; −0.02)
Du, 2002^6^ Country: China Ca++ intake difference in comparison groups: NR/NR | group (>128±165 g/day) | Distal one-tenth ulna | Crude | −0.03 (−0.05; −0.02)
Country: Hong Kong Elderly Chinese vegetarian women Ca++ intake difference in comparison groups: NR/NR | vs. omnivores | BMD (g=cm^2^) spine (L1±L4) | | 0.00 (−0.06; 0.06)
Country: Hong Kong Elderly Chinese vegetarian women Ca++ intake difference in comparison groups: NR/NR | vs. omnivores | BMD (g=cm^2^) femoral neck | | −0.03 (−0.06; 0.00)
Country: Hong Kong Elderly Chinese vegetarian women Ca++ intake difference in comparison groups: NR/NR | vs. omnivores | BMD (g=cm^2^) Intertrochanteric area | | −0.04 (−0.09; 0.01)
Country: Hong Kong Elderly Chinese vegetarian women Ca++ intake difference in comparison groups: NR/NR | vs. omnivores | BMD (g=cm^2^) ward triangle | | −0.05 (−0.08; −0.02)
Genetic polymorphism
Country: Austria Postmenopausal women Ca++ intake difference in comparison groups: 0.55/Y | | Lumbar BMD | | 0.07 (0.01; 0.13)
Country: Austria Postmenopausal women Ca++ intake difference in comparison groups: 0.55/Y | | Femoral neck | | 0.05 (0.01; 0.09)
Country: Austria Postmenopausal women Ca++ intake difference in comparison groups: 0.55/Y | | Total hip | | 0.07 (0.02; 0.12)
Country: Austria Postmenopausal women Ca++ intake difference in comparison groups: 0.55/Y | | Ward’s triangle | | 0.06 (0.01; 0.11)
Country: Austria Postmenopausal women Ca++ intake difference in comparison groups: 0.55/Y | | Lumbar BMD | | 0.00 (−0.05; 0.05)
Country: Austria Postmenopausal women Ca++ intake difference in comparison groups: 0.55/Y | | Femoral neck | | 0.01 (−0.03; 0.05)
Country: Austria Postmenopausal women Ca++ intake difference in comparison groups: 0.55/Y | | Total hip | | 0.03 (−0.01; 0.07)
Country: Austria Postmenopausal women Ca++ intake difference in comparison groups: 0.55/Y | | Ward’s triangle | | 0.02 (−0.02; 0.06)
Country: Austria Postmenopausal women Ca++ intake difference in comparison groups: 0.55/Y | | Lumbar BMD | | 0.07 (0.03; 0.11)
Country: Austria Postmenopausal women Ca++ intake difference in comparison groups: 0.55/Y | | Femoral neck | | 0.04 (0.01; 0.08)
Country: Austria Postmenopausal women Ca++ intake difference in comparison groups: 0.55/Y | | Total hip | | 0.04 (0.00; 0.08)
Country: Austria Postmenopausal women Ca++ intake difference in comparison groups: 0.55/Y | | Ward’s triangle | | 0.04 (0.00; 0.08)
Country: Austria Postmenopausal women Ca++ intake difference in comparison groups: 349/Y | | Lumbar BMD | | 0.07 (−0.01; 0.15)
Country: Austria Postmenopausal women Ca++ intake difference in comparison groups: 349/Y | | Femoral neck BMD [g/cm^2^] | | 0.05 (0.00; 0.10)
Country: Austria Postmenopausal women Ca++ intake difference in comparison groups: 349/Y | | Total hip BMD | | 0.07 (0.01; 0.13)
Country: Finland Young men Ca++ intake difference in comparison groups: NR/NR | | Lumbar spine BMD (g/cm^2^) | | 0.05 (−0.49; 0.59)
Country: Finland Young men Ca++ intake difference in comparison groups: NR/NR | | Femoral neck BMD (g/cm^2^) | | 0.04 (−0.59; 0.67)
Country: Finland Young men Ca++ intake difference in comparison groups: NR/NR | | Trochanter BMD | | 0.04 (−0.45; 0.53)
Country: Finland Young men Ca++ intake difference in comparison groups: NR/NR | | Total hip BMD | | 0.03 (−0.44; 0.50)
Country: Finland Young men Ca++ intake difference in comparison groups: NR/NR | | BMD, lumbar spine | weight, smoking, alcohol consumption and current exercise | 0.03 (−0.03; 0.09)
Country: Finland Young men Ca++ intake difference in comparison groups: NR/NR | | BMD, femoral neck | weight, smoking, alcohol consumption and current exercise | 0.01 (−0.05; 0.08)
Country: Finland Young men Ca++ intake difference in comparison groups: NR/NR | | BMD, total hip | weight, smoking, alcohol consumption and current exercise | 0.02 (−0.04; 0.09)
Country: Finland Young men Ca++ intake difference in comparison groups: NR/NR | C/T vs. C/C | Lumbar spine BMD | Crude | 0.01 (−0.60; 0.63)
Country: Finland Young men Ca++ intake difference in comparison groups: NR/NR | C/T vs. C/C | Femoral neck BMD | Crude | 0.01 (−0.50; 0.52)
Country: Finland Young men Ca++ intake difference in comparison groups: NR/NR | C/T vs. C/C | Trochanter BMD | Crude | −0.01 (−0.56; 0.55)
Country: Finland Young men Ca++ intake difference in comparison groups: NR/NR | C/T vs. C/C | Total hip BMD | Crude | 0.00 (−0.49; 0.50)
Country: Finland Young men Ca++ intake difference in comparison groups: NR/NR | C/T vs. C/C | BMD, lumbar spine | weight, smoking, alcohol consumption and current exercise | 0.05 (−0.01; 0.10)
Country: Finland Young men Ca++ intake difference in comparison groups: NR/NR | C/T vs. C/C | BMD, femoral neck | weight, smoking, alcohol consumption and current exercise | 0.01 (−0.05; 0.08)
Country: Finland Young men Ca++ intake difference in comparison groups: NR/NR | C/T vs. C/C | BMD, total hip | weight, smoking, alcohol consumption and current exercise | 0.02 (−0.04; 0.08)
Country: Finland Young men Ca++ intake difference in comparison groups: NR/NR | | Lumbar spine BMD | | 0.04 (−0.50; 0.57)
Country: Finland Young men Ca++ intake difference in comparison groups: NR/NR | | Femoral neck BMD | | 0.03 (−0.59; 0.64)
Country: Finland Young men Ca++ intake difference in comparison groups: NR/NR | | Trochanter BMD | | 0.04 (−0.46; 0.55)
Country: Finland Young men Ca++ intake difference in comparison groups: NR/NR | | Total hip BMD | | 0.03 (−0.45; 0.51)
Country: Finland Young men Ca++ intake difference in comparison groups: NR/NR | | BMD, lumbar spine | weight, smoking, alcohol consumption and current exercise | −0.01 (−0.06; 0.03)
Country: Finland Young men Ca++ intake difference in comparison groups: NR/NR | | BMD, femoral neck | weight, smoking, alcohol consumption and current exercise | 0.00 (−0.06; 0.06)
Country: Finland Young men Ca++ intake difference in comparison groups: NR/NR | | BMD, total hip | weight, smoking, alcohol consumption and current exercise | 0.00 (−0.05; 0.06)
Country: Estonia Adults Ca++ intake difference in comparison groups: NR/NR | | Femoral BMD (total) | Crude | −0.03 (−0.07; 0.02)
Country: Estonia Adults Ca++ intake difference in comparison groups: NR/NR | | Spinal BMD (L1– L4) | Crude | −0.01 (−0.07; 0.05)
Country: Estonia Adults Ca++ intake difference in comparison groups: NR/NR | | Femoral BMD (total) | Crude | −0.03 (−0.07; 0.01)
Country: Estonia Adults Ca++ intake difference in comparison groups: NR/NR | | Spinal BMD (L1– L4) | Crude | −0.02 (−0.07; 0.03)
Country: Estonia Adults Ca++ intake difference in comparison groups: NR/NR | | Femoral BMD (total) | Crude | 0.00 (−0.03; 0.04)
Country: Estonia Adults Ca++ intake difference in comparison groups: NR/NR | | Spinal BMD (L1– L4) | Crude | 0.00 (−0.05; 0.05)
Country: Estonia Adults Ca++ intake difference in comparison groups: NR/NR | | Femoral BMD (total) | Crude | 0.03 (−0.01; 0.07)
Country: Estonia Adults Ca++ intake difference in comparison groups: NR/NR | | Spinal BMD (L1– L4) | Crude | 0.02 (−0.03; 0.06)
Lactose intolerance
Corazza, 1995^4^ Country: Italy Postmenopausal women Ca++ intake difference in comparison groups: −246/Y | Lactose malabsorbers with symptoms of intolerance vs. without symptoms | BMD z score | Crude | −0.60 (−1.17; −0.03)
Country: Italy Adults Ca++ intake difference in comparison groups: −240/Y | | BMD (T-score): lumbar spine | | −0.98 (−1.32; −0.64)
Country: Italy Adults Ca++ intake difference in comparison groups: −240/Y | | BMD (T-score): femoral neck | | −0.94 (−1.28; −0.60)
Country: Italy Adults Ca++ intake difference in comparison groups: −240/Y | | BMD (z-score): lumbar spine | | −0.90 (−1.24; −0.56)
Country: Italy Adults Ca++ intake difference in comparison groups: −240/Y | | BMD (z-score): femoral neck | | −0.88 (−1.22; −0.54)
Corazza, 1995^4^ Country: Italy Postmenopausal women Ca++ intake difference in comparison groups: −138/NR | Lactose intolerace (clinical diagnosis) vs. not | BMD z score | Crude | 0.30 (−0.16; 0.76)
Country: Estonia Adults Ca++ intake difference in comparison groups: NR/NR | vs. not | Femoral BMD (total) g/cm^2^ | | −0.01 (−0.06; 0.04)
Country: Estonia Adults Ca++ intake difference in comparison groups: NR/NR | vs. not | Spinal BMD (L1– L4) g/cm^2^ | | −0.04 (−0.10; 0.02)
Country: Israel Adults Ca++ intake difference in comparison groups: NR/NR | population; BMD z-Scores | BMD z-Scores: femoral neck in Premenopausal women | | 0.15 (−0.20; 0.50)
Country: Israel Adults Ca++ intake difference in comparison groups: NR/NR | population; BMD z-Scores | Hip in premenopausal women | | 0.25 (−0.01; 0.51)
Country: Israel Adults Ca++ intake difference in comparison groups: NR/NR | population; BMD z-Scores | L2–L4 in premenopausal women | | −0.59 (−0.96; −0.22)
Country: Israel Adults Ca++ intake difference in comparison groups: NR/NR | population; BMD z-Scores | Femoral neck in postmenopausal women | | −0.07 (−0.38; 0.24)
Country: Israel Adults Ca++ intake difference in comparison groups: NR/NR | population; BMD z-Scores | Hip in postmenopausal women | | 0.04 (−0.28; 0.36)
Country: Israel Adults Ca++ intake difference in comparison groups: NR/NR | population; BMD z-Scores | L2–L4 in Postmenopausal women | | −0.87 (−0.95; −0.79)
Country: Israel Adults Ca++ intake difference in comparison groups: NR/NR | population; BMD z-Scores | Femoral neck in men | | −0.45 (−0.88; −0.02)
Country: Israel Adults Ca++ intake difference in comparison groups: NR/NR | population; BMD z-Scores | Hip in men | | −0.45 (−0.92; 0.02)
Country: Israel Adults Ca++ intake difference in comparison groups: NR/NR | population; BMD z-Scores | L2–L4 in men | | −1.32 (−.74; −0.90)
Lactose malabsorption
Country: Finland Perimenopausal women Ca++ intake difference in comparison groups: −280/Y | tolerance test | Femoral BMD, no fractures | menopausal status, weight, and HRT history | −0.01 (−0.03; 0.01)
Country: Finland Perimenopausal women Ca++ intake difference in comparison groups: −280/Y | tolerance test | Femoral BMD, wrist fractures | menopausal status, weight, and HRT history | −0.01 (−0.06; 0.04)
Country: Finland Perimenopausal women Ca++ intake difference in comparison groups: −280/Y | tolerance test | Femoral BMD, ankle fractures | menopausal status, weight, and HRT history | −0.03 (−0.12; 0.06)
Country: Finland Perimenopausal women Ca++ intake difference in comparison groups: −280/Y | tolerance test | Femoral BMD, tibial fracture | menopausal status, weight, and HRT history | −0.14 (−0.23; −0.05)
Country: Finland Perimenopausal women Ca++ intake difference in comparison groups: −280/Y | tolerance test | Spinal bone BMD, no fractures | menopausal status, weight, and HRT history | −0.01 (−0.03; 0.02)
Country: Finland Perimenopausal women Ca++ intake difference in comparison groups: −280/Y | tolerance test | Spinal bone BMD, wrist fractures | menopausal status, weight, and HRT history | −0.04 (−0.08; 0.00)
Country: Finland Perimenopausal women Ca++ intake difference in comparison groups: −280/Y | tolerance test | Spinal bone BMD, ankle fracture | menopausal status, weight, and HRT history | −0.05 (−0.15; 0.05)
Country: Finland Perimenopausal women Ca++ intake difference in comparison groups: −280/Y | tolerance test | Spinal bone BMD, tibial fracture | menopausal status, weight, and HRT history | −0.08 (−0.17; 0.00)
Honkanen, 1996^16^ Country: Finland perimenopausal women Ca++ intake difference in comparison groups: −270/Y | Positive vs. negative lactose tolerance test | Femoral BMD | Adjusted for Calcium intake, weight, age, years since menopause, HRT | 0.15 (−18.02; 18.32)
Honkanen, 1996^16^ Country: Finland perimenopausal women Ca++ intake difference in comparison groups: −270/Y | Positive vs. negative lactose tolerance test in premenopausal | Spinal BMD | Crude | 0.01 (−0.04; 0.06)
Honkanen, 1996^16^ Country: Finland perimenopausal women Ca++ intake difference in comparison groups: −270/Y | Positive vs. negative lactose tolerance test in postmenopausal | Spinal BMD | Crude | −0.05 (−0.09; −0.01)
Honkanen, 1996^16^ Country: Finland perimenopausal women Ca++ intake difference in comparison groups: −270/Y | Positive vs. negative lactose tolerance test in postmenopausal, hormone replacement therapy 6 months or more | Spinal BMD | Crude | −0.08 (−0.12; −0.03)
Honkanen, 1996^16^ Country: Finland perimenopausal women Ca++ intake difference in comparison groups: −270/Y | Positive vs. negative lactose tolerance test in postmenopausal, no HRT | Spinal BMD | Crude | −0.02 (−0.07; 0.04)
Honkanen, 1996^16^ Country: Finland perimenopausal women Ca++ intake difference in comparison groups: −270/Y | Positive vs. negative lactose tolerance test in premenopausal | | Crude | −0.02 (−0.07; 0.04)
Honkanen, 1996^16^ Country: Finland perimenopausal women Ca++ intake difference in comparison groups: −270/Y | Positive vs. negative lactose tolerance test in postmenopausal | | Crude | −0.03 (−0.06; 0.00)
Honkanen, 1996^16^ Country: Finland perimenopausal women Ca++ intake difference in comparison groups: −270/Y | Positive vs. negative lactose tolerance test in postmenopausal, hormone replacement therapy 6 months or more | | Crude | −0.05 (−0.09; −0.01)
Honkanen, 1996^16^ Country: Finland perimenopausal women Ca++ intake difference in comparison groups: −270/Y | Positive vs. negative lactose tolerance test in postmenopausal, no HRT | | Crude | −0.01 (−0.06; 0.04)
Country: Italy Adults Ca++ intake difference in comparison groups: −54/Y | | BMD (T-score): lumbar spine | | −0.22 (−0.49; 0.05)
Country: Italy Adults Ca++ intake difference in comparison groups: −54/Y | | BMD (T-score): femoral neck | | −0.21 (−0.48; 0.06)
Country: Italy Adults Ca++ intake difference in comparison groups: −54/Y | | BMD (z-score): lumbar spine | | −0.25 (−0.52; 0.02)
Country: Italy Adults Ca++ intake difference in comparison groups: −54/Y | | BMD (z-score): femoral neck | | −0.22 (−0.49; 0.05)
Corazza, 1995^4^ Country: Italy Postmenopausal women Ca++ intake difference in comparison groups: −2/N | Lactose malabsroption vs. no | BMD z score | Crude | −0.30 (−0.77; 0.17)
Country: Finland Adults Ca++ intake difference in comparison groups: NR/NR | Malabsorbers vs. absorbers (men only) | Mineral density distal radius | | 0.01 (−0.02; 0.03)
Country: Finland Adults Ca++ intake difference in comparison groups: NR/NR | Malabsorbers vs. absorbers (women only) | Mineral density distal radius | | 0.03 (0.00; 0.05)
Country: Austria Adults Ca++ intake difference in comparison groups: NR/NR | Moderate lactose malabsorption vs. no | DEXA (radial) (g/cm^2^) | | −0.01 (−0.19; 0.17)
Country: Austria Adults Ca++ intake difference in comparison groups: NR/NR | Severe lactose malabsorption vs. no | DEXA (radial)(g/cm^2^) | | −0.07 (−0.29; 0.15)
Country: Austria Adults Ca++ intake difference in comparison groups: NR/NR | Severe lactose malabsorption vs. moderate | DEXA (radial)(g/cm^2^) | | −0.06 (−0.21; 0.09)
Horowitz, 1987^17^ Country: Austria Postmenopausal women Ca++ intake difference in comparison groups: NR/NR | Lactose malabsroption vs. no | BMD of the right forearm, mg/ml | Crude | −17.00 (−61.44; 27.44)
Country: Finland Adults Ca++ intake difference in comparison groups: NR/NR | only) | Bone mineral linear density (g/cm), distal radius | | 0.00 (−0.17; 0.17)
Country: Finland Adults Ca++ intake difference in comparison groups: NR/NR | only) | Bone mineral linear density (g/cm), midshaft radius | | 0.06 (−0.09; 0.21)
Country: Finland Adults Ca++ intake difference in comparison groups: NR/NR | only) | Bone mineral linear density (g/cm), midshaft ulna | | 0.02 (−0.12; 0.16)
Country: Finland Adults Ca++ intake difference in comparison groups: NR/NR | Malabsorbers vs. absorbers (women only) | Bone mineral linear density (g/cm), distal radius | | 0.03 (−0.10; 0.16)
Country: Finland Adults Ca++ intake difference in comparison groups: NR/NR | Malabsorbers vs. absorbers (women only) | Bone mineral linear density (g/cm), midshaft radius | | 0.02 (−0.08; 0.12)
Country: Finland Adults Ca++ intake difference in comparison groups: NR/NR | Malabsorbers vs. absorbers (women only) | Bone mineral linear density (g/cm), midshaft ulna | | 0.03 (−0.05; 0.11)

Bold – statistically significant

Appendix Table D7 Association between lactose intake and metabolism and bone density (BD)

Study Difference in Daily Ca++ Intake in Comparison Groups | Comparison | Outcome | Estimate | Mean Difference (95% CI)
Honkanen, 1996^16^ Country: Finland Perimenopausal women Ca++ intake difference in comparison groups: −270/Y | Positive vs. negative lactose tolerance test | Spinal BD, mg/cm | Adjusted for calcium intake, weight, age, years since menopause, HRT | 28.27 (3.73; 52.81)
Gugatschka, 2007^13^ Country: Austria Elderly male Ca++ intake difference in comparison groups: −221/Y | | Spinal BD (L1–L4) Z score | | 0.02 (−0.55; 0.59)
Gugatschka, 2007^13^ Country: Austria Elderly male Ca++ intake difference in comparison groups: −221/Y | | Femoral BD (total) Z score | | −0.13 (−0.48; 0.22)
Gugatschka, 2007^13^ Country: Austria Elderly male Ca++ intake difference in comparison groups: −221/Y | | Femoral BD (neck) Z score | | −0.14 (−0.47; 0.19)
Gugatschka, 2007^13^ Country: Austria Elderly male Ca++ intake difference in comparison groups: −221/Y | | Femoral BD (trochanteric) Z score | | −0.26 (−0.62; 0.10)
Gugatschka, 2007^13^ Country: Austria Elderly male Ca++ intake difference in comparison groups: −221/Y | | Spinal BD (L1–L4) Z score | | −0.07 (−0.68; 0.54)
Gugatschka, 2007^13^ Country: Austria Elderly male Ca++ intake difference in comparison groups: −221/Y | | Femoral BD (total) Z score | | −0.17 (−0.56; 0.22)
Gugatschka, 2007^13^ Country: Austria Elderly male Ca++ intake difference in comparison groups: −221/Y | | Femoral BD (neck) Z score | | −0.02 (−0.38; 0.34)
Gugatschka, 2007^13^ Country: Austria Elderly male Ca++ intake difference in comparison groups: −221/Y | | Femoral BD (trochanteric) Z score | | −0.27 (−0.67; 0.13)
Gugatschka, 2005^12^ Country: Austria Adult males Ca++ intake difference in comparison groups: −3/N | | Spinal BD (L1–L4) Z score | | 0.41 (−0.11; 0.92)
Gugatschka, 2005^12^ Country: Austria Adult males Ca++ intake difference in comparison groups: −3/N | | Femoral BD (total) Z score | | 0.04 (−0.27; 0.34)
Gugatschka, 2005^12^ Country: Austria Adult males Ca++ intake difference in comparison groups: −3/N | | Spinal BD (L1–L4) Z score | | 0.29 (−0.26; 0.83)
Gugatschka, 2005^12^ Country: Austria Adult males Ca++ intake difference in comparison groups: −3/N | | Femoral BD (total) Z score | | 0.01 (−0.33; 0.34)
Gugatschka, 2005^12^ Country: Austria Adult males Ca++ intake difference in comparison groups: −3/N | | Spinal BD (L1–L4) Z score | | −0.12 (−0.49; 0.26)
Gugatschka, 2005^12^ Country: Austria Adult males Ca++ intake difference in comparison groups: −3/N | | Femoral BD (total) Z score | | −0.03 (−0.27; 0.21)
Gugatschka, 2007^13^ Country: Austria Elderly male Ca++ intake difference in comparison groups: 14/N | | Spinal BD (L1–L4) Z score | | −0.09 (−0.49; 0.31)
Gugatschka, 2007^13^ Country: Austria Elderly male Ca++ intake difference in comparison groups: 14/N | | Femoral BD (total) Z score | | −0.04 (−0.31; 0.23)
Gugatschka, 2007^13^ Country: Austria Elderly male Ca++ intake difference in comparison groups: 14/N | | Femoral BD (neck) Z score | | 0.12 (−0.16; 0.40)
Gugatschka, 2007^13^ Country: Austria Elderly male Ca++ intake difference in comparison groups: 14/N | | Femoral BD (trochanteric) Z score | | −0.01 (−0.31; 0.29)

Bold – statistically significant

Appendix Table D8 Evidence table for blinded lactose intolerance treatment studies: Question 3 and 4

Author, Year, Study Design, Study Sponsorship, Country, Length of Followup | Subject Selection, Data Source, Methods to Measure Outcomes, Inclusion/Exclusion Criteria | Subject Characteristics | Treatment-Active, Adherence Evaluations | Treatment- Control, Adherence Evaluations | Outcome assessment/Results and Conclusions | Quality of the Study
A. Commercially-available lactase/lactose hydrolysed milk, or non-lactose solutions
Montalto, 2005^54^ RCT, crossover Sponsorship: not reported Italy Duration of symptom recording: 8 hours | Data source: 30 Italian subjects referred because of symptoms compatible with lactose intolerance with a positive lactose H2 breath test. Each patient underwent, in a random order, three H2 breath tests. An interval of at least 72 hours was allowed among successive tests (20 g lactose), to avoid the effect of colonic acidification. Inclusion criteria: Symptoms compatible with lactose intolerance. Methods to measure outcomes: Subjects kept a diary where they recorded occurrence of intolerance symptoms for 8 hours following milk ingestion. | Mean age (range): 43 (18–65) Gender: women 63%. Race/ethnicity: not reported Comorbidities: not reported Cointerventions: not reported | β-d-galactosidase from Kluyveromyces lactis 1) Test A -enzyme (3000 UI) added to 400 mL milk (lactose content 20 g) 10 h before milk consumption x 1 dose 2) Test B-enzyme (6000 UI) added 5 min before 400 mL milk (lactose content 20 g) consumption x 1 dose | Placebo before 400 mL milk (lactose content 20 g) plus aspartame (to simulate the taste of lactase-treated milk x 1 dose | Clinical score based on symptoms whose severity was indicated by a score for each symptom (0=absent; 1=mild; 2=moderate; 3=severe). Conclusion(s): A significant reduction of the mean clinical score after both test A (0.36 ± 0.55) and test B (0.96 ± 0.85) versus placebo (3.77 ± 0.79) (P<0.001). There was also a significant reduction after Test A versus Test B (P=0.03). | Allocation concealment: adequate (numbered containers, identical in shape and color) Blinding: double + analysis by a blinded statistician. Intent-to-treat analyses: 100% followup Study withdrawals adequately described: no withdrawals reported
Gremse, 2003^55^ RCT, crossover Sponsorship: not reported USA Duration of symptom recording: 2 weeks | Data source: 30 American child subjects with lactose mal- digestion a positive lactose H2 breath test. Inclusion criteria: Recurrent abdominal pain of childhood with at least 3 discrete episodes of abdominal pain severe enough to affect daily activities for 3 months or more. Exclusion criteria: Organic causes of abdominal pain. Methods to measure outcomes: Subjects and/or their parents recorded their symptoms daily in a diary that was collected at weekly intervals during each study period. | Mean age (range): 11 (3–17) Gender: women 63%. Race/ethnicity: black 53%, white 47%. Comorbidities: not reported Cointerventions: not reported | 240 mL Lactose‐free milk (LFM) to which lactase 2 g from Kluyveromyces lactis (Lactaid, Pleasantville, NY) was added to 2% homogenized milk (lactose content 12 g) taken for 14 days (2 week washout period) | 240 mL Milk (lactose content 12 g) 2% homogenized milk plus aspartame (to simulate the taste of lactase-treated milk) taken for 14 days | Symptom scores for the 14 day period (mean ± SEM). Severity of symptoms was graded as: 0=none; 1=trivial, 2=mild; 3= moderate; 4=severe. Sum of the individual symptom scores was calculated for each 14-day study period and averaged for all subjects. Significant increase in abdominal pain during the lactose ingestion period compared to the lactose-free period. Conclusion(s): Authors conclude that ingestion of 12 g of lactose daily is associated with increased abdominal pain in susceptible children with lactose maldigestion. | Allocation concealment: unclear Blinding: Double Intent-to-treat analyses: 100% followup Study withdrawals adequately described: no withdrawals reported
Järvinen, 2003^56^ RCT, crossover Sponsorship: not reported Finland Duration of symptom recording: 8 hours | Data source: 27 Finnish subjects who had experienced gastrointestinal symptoms after consuming milk or food containing lactose. Inclusion criteria: lactose maldigestion based on rise in blood glucose <1.1 mmol/l within 1 hour after ingesting 50 g lactose dissolved in water. Methods to measure outcomes: Gastrointestinal symptoms including flatulence, abdominal bloating, abdominal pain, borgorygmi and nausea were recorded on a questionnaire with a scale ranging from 0 (no symptoms) to 10 (very severe symptoms disturbing normal life) once every hour for the first 3 hours and then two more times (at 4–6 and 7–8 hours) until 8 hours had elapsed since the test meal. | Students and staff at a university. No further information provided. | 100 g chocolate sample consisting of lactose-free milk powder. | 100 g chocolate sample consisting of low-lactose milk powder (lactose content 2 g). 100 g chocolate sample consisting of whole milk powder (lactose content 12 g). 100 g chocolate sample consisting of whole milk (lactose content 12 g). The chocolate sample was eaten in the morning between 8 and 10 o’clock after an overnight fast | Number of subjects reporting symptoms and mean symptom scores for individual gastrointestinal symptoms. Conclusion(s): Numbers of subjects reporting GI symptoms did not differ significantly after eating chocolate samples. | Allocation concealment: unclear Blinding: described as “blinded,” no further details. Intent-to-treat analyses: 100% followup Study withdrawals adequately described: no withdrawals reported
Suarez, 1998^57^ RCT, crossover Sponsorship: Department of Veteran Affairs, the National Institute of Diabetes and Digestive and Kidney Diseases, and the National Dairy Council. USA Duration of symptom recording: 1 week | Data source: 31 American women subjects with lactose maldigestion a positive lactose H2 breath test plus 31 American women digester controls. Inclusion criteria: Lactose maldigestion based on an increase in the breath-hydrogen concentration of >0.45 mmol/L (10 ppm) after the oral ingestion of a 250-mL aqueous solution containing 15 g lactose (0.18 mol/L) was used as the indicator of lactose maldigestion. Exclusion criteria: Previously had gastrointestinal surgery, had significant intercurrent illnesses, had received antibiotic therapy within the past 2 months, or allergy to aspartame, milk, yogurt, or cheese. Methods to measure outcomes: The occurrence and severity of symptoms (bloating, abdominal pain or cramps, and subjective impressions of rectal gas excretion) were self-rated by subjects on 2 occasions daily (for the periods from breakfast time to dinnertime and from dinnertime to bedtime) during the baseline and the 2 test periods. | Maldigestion group (n=31): Mean age 46.9 2.6 y Gender: women 100%. Race/ethnicity: Asian 29%; Hispanic 16%; black 6%; white 45%, of whom 4 were Jewish Digestion group Mean age 49.4 ±2.4 Gender: women 100%. Race/ethnicity: white 100% Prior to the study, 23 women in the lactose mal- digestion group and 2 in the lactose digestion group believed that the ingestion of dairy products resulted in appreciable abdominal symptoms. | Lactose hydrolyzed products (LHP), lactose totaling 34 g daily. The lactose in fresh, low-fat milk was hydrolyzed by adding 1.07 g of a lactase preparation obtained from Kluyveromyces lactis 240 mL lactose hydrolyzed,1%-fat milk with breakfast and dinner; 1 serving (28 g) of a hard cheese at lunch and at dinner; and 240 mL low-fat, strawberry flavored, lactose-hydrolyzed yogurt at lunch. Subjects ingested their regular diets with the exception of the additional dairy products. The dairy products provided <1300 mg Ca/d; it was assumed that the remainder of the diet provided <200 mg. | Conventional diary products (CDP) lactose totaling 34 g daily. 240 mL conventional, 1%‐ fat milk with breakfast and dinner; 1 serving (28 g) of a hard cheese at lunch and at dinner; and 240 mL (8 oz) lowfat, strawberry-flavored yogurt at lunch time | Severity of symptoms, (Mean ± SEM), ranked on a continuous scale from 0 to 5 as follows: 0 (no symptoms), 1 (trivial), 2 (mild), 3 (moderate), 4 (strong), or 5 (severe symptoms). Women with lactose maldigestion reported significantly increased flatus frequency and subjective impression of rectal gas during the period of high lactose intake; however, bloating, abdominal pain, diarrhea, and the global perception of overall symptom severity were not significantly different between the 2 treatment periods. Conclusion(s): Authors conclude that the symptoms resulting from lactose maldigestion are not a major impediment to the ingestion of a dairy-rich diet supplying <1500 mg Ca/day. | Allocation concealment: unclear Blinding: Double Intent-to-treat analyses: 100% followup Study withdrawals adequately described: no withdrawals reported
Xenos, 1998^58^ RCT, crossover Sponsorship: not reported Greece Duration of symptom recording: 1 day | Data source: 8 Greek lactose intolerant volunteers. Inclusion criteria: Rise in blood glucose levels <1.1 mmol/L above fasting level after ingestion of lactose (1 g/kg of body weight) and if intestinal symptoms occurred. Methods to measure outcomes: Subjects completed questionnaire regarding symptoms 8 hours after consuming tests and then every 8 hours until 24 hours elapsed. Symptoms were rated from 0=none to 4=severe. | Mean age 32 No other data were provided. | Lactose treatment: β-D-galactosidase 100 u/mL + 100 g lactose dissolved in water. There was a washout period of 1 week between challenges. | Matching placebo + 100 g lactose dissolved in water. | Subjects reporting symptoms based on ratings (0=none to 4=severe), 8 hours after lactose challenge. Conclusion(s): Subjective ratings of the severity of symptoms (cramps, belching, flatulence, diarrhea) were significantly decreased with the lactose treatment compared to placebo. | Allocation concealment: unclear Blinding: Double Intent-to-treat analyses: 100% followup Study withdrawals adequately described: no withdrawals reported
Suarez, 1997^59^ RCT, crossover Sponsorship: Department of Veteran Affairs, the National Institute of Diabetes and Digestive and Kidney Diseases, and the National Dairy Council. USA Duration of symptom recording: 1 week | Data source: 19 American symptomatic lactase-nonpersistent (S-LNP) subjects self-described as “severely lactose intolerant,” plus 13 LNP subjects who denied lactose intolerance (A-LNP), and 10 lactase- persistent subjects who believed they were lactose intolerant (S‐ LP). Inclusion criteria: Individuals who reported GI symptoms after one cup of milk. Lactose maldigestion based on an increase in the breath-hydrogen concentration of >10 ppm after the oral ingestion of a 250-mL aqueous solution containing 15 g lactose was used as the indicator of lactose malabsorption, hence LNP. Exclusion criteria: Inconsistent GI symptoms (bloating, abdominal pain, flatulence, or diarrhea), prior gastrointestinal surgery or other significant illnesses, received antibiotic therapy within the past 2 months, or inability to consume aspartame. Methods to measure outcomes: Subjects rated symptoms (bloating, borborygmi, abdominal pain or cramps, and subjective impressions of rectal gas excretion) on 4 occasions daily (morning, noon, afternoon, night) during the baseline and the 2 test periods. Subjects also recorded diarrhea, and each passage of flatus. | S-LNP Group (n=19) Mean age 34 ±22 years (range 18–43) Gender: women 53%. Race/ethnicity: Asian 63%; black 11%; Hispanic 5%; white 21% A-LNP Group (n=13) Mean age 35.9 ±11 years (range 25–69) Gender: women 38%. Race: Asian 69%; black 8%; Hispanic 15%; white 8% S-LP Group (n=10) Mean age 35.9 ±11 years (range 25–69) Gender: women 38%. Race/ethnicity: Asian 69%; black 8%; Hispanic 15%; white 8% | 240 mL lactose hydrolyzed milk (lactose totaling 11.8 g, 23.6 daily), consumed at breakfast and dinner. The lactose in fresh, low-fat milk was hydrolyzed by adding 1.07 g of a lactase preparation obtained from Kluyveromyces lactis to 1 L milk. A washout period of 7 days between treatments. | 240 mL regular milk (lactose totaling 11.8 g, 23.6 daily), plus aspartame (to simulate the taste of lactase-treated milk, consumed at breakfast and dinner. | Mean symptom severity scores ranked scale on a scale as follows: 0=none; 1=trivial; 2= mild; 3=moderate; 4= strong; 5= severe. Extracted from graph Neither LNP group had a significant increased in symptoms during the regular milk period compared to the lactose hydrolyzed milk period. S-NLP subjects reported significantly greater gaseous symptoms compared to A-NLP during both feeding periods. Conclusion(s): Authors concluded lactase-nonpersistent subjects can tolerate two cups of milk per day without appreciable symptoms. | Allocation concealment: unclear Blinding: Double Intent-to-treat analyses: 100% followup Study withdrawals adequately described: no withdrawals reported
Vesa, 1997^60^ RCT, crossover Sponsorship: Finnish Association of Agronomists Finland Duration of symptom recording: 2 days | Data source: 30 Estonian subjects with lactose maldigestion. Inclusion criteria: Lactose maldigestion based on measuring of urinary galactose concentration after ingesting 50 g lactose with 150 mg ethanol/kg body weight, with symptom followup during the test day. Exclusion criteria: No gastrointestinal diseases, were not on medications, on antibiotics at least two months prior to study, or had irritable bowel syndrome. Methods to measure outcomes: On test days, after consuming milk, subjects noted symptoms (flatulence, nausea, abdominal bloating, abdominal pain) on a questionnaire with a visual analog scale (VAS). | Mean age (range): 46 (18–74) Gender: women 90%. Race/ethnicity: not reported Comorbidities: not reported Cointerventions: not reported | 200 mL lactose-free milk (0.1% fat) x 2 daily (lactose totaling 0 g over 2 days) | 200 mL fat-free milk (0.1% fat) x 2 daily, (lactose totaling 19.6 g over 2 days) 200 mL high-fat milk (4.9% fat) x 2 daily (lactose totaling 19.6 g over 2 days) Milk-free period over 5 days | Percentage of subjects who experienced symptoms during the test day after each lactose dose The sum of symptoms was higher during all milk periods than during the milk-free period (P<0.01). There were no statistically significant differences in the occurrence or severity of symptoms during the fat-free milk period compared with the high-fat milk period. Conclusion(s): A marked difference in the fat content of milk did not affect the symptoms of lactose intolerance. | Allocation concealment: unclear Blinding: Double blinding attempted, although it was noted that full fat milk can be readily discerned from fat- free milk. Intent-to-treat analyses: 100% followup Study withdrawals adequately described: no withdrawals reported
Vesa, 1996^61^ RCT, crossover Sponsorship: not reported Finland Duration of symptom recording: 1 day | Data source: 39 Finnish subjects with lactose maldigestion and 15 lactose digesters. Inclusion criteria: Lactose maldigestion based on a positive lactose H2 breath test (39%) or lactose tolerance test with ethanol (61%). Lactose maldigesters who experienced at least moderate gastrointestinal symptoms, i.e., loose stools, abdominal pain, abdominal bloating, or flatulence, were selected for in the study group. Exclusion criteria: No gastrointestinal diseases or on antibiotics one month prior to study. Methods to measure outcomes: On test, for 12 h after consuming milk, subjects noted symptoms (flatulence, abdominal bloating, abdominal pain, borborygmi, and loose stools) on a questionnaire with a visual analog scale (VAS) | 1. Lactose maldigesters (n=39) Mean age (range): 47.2 (27–70) Gender: women 62%. Race/ethnicity: white 100%. 2. Lactose digesters (n=15) Mean age (range): 38.3 (25–54) Gender: women 66%. Race: white 100%. Comorbidities: 5 hypertensives and one diabetic. Cointerventions: not reported | 200 mL fat-free, lactose-free milk x 1 serving (lactose was separated chromatographically). The taste of the milk was disguised with 0.2 g lemon flavoring and the sweetness and osmolarity of the test milks were equalized with glucose. | 200 mL fat-free, lactose-free milk x 1 serving (lactose was separated chromatographically) plus 0.1%/3‐ galactosidase was added to ensure that it contained no traces of lactose. Milk 1. plus 0.5 g lactose Milk 2. plus 1.5 g lactose Milk 3. plus 7 g lactose | Percentage of subjects who experienced symptoms during the test day after each lactose dose. Maldigesters reported significantly more abdominal bloating and abdominal pain than the digesters. There was no difference in the mean severity of the reported symptoms between the test milks and the lactose-free milk in the group of lactose maldigesters, of whom one-third did not experience any symptoms from any of the test doses. The same proportion (64%) of the maldigesters experienced symptoms after both the lactose-free milk and the milk with 7 g lactose. Conclusion(s): Gastrointestinal symptoms in most lactose maldigesters are not induced by lactose when small amounts (0.5–7.0 g) of lactose are included in the diet. | Allocation concealment: unclear Blinding: Double Intent-to-treat analyses: 100% followup Study withdrawals adequately described: no withdrawals reported
Saurez, 1995^62^ RCT, crossover Sponsorship: Department of Veterans Affairs, National Institute of Diabetes and Digestive and Kidney Diseases, and the University of Minnesota USA Duration of symptom recording: 1 week | Data source: 30 American subjects who reported severe lactose intolerance with consistent related symptoms. Subjects were classified as having lactose mal‐ absorption if their breath H2 concentrations increased by more than 10 parts per million (ppm) (0.93 x 10^−6^ g of H2 per liter of air or 0.45 μmol per liter). The ability of the colonic flora to produce hydrogen through fermentation in response to carbohydrate malabsorption was tested in seven of the nine subjects who were able to absorb lactose after they ingested 10 g of lactulose. Exclusion criteria: Subjects were excluded if they did not report consistently having symptoms after drinking less than 240 ml of milk; if they had undergone gastro-intestinal surgery, had other major illnesses, or received antibiotic therapy within the previous two months; or if they indicated that they could not consume aspartame. Methods to measure outcomes: Subjects rated the occurrence and severity of gastro‐ intestinal symptoms experienced during the 24-hour period after each test meal. | Lactose mal- absorbers (n=21) Mean age (range): 29.4 (18–50) Gender: women 62%. Race/ethnicity: white 38%; Asian 33%, Hispanic 24%; black 5%. Lactose absorbers (n=9, those with increase in H2 <10 ppm) Mean age (range): 25.1(18–45) Gender: women 56%. Race/ethnicity: white 89%; East Indian 11% Comorbidities: not reported Cointerventions: not reported. | Hydrolyzed low-fat milk (HM) (lactose content <0.05 g) by adding 1.07 g of lactase from Kluyveromyces lactis (Lactaid, Pleasantville, NY) to 1 liter of milk at breakfast daily for a one-week period. | Low-fat milk (lactose content 12.1 g) to plus aspartame (to simulate the taste of lactase-treated milk) at breakfast daily for a one- week period. | Intensity of daily gastrointestinal symptoms over the one week period (mean ± SEM), 0=none; 1=trivial; 2=mild; 3=moderate; 4=strong symptoms; and 5=severe. Diarrhea or loose stool was defined as “an urgent, watery defecation.” In Subjects recorded each passage of flatus. During the study periods, gastrointestinal symptoms were minimal. When the periods were compared, there were no statistically significant differences in the severity of these four gastrointestinal symptoms. Conclusion(s): People who identify themselves as severely lactose-intolerant may mistakenly attribute a variety of abdominal symptoms to lactose intolerance. When lactose intake is limited to the equivalent of 240 ml of milk or less a day, symptoms are likely to be negligible and the use of lactose-digestive aids unnecessary. | Allocation concealment: unclear Blinding: double Intent-to-treat analyses: 100% followup Study withdrawals adequately described: no withdrawals reported
Johnson, 1993^63^ RCT, crossover Sponsorship: The National Dairy Board In cooperation with the National Dairy Council USA Duration of symptom recording: unclear | Data source: 45 lactose‐ maldigesting and lactose intolerant African Americans. All subjects claimed to have GI symptoms after consuming one cup of milk or less. Inclusion criteria: Subjects who had an increase in hydrogen concentration from baseline of ≥ 20 ppm. Exclusion criteria: Chronic constipation and other GI problems, regular cigarette smokers, and subjects on antibiotic therapy. Methods to measure outcomes: Subjects were to record symptoms after ingestion (time period unclear) | Ages ranged from 12–40 in the eligible population. Gender: not reported but mostly female (70%) in the eligible population. Race/ethnicity: black 100% Comorbidities: not reported Cointerventions: not reported | 315 mL hydrolyzed milk (lactose content 0 g) by adding 30 drops of lactase (Lactaid, Pleasantville, NY) to of milk. Subjects took 3 samples, either HM twice and M once or the opposite on 3 different days, assigned in a random order. | 315 mL milk (lactose content 16.4 g) plus artificial sweetener (to simulate the taste of lactase- treated milk) Subjects took three samples, either M twice and HM once or the opposite on 3 different days, assigned in a random order. | absorption. 33% (n=10) reported symptoms consistent with lactose mal‐ absorption with both HM and milk. Conclusion(s): Authors conclude that the cause of milk intolerance in up to 1/3^rd^ African Americans claiming symptoms after ingestion of a moderate amount of milk cannot be due to its lactose content. | Allocation concealment: unclear Blinding: double Intent-to-treat analyses: 100% followup Study withdrawals adequately described: no withdrawals reported
Lin, 1993 Study 2^64^ RCT, crossover Sponsorship: Thompson Medical Co., Inc. and the Minnesota Agricultural Experiment Station USA Duration of symptom recording: 8 hours | Data source: 11 American adults similarly characterized as maldigesters as in Study 1 by breath hydrogen analysis following a 50-g lactose load and by past experience with intolerance symptoms following the consumption of dairy foods Inclusion and exclusion criteria: Same as Study 1. Methods to measure outcomes: Subjects kept a similar diary to Study 1, except that symptoms of bloating, abdominal cramps, nausea, abdominal pain, diarrhea and gas were self-scored by subjects at baseline and 4 and 8 hr on a 1–5 scale (none to worst ever experienced). | Age range: 18–60 Gender: women 91%. Race/ethnicity: not reported Comorbidities: not reported Cointerventions: not reported | 50 g of lactose dissolved in 200 ml of water plus β‐ galactosidase (β‐ gal) enzyme preparations 1) Lactogest soft gel capsules × 2 (Thompson Medical Inc, New York, New York), 2) Lactogest capsules × 4 3) Lactaid caplets × 2 (Lactaid Inc, Pleasantville, New Jersey) or 4) DairyEase chewable tablets x 2 (Glenbrook Laboratories, New York, NY) | 50 g of lactose dissolved in 200 ml of water plus two soft gel vitamin E capsules containing 420 rag/capsule of α-tocopherol in soybean oil as a Placebo (Pharmacaps Inc, Elizabeth, New Jersey) | Symptom scores, expressed as the sum of mean scores rating symptoms from 1 (none) to 5 (worst ever experienced) at baseline and 4 and 8 hours after challenge. Conclusion(s): Symptom scores for bloating, cramping, nausea, pain, diarrhea, and flatus were not significantly different between treatments and the control. | Allocation concealment: adequate (small brown coded envelopes) Blinding: double Intent-to-treat analyses: 100% followup Study withdrawals adequately described: no withdrawals reported Funding: Some industry support
Nielsen, 1984^65^ RCT, crossover Sponsorship: Danish Medical Research Council Denmark Duration of symptom recording: 1 day | Data source: 9 lactose intolerant Danish children Inclusion criteria: Subjects had to fulfill two of the following: 1) An increase in blood glucose during a lactose tolerance test (2 g of lactose per kilogram of body weight); 2) Diarrhea, borborygmus, and/or flatulence during a lactose tolerance test; 3) Low or no lactase activity in an intestinal biopsy specimen taken at the ligament of Treitz. Exclusion criteria: Subjects with acute or chronic diarrhea or other GI orders. Methods to measure outcomes: At 10 times during the 24 test periods, a 0 was recorded in the scoring chart to indicate no symptoms and a 1 was recorded if symptoms or defecation was observed by the children’s parents. | Median age (range): 10 (9–16) Gender: female 33%. Ethnicity: 6 subjects immigrants from Korea, Pakistan, or Turkey (plus 3 native Danes) Comorbidities: No subjects had renal or endocrine disorders or hereditary diseases. Cointerventions: None received any medicine during the period of examination. | One half liter of hydrolyzed milk (HM) (lactose content 1.25 g) by adding 2 mL of lactase from Kluyveromyces fragilis (Lactozym 3000 L, Novo Industri A/S, Bagsvaerd, Denmark), given after 8 hours of fasting | One half liter of ordinary milk (lactose content 25 g) given after 8 hours of fasting | Summation of observed symptoms from the scoring charts of the 9 subjects. Conclusion(s): Children had significantly fewer clinical symptoms and signs within 24 hours after consuming lactose-hydrolyzed milk compared to regular milk. | Allocation concealment: unclear Blinding: double Intent-to-treat analyses: 100% followup Study withdrawals adequately described: no withdrawals reported Funding: non- industry
Lybeck Sørensen, 1983^66^ RCT, crossover Sponsorship: Not reported Denmark Duration of symptom recording: 8 hours | Data source: 35 symptomatic lactose intolerant Danish adults from Latin America. Inclusion criteria: Lactose intolerance based on a lactose tolerance test (not defined), with no known disorders of the gastrointestinal tract. Exclusion criteria: lactose tolerance Methods to measure outcomes: Subjects completed questionnaire concerning the development of symptoms (borborygmus and meteorism, colic attacks, flatulence, and/or diarrhea) based on the following: 0=no symptoms; 1=slight; 2=moderate; 3=severe. The total symptom score was calculated as the sum of the score for each person. | Mean age (range): 32 (20–60) Gender: women 54%. Race/ethnicity: Latin American 100% Comorbidities: not reported Cointerventions: not reported | 250 and 500 mL low-lactose milk (lactose content 1.6 g), 86% of the lactose was removed by ultrafiltration and replaced with the addition of maltodextrose. 48 hours between tests. | 250 and 500 mL skim milk (SM) (lactose content 11.3 g). | Frequency of symptoms in percent following milk ingestion. Conclusion(s): Ingestion of 500 mL low-lactose milk resulted in significantly fewer symptoms compared to regular skim milk. After ingestion of 250 mL low-lactose milk there was a tendency to fewer symptoms but the difference was not statistically significant. | Allocation concealment: unclear Blinding: double Intent-to-treat analyses: 100% followup Study withdrawals adequately described: no withdrawals reported
Rask Pedersen, 1982^67^ RCT, crossover Sponsorship: NOVO Industries supplied the lactase and performed the HPLC analyses Denmark Duration of symptom recording: 1 day | Data source: 11 symptomatic lactose intolerant Danish adults. Inclusion criteria: Rise in blood glucose levels <1.4 mmol/L above fasting level after ingestion of 50 g lactose with symptoms (abdominal cramp, meteorism, and/or diarrhea). Methods to measure outcomes: On a 24 hour diary sheet, subjects reported abdominal symptoms based on the following. 0=none; 1= mild/moderate; 2= severe. For diarrhea, No diarrhea=formed stools; mild/moderate= ≤ 3 liquid/soft stools; severe= ≥ 4 liquid/soft stools. | Mean age: 43 Gender: women 64%. Race/ethnicity: not reported Comorbidities: not reported Cointerventions: not reported | 500 mL low-lactose milk (lactose content 3.75 g), 85% hydrolyzed by adding 2 mL of lactase from Kluyveromyces fragilis (Lactozym 3000 L, Novo Industri A/S, Bagsvaerd, Denmark) to of milk x 1 dose. | 500 mL ordinary milk (lactose content 25 g), x 1 dose. | Number of subjects reporting symptoms after ingestion Conclusion(s): There was a significant reduction in abdominal symptoms after ingestion of lactose-hydrolyzed milk compared to regular milk. | Allocation concealment: unclear Blinding: double Intent-to-treat analyses: 100% followup Study withdrawals adequately described: no withdrawals reported
Reasoner, 1981^68^ RCT, crossover Sponsorship: University of Rhode Island and Shadow Research Foundation, Inc. USA Duration of symptom recording: 1 week | Data source: 9 symptomatic American adults from an outpatient clinic and 5 milk tolerant controls. Inclusion criteria: Subjects with a blood sugar <20 mg/100 mL after ingestion of 50 g lactose and had symptoms when challenged with 250 mL of skim milk. Methods to measure outcomes: Subjects rated the occurrence and severity of gastro‐ intestinal symptoms experienced during the 24-hour period after each test meal. 0=none; 1= mild; 2=moderate; and 3=severe. Number of days that the subject responded per week was totaled. A quotient was then calculated, giving a symptom index for the week. | “Milk-intolerant” (n=9) Mean age (range): 41 (22–60) Gender: women 44%. Race/ethnicity: not reported Comorbidities: 2 subjects had LI due to Crohn’s disease (one also had an intestinal resection), and one subject had a subtotal gastrectomy. Cointerventions: not reported “Milk-tolerant” (n=5) Mean age (range): 33 (22–48) Gender: women 60%. Race/ethnicity: not reported | Low-lactose milk (lactose content ~2.9 g/d) x 1 week), 74–91% hydrolyzed with lactase (Maxilact 40,000, GB Fermentation, Des Plains, Illinois). Average weekly consumed was 1.79 L. | 1) Skim milk (lactose content ~28.5 g/d) x 1 week. Average weekly consumed was 1.58 L. 2) Skim milk + glucose (simulates the taste of lactase- treated milk) x 1 week. Average weekly consumed was 1.8 L. 3) Sweet acidophilus milk x 1 week. Average weekly consumed was 1.50 L. | Abdominal symptom responses trans‐ formed into a numerical value. Numbers correlate with the following: 0 to 0.33 = none to mild; 0.34 to 0.66 = moderate; 0.67 to 1.0 = severe. Conclusion(s): Lactose-hydrolyzed milk significantly reduced pain and gas symptoms in the “Milk-intolerant” group compared to regular skim milk. | Allocation concealment: unclear Blinding: double Intent-to-treat analyses:100% followup Study withdrawals adequately described: no withdrawals reported
Unger, 1981^69^ RCT, crossover Sponsorship: not reported USA Duration of symptom recording: 1 day | Data source: 24 American lactose malabsorbers (determined by breath hydrogen test) and 75 lactose absorbing adolescent volunteers. Subjects were to report all symptoms during breath hydrogen test period. Presence of ≥ 1 GI symptom was considered a positive response to lactose. Methods to measure outcomes: Symptomatology questionnaires were given to subjects each day after the test beverage was consumed. One or more relevant symptoms occurring between one and 24 hours indicated a positive response to the dairy drink for that test day. The 4 symptoms (bloating, flatulence, cramps, diarrhea) indicative of lactose intolerance were rated according: 0=none; 1=mild; 2=moderate; 3=severe | Mean age (range): 24 (18–46) Gender: women 49%. Race/ethnicity: white 87% (northern European n=65; southern- European n=8; Jewish n=14), Asian 10%, black 3%. | 240 or 480 mL lactose-free chocolate dairy drink. | 240 or 480 mL lactose-containing (lactose content 10.8–21.6 g) chocolate dairy drink. | Subjects reporting symptoms during 24 hours after consumption. Conclusion(s): 12.5% of lactose malabsorbers were symptomatic after consuming 240 mL of lactose-free solution versus 33.3% after consuming 240 mL lactose solution. | Allocation concealment: Blinding: double Intent-to-treat analyses: Study withdrawals adequately described:
Cheng, 1979^70^ RCT, crossover Sponsorship: Chile Foundation Chile Duration of symptom recording: 1 day | Data source: Chilean volunteers from the Santiago penitentiary. 15 were lactose intolerant and 16 were lactose tolerant controls. Inclusion criteria: Lactose intolerance, determined by blood glucose analysis [<20 mg/100 considered deficient lactase activity] and developed symptoms after ingestion of 50 g lactose. Methods to measure outcomes: A standard questionnaire was applied twice daily. All symptoms, attributable or not to lactose intolerance, were recorded. No symptoms = 0, mild (symptoms present but not interfering with daily activities or <2 liquid bowel movements) = 1, severe (symptoms present and interfering with daily activities or caused great discomfort or >2 liquid bowel movements) = 2. No data on statistical analyses. | Lactose intolerant subjects (n=15) Mean age (range): 27 (19–34) Gender: men 100% Race/ethnicity: Latin American 100%. Lactose tolerant subjects (n=16) Mean age (range): 27 (18–38) Gender: men 100% Race/ethnicity: Latin American 100%. Comorbidities: not reported Cointerventions: not reported | 500 mL low lactose milk (lactose content 0.5 to 1.25 g), hydrolyzed with lactase (galactosidase, Maxilact, Enzyme Development Corporation, New York, NY), x 2 daily for 1 month. | 500 mL skim milk (lactose content 25 g), sweetened with sucrose to imitate taste of low-lactose milk. All subjects received at least 4 of these tests. | Results are expressed as the number of times a score was given to each symptom during the experiment. Conclusion(s): Lactose intolerant subjects had more symptoms and more severe symptoms with skim milk. | Allocation concealment: unclear Blinding: noted as double, unclear if milks were given out randomly. Intent-to-treat analyses: 100% followup Study withdrawals adequately described: no withdrawals reported
Jones, 1976 Study 2^71^ Single blind RCT no masking to taste, crossover USA Duration:8 hours Funded by National Dairy Council and NY State Agriculture Experiment station hatch project | Data Source: 17 American volunteers who reported symptoms after ingesting 25 g lactose but not after placebo. Inclusion criteria: LI on basis of rise in blood glucose of less than 25 mg/100mL after 50 g lactose injection | Mean age 24 (range 20–34) Gender: women 41% Race/ethnicity: Asian 41%; black 18%; Latin- American 12%; Other 29% Comorbid: none Co-intervention: none | 60% reduced skim milk 500 ml (10 g lactose) 60% reduced lactose whole milk 500 ml (10 g lactose). Placebo 250 ml (saccharin, lemon juice water) | Regular skim milk 500 ml (25 g lactose). Regular whole milk 500 ml (25 g lactose) | Sum of score of bloating, gas, cramps and diarrhea on scale: 0-none, 1=mild, 2= moderate, 3=severe. Conclusion(s): 1) Lower lactose milk better tolerated; 2.) No differences in tolerance between test beverages | Allocation concealment: unclear Blinding: single no masking Intent-to-treat analyses: 100% followup Study withdrawals adequately described: no withdrawals reported
Studies in which subjects were not noted to be symptomatic at baseline or symptoms were not required for study inclusion (based on biochemical measures only)
Lin, 1993 Study 1^64^ RCT, crossover Sponsorship: Thompson Medical Co., Inc. and the MinnesotaAgricultur al Experiment Station USA Duration of symptom recording: 8 hours | Data source: 20 “healthy” American lactose maldigesters adults based soley on breath hydrogen test. Inclusion criteria: Breath hydrogen concentration to >20 ppm (>1.80 × 10 ^−6^ g H_2_/liter air) after ingestion of 400 ml of low-fat (2%) milk containing approximately 20 g of lactose. Exclusion criteria: Pregnant or lactating, had prior gastro‐ intestinal surgery, had illness that would interfere with the experiment, or had used antibiotics within the past 30 days. Methods to measure outcomes: Subjects kept a dairy of symptoms and self- rated gas, stomach pain and/or cramps and diarrhea and/or loose stool for each hour from 0 to 8 hours following the test meal. Scores are expressed as the mean of the sum of scores rating symptoms from 0 (none) to 5 (severe) for each hour from baseline to 8 hr after the challenge. | Age range: 25–40 Gender: women 50%. Race/ethnicity: not reported Comorbidities: not reported Cointerventions: not reported | 400 ml of low-fat (2%) milk (lactose content 20 g) plus β-galactosidase (β‐ gal) enzyme preparations 1) Lactogest soft gel capsules x 2 (Thompson Medical Inc, New York, NY), 2) Lactogest capsules x 4 3) Lactaid caplets x 2 (Lactaid Inc, Pleasantville, New Jersey) or 4) DairyEase chewable tablets 2 (Glenbrook Laboratories, New York, NY) | 400 ml of low-fat (2%) (lactose content 20 g) plus two soft gel vitamin E capsules containing 420 rag/capsule of α‐ tocopherol in soybean oil as a Placebo (Pharmacaps Inc, Elizabeth, New Jersey) | The difference in symptom scores (from baseline), based on the summation of observed symptoms from the scoring charts (on a 0 = none to 5 = severe scale) of the 20 subjects. Conclusion(s): Symptoms were significantly less severe with all the β‐ galactosidase products. | Allocation concealment: adequate (small brown coded envelopes) Blinding: double Intent-to-treat analyses: 100% followup Study withdrawals adequately described: no withdrawals reported
Brand, 1991^72^ RCT, crossover Sponsorship: Not reported Australia Duration of symptom recording: 4 hours | Data source: Six healthy adult Australian subjects with lactose malabsorption. Subjects were not noted to be symptomatic at baseline. Inclusion criteria: Diagnosis of lactose malabsorption was based on the results of a challenge with 300 mL whole milk containing 14 g lactose after an overnight fast based on a peak breath hydrogen excretion >20 ppm. Methods to measure outcomes: At hourly intervals they rated their symptoms (cramps, flatulence, and diarrhea) on a scale of 0, no symptoms; 1, mild; 2, moderate; and 3, severe. | Mean age (range): 33 (29 to 44) Gender: female 83%. Ethnicity: The 6 subjects were immigrants from Indonesia, Japan, Malaysia, and Laos. Comorbidities: not reported Cointerventions: not reported | 300 mL 50% lactose reduced milk (Lacto Lo) (lactose content 2.4 g) 300 mL 80% lactose reduced milk (Cotee) (lactose content 1 g) 300 mL 80% lactose reduced milk (Balance) (lactose content 1 g) 300 mL 95% lactose reduced milk (Digestelact) (lactose content <0.25 g) | 300 mL whole milk (lactose content 4.8 g), tested twice in each individual (n = 12). After an overnight fast the subjects consumed 300 mL of each of five milk products in a single-blind fashion and random order on separate occasions 3–5 d apart. | Number of subjects who reported specific symptoms. Conclusion(s): The results suggest that a 50% level of lactose reduction in milk may be adequate to relieve the signs and symptom s of milk intolerance in the majority of healthy adults with lactose malabsorption. | Allocation concealment: unclear Blinding: single Intent-to-treat analyses: 100% followup Study withdrawals adequately described: no withdrawals reported
Cavalli-Sforza, 1986^73^ RCT, crossover Sponsorship: Parmalat Spa Italy Duration of symptom recording: 1 day | Data source: 80 Italian adults, data from 71 subjects: 40 lactose malabsorbers and 30 lactose absorbers. Inclusion criteria: Adults free from gastrointestinal diseases and diabetes. All subjects were give lactose tolerance test (50 g lactose in 200 mL water). Subjects were defined as lactose malabsorber if maximum increase in blood glucose concentration above fasting level was <20 mg/dL. Methods to measure outcomes: Questionnaire was given to subjects to indicate whether they experienced diarrhea, flatulence, bloating, or abdominal pain during the 24 hours after consuming the milk test. Symptoms were rated mild = 1, moderate = 2 or severe = 3 in intensity. A total for the 4 symptoms could range from 0 to 12. | All subjects (N=80) Mean age (range): 34 (18 to 69) Gender: female 66% Ethnicity: not reported Comorbidities: not reported Cointerventions: not reported | Regular whole hydrolyzed milk (lactose content 0.5 g/dL) and fat content of 3.2 g. Regular skim hydrolyzed milk (lactose content 0.65 g/dL and fat content of 0.10 g.) Each type of milk was taken on 4 consecutive days in Increasing quantities: 125, 250, 500, 1000 mL. The larger quantities could be divided into 2 to 6 intakes during the day. | Regular whole milk (lactose content 4.9 g/dL) and fat content of 3.3 g. Regular skim milk (lactose content 5.10 g/dL and fat content of 0.15 g; 12.75 per milk serving) | Symptom response to the intake of the 4 milk types, percent of cases. Conclusion(s): Lactose malabsorbers had significantly fewer symptoms with skim milk vs. whole milk. The authors found, contrary to earlier findings, that fat seemed to contribute to milk intolerance in lactose malabsorbers rather than reduce it. | Allocation concealment: unclear Blinding: double Intent-to-treat analyses: no, 74 of 80 completed study satisfactorily but data only for 71 (3 refused to drink milk at room temperature) Study withdrawals described: yes
Rosado, 1984^74^ RCT Sponsorship: Limited, industries provided the enzymes (SugarLo Co. (Pleasantville, NJ) and G.B. Fermentation (Kingstree, SC)) USA/Mexico Duration of symptom recording: 1 day | Data source: 50 Mexican adults were enrolled, 25 lactose malabsorbers and 25 absorbers. Inclusion criteria: No inclusion criteria, subjects unselected. Methods to measure outcomes: Subjects completed symptom questionnaire document presence or absence of 4 gastrointestinal symptoms (abdominal cramps, gas/flatulence, vomiting, and/or diarrhea). Absence of all 4 symptoms = lactose tolerance. 0 =absent; 1=mild; 2=moderate; 3=severe, except for diarrhea which was always marked a 3. Total points were then summed for each of the treatment periods. A score ≥ 4 = major symptomaology, ≤ 3 = minor. Exclusion criteria: recent history or concurrent use of antibiotics or recent gastrointestinal disease. | Age range: 19–53 Gender: women 64%. Race/ethnicity: Mostly Mexican with various degrees of European and Indian descent. Comorbidities: NR Cointerventions: NR | 1) LactAid 1g combined with 360 mL milk, reconstituted from powdered whole milk (lactose content 18 g) 2) 360 mL pre- hydrolyzed milk. A minimum of 72 hours between tests. | 360 mL milk, reconstituted from powdered whole milk (lactose content 18 g) | Number of subjects reporting symptoms (minor or major). Conclusion(s): Addition of LactAid significantly reduced symptoms of intolerance among the 25 lactose malabsorbers subjects. | Allocation concealment: unclear Blinding: double Intent-to-treat analyses: 100% followup Study withdrawals adequately described: no withdrawals reported Funding: industry supplied supplies
Haverberg, 1980^75^ RCT, crossover Sponsorship: National Dairy Council USA Duration of symptom recording: 1 day | Data source: 67 American lactose malabsorbing (determined by blood glucose analysis) and 43 lactose absorbing adolescent volunteers. Classification was based on biochemical vs. subjective symptomatic response to lactose. Methods to measure outcomes: Subjects reported abdominal symptoms on a questionnaire containing yes/no or multiple choice questions regarding symptoms over 24 hours after consumption. Occurrence of diarrhea, ≥ 2 mild GI symptoms or ≥ 1 moderate or severe symptom was noted as a positive response of intolerance to the test drink. | Age range: 14–19 Gender: not reported Race/ethnicity: black 53%, white 40%; Latin American 7%. Comorbidities: not reported Cointerventions: not reported | 240 or 480 mL lactose-free chocolate dairy drink. | 240 or 480 mL lactose-containing (lactose content 10.8–21.6 g) chocolate dairy drink. | Number of subjects reporting symptoms during 24 hours after consumption 18% of lactose malabsorbers were symptomatic after consuming 240 mL of lactose-free solution versus 28% after consuming 240 mL lactose solution. Conclusion(s): Results indicate that most of the individuals who reported GI symptoms after consuming the beverages did so due to other reasons besides the lactose content. | Allocation concealment: unclear Blinding: double Intent-to-treat analyses:100% followup Study withdrawals adequately described: no withdrawals reported
Kwon, 1980^76^ RCT, crossover Sponsorship: National Dairy Council USA Duration of symptom recording: 1 day | Data source: 45 American lactose malabsorbing (determined by blood glucose analysis) and 42 lactose absorbing adolescent volunteers. Classification was based on biochemical vs. subjective symptomatic response to lactose. Methods to measure outcomes: Subjects reported abdominal symptoms on a questionnaire containing yes/no or multiple choice questions regarding symptoms (bloating, flatulence, cramps, or diarrhea) over 24 hoursafter consumption by checking 1=none; 2= mild; 3=moderate; and 4=severe. Presence of ≥1 symptom was considered as a positive intolerant response. | All subjects (N=87) Age range: (14–19) Gender: not reported Race/ethnicity: black 30%, white 64%; Asian 6%. Comorbidities: not reported Cointerventions: not reported | 240 or 480 mL lactose-free chocolate dairy drink. | 240 or 480 mL lactose-containing (lactose content 10.8 or 21.6 g) chocolate dairy drink. | Number of subjects reporting symptoms during 24 hours after consumption Among lactose malabsorbers, 27% were symptomatic after consuming 240 mL of lactose-free solution versus 9% after consuming 240 mL lactose solution. Conclusion(s): Factors other than lactose malabsorption may be responsible for a significant proportion of mild symptoms of “milk intolerance” in an adolescent population similar to this study. | Allocation concealment: unclear Blinding: double Intent-to-treat analyses: 100% followup Study withdrawals adequately described: no withdrawals reported
Rorick, 1979^77^ RCT, crossover Sponsorship: National Dairy Council USA Duration of symptom recording: 1 day | Data source: 87 American elderly volunteers, in which 23 were lactose malabsorbers (determined by breath hydrogen analysis after ingestion of 25 g lactose) and 64 lactose absorbers. Inclusion criteria: Subjects with no known gastrointestinal disease. Methods to measure outcomes: Subjects were interviewed the following morning after the test and were asked to state the occurrence severity of gas, bloating, cramps, or diarrhea during the previous afternoon. Symptom severity was based as follows: none; mild (noticeable, but not troublesome); moderate (troublesome, but not seriously uncomfortable); severe (uncomfortable, could not carry out normal activities). | All subjects (N=87) Mean age (range): 77 (60–97). Gender: women 77% Race/ethnicity: Northern/western European ancestry 76% (35% of the malabsorbers), Jewish 11% (30%), black 8% (22%), Southern Italian 5% (13%). Comorbidities: not reported Cointerventions: not reported | 240 mL lactose-free chocolate dairy drink. | 240 mL lactose- containing (lactose content 10.8 g) chocolate dairy drink. | Number of subjects reporting intolerance to test drinks based on GI symptoms during the afternoon after consumption. Symptom frequency was not significantly different between beverages in both malabsorbers and absorbers. Conclusion(s): Authors conclude factors other than lactose malabsorption appeared to be responsible for the symptoms of intolerance reported and most may have been psychosomatic in origin. | Allocation concealment: unclear Blinding: double Intent-to-treat analyses: 100% followup Study withdrawals adequately described: no withdrawals reported
Lisker, 1978^78^ RCT, crossover Sponsorship: Programa Nacional de Alimentos of the Consejo Nacional de Ciencia Y Tecnología de México. Mexico Duration of symptom recording: 6 hours | Data source: 150 Mexican volunteers, in which 97 were lactose malabsorbers (determined by blood glucose analysis [<25 mg/dl considered deficient lactase activity] after ingestion of 50 g lactose). Inclusion criteria: Subjects with no known gastrointestinal disease, diabetes. Methods to measure outcomes: Symptoms were rated according: 1+ if mild; 2+ if moderate; 3+ if marked. Symptoms were scored as severe if diarrhea was present or if a cumulative rating of other symptoms (abdominal cramps, bloating, flatulence) was 4+. Cumulative rating less than 4+ was considered mild | All subjects (N=150) Mean age (range): 24 (16–50). Gender: women 41% Race/ethnicity: Mexican 100% 60 of the volunteers had previously participated in lactose mal‐ absorption studies and were also aware they could tolerate at least 250 mL of milk at one time without difficulty. Comorbidities: not reported Cointerventions: not reported | 250 mL lactose-free milk plus 7.1 glucose. Powdered chocolate added to mask flavors. | 250 mL regular milk (lactose content 12.5 g). 250 mL regular milk plus additional 25 g lactose added (lactose content 37.5 g). | Conclusion: Authors concluded that lactose-intolerant subjects are indeed lactose-intolerant and that the frequency of abdominal symptoms that occur in persons with lactose malabsorption increases directly with the lactose content in milk. | Allocation concealment: unclear Blinding: double Intent-to-treat analyses: 100% followup Study withdrawals adequately described: no withdrawals reported
Paige, 1975^79^ RCT, crossover Sponsorship: Maternal and Child Health Services and National Institutes of Health USA Duration of symptom recording: 90 minutes | Data source: 22 lactose‐ malabsorbers and 10 lactose absorber African American volunteers. Malabsorption was based on blood sugar rise of 26 mg/mL following ingestion of lactose load (50 g/m^2^ of body surface) Inclusion criteria: no overt gastrointestinal or metabolic disease, Methods to measure outcomes: Symptoms voluntarily mentioned were recorded. Subjects were not specifically asked if they developed any symptoms commonly associated with lactose intolerance. | All subjects (N=32) Age range: 13–19. Gender: not reported Race: black 100%. Comorbidities: not reported Cointerventions: not reported | 240 mL whole milk, 90% hydrolyzed (lactose content 1.2 g) by adding lactase from Saccharomyces lactis 240 mL. whole milk, 50% hydrolyzed (lactose content 6 g) by adding lactase from Saccharomyces lactis. | 240 mL whole milk (lactose content 12 g). | Number of subjects reporting symptoms during 90 minutes after consumption. 90% hydrolyzed milk (n=22): 3 including 2 from the whole milk group) 90% hydrolyzed milk (n=18): none Whole milk (n=22): 3 Conclusion(s): Authors concluded hydrolyzed milk may serve as alternative to milk in subjects with low lactase levels. | Allocation concealment: unclear Blinding: double Intent-to-treat analyses: 100% followup Study withdrawals adequately described: no withdrawals reported
Jones 1976, Study 1^71^ Single blind RCT no masking to taste, crossover USA Duration:8 hours Funded by National Dairy Council and NY State Agriculture Experiment station hatch project Hypothesis: 1. milk with lower lactose better tolerated than regular milk, 2. compare symptoms after whole, skim milk, and lactose solutions | Data Source: 16 American adult volunteers Inclusion criteria: LI on basis of rise in blood glucose of less than 25 mg/100mL after 50 g lactose injection Methods to measure outcome: Asked about any symptoms of bloating, gas, abdominal cramps and diarrhea on 0–3 point scale, summed | Mean age 25 (range 23–55) Gender: women 31% Race/ethnicity: Asian 25%; black 19%; Latin‐ American 13%; other 44% Comorbid: none Co-intervention: none | 1. 50% lactose reduced skim milk 591 ml (30 g lactose) 2. 75% lactose reduced skim milk 591 ml (15 g lactose) | Regular skim milk 591 ml (50 g lactose | Sum of score of bloating, gas, cramps and diarrhea on scale: 0-none, 1=mild, 2= moderate, 3=severe. Conclusion(s): 1) Lower lactose milk better tolerated; 2.) Whether milks were given with or without food had no significant effect on symptoms | Allocation concealment: unclear Blinding: single no masking Intent-to-treat analyses: 100% followup Study withdrawals adequately described: no withdrawals reported
B. Prebiotics or probiotics
I. Studies where subjects were reported to be symptomatic at baseline in addition to LI testing
Newcomer, 1983^80^ RCT, crossover Funding: US national diary council and NC State University Dairy Foundation USA Duration: 10 weeks Hypothesis: Unfermented acidophilus milk is better tolerated than regular milk | Data source: 28 US volunteers Inclusion criteria: No symptoms and negative hydrogen breath test for controls and symptoms and positive hydrogen breath test for cases (defined as H2 excretion of. 30 ml/min after 50gm lactose plus symptoms) Methods to measure outcomes: Subjects kept a diary for scoring 0–4; 0=no trouble, 1=slight symptoms, 2=mild s/s, 3= moderate, 4= severe) for 4–10 weeks Loss to followup: none | Range age: 18–69 Gender: NR Race: NR Comorbid: 5/18 cases also had IBS Co-intervention: none | Unfermented acidophilus milk: 2% milk with L. acidophilus added for approx 7x10(6) colony/ml (one 8 oz glass with three meals, 3x/day for total of 720 ml/day) | 2% milk: 3 8 oz glasses per day, one with each meal for total of 720 ml/day | Median of cumulative s/s score over 10 weeks as sum of diarrhea+pain+gas+ borborygmi over 5 2‐ week periods for LI group Conclusion(s): No difference in tolerance of regular milk vs. unfermented acidophilus milk | Allocation concealment: unclear Blinding: double Intent-to-treat analyses: 100% followup Study withdrawals adequately described: no withdrawals reported
II. Studies where subjects did not have symptoms of LI at baseline or not reported and only underwent breath/other testing
Lin, 1998^81^ RCT, crossover Sponsorship: National Science Council of Taiwan Taiwan Duration of symptom recording: 8 hours | Data source: 20 Taiwanese subjects. Inclusion criteria: Maldigesters were classified on the basis of a rise in breath hydrogen concentration of >20 ppm after ingestion of 400 ml of milk containing approximately 20 g of lactose. Methods to measure outcomes: Subjects rated symptoms on a 0‐ 5 (none to severe) scale for each hour from hour 1 to hour 8 following each of the diets. | No information on age and gender provided. Comorbidities: not reported Cointerventions: not reported | 1) 400 ml of 2% low-fat milk containing L. acidophilus at a cell concentration of 108 CFU/ml; 2) 400 ml of 2% low-fat milk containing L. acidophilus at 109 CFU/ml; 3) 400 ml of 2% low-fat milk containing L. bulgaricus at 108 CFU/ml; 4) 400 ml of 2% low-fat milk containing L. bulgaricus at 109 CFU/ml. All milk products were non- fermented. | 400 ml of 2% low- fat milk | Symptom scores are expressed as the mean of the sum of stomach pain, gas, and diarrhea scores rated from 0 to 5 (none to severe) for each hour from 0 to 8 hr after consumption of the diets. Conclusion(s): Non- fermented milks containing L. bulgaricus 449 at 10^8^ and 10^9^ CFU/ml were effective in reducing symptoms. | Allocation concealment: unclear Blinding: double Intent-to-treat analyses: 100% followup Study withdrawals adequately described: no withdrawals reported
Mustapha, 1997^82^ RCT, crossover Sponsorship: Minnesota-South Dakota Diary Foods Research Center United States Duration of symptom recording: 8 hours | Data source: 11 lactose maldigesting American subjects Inclusion criteria: Maldigesters were classified on the basis of a rise in breath hydrogen concentration of >20 ppm after ingestion of 400 ml of milk containing approximately 18 g of lactose. None had any GI illness or had taken antibiotics in the prior three months of the study. Methods to measure outcomes: Subjects rated symptoms on a 0‐ 5 (none to severe) scale for each hour from hour 1 to hour 8 following each of the diets. Diarrhea was monitored 24 hours after diet. | Age range: 25–42 Gender: women 55%. Race/ethnicity: not reported Comorbidities: not reported Cointerventions: not reported | 1) 400 mL L. acidophilus 4356 (b-galactosidase (b-gal) activity 1.22; lactose content 15‐ 16 g). 2) 400 mL L. acidophilus B (b‐ gal) activity 0.81; lactose content 15‐ 16 g). 3) 400 mL L. acidophilus N1 (lowest b-gal activity 0.50; lactose content 15‐ 16 g). 4) 400 mL L. acidophilus E (b‐ gal) activity 0.79; lactose content 15–16 g). | 400 mL low fat milk (b-gal activity 0; lactose content 15 g) | Mean symptom response 0–5 (none to severe), summed from hour 1 to hour 8. Conclusion(s): Acidophilus milk containing L. acidophilus N1 was the most effective of the four strains in improving lactose digestion and tolerance. | Allocation concealment: unclear Blinding: double Intent-to-treat analyses: 100% followup Study withdrawals adequately described: no withdrawals reported
Jiang, 1996^83^ RCT, crossover Sponsorship: Minnesota Agricultural Experiment Station USA Duration of symptom recording: 1 day with 3 days in b/w Hypothesis: HB after ingestion of milk with different strains of B. longum | Data source: 15 American volunteers Inclusion criteria: lactose maldigesters on basis of rise of >20ppm after ingestion of 400 ml of milk (16 gm lactose) on hydrogen breath test using Levitt/Donaldson method. Methods to measure outcomes: ranked scale of symptoms for abdominal pain, flatulence, borborygmi, diarrhea and meteoism: 0=none, 1=slight, 2=mild, 3=moderate, 4=moderately severe, 5= severe summed for hours 1–8. flatus frequency: mean num of gas passages over 8 hours, plus hydrogen breath test mean reading over 8 hours | Age range: 24–42, mean 29.7 Gender: women 8(52%). Race: white 100% Comorbidities: no GI disorders Cointerventions: not reported | 3 test meals: 1) 400 ml 2% milk with Bifidobacterium longum appd.r6 from m- MRS broth containing lactose 2) 400 ml 2% milk with B. longum appd.r6 from Sanofi biomed as a concentrated frozen culture 3) 400 ml of bifidus milk with B. longum ATCC 15708 from m-MRS broth containing lactose | One meal 400 ml of 2% milk | Mean symptom response 0–5 (none to severe), summed from hour 1 to hour 8. Conclusion(s): Consumption of milk containing appd.r6 grown with lactose resulted in significantly less flatulence vs. milk or the milk containing appd.r6 grown with both lactose and glucose. Authors concluded that milks containing B. longum might reduce symptoms from lactose malabsorption when the culture is grown in a medium containing only lactose to induce a higher β- galactosidase level and increase rate of lactose uptake. | Allocation concealment: yes Blinding: double Intent-to-treat analyses: 100% followup Study withdrawals adequately described: no withdrawals reported
Vesa, 1996^84^ RCT crossover France Funding: Yoplait Sodima, France Duration of symptom recording: 8 hours Hypothesis: Addition of L. bulgaricus to increase lactase activity may make milk easier to tolerate compared to yogurt and milk with L. acidohpilus and bifidobacterium | Data source: 15 Healthy French volunteers (reported 14) Inclusion criteria: lactase deficient by hydrogen breath test Methods to measure outcomes: symptom score 0–4 (0=no symptoms, 1=mild, 2=moderate, 3= fairly strong, 4=very strong symptoms) for abdominal bloating, flatulence, abdominal pain and loose stool compared mean+/−SE and sum of symptoms | Age range: 20–45 Gender: women 11 (73%) Race: 100% Caucasian Comorbidities: none Cointerventions: not reported | 3 fermented dairy products each with 18gm lactose in 250 ml water: 1) Ofilus (Yoplait, France; has L. acidophilus and bifidobacterium ) 320 ml 2) Bulgofilus (ofilus bacteria+ L. bulgaricus) 400 ml 3) Yoplait yogurt 500 ml | Lactulose 10gm in 250 ml water | Conclusion(s): Significantly less bloating with bulgofilus compared to lactulose and sum score less with bulgofilus compared to lactulose | Allocation concealment: unclear Blinding: unclear if double Intent-to-treat analyses: no 15 enrolled, 14 reported Study withdrawals adequately described: 1 withdrawal reported Industry funding
Lerebours, 1989^85^ RCT, parallel study Sponsorship: none reported. France Duration of symptom recording: unclear | Data source: 16 healthy subjects born in Cameroon. Inclusion criteria: lactose intolerance on the basis of an increase in breath hydrogen concentration >20 ppm after ingestion of 440 mL milk containing 18 g lactose. Only two subjects experienced mild flatulence after milk ingestion. Methods to measure outcomes; No methods reported. | Age range: 20–53 Gender: NR Race: black 100%. Comorbidities: not reported Cointerventions: not reported | 125 g yogurt (n=8) three times daily (breakfast, bunch, and dinner) (lactose content 18 g/d) Meals were given over 8 consecutive days. | 125 g fermented‐ then-pasteurized milk (FPM) (n=8) without living acid bacteria times daily (breakfast, bunch, and dinner) (lactose content 18 g/d) | Presence or absence of symptoms. Conclusion(s): Although lactose malabsorption was higher with FPM than with yogurt, the subjects reported no gastrointestinal distress after consuming 1PM for 8 days but it must be stressed that only two subjects experienced mild symptoms after milk ingestion. These data indicate that besides lactose digestion, other factors are involved in inducing or preventing gastrointestinal distress during the consumption of dairy products by lactase- deficient subjects. | Allocation concealment: unclear Blinding: double Intent-to-treat analyses: 100% followup Study withdrawals adequately described: no withdrawals reported
Martini, 1987^86^ RCT crossover Sponsorship: The National Dairy Board In cooperation with the National Dairy Council USA Duration of symptom recording:8 hours | Data source: 16 American healthy subjects. Inclusion criteria: lactose intolerance on the basis of an increase in breath hydrogen concentration >20 ppm after ingestion of milk containing 20 g lactose. Methods to measure outcomes; intolerance symptoms were recorded by the subjects. | Age range: 18–26 Gender: male 100% Race: NR Comorbidities: not reported Cointerventions: not reported | A. Flavored products (n=9) 1) 465 g strawberry flavored yogurt (lactose content 20 g) 2) 410 g ice milk (lactose content 20 g) 3) 400 g ice cream (lactose content 20g) B. unflavored products (n=8) 1) 455 g unflavored yogurt (lactose content 20 g) 2) 410 g unflavored yogurt FY-1 (lactose content 20 g) 3) 410 g unflavored yogurt FY-2 (lactose content 20 g) 4) 410 g unflavored yogurt FY-3 (lactose content 20 g) One subject received both products. | 415 g whole milk (lactose content 20 g) | Subjects reporting symptoms of gastrointestinal distress. Conclusion(s): Subjects were free of symptoms after consuming flavored and unflavored yogurts. Tolerance to frozen yogurt same as for ice cream and ice milk. | Allocation concealment: unclear Blinding: single- blind (subjects were not informed of the identity of each product but no attempt to mask flavors was undertaken) Intent-to-treat analyses: 100% followup Study withdrawals adequately described: no withdrawals reported
Savaiano, 1984^87^ RCT crossover, single blind (no attempt to mask flavor or texture) USA University of MN Agricultural Experiment Station, VA, NIH Duration of s/s recording: 8 hours Hypothesis: yogurt produces less symptoms than other milk products | Data source: 9 American healthy subjects. Inclusion criteria: lactose intolerance on the basis of an increase in breath hydrogen concentration >20 ppm after ingestion of milk containing 20 g lactose. Methods to measure outcomes; intolerance symptoms were recorded by the subjects, scale not reported. Symptoms reported were diarrhea, flatulence, abdominal pain | Age range: 20–28 Gender: NR Race: NR Comorbidities: not reported Cointerventions: not reported | 1) 500 gm yogurt 2) 420 gm sweet acidophilus milk 3) 465 gm cultured milk (buttermilk) 4) 500 gm pasteurized yogurt | 410 gm milk | No symptoms reported when yogurt or pasteurized yogurt was fed. 4 and 5 of the nine reported symptoms with milk and sweet acidophilus milk respectively. Conclusion(s): Yogurt is unique due to ability to enhance lactose digestion | Allocation concealment: unclear Blinding: single (no attempt to mask flavor or texture) Intent-to-treat analyses: 100% followup Study withdrawals adequately described: no withdrawals reported
C. Modifications to diet or other therapies
Cappello, 200^88^ RCT Sponsorship: not reported Italy Duration of symptom recording: 40 days | 40 symptomatic Italian subjects with positive breath H2 test for lactose intolerance Methods to measure outcomes: Subjects filled in a questionnaire related to the intensity of symptoms (bloating, abdominal pain, flatulence and diarrhea). Symptoms score referred to the 5 days preceding each evaluation and scored as: 0=absent; 1=mild (awareness of a symptom but easily tolerated); 2=moderate; 3=severe; and 4=very severe. | Mean age: 44 Gender: women 80%. Race: Not reported Comorbidities: not reported Cointerventions: not reported | 1) Rifaximin 800 mg/day x 10 days (n=14) 2) No-milk diet x 40 days (n=13) | Placebo (n=5) x 10 days | Intensity of symptoms at baseline, 10d and 40 d (mean ± SD). Conclusion(s): The total symptom score significantly improved after rifaximin and lactose-free diet. | Allocation concealment: unclear Blinding: partially open. blinding of rifaximin and placebo not reported Intent-to-treat analyses: no Study withdrawals adequately described: no Funding: not reported
D. Colonic adaptation studies
Hertzler, 1996^89^ RCT, crossover Sponsorship: The National Dairy Board In cooperation with the National Dairy Council USA Duration of symptom recording: 10 days | Data source: 20 American lactose maldigesting subjects. Inclusion criteria: Healthy nonsmokers who had not used antibiotics in the preceding 2 months and reported no history of functional bowel complaints. Subjects were classified as lactose maldigesters based on a rise in breath hydrogen of >20 ppm (0.9 imol hydrogen/L air) after a challenge dose of lactose (0.7 g/kg body wt) administered after an overnight fast. Methods to measure outcomes: Subjects rated symptoms hourly during the breath hydrogen tests using a ranked scale: 0=none, 1=slight, 2=mild, 3=moderate, 4= moderately severe, 5= severe. Data are reported as the sum of hours 1–8. During the feeding periods, subjects recorded symptoms once per day each evening during the feeding periods using the same scale mentioned above. | Mean age: 30 Gender: women 25%. Race: Asian 70%, black, Latin- American, and white 10% each Comorbidities: not reported Cointerventions: not reported | Dextrose for days 1–10 and crossed over to the other feeding period for days 12–21. Initial dosage was 0.6 g · kg body wt^−1^ · d^−1^, which was increased by 0.2‐ g/kg increments every other day up to a maximum of 1.0 g · kg^−1^ · d^−1^. On days 11 and 22 an aqueous lactose challenge (0.35 g/kg) was administered after an overnight (>12 hours) fast. Breath hydrogen excretion and intolerance symptoms were monitored hourly for 8 hours after the challenge dose was consumed | Lactose for days 1‐ 10 and crossed over to the other feeding period for days 12–21. Initial dosage was 0.6 g · kg body wt^−1^ · d^−1^, which was increased by 0.2‐ g/kg increments every other day up to a maximum of 1.0 g · kg^−1^ · d^−1^. On days 11 and 22 an aqueous lactose challenge (0.35 g/kg) was administered after an overnight (>12 hours) fast. Breath hydrogen excretion and intolerance symptoms were monitored hourly for 8 hours after the challenge dose was consumed. | Symptoms rating after lactose (L) or dextrose (D) feeding periods (mean ± SEM). The maximum possible score for any individual symptom would be 40 (a “5” rating each hour for 8 hours). Conclusion(s): Authors concluded that there is colonic adaptation to regular lactose ingestion and this adaptation reduces lactose intolerance symptoms. | Allocation concealment: unclear Blinding: noted as blinded, unclear if double-blinded Intent-to-treat analyses: no Study withdrawals adequately described: no
E. Incremental lactose loads or studies examining different levels of lactose
Hertzler, 1996^90^ RCT, crossover Sponsorship: Minnesota Agricultural Experiment Station USA Duration of symptom recording: 1 day | Data source: 13 American lactose maldigesting subjects. Inclusion criteria: Subjects were classified as lactose maldigesters based on a rise in breath hydrogen of >20 ppm (0.9 imol hydrogen/L air) during a challenge dose of lactose (20 g) after a 12 hours fast. Methods to measure outcomes: Subjects rated symptoms of flatulence, abdominal pain, and diarrhea hours 1 through 8 following challenge dose. A ranked scale was used; 0=none, 1=slight, 2=mild, 3=moderate, 4= moderately severe, 5= severe. | Mean age: 32 (range 21 to 42) Gender: women 46%. Race: NR Comorbidities: not reported Cointerventions: not reported | Five treatment solutions consisting of lactose dissolved in 240 mL of tap water. 1) Lactose 0 g 2) Lactose 2 g 3) Lactose 6 g 4) Lactose 12 g 5) Lactose 20 g | | Symptoms rating after each challenge dose (mean ± SEM). The maximum possible score for any individual symptom would be 40 (a “5” rating each hour for 8 hours). Conclusion(s): Lactose maldigesters may be able to tolerate foods with ≤6 g lactose per serving such as hard cheeses and small servings (≤120 mL) of milk. | Allocation concealment: unclear Blinding: double-blinded Intent-to-treat analyses: no Study withdrawals adequately described: no
Newcomer, 1978^91^ RCT, crossover Sponsorship: National Institutes of Health and United States Public Health Service. USA Duration of symptom recording: 8 hours | Data source: 59 lactase deficient American Indians. Inclusion criteria: lactase deficiency determined by breath hydrogen concentration to >20 mL/min after ingestion of 50 g (less for children) of lactose. Methods to measure outcomes: A subject was considered to have a positive symptomatic response if he/she had ≥1 loose stools or had a grade 2+ or higher in at least one of the following symptoms: abdominal cramps/pain, bloating or gas, borborygmi, flatulence. Symptoms were rated according: 0 = no trouble; 1+ = slight; 2+ = mild; 3+ = moderate, subject would normally avoid a breakfast causing these symptoms; 4+ = severe, subject would be unable to carry on usual activities. | Mean age (range): 18.7 (5–62). 44 were <18 years of age. Gender: women 47% Race/ethnicity: American Indian 100% | 6 breakfasts randomly distributed. Sugar packets with lactose ranging from 0 to 18 g added to 8 ounces of Ensure drink. Breakfast 1: 0 g lactose + 18 g glucose plus galactose (G+G). Breakfast 2: 3 g lactose + 15 g G+G. Breakfast 3: 6 g lactose + 12 g G+G. Breakfast 4: 9 g lactose + 9 g G+G. Breakfast 5: 12 g lactose + 6 g G+G. Breakfast 6: 18 g lactose + 0 g G+G. | | Number of subjects with symptoms. Conclusion(s): A modest amount of lactose (1–1½ glasses of milk), when consumed with a meal, was well tolerated by lactase-deficient American Indians. | Allocation concealment: unclear Blinding: double, symptoms assessed by “blinded observer” Intent-to-treat analyses: 100% followup Study withdrawals adequately described: no withdrawals reported
Stephenson, 1974^92^ Un-blinded RCT, attempt made to mask to taste, crossover USA Duration:8 hours Funded by National Dairy Council and NY State Agriculture Experiment Station hatch project Hypothesis: Higher doses of lactose poorly tolerated | Data Source: n=35 U.S. adults, with and without LI on basis of rise in blood glucose of less than 20 mg/100mL after 50 g lactose ingestion Methods to measure outcome: Asked about any symptoms of bloating, gas, abdominal cramps and diarrhea on scale of mild moderate and severe, summed | Median age 25 (23–55 range) Gender: women 54% Race/ethnicity: white 71%, non‐ white 29% Co-morbid: none Co-intervention: none | Day 1, all 35 got 50 gm lactose. Those with symptoms got 15, 30, 50 gm lactose in water or milk serially. Those with no symptoms got 100, 150 and 200 gm lactose in water and milk serially | Placebo 250 ml (saccharin, lemon juice water) | Sum of score of bloating, gas, cramps and diarrhea on scale: 0=none, 1=mild, 2= moderate, 3=severe. Conclusion(s): Most adults with lactose intolerance can tolerate up to 30 gm lactose | Allocation concealment: unclear Blinding: single no masking Intent-to-treat analyses: one person lost to followup Study withdrawals adequately described: yes, one withdrawal reported, data missing on up to 3 individuals in different groups
F. Studies with irritable bowel syndrome subjects
Parker, 2001^93^ RCT, crossover Sponsorship: NR UK Duration of symptom recording: 1 week | Data source: 122 British IBS patients were referred for a lactose hydrogen breath test. The breath test was positive in 33 (27%) and negative in 89 (73%). Subjects in the positive group were then placed on a low lactose diet for 3 weeks. The daily intake of lactose from this diet was <1 g. Patients improving on the low lactose diet were given double-blind, placebo-controlled challenges to confirm lactose intolerance. Methods to measure outcomes: Symptom score was based on eight variables: abdominal pain, daily bowel movements, urgency to defecate, consistency of feces, flatulence, headache, abdominal distension, and general well-being. Each symptom was scored from 0 to 4, 0 being no symptoms and 4 most severe. Urgency was scored from 0 to 3. The maximum cumulative score = 31. | Data for the 33 subjects with positive hydrogen breath test. Mean age NR. Age <50 years 73%; Gender: women 76% Race/ethnicity White 85% (n=28), Asian 9% (n=3), Middle-Eastern 6% (n=2), Comorbidities: not reported Cointerventions: not reported | Three active tests were given in random order for 7 of 9 subjects improving on low- lactose diet: lactose 5 g, 10 g, or 15 g, and placebo mixed with 285 ml water and taken at breakfast on 2 consecutive days with 5 days' rest between each test. Symptoms scores were completed daily for test and rest days. Subjects remained on low lactose diet during double-blind, placebo-controlled test period. | | Conclusion(s): During double-blind phase, 2/7 subjects (29%) developed increasing symptoms with increasing doses of lactose. Although 5 of the 7 were affected by 15 g lactose, 5 subjects had worse symptoms with 5 g than 10 g, suggesting that many LM patients can tolerate up to 12 g per day. Patients with lactose intolerance were not distinguishable from others with IBS on the basis of symptoms, and treatment with a low lactose diet gave disappointing results. | Allocation concealment: unclear Blinding: double-blinded Intent-to-treat analyses: 100% followup although 2 subjects meeting eligibility did not participate for unknown reasons Study withdrawals adequately described: no withdrawals reported
Böhmer 1996^94^ Sponsorship: not reported The Netherlands Duration of symptom recording: 6 weeks | Data source: 105 Caucasian Dutch subjects, 70 with IBS and 35 healthy controls Inclusion criteria: Subjects were screened for lactose mal‐ absorption (LM) and were not aware of the test results. Diagnosis of IBS after exclusion of organic causes. Subjects had to fulfill at least two criteria: visible abdominal distension; pain relief with defecation; more frequent stools at pain onset; looser stools at pain onset; passage of rectal mucus; and feeling of incomplete evacuation. Subjects were classified as lactose malabsorbers based on a rise in breath hydrogen of >20 ppm above basal level during a challenge dose of lactose (50 g) after a 12 hours fast. Methods to measure outcomes: subjects scored symptoms (pain, flatulence, distension, diarrhea, mucus, incomplete evacuation) 0=no complaints, 1=mild; 2=moderate; and 3 as severe. A maximum cumulative score = 18. | IBS subjects (n=70 of which 17 had LM) Median age (range): 35.7 years (18 to 59) Gender: women 74% Race/ethnicity: white 100% Healthy control subjects (n=35) Median age (range): 33 years (21 to 51) Gender: women 74% Race/ethnicity: white 100% | Lactose restricted diet | | Cumulative symptom scores at 3 and 6 weeks, comparing IBS subjects with LM vs. IBS subjects without LM. Conclusion(s): the mean symptom score of the IBS with LM showed a statistically significant decrease after 6 weeks of a lactose restricted diet. | Allocation concealment: unclear Blinding: double-blinded Intent-to-treat analyses: no dropouts reported Study withdrawals adequately described: none
Lisker 1989^95^ RCT, crossover Sponsorship: Mr. A. Kligerman, President of Sugar Lo/Lact Aid company (lactase and placebo vials) Mexico Duration of symptom recording: months: 3 months | Data source: 12 Mexican subjects with IBS whose diets regularly included milk. Eight of the subjects were lactose mal-digesters (when challenged with 12.5 lactose and diagnosed by hydrogen breath test ≥ 20 ppm). Inclusion criteria: 1) diagnosis of IBS based on chronic abdominal pain, altered bowel habits, and absence of organic disease; 2) regular diet included consumption of milk/dairy products ≥8 oz. glass of milk daily or equivalent lactose intake; 3) patients lived close enough to center to allow adherence to frequent interviews; and 4) showed proper compliance and reliability during first (control) month. Methods to measure outcomes: Diary record of symptoms filled out daily. Symptoms included constipation, diarrhea, abdominal pain, abdominal distension, and flatulence. | Mean age (range): 49 years (24 to 72) Gender: women 75% Race/ethnicity: not reported Comorbidities: not reported Cointerventions: not reported | Treatment A group Lactase x 4 weeks, then placebo x 4 weeks, then lactase x 4 weeks. Prior to 3 month study phase there was a 1 month non‐ intervention, control period. Lactase (derived from Kluyveromyces lactis) was used in vitro (added in entirety to liter of milk the day before consumption) and in vivo (added at mealtime when consuming lactose- containing foods away from home) | Treatment B group Placebo x 4 weeks, then lactase x 4 weeks, then lactase x 4 weeks. Prior to 3 month study phase there was a 1 month non‐ intervention, control period. | Symptoms noted as better, same, or worse for each intervention month Conclusion(s): GI symptoms were found to be independent of lactase treatment. In this study population with a high prevalence of lactose deficiency, IBS symptoms appeared to be independent of lactose maldigestion. | Allocation concealment: unclear Blinding: double-blinded Intent-to-treat analyses: 100% followup Study withdrawals adequately described: no withdrawals reported
Newcomer 1983^80^ RCT, crossover Sponsorship: National Dairy Council and North Carolina State University Dairy Foundation USA Duration of symptom recording: 1 week | Data source: 79 American subjects, 61 lactase sufficient subjects with IBS and 18 lactase deficient (all had histories of milk intolerance) subjects. There were also 10 healthy controls. Inclusion criteria: lactase deficiency was diagnosed by an increase in the breath hydrogen ≥0.30 ml/min above basal level after challenge of 50 g lactose in 500 ml water. IBS was diagnosed on the basis of a typical history and a minimal number of negative diagnostic studies. Methods to measure outcomes: Symptom (diarrhea, abdominal pain/cramps*, gas/flatus*, rumbling*, constipation) diary at end of each day. Diarrhea was yes/no, # stools per day. Scored as following for *: 0=no trouble; 1=slight trouble; 2=mild; 3=moderate; 4=severe. Constipation was better, same, worse. | 1) Lactase deficiency subjects (n=18) Age range (18–69) Gender: not reported Race/ethnicity: not reported 2) lactase sufficient subjects with IBS (n=61) Age range (20–82) Gender: not reported Race/ethnicity: not reported 3) healthy controls (n=10) Age range (21–64) Gender: not reported Race/ethnicity: not reported | Lactase deficient subjects Acidophilus milk (mean 1½ glasses daily) x 1 week (either week 1 or week 4). 2 week control period between weeks of starting new treatment Lactase sufficient subjects with IBS and controls Acidophilus milk (3 8 oz. glasses daily) x 2 weeks (either week 3 or week 7). Three 2- week control periods (milk-drinking periods in between). | lactase deficient subjects Unaltered milk (mean 1½ glasses daily) x 1 week (either week 1 or week 4). lactase sufficient subjects with IBS and controls Unaltered milk (3 8 oz. glasses daily) x 2 weeks (either week 3 or week 7). | Cumulative symptom indices for the 18 lactase deficiency subjects Conclusion(s): There was no difference in the tolerance of the acidophilus and unaltered milks in the lactase deficient group. IBS subjects were also not helped by the ingestion of acidophilus milk. | Allocation concealment: unclear Blinding: double-blinded Intent-to-treat analyses: 100% followup Study withdrawals adequately described: no withdrawals reported

## References for Appendix D

(Note that this set of references is different from those in the text of the report and the numbers are different.)

1 Alhava EM, Jussila J, Karjalainen P, et al. Lactose malabsorption and bone mineral content. Acta Med Scand. 1977;201(4):281-3. [pmid: 576770].
2 Birge SJ Jr, Keutmann HT, Cuatrecasas P, et al. Osteoporosis, intestinal lactase deficiency and low dietary calcium intake. N Engl J Med. Feb 23. 1967;276(8):445-8. [pmid: 6071242].
3 Buchowski MS, Semenya J, Johnson AO. Dietary calcium intake in lactose maldigesting intolerant and tolerant African-American women. J Am Coll Nutr. Feb. 2002;21(1):47-54. [pmid: 11838887].
4 Corazza GR, Benati G, Di Sario A, et al. Lactose intolerance and bone mass in postmenopausal Italian women. Br J Nutr. Mar. 1995;73(3):479-87. [pmid: 7766570].
5 Di Stefano M, Veneto G, Malservisi S, et al. Lactose malabsorption and intolerance and peak bone mass. Gastroenterology. Jun. 2002;122(7):1793-9. [pmid: 12055586].
6 Du XQ, Greenfield H, Fraser DR, et al. Milk consumption and bone mineral content in Chinese adolescent girls. Bone. Mar. 2002;30(3):521-8. [pmid: 11882468].
7 Enattah N, Valimaki VV, Valimaki MJ, et al. Molecularly defined lactose malabsorption, peak bone mass and bone turnover rate in young finnish men. Calcif Tissue Int. Dec. 2004;75(6):488-93. [pmid: 15365657].
8 Enattah N, Pekkarinen T, Valimaki MJ, et al. Genetically defined adult-type hypolactasia and self-reported lactose intolerance as risk factors of osteoporosis in Finnish postmenopausal women. Eur J Clin Nutr. Oct. 2005;59(10):1105-11. [pmid: 16015262].
9 Enattah NS, Sulkava R, Halonen P, et al. Genetic variant of lactase-persistent C/T-13910 is associated with bone fractures in very old age. J Am Geriatr Soc. Jan. 2005;53(1):79-82. [pmid: 15667380].
10 Finkenstedt G, Skrabal F, Gasser RW, et al. Lactose absorption, milk consumption, and fasting blood glucose concentrations in women with idiopathic osteoporosis. Br Med J (Clin Res Ed). Jan 18. 1986;292(6514):161-2.
11 Goulding A, Taylor RW, Keil D, et al. Lactose malabsorption and rate of bone loss in older women. Age Ageing. Mar. 1999;28(2):175-80. [pmid: 10350415].
12 Gugatschka M, Dobnig H, Fahrleitner-Pammer A, et al. Molecularly-defined lactose malabsorption, milk consumption and anthropometric differences in adult males. QJM. Dec. 2005;98(12):857-63. [pmid: 16299058].
13 Gugatschka M, Hoeller A, Fahrleitner-Pammer A, et al. Calcium supply, bone mineral density and genetically defined lactose maldigestion in a cohort of elderly men. J Endocrinol Invest. Jan. 2007;30(1):46-51. [pmid: 17318022].
14 Harma M, Alhava E. Is lactose malabsorption a risk factor in fractures of the elderly?. Ann Chir Gynaecol. 1988;77(5–6):180-3. [pmid: 3267105].
15 Honkanen R, Kroger H, Alhava E, et al. Lactose intolerance associated with fractures of weight-bearing bones in Finnish women aged 38–57 years. Bone. Dec. 1997;21(6):473-7. [pmid: 9430235].
16 Honkanen R, Pulkkinen P, Jarvinen R, et al. Does lactose intolerance predispose to low bone density? A population-based study of perimenopausal Finnish women. Bone. Jul. 1996;19(1):23-8. [pmid: 8830983].
17 Horowitz M, Wishart J, Mundy L, et al. Lactose and calcium absorption in postmenopausal osteoporosis. Arch Intern Med. Mar. 1987;147(3):534-6. [pmid: 3827431].
18 Infante D, Tormo R. Risk of inadequate bone mineralization in diseases involving long-term suppression of dairy products. J Pediatr Gastroenterol Nutr. Mar. 2000;30(3):310-3. [pmid: 10749417].
19 Kanis JA, Johansson H, Oden A, et al. A meta-analysis of milk intake and fracture risk: low utility for case finding. Osteoporos Int. Jul. 2005;16(7):799-804. [pmid: 15502959].
20 Kudlacek S, Freudenthaler O, Weissboeck H, et al. Lactose intolerance: a risk factor for reduced bone mineral density and vertebral fractures?. J Gastroenterol. 2002;37(12):1014-9. [pmid: 12522532].
21 Kull M, Kallikorm R, Lember M. Impact of molecularly defined hypolactasia, self-perceived milk intolerance and milk consumption on bone mineral density in a population sample in Northern Europe. Scand J Gastroenterol. 2009;44(4):415-21. [pmid: 19039706].
22 Lehtimaki T, Hemminki J, Rontu R, et al. The effects of adult-type hypolactasia on body height growth and dietary calcium intake from childhood into young adulthood: a 21-year follow-up study--the Cardiovascular Risk in Young Finns Study. Pediatrics. Oct. 2006;118(4):1553-9. [pmid: 17015546].
23 Matlik L, Savaiano D, McCabe G, et al. Perceived milk intolerance is related to bone mineral content in 10- to 13-year-old female adolescents. Pediatrics. Sep. 2007;120(3):e669-77. [pmid: 17766507].
24 Obermayer-Pietsch BM, Gugatschka M, Reitter S, et al. Adult-type hypolactasia and calcium availability: decreased calcium intake or impaired calcium absorption?. Osteoporos Int. Apr. 2007;18(4):445-51. [pmid: 17103297].
25 Obermayer-Pietsch BM, Bonelli CM, Walter DE, et al. Genetic predisposition for adult lactose intolerance and relation to diet, bone density, and bone fractures. J Bone Miner Res. Jan. 2004;19(1):42-7. [pmid: 14753735].
26 Segal E, Dvorkin L, Lavy A, et al. Bone density in axial and appendicular skeleton in patients with lactose intolerance: influence of calcium intake and vitamin D status. J Am Coll Nutr. Jun. 2003;22(3):201-7. [pmid: 12805246].
27 Stallings VA, Oddleifson NW, Negrini BY, et al. Bone mineral content and dietary calcium intake in children prescribed a low-lactose diet. J Pediatr Gastroenterol Nutr. May. 1994;18(4):440-5. [pmid: 8071779].
28 Vigorita VJ, Lane M, Suda MK, et al. Differences between lactase deficient and non-lactase deficient women with spinal osteoporosis. Clin Orthop Relat Res. Feb. 1987;(215):248-53. [pmid: 3100122].
29 Wheadon M, Goulding A, Barbezat GO, et al. Lactose malabsorption and calcium intake as risk factors for osteoporosis in elderly New Zealand women. N Z Med J. Oct 9. 1991;104(921):417-9. [pmid: 1923091].
30 Appleby P, Roddam A, Allen N, et al. Comparative fracture risk in vegetarians and nonvegetarians in EPIC-Oxford. Eur J Clin Nutr. Dec. 2007;61(12):1400-6. [pmid: 17299475].
31 Bauer DC, Browner WS, Cauley JA, et al. Factors associated with appendicular bone mass in older women. The Study of Osteoporotic Fractures Research Group. Ann Intern Med. May 1. 1993;118(9):657-65. [pmid: 8460853].
32 Black RE, Williams SM, Jones IE, et al. Children who avoid drinking cow milk have low dietary calcium intakes and poor bone health. Am J Clin Nutr. Sep. 2002;76(3):675-80. [pmid: 12198017].
33 Chiu JF, Lan SJ, Yang CY, et al. Long-term vegetarian diet and bone mineral density in postmenopausal Taiwanese women. Calcif Tissue Int. Mar. 1997;60(3):245-9. [pmid: 9069160].
34 Cumming RG, Klineberg RJ. Case-control study of risk factors for hip fractures in the elderly. Am J Epidemiol. Mar 1. 1994;139(5):493-503. [pmid: 8154473].
35 Feskanich D, Willett WC, Stampfer MJ, et al. Milk, dietary calcium, and bone fractures in women: a 12-year prospective study. Am J Public Health. Jun. 1997;87(6):992-7. [pmid: 9224182].
36 Fujiwara S, Kasagi F, Yamada M, et al. Risk factors for hip fracture in a Japanese cohort. J Bone Miner Res. Jul. 1997;12(7):998-1004. [pmid: 9199997].
37 Goulding A, Rockell JE, Black RE, et al. Children who avoid drinking cow's milk are at increased risk for prepubertal bone fractures. J Am Diet Assoc. Feb. 2004;104(2):250-3. [pmid: 14760576].
38 Johansson H, Oden A, Johnell O, et al. Optimization of BMD measurements to identify high risk groups for treatment--a test analysis. J Bone Miner Res. Jun. 2004;19(6):906-13. [pmid: 15190881].
39 Johnell O, Gullberg B, Kanis JA, et al. Risk factors for hip fracture in European women: the MEDOS Study. Mediterranean Osteoporosis Study. J Bone Miner Res. Nov. 1995;10(11):1802-15. [pmid: 8592959].
40 Kalkwarf HJ, Khoury JC, Lanphear BP. Milk intake during childhood and adolescence, adult bone density, and osteoporotic fractures in US women. Am J Clin Nutr. Jan. 2003;77(1):257-65. [pmid: 12499350].
41 Kelsey JL, Browner WS, Seeley DG, et al. Risk factors for fractures of the distal forearm and proximal humerus. The Study of Osteoporotic Fractures Research Group. Am J Epidemiol. Mar 1. 1992;135(5):477-89. [pmid: 1570814].
42 Lau EM, Kwok T, Woo J, et al. Bone mineral density in Chinese elderly female vegetarians, vegans, lacto-vegetarians and omnivores. Eur J Clin Nutr. Jan. 1998;52(1):60-4. [pmid: 9481534].
43 Looker AC, Harris TB, Madans JH, et al. Dietary calcium and hip fracture risk: the NHANES I Epidemiologic Follow-Up Study. Osteoporos Int. Jul. 1993;3(4):177-84. [pmid: 8338972].
44 Nieves JW, Grisso JA, Kelsey JL. A case-control study of hip fracture: evaluation of selected dietary variables and teenage physical activity. Osteoporos Int. May. 1992;2(3):122-7. [pmid: 1627898].
45 Parsons TJ, van Dusseldorp M, van der Vliet M, et al. Reduced bone mass in Dutch adolescents fed a macrobiotic diet in early life. J Bone Miner Res. Sep. 1997;12(9):1486-94. [pmid: 9286766].
46 Rockell JE, Williams SM, Taylor RW, et al. Two-year changes in bone and body composition in young children with a history of prolonged milk avoidance. Osteoporos Int. Sep. 2005;16(9):1016-23. [pmid: 15565350].
47 Shaw CK. An epidemiologic study of osteoporosis in Taiwan. Ann Epidemiol. May. 1993;3(3):264-71. [pmid: 8275199].
48 Soroko S, Holbrook TL, Edelstein S, et al. Lifetime milk consumption and bone mineral density in older women. Am J Public Health. Aug. 1994;84(8):1319-22. [pmid: 8059895].
49 Tavani A, Negri E, La Vecchia C. Calcium, dairy products, and the risk of hip fracture in women in northern Italy. Epidemiology. Sep. 1995;6(5):554-7. [pmid: 8562636].
50 Turner LW, Wang MQ, Fu Q. Risk factors for hip fracture among southern older women. South Med J. Jun. 1998;91(6):533-40. [pmid: 9634114].
51 Vatanparast H, Baxter-Jones A, Faulkner RA, et al. Positive effects of vegetable and fruit consumption and calcium intake on bone mineral accrual in boys during growth from childhood to adolescence: the University of Saskatchewan Pediatric Bone Mineral Accrual Study. Am J Clin Nutr. Sep. 2005;82(3):700-6. [pmid: 16155286].
52 Wyshak G, Frisch RE, Albright TE, et al. Nonalcoholic carbonated beverage consumption and bone fractures among women former college athletes. J Orthop Res. 1989;7(1):91-9. [pmid: 2908917].
53 Chevalley T, Bonjour JP, Ferrari S, et al. Skeletal site selectivity in the effects of calcium supplementation on areal bone mineral density gain: a randomized, double-blind, placebo-controlled trial in prepubertal boys. J Clin Endocrinol Metab. Jun. 2005;90(6):3342-9. [pmid: 15755866].
54 Montalto M, Nucera G, Santoro L, et al. Effect of exogenous beta-galactosidase in patients with lactose malabsorption and intolerance: a crossover double-blind placebo-controlled study. Eur J Clin Nutr. Apr. 2005;59(4):489-93. [pmid: 15674309].
55 Gremse DA, Greer AS, Vacik J, et al. Abdominal pain associated with lactose ingestion in children with lactose intolerance. Clin Pediatr (Phila). May. 2003;42(4):341-5. [pmid: 12800728].
56 Jarvinen RM, Loukaskorpi M, Uusitupa MI. Tolerance of symptomatic lactose malabsorbers to lactose in milk chocolate. Eur J Clin Nutr. May. 2003;57(5):701-5. [pmid: 12771971].
57 Suarez FL, Adshead J, Furne JK, et al. Lactose maldigestion is not an impediment to the intake of 1500 mg calcium daily as dairy products. Am J Clin Nutr. Nov. 1998;68(5):1118-22. [pmid: 9808231].
58 Xenos K, Kyroudis S, Anagnostidis A, et al. Treatment of lactose intolerance with exogenous beta-D-galactosidase in pellet form. Eur J Drug Metab Pharmacokinet. Apr–Jun. 1998;23(2):350-5. [pmid: 9725505].
59 Suarez FL, Savaiano D, Arbisi P, et al. Tolerance to the daily ingestion of two cups of milk by individuals claiming lactose intolerance. Am J Clin Nutr. May. 1997;65(5):1502-6. [pmid: 9129483].
60 Vesa TH, Lember M, Korpela R. Milk fat does not affect the symptoms of lactose intolerance. Eur J Clin Nutr. Sep. 1997;51(9):633-6. [pmid: 9306091].
61 Vesa TH, Korpela RA, Sahi T. Tolerance to small amounts of lactose in lactose maldigesters. Am J Clin Nutr. Aug. 1996;64(2):197-201. [pmid: 8694020].
62 Suarez FL, Savaiano DA, Levitt MD. A comparison of symptoms after the consumption of milk or lactose-hydrolyzed milk by people with self-reported severe lactose intolerance. N Engl J Med. Jul 6. 1995;333(1):1-4. [pmid: 7776987].
63 Johnson AO, Semenya JG, Buchowski MS, et al. Correlation of lactose maldigestion, lactose intolerance, and milk intolerance. Am J Clin Nutr. Mar. 1993;57(3):399-401. [pmid: 8438774].
64 Lin MY, Dipalma JA, Martini MC, et al. Comparative effects of exogenous lactase (beta‐galactosidase) preparations on in vivo lactose digestion. Dig Dis Sci. Nov. 1993;38(11):2022-7. [pmid: 8223076].
65 Nielsen OH, Schiotz PO, Rasmussen SN, et al. Calcium absorption and acceptance of low-lactose milk among children with primary lactase deficiency. J Pediatr Gastroenterol Nutr. Mar. 1984;3(2):219-23. [pmid: 6368790].
66 Lybeck Sorensen K, Vergara Meersohn M, Sonne J, et al. A new type of low-lactose milk. Tolerance by lactose malabsorbers and evaluation of protein nutritional value. Scand J Gastroenterol. Nov. 1983;18(8):1063-8. [pmid: 6424228].
67 Rask Pedersen E, Jensen BH, Jensen HJ, et al. Lactose malabsorption and tolerance of lactose-hydrolyzed milk. A double-blind controlled crossover study. Scand J Gastroenterol. Oct. 1982;17(7):861-4. [pmid: 6818684].
68 Reasoner J, Maculan TP, Rand AG, et al. Clinical studies with low-lactose milk. Am J Clin Nutr. Jan. 1981;34(1):54-60. [pmid: 6893787].
69 Unger M, Scrimshaw NS. Comparative tolerance of adults of differing ethnic backgrounds to lactose-free and lactose-containing dairy drinks. Nutr Res. 1981;1:227-33.
70 Cheng AH, Brunser O, Espinoza J, et al. Long-term acceptance of low-lactose milk. Am J Clin Nutr. Oct. 1979;32(10):1989-93. [pmid: 114042].
71 Jones DV, Latham MC, Kosikowski FV, et al. Symptom response to lactose-reduced milk in lactose-intolerant adults. Am J Clin Nutr. Jun. 1976;29(6):633-8. [pmid: 946937].
72 Brand JC, Holt S. Relative effectiveness of milks with reduced amounts of lactose in alleviating milk intolerance. Am J Clin Nutr. Jul. 1991;54(1):148-51. [pmid: 2058576].
73 Cavalli-Sforza LT, Strata A. Double-blind study on the tolerance of four types of milk in lactose malabsorbers and absorbers. Hum Nutr Clin Nutr. Jan. 1987;41(1):19-30. [pmid: 3570859].
74 Rosado JL, Solomons NW, Lisker R, et al. Enzyme replacement therapy for primary adult lactase deficiency. Effective reduction of lactose malabsorption and milk intolerance by direct addition of beta-galactosidase to milk at mealtime. Gastroenterology. Nov. 1984;87(5):1072-82. [pmid: 6434367].
75 Haverberg L, Kwon PH, Scrimshaw NS. Comparative tolerance of adolescents of differing ethic backgrounds to lactose-containing and lactose-free dairy drinks. I. Initial experience with a double-blind procedure. Am J Clin Nutr. Jan. 1980;33(1):17-21. [pmid: 7188826].
76 Kwon PH Jr, Rorick MH, Scrimshaw NS. Comparative tolerance of adolescents of differing ethnic backgrounds to lactose-containing and lactose-free dairy drinks. II. Improvement of a double-blind test. Am J Clin Nutr. Jan. 1980;33(1):22-6. [pmid: 7188827].
77 Rorick MH, Scrimshaw NS. Comparative tolerance of elderly from differing ethnic backgrounds to lactose-containing and lactose-free dairy drinks: a double-blind study. J Gerontol. Mar. 1979;34(2):191-6. [pmid: 374454].
78 Lisker R, Aguilar L. Double blind study of milk lactose intolerance. Gastroenterology. Jun. 1978;74(6):1283-5. [pmid: 348553].
79 Paige DM, Bayless TM, Huang SS, et al. Lactose hydrolyzed milk. Am J Clin Nutr. Aug. 1975;28(8):818-22. [pmid: 1173737].
80 Newcomer AD, Park HS, O'Brien PC, et al. Response of patients with irritable bowel syndrome and lactase deficiency using unfermented acidophilus milk. Am J Clin Nutr. Aug. 1983;38(2):257-63. [pmid: 6410897].
81 Lin MY, Yen CL, Chen SH. Management of lactose maldigestion by consuming milk containing lactobacilli. Dig Dis Sci. Jan. 1998;43(1):133-7. [pmid: 9508514].
82 Mustapha A, Jiang T, Savaiano DA. Improvement of lactose digestion by humans following ingestion of unfermented acidophilus milk: influence of bile sensitivity, lactose transport, and acid tolerance of Lactobacillus acidophilus. J Dairy Sci. Aug. 1997;80(8):1537-45. [pmid: 9276791].
83 Jiang T, Mustapha A, Savaiano DA. Improvement of lactose digestion in humans by ingestion of unfermented milk containing Bifidobacterium longum. J Dairy Sci. May. 1996;79(5):750-7. [pmid: 8792277].
84 Vesa TH, Marteau P, Zidi S, et al. Digestion and tolerance of lactose from yoghurt and different semi-solid fermented dairy products containing Lactobacillus acidophilus and bifidobacteria in lactose maldigesters--is bacterial lactase important?. Eur J Clin Nutr. Nov. 1996;50(11):730-3. [pmid: 8933119].
85 Lerebours E, N'Djitoyap Ndam C, Lavoine A, et al. Yogurt and fermented-then-pasteurized milk: effects of short-term and long-term ingestion on lactose absorption and mucosal lactase activity in lactase-deficient subjects. Am J Clin Nutr. May. 1989;49(5):823-7. [pmid: 2497632].
86 Martini MC, Smith DE, Savaiano DA. Lactose digestion from flavored and frozen yogurts, ice milk, and ice cream by lactase-deficient persons. Am J Clin Nutr. Oct. 1987;46(4):636-40. [pmid: 3116836].
87 Savaiano DA, AbouElAnouar A, Smith DE, et al. Lactose malabsorption from yogurt, pasteurized yogurt, sweet acidophilus milk, and cultured milk in lactase-deficient individuals. Am J Clin Nutr. Dec. 1984;40(6):1219-23. [pmid: 6439026].
88 Cappello G, Marzio L. Rifaximin in patients with lactose intolerance. Dig Liver Dis. May. 2005;37(5):316-9. [pmid: 15843080].
89 Hertzler SR, Savaiano DA. Colonic adaptation to daily lactose feeding in lactose maldigesters reduces lactose intolerance. Am J Clin Nutr. Aug. 1996;64(2):232-6. [pmid: 8694025].
90 Hertzler SR, Huynh BC, Savaiano DA. How much lactose is low lactose?. J Am Diet Assoc. Mar. 1996;96(3):243-6. [pmid: 8613657].
91 Newcomer AD, McGill DB, Thomas PJ, et al. Tolerance to lactose among lactase-deficient American Indians. Gastroenterology. Jan. 1978;74(1):44-6. [pmid: 336450].
92 Stephenson LS, Latham MC. Lactose intolerance and milk consumption: the relation of tolerance to symptoms. Am J Clin Nutr. Mar. 1974;27(3):296-303. [pmid: 4405996].
93 Parker TJ, Woolner JT, Prevost AT, et al. Irritable bowel syndrome: is the search for lactose intolerance justified?. Eur J Gastroenterol Hepatol. Mar. 2001;13(3):219-25. [pmid: 11293439].
94 Bohmer CJ, Tuynman HA. The clinical relevance of lactose malabsorption in irritable bowel syndrome. Eur J Gastroenterol Hepatol. Oct. 1996;8(10):1013-6. [pmid: 8930569].
95 Lisker R, Solomons NW, Perez Briceno R, et al. Lactase and placebo in the management of the irritable bowel syndrome: a double-blind, cross-over study. Am J Gastroenterol. Jul. 1989;84(7):756-62. [pmid: 2500848].