# List of Excluded Studies

1. Lactase deficiency. N Engl J Med 1965 Nov 11; 273(20):1108–9. Not relevant to key questions
2. Synthetic foods and deficiency states. Lancet 1965 Nov 6; 2(7419):937–8. Not relevant to key questions
3. Primary intestinal lactase deficiency. Nutr Rev 1967 Sep; 25(9):265–70. Not relevant to key questions
4. Recurrent abdominal pain. Pediatrics 1970 Dec; 46(6):968–75. Not relevant to key questions
5. Correspondence re iron fortified formulas. Pediatrics 1971 Jul; 48(1):152–6 passim. Not relevant to key questions
6. Background information on lactose and milk intolerance. A statement of the Food and Nutrition Board Division of Biology and Agriculture, National Research Council. Nutr Rev 1972 Aug; 30(8):175–6. Review
7. Lactose intolerance in Greeks. Lancet 1973 Feb 17; 1(7799):367–8. Not relevant to key questions
8. American Academy of Pediatrics Committee on Nutrition. Should milk drinking by children be discouraged? Pediatrics 1974 Apr; 53(4):576–82. Not relevant to key questions
9. Editorial: Lactase deficiency. Lancet 1975 Nov 8; 2(7941):910–1. Editorial
10. Editorial: When does lactose malabsorption matter in adults? Br Med J 1975 May 17; 2(5967):351–2. Editorial
11. Soy-based formulas for infants. Med Lett Drugs Ther 1976 Nov 19; 18(24):104. Not relevant to key questions
12. The lactose intolerance test and milk consumption. Nutr Rev 1976 Oct; 34(10):302–4. Not relevant to key questions
13. Clinical case presentation: diarrhea following tube feeding. JPEN J Parenter Enteral Nutr 1978; 2(1):41–2. Not relevant to key questions
14. From the NIH: Recurrent abdominal pain in a healthy school-aged child can be lactose intolerance. JAMA 1979 Dec 14; 242(24):2670. Not relevant to key questions
15. Metabolic bone disease as a result of lactase deficiency. Nutr Rev 1979 Mar; 37(3):72–3. Comment
16. Efficacy and indications of ursodeoxycholic acid treatment for dissolving gallstones. A multicenter double-blind trial. Tokyo Cooperative Gallstone Study Group. Gastroenterology Vol 78; 1980: 542–8. Not lactose intolerance study
17. Treatment of lactose intolerance. Med Lett Drugs Ther 1981 Jul 24; 23(15):67–8. Not relevant to key questions
18. Soy-protein formulas: recommendations for use in infant feeding. Pediatrics 1983 Sep; 72(3):359–63. Not relevant to key questions
19. Nonpharmacological approaches to the control of high blood pressure. Final report of the Subcommittee on Nonpharmacological Therapy of the 1984 Joint National Committee on Detection, Evaluation, and Treatment of High Blood Pressure. Hypertension 1986 May; 8(5):444–67. Guideline
20. American Academy of Pediatrics Committee on Nutrition: Practical significance of lactose intolerance in children: supplement. Pediatrics 1990 Oct; 86(4):643–4. Not relevant to key questions
21. Evaluation of an algorithm for the treatment of persistent diarrhoea: a multicentre study. International Working Group on Persistent Diarrhoea. Bulletin of the World Health Organization 1996; 74(5):479–89. Not relevant to key questions
22. More lactose in your life? Health News 1999 Jan 5; 5(1):6. Not relevant to key questions
23. Milk: got proof? We assess the evidence behind the dairy industry's ads and critics' claims. Consum Rep 2001 Sep; 66(9):62–3. Not relevant to key questions
24. Information from your family doctor. Lactose intolerance. Am Fam Physician 2002 May 1; 65(9):1855–6. Not relevant to key questions
25. Probiotics: using bacteria to improve health. Harv Health Lett 2002 Mar; 27(5):1–3. Not relevant to key questions
26. Why milk matters: questions and answers for professionals. Nutr Clin Care 2003 Oct–Dec; 6(3):140–2. Review
27. Got milk? No thanks! Up to 20% of Americans believe they're lactose intolerant. Just how intolerant varies with the person and the food. Harv Health Lett 2003 Dec; 29(2):6–7. Not relevant to key questions
28. Position of the American Dietetic Association and Dietitians of Canada: vegetarian diets. Can J Diet Pract Res 2003 Summer; 64(2):62–81. Guideline
29. Asthma inhalers may pose risks in the milk-allergic child. Child Health Alert 2005 Jan; 23:1‐ 2. Not relevant to key questions
30. Lactose intolerance in children and adolescents. Child Health Alert 2006 Oct; 24:3. Not relevant to key questions
31. I love milk, but I notice that as I get older I seem to tolerate it less--experiencing gas and bloating. Is this normal? Mayo Clin Womens Healthsource 2006 May; 10(5):10. Not relevant to key questions
32. Aalberts JS, Weegels PL, van der Heijden L, et al. Calcium supplementation: effect on blood pressure and urinary mineral excretion in normotensive male lactoovovegetarians and omnivores. Am J Clin Nutr 1988 Jul; 48(1):131–8. Not eligible outcomes
33. Abate G, Taormina F, Brillante C, et al. [The effects of the carbocalcitonin + arginine-lysine‐lactose combination in senile involutional osteoporosis]. Minerva medica Vol 85; 1994: 253‐ 9. Not lactose intolerance study
34. Abbas H. A genetic study of lactose digestion in Pakistani families. Indian J Med Sci 1984 Jul; 38(7):129–33. Not relevant to key questions
35. Abbas H. Primary adult hypolactasia. J Pak Med Assoc 1985 Feb; 35(2):55–7. Not relevant to key questions
36. Abbas H, Ahmad M. Persistence of high intestinal lactase activity in Pakistan. Hum Genet 1983; 64(3):277–8. Not relevant to key questions
37. Abbott WG, Tasman-Jones C. Incidence of acquired primary hypolactasia in three New Zealand racial groups. N Z Med J 1985 Apr 10; 98(776):228–9. Not relevant to key questions
38. Abdo-Bassols F, Lifshitz F, Del Castillo ED, et al. Transient lactose intolerance in premature infants. Pediatrics 1971 Nov; 48(5):816–21. Not relevant to key questions
39. Abdulla M. Public health/clinical significance of inorganic chemical elements. Experientia Suppl 1983; 44:339–55. Not eligible outcomes
40. Abdulla M, Andersson I, Asp NG, et al. Nutrient intake and health status of vegans. Chemical analyses of diets using the duplicate portion sampling technique. Am J Clin Nutr 1981 Nov; 34(11):2464–77. Not relevant to key questions
41. Abelow BJ, Holford TR, Insogna KL. Cross-cultural association between dietary animal protein and hip fracture: a hypothesis. Calcif Tissue Int 1992 Jan; 50(1):14–8. Secondary data analysis
42. Abraham G, Varsha P, Mathew M, et al. Malnutrition and nutritional therapy of chronic kidney disease in developing countries: the Asian perspective. Adv Ren Replace Ther 2003 Jul; 10(3):213–21. Review
43. Abraham JM, Levin B, Oberholzer VG, et al. Glucose-galactose malabsorption. Arch Dis Child 1967 Dec; 42(226):592–7. Not relevant to key questions
44. Abramowitz A, Granot E, Tamir I, et al. Two-hour lactose breath hydrogen test. J Pediatr Gastroenterol Nutr 1986 Jan; 5(1):130–3. Not relevant to key questions
45. Abrams SA, Griffin IJ, Davila PM. Calcium and zinc absorption from lactose-containing and lactose-free infant formulas. The American journal of clinical nutrition Vol 76; 2002: 442–6. Not lactose intolerance
46. Acheson KJ, Ravussin E, Schoeller DA, et al. Two-week stimulation or blockade of the sympathetic nervous system in man: influence on body weight, body composition, and twenty four-hour energy expenditure. Metabolism: clinical and experimental Vol 37; 1988: 91–8. Not lactose intolerance study
47. Acosta PB. Availability of essential amino acids and nitrogen in vegan diets. Am J Clin Nutr 1988 Sep; 48(3 Suppl):868–74. Review
48. Addolorato G, Marsigli L, Capristo E, et al. Anxiety and depression: a common feature of health care seeking patients with irritable bowel syndrome and food allergy. Hepato-Gastroenterology 1998 Sep–Oct; 45(23):1559–64. No prevalence data
49. Afzal N, Thomson M. Diarrhoea and gastroenteritis in the infant and young child. J Fam Health Care 2002; 12(6):146–50. Review
50. Agampodi SB, Agampodi TC, Piyaseeli UK. Breastfeeding practices in a public health field practice area in Sri Lanka: a survival analysis. Int Breastfeed J 2007; 2:13. Not relevant to key questions
51. Agarwal MM, Khandelwal N, Mandal AK, et al. Factors affecting bone mineral density in patients with prostate carcinoma before and after orchidectomy. Cancer 2005 May 15; 103(10):2042–52. Not eligible target population
52. Agarwal MM, Rana SV, Mandal AK, et al. Lactose intolerance in prostate cancer patients: incidence and associated factors. Scandinavian Journal of Gastroenterology 2008 Mar; 43(3):270–6. No prevalence data
53. Aggett PJ, More J, Thorn JM, et al. Evaluation of the trace metal supplements for a synthetic low lactose diet. Arch Dis Child 1983 Jun; 58(6):433–7. Not relevant to key questions
54. Agte V, Chiplonkar S, Joshi N, et al. Apparent absorption of copper and zinc from composite vegetarian diets in young Indian men. Ann Nutr Metab 1994; 38(1):13–9. Not relevant to key questions
55. Aguilo A, Tauler P, Fuentespina E, et al. Antioxidant diet supplementation influences blood iron status in endurance athletes. International journal of sport nutrition and exercise metabolism Vol 14; 2004: 147–60. Not lactose intolerance study
56. Agustina R, Lukito W, Firmansyah A, et al. The effect of early nutritional supplementation with a mixture of probiotic, prebiotic, fiber and micronutrients in infants with acute diarrhea in Indonesia. Asia Pacific journal of clinical nutrition Vol 16; 2007: 435–42. Not lactose intolerance study
57. Ahlskog JE, Muenter MD, Bailey PA, et al. Parkinson's disease monotherapy with controlled-release MK-458 (PHNO): double-blind study and comparison to carbidopa/levodopa. Clinical neuropharmacology Vol 14; 1991: 214–27. Not lactose intolerance study
58. Aires CP, Tabchoury CM, Del BCAA, et al. Cariogenicity of sweetners containing lactose - in situ study in root dentine (AADR Abstract Annual Meeting March 7–10 2001). Journal of Dental Research Vol 80; 2001: 119 (Abs No 665). Not lactose intolerance study
59. Aires CP, Tabchoury CP, Del BCAA, et al. Effect of a lactose-containing sweetener on root dentine demineralization in situ. Caries research Vol 36; 2002: 167–9. Not lactose intolerance study
60. Alarcon P, Montoya R, Perez F, et al. Clinical trial of home available, mixed diets versus a lactose-free, soy-protein formula for the dietary management of acute childhood diarrhea. Journal of pediatric gastroenterology and nutrition Vol 12; 1991: 224–32. Not lactose intolerance study
61. Albani S, Avanzini MA, Plebani A, et al. Diagnostic value of a lymphocyte stimulation test in cow milk protein intolerance. Ann Allergy 1989 Dec; 63(6 Pt 1):489–92. Not relevant to key questions
62. Alexander D, Ball MJ, Mann J. Nutrient intake and haematological status of vegetarians and age-sex matched omnivores. Eur J Clin Nutr 1994 Aug; 48(8):538–46. Not relevant to key questions
63. Alexander FW. Chronic diarrhoea of unknown cause with response to steroids. Proc R Soc Med 1973 Nov; 66(11):1067–8. Not relevant to key questions
64. Alford SC. Lactose intolerance in Asians. Nature 1969 Feb 8; 221(5180):562–3. Not relevant to key questions
65. Alfven G. One hundred cases of recurrent abdominal pain in children: diagnostic procedures and criteria for a psychosomatic diagnosis.[erratum appears in Acta Paediatr. 2003 May;92(5):641]. Acta Paediatrica 2003; 92(1):43–9. No prevalence data
66. Al-Habbal MJ, Al-Habbal Z, Huwez FU. A double-blind controlled clinical trial of mastic and placebo in the treatment of duodenal ulcer. Clin Exp Pharmacol Physiol Vol 11; 1984: 541–4. Not lactose intolerance study
67. Allan SJ, Kavanagh GM, Herd RM, et al. The effect of inositol supplements on the psoriasis of patients taking lithium: a randomized, placebo-controlled trial. The British journal of dermatology Vol 150; 2004: 966–9. Not lactose intolerance study
68. Allen UD, McLeod K, Wang EE. Cow's milk versus soy-based formula in mild and moderate diarrhea: a randomized, controlled trial. Acta paediatrica (Oslo, Norway : 1992) Vol 83; 1994: 183–7. Not relevant to key questions
69. Alm L. Effect of fermentation on lactose, glucose, and galactose content in milk and suitability of fermented milk products for lactose intolerant individuals. J Dairy Sci 1982 Mar; 65(3):346–52. Not relevant to key questions
70. Almeida JA, Kim R, Stoita A, et al. Lactose malabsorption in the elderly: role of small intestinal bacterial overgrowth. Scandinavian Journal of Gastroenterology 2008; 43(2):146‐54. Ineligible number of subjects
71. Almendingen K, Trygg K, Hofstad B, et al. Results from two repeated 5 day dietary records with a 1 y interval among patients with colorectal polyps. European journal of clinical nutrition Vol 55; 2001: 374–9. Not lactose intolerance study
72. Almy TP. Editorial: Evolution, lactase levels, and global hunger. N Engl J Med 1975 May 29; 292(22):1183–4. Editorial
73. Alpers DH, Gerber JE. Monosaccharide inhibition of human intestinal lactase. J Lab Clin Med 1971 Aug; 78(2):265–74. Not relevant to key questions
74. Al-Sanae H, Saldanha W, Sugathan TN, et al. Comparison of lactose intolerance in healthy Kuwaiti and Asian volunteers. Medical Principles & Practice 2003 Jul–Sep; 12(3):160–3. Ineligible number of subjects
75. Alvarez-Coca J, Perez-Miranda M, Iritia M, et al. Usefulness of urinary galactose for diagnosis of hypolactasia. J Clin Gastroenterol 1996 Jul; 23(1):79–80. Not relevant to key questions
76. Alves MN, Ferrari-Auarek WM, Pinto KM, et al. Effects of caffeine and tryptophan on rectal temperature, metabolism, total exercise time, rate of perceived exertion and heart rate. Brazilian journal of medical and biological research = Revista brasileira de pesquisas médicas e biológicas / Sociedade Brasileira de Biofísica ... [et al.] Vol 28; 1995: 705–9. Not lactose intolerance study
77. Alzate H, Gonzalez H, Guzman J. Lactose intolerance in South American Indians. Am J Clin Nutr 1969 Feb; 22(2):122–3. Not relevant to key questions
78. Ambroszkiewicz J, Klemarczyk W, Gajewska J, et al. Serum concentration of biochemical bone turnover markers in vegetarian children. Adv Med Sci 2007; 52:279–82. Not eligible exposure
79. Ameen VZ, Powell GK. Quantitative fecal carbohydrate excretion in premature infants. The American journal of clinical nutrition Vol 49; 1989: 1238–42. Not lactose intolerance study
80. Ameen VZ, Shivpuri C, King RC. Total fecal carbohydrate (CHO) and short chain fatty acid (SCFA) excretion in prematures fed 100% lactose (L) vs 50% lactose plus 50% glucose polymers (GP). Pediatric Research Vol 23; 1988: 297a. Not lactose intolerance study
81. Anand AN, Seshadri S. A quantitative model for prediction of iron bioavailability from Indian meals: an experimental study. Int J Food Sci Nutr 1995 Nov; 46(4):335–42. Not eligible outcomes
82. Anderson B, Vullo C. Did malaria select for primary adult lactase deficiency? Gut 1994 Oct; 35(10):1487–9. Not relevant to key questions
83. Anderson TW, Reid DB. A double-blind trial of vitamin E in angina pectoris. The American journal of clinical nutrition Vol 27; 1974: 1174–8. Not lactose intolerance study
84. Andersson DE, Nygren A. Four cases of long-standing diarrhoea and colic pains cured by fructose-free diet--a pathogenetic discussion. Acta Med Scand 1978; 203(1–2):87–92. Not relevant to key questions
85. Andersson-Wenckert I, Blomquist HK, Fredrikzon B. Oral health in coeliac disease and cow's milk protein intolerance. Swed Dent J 1984; 8(1):9–14. Not relevant to key questions
86. Andiran F, Dayi S, Mete E. Cows milk consumption in constipation and anal fissure in infants and young children. J Paediatr Child Health 2003 Jul; 39(5):329–31. Not relevant to key questions
87. Andrews BF, Cook LN. Low birth-weight infants fed a new carbohydrate-free formula with different sugars. I. Growth and clinical course. The American journal of clinical nutrition Vol 22; 1969: 845–50. Not lactose intolerance study
88. Angelides AG, Davidson M. Lactose intolerance and diarrhea: are they related? Pediatr Ann 1985 Jan; 14(1):62–3, 6–7, 70–1 passim. Not relevant to key questions
89. Anh NT, Thuc TK, Welsh JD. Lactose malabsorption in adult Vietnamese. Am J Clin Nutr 1977 Apr; 30(4):468–9. Not relevant to key questions
90. Anonymous. Intal compound for asthma. Drug & Therapeutics Bulletin Vol 6; 1968: 37–8. Not lactose intolerance study
91. Ansari Z, Malik AS, Dutta AK, et al. Prevalence of sugar intolerance in diarrhoea of infancy and childhood. Indian Pediatrics 1979 Oct; 16(10):879–85. No prevalence data
92. Anslow JA, Balm TK, Hooper JW, et al. Minimization of gastric damage with enteric-coated aspirin granules compared to buffered aspirin. Pharmacology Vol 30; 1985: 40–4. Not lactose intolerance study
93. Anthoni S, Elg P, Haahtela T, et al. Should milk-specific IgE antibodies be measured in adults in primary care? Scandinavian Journal of Primary Health Care 2008 Dec; 26(4):197‐202. No prevalence data
94. Antia FP. Lactase deficiency a realistic approach. J Assoc Physicians India 1979 Feb; 27(2):152–4. Not relevant to key questions
95. Antonowicz I, Reddy V, Khaw KT, et al. Lactase deficiency in patients with cystic fibrosis. Pediatrics 1968 Sep; 42(3):492–500. Not relevant to key questions
96. Arashima S, Matsuda I, Sato N, et al. Intestinal disaccharidase activity in an infant with lactose intolerance. Helv Paediatr Acta 1971 Jun; 26(2):215–9. Not relevant to key questions
97. Araya M, Baiocchi N, Espinoza J, et al. Persistent diarrhoea in the community. Characteristics and risk factors. Acta Paediatr Scand 1991 Feb; 80(2):181–9. Not relevant to key questions
98. Ariyoshi Y, Ota K, Taguchi T, et al. [Anti-emetic effect and safety of ondansetron tablet in double-blind comparison with placebo]. Gan to kagaku ryoho. Cancer & chemotherapy Vol 19; 1992: 2057–70. Not lactose intolerance study
99. Arlettaz A, Portier H, Lecoq AM, et al. Effects of short-term prednisolone intake during submaximal exercise. Medicine and science in sports and exercise Vol 39; 2007: 1672–8. Not lactose intolerance study
100. Armitstead J, Kelly D, Walker-Smith J. Evaluation of infant feeding in acute gastroenteritis. Journal of pediatric gastroenterology and nutrition Vol 8; 1989: 240–4. Not relevant to key questions
101. Arnold AJ, Simpson JG, Jones HE, et al. Suppression of histamine-induced pruritus by hydroxyzine and various neuroleptics. Journal of the American Academy of Dermatology Vol 1; 1979: 509–12. Not lactose intolerance study
102. Aro A, Pelkonen R, Leino U. Glucose and insulin responses to meals containing milk, lactose, glucose or fructose in subjects with non-insulin-dependent diabetes. Diabète & métabolisme Vol 13; 1987: 603–6. Not relevant to key questions
103. Arola H. The strip test for hypolactasia also works without ethanol. Scand J Gastroenterol 1988 Sep; 23(7):851–5. Not relevant to key questions
104. Arola H, Koivula T, Jokela H, et al. Simple urinary test for lactose malabsorption. Lancet 1982 Sep 4; 2(8297):524–5. Not relevant to key questions
105. Arola H, Koivula T, Jokela H, et al. Comparison of indirect diagnostic methods for hypolactasia. Scand J Gastroenterol 1988 Apr; 23(3):351–7. Not relevant to key questions
106. Arola H, Koivula T, Jokela H, et al. Strip test is reliable in common prevalences of hypolactasia. Scandinavian Journal of Gastroenterology 1987 May; 22(4):509–12. No prevalence data
107. Arola H, Sillanaukee P, Aine E, et al. Galactitol is not a cause of senile cataract. Graefes Arch Clin Exp Ophthalmol 1992; 230(3):240–2. Not relevant to key questions
108. Arrigoni E, Marteau P, Briet F, et al. Tolerance and absorption of lactose from milk and yogurt during short-bowel syndrome in humans. Am J Clin Nutr 1994 Dec; 60(6):926–9. Not relevant to key questions
109. Arthur AB, Clayton BE, Cottom DG, et al. Importance of disaccharide intolerance in the treatment of coeliac disease. Lancet 1966 Jan 22; 1(7430):172–4. Not relevant to key questions
110. Arunachalam K, Gill HS, Chandra RK. Enhancement of natural immune function by dietary consumption of Bifidobacterium lactis (HN019). European journal of clinical nutrition 2000 Mar; 54(3):263–7. Not relevant to key questions
111. Arvanitakis C, Chen GH, Folscroft J, et al. Lactase deficiency--a comparative study of diagnostic methods. American Journal of Clinical Nutrition 1977 Oct; 30(10):1597–602. Ineligible number of subjects
112. Ashraf H, Ahmed S, Fuchs GJ, et al. Persistent diarrhoea: associated infection and response to a low lactose diet. Journal of tropical pediatrics 2002 Jun; 48(3):142–8. Not relevant to key questions
113. Asmawi MZ, Seppo L, Vapaatalo H, et al. Hypolactasia & lactose intolerance among three ethnic groups in Malaysia. Indian Journal of Medical Research 2006 Dec; 124(6):697–704. Not eligible test for lactose malabsorption
114. Asp NG. Human small-intestinal -galactosidases. Separation and characterization of three forms of an acid-galactosidase. Biochem J 1971 Jan; 121(2):299–308. Not relevant to key questions
115. Asp NG, Berg NO, Dahlqvist A, et al. The activity of three different small-intestinal ‐galactosidases in adults with and without lactase deficiency. Scand J Gastroenterol 1971; 6(8):755–62. Not relevant to key questions
116. Asp NG, Dahlqvist A. Multiplicity of intestinal beta-galactosidases. Contribution of each enzyme to the total lactase activity in normal and lactose-intolerant patients. Acta Paediatr Scand 1971 May; 60(3):364–5. Not relevant to key questions
117. Asp NG, Dahlqvist A. Human small intestine-galactosidases: specific assay of three different enzymes. Anal Biochem 1972 Jun; 47(2):527–38. Not relevant to key questions
118. Asp NG, Dahlqvist A. Intestinal beta-galactosidases in adult low lactase activity and in congenital lactase deficiency. Enzyme 1974; 18(1):84–102. Not relevant to key questions
119. Asp NG, Dahlqvist A, Koldovsky O. Human small-intestinal beta-galactosidases. Separation and characterization of one lactase and one hetero beta-galactosidase. Biochem J 1969 Sep; 114(2):351–9. Not relevant to key questions
120. Asp NG, Dahlqvist A, Kuitunen P, et al. Complete deficiency of brush-border lactase in congenital lactose malabsorption. Lancet 1973 Aug 11; 2(7824):329–30. Not relevant to key questions
121. Atkins D, Briss PA, Eccles M, et al. Systems for grading the quality of evidence and the strength of recommendations II: pilot study of a new system. BMC Health Serv Res 2005 Mar 23; 5(1):25. Not relevant to key questions
122. Atkins D, Eccles M, Flottorp S, et al. Systems for grading the quality of evidence and the strength of recommendations I: critical appraisal of existing approaches The GRADE Working Group. BMC Health Serv Res 2004 Dec 22; 4(1):38. Not relevant to key questions
123. Auld G, Boushey CJ, Bock MA, et al. Perspectives on intake of calcium-rich foods among Asian, Hispanic, and white preadolescent and adolescent females. J Nutr Educ Behav 2002 Sep–Oct; 34(5):242–51. Not eligible outcomes
124. Auricchio S. Lactase deficiency phenotype has not been selected by malaria.[comment]. Italian Journal of Gastroenterology & Hepatology 1998 Oct; 30(5):494–5. No prevalence data
125. Aurisicchio LN, Pitchumoni CS. Lactose intolerance. Recognizing the link between diet and discomfort. Postgraduate Medicine 1994 1994 Jan; 95(1):113–6. Not original research
126. Avni EF, Van Gansbeke D, Rodesch P, et al. Sonographic demonstration of malabsorption in neonates. J Ultrasound Med 1986 Feb; 5(2):85–7. Not relevant to key questions
127. Aziz EM. Neonatal pneumatosis intestinalis associated with milk intolerance. Am J Dis Child 1973 Apr; 125(4):560–2. Not relevant to key questions
128. Babb RR. Coffee, sugars, and chronic diarrhea. Why a dietary history is important. Postgrad Med 1984 Jun; 75(8):82, 6–7. Not relevant to key questions
129. Baer D. Lactase deficiency and yogurt. Soc Biol 1970 Jun; 17(2):143. Not relevant to key questions
130. Bahk YW, Ahn GS. Lactose intolerance in the Koreans. Mod Med Asia 1977 Mar; 13(3):7–8. Not relevant to key questions
131. Bahna SL. Cow's milk allergy versus cow milk intolerance. Annals of Allergy, Asthma, & Immunology 2002 Dec; 89(6 Suppl 1):56–60. No prevalence data
132. Bain HW. Chronic vague abdominal pain in children. Pediatr Clin North Am 1974 Nov; 21(4):991–1000. Not relevant to key questions
133. Bakan R, Birmingham CL, Aeberhardt L, et al. Dietary zinc intake of vegetarian and nonvegetarian patients with anorexia nervosa. Int J Eat Disord 1993 Mar; 13(2):229–33. Not relevant to key questions
134. Bakken AF. Letter: Intestinal lactase deficiency as a factor in the diarrhea of light-treated jaundiced infants. N Engl J Med 1976 Mar 11; 294(11):615. Not relevant to key questions
135. Bakken AF. Temproary intestinal lactase deficiency in light-treated jaundiced infants. Acta Paediatr Scand 1977 Jan; 66(1):91–6. Not relevant to key questions
136. Bakken AF. The application of the "Lojda" method for intestinal lactase in intestinal biopsies from jaundiced newborn infants. Histochemistry 1977 Mar 4; 51(2–3):253–5. Not relevant to key questions
137. Bakken AF, Motzfeldt C. Intestinal lactase deficiency in newborns with cystic fibrosis-‐dietary consequences. Monogr Paediatr 1979; 10:5–7. Not relevant to key questions
138. Bakry F, Sunoto, Hendardji H, et al. The severity of lactose intolerance in Indonesian children. Paediatr Indones 1973 Jul–Aug; 13(7):185–90. Not relevant to key questions
139. Balanza E, Taboada G. The frequency of lactase phenotypes in Aymara children. J Med Genet 1985 Apr; 22(2):128–30. Not relevant to key questions
140. Ball D, Maughan RJ. Blood and urine acid-base status of premenopausal omnivorous and vegetarian women. Br J Nutr 1997 Nov; 78(5):683–93. Not eligible outcomes
141. Balslev I, Kramhoft J, Backer OG. Lactose malabsorption before and after truncal and selective vagotomy. Scand J Gastroenterol Suppl 1971; 9:71–4. Not relevant to key questions
142. Bampoe V, Sapsford RJ, Avigad S, et al. Lactase degradation by human enteric bacteria. Lancet 1979 Jul 21; 2(8134):125–7. Not relevant to key questions
143. Banai J, Surjan L, Szanto I, et al. Jejunoscopic lactose provocation. Gastroenterol Jpn 1984 Apr; 19(2):127–30. Not relevant to key questions
144. Bandera EV, Kushi LH, Moore DF, et al. Consumption of animal foods and endometrial cancer risk: a systematic literature review and meta-analysis. Cancer Causes Control 2007 Nov; 18(9):967–88. Not eligible outcomes
145. Barbeau A, Mars H, Botez MI, et al. Amantadine-HCl (Symmetrel) in the management of Parkinson's disease: a double-blind cross-over study. Canadian Medical Association journal Vol 105; 1971: 42–6 passim. Not lactose intolerance study
146. Barillas C, Solomons NW. Effective reduction of lactose maldigestion in preschool children by direct addition of beta-galactosidases to milk at mealtime. Pediatrics 1987 May; 79(5):766–72. Not relevant to key questions
147. Barillas-Mury C, Solomons NW. Test-retest reproducibility of hydrogen breath test for lactose maldigestion in preschool children. J Pediatr Gastroenterol Nutr 1987 Mar–Apr; 6(2):281–5. Not relevant to key questions
148. Barnes GL. Management of sugar intolerance in children. N Z Med J 1976 Mar 10; 83(559):149–51. Not relevant to key questions
149. Barnes GL, Doyle LW, Hewson PH, et al. A randomised trial of oral gammaglobulin in low-birth-weight infants infected with rotavirus. Lancet Vol 1; 1982: 1371–3. Not lactose intolerance study
150. Baron ML. Assisting families in making appropriate feeding choices: cow's milk protein allergy versus lactose intolerance. Pediatr Nurs 2000 Sep–Oct; 26(5):516–20. Not relevant to key questions
151. Barr RG, Hanley J, Patterson DK, et al. Breath hydrogen excretion in normal newborn infants in response to usual feeding patterns: evidence for "functional lactase insufficiency" beyond the first month of life. Journal of Pediatrics 1984 Apr; 104(4):527–33. Ineligible number of subjects
152. Barr RG, Kushner DC. Roentgenographic observation of gas-fluid levels in the colon of children with abdominal pain and malabsorption of lactose. Can Med Assoc J 1985 May 15; 132(10):1158–60. Not relevant to key questions
153. Barr RG, Watkins JB, Perman JA. Mucosal function and breath hydrogen excretion: comparative studies in the clinical evaluation of children with nonspecific abdominal complaints. Pediatrics 1981 Oct; 68(4):526–33. Not relevant to key questions
154. Barr RG, Wooldridge J, Hanley J. Effects of formula change on intestinal hydrogen production and crying and fussing behavior. J Dev Behav Pediatr 1991 Aug; 12(4):248–53. Not relevant to key questions
155. Barrett-Connor E, Chang JC, Edelstein SL. Coffee-associated osteoporosis offset by daily milk consumption. The Rancho Bernardo Study. Jama 1994 Jan 26; 271(4):280–3. Not eligible outcomes
156. Barrie H. Lactose malabsorption. Dev Med Child Neurol 1977 Jun; 19(3):402–3. Not relevant to key questions
157. Barsotti G, Morelli E, Cupisti A, et al. A low-nitrogen low-phosphorus Vegan diet for patients with chronic renal failure. Nephron 1996; 74(2):390–4. Not eligible target population
158. Bartholomew C, Pong OY. Lactose intolerance in East Indians of Trinidad. Trop Geogr Med 1976 Dec; 28(4):336–8. Not relevant to key questions
159. Bartlett K, Dobson JV, Eastham E. A new method for the detection of hydrogen in breath and its application to acquired and inborn sugar malabsorption. Clin Chim Acta 1980 Dec 8; 108(2):189–94. Not relevant to key questions
160. Bartrop RW, Hull D. Transient lactose intolerance in infancy. Arch Dis Child 1973 Dec; 48(12):963–6. Not relevant to key questions
161. Basford RL, Henry JB. Lactose intolerance in the adult. Postgrad Med 1967 Jan; 41(1):A70‐ 7. Not relevant to key questions
162. Basran GS, Darbyshire JH, Nunn AJ, et al. Inhaled lactose-free sodium cromoglycate powder in the treatment of recurrent asthma. British journal of diseases of the chest Vol 78; 1984: 254–60. Not lactose intolerance study
163. Bassindale T, Cowan DA, Dale S, et al. Effects of oral administration of androstenedione on plasma androgens in young women using hormonal contraception. The Journal of clinical endocrinology and metabolism Vol 89; 2004: 6030–8. Not lactose intolerance study
164. Batar I. Study of the efficacy of combined ColpoCleaner and Diflucan therapy. Magyar Noorvosok Lapja Vol 65; 2002: 41–4. Not lactose intolerance study
165. Bates CJ, Evans PH, Allison G, et al. Biochemical indices and neuromuscular function tests in rural Gambian schoolchildren given a riboflavin, or multivitamin plus iron, supplement. The British journal of nutrition Vol 72; 1994: 601–10. Not lactose intolerance study
166. Bayar N, Böke B, Turan E, et al. Efficacy of amitriptyline in the treatment of subjective tinnitus. The Journal of otolaryngology Vol 30; 2001: 300–3. Not lactose intolerance study
167. Bayless TM. Recognition of lactose intolerance. Hosp Pract 1976 Oct; 11(10):97–102. Not relevant to key questions
168. Bayless TM. Lactose intolerance in the adolescent. J Adolesc Health Care 1982 Aug; 3(1):65‐ 8. Not relevant to key questions
169. Bayless TM, Huang SS. Inadequate intestinal digestion of lactose. Am J Clin Nutr 1969 Mar; 22(3):250–6. Not relevant to key questions
170. Bayless TM, Huang SS. Recurrent abdominal pain due to milk and lactose intolerance in school-aged children. Pediatrics 1971 Jun; 47(6):1029–32. Not relevant to key questions
171. Bayless TM, Paige DM. Lactose intolerance. Curr Concepts Nutr 1979; 8:79–90. Not relevant to key questions
172. Bayless TM, Paige DM, Ferry GD. Lactose intolerance and milk drinking habits. Gastroenterology 1971 Apr; 60(4):605–8. Not relevant to key questions
173. Bayless TM, Partin JS, Rosensweig NS. Absence of milk antibodies in milk intolerance in adults. JAMA 1967 Jul 3; 201(1):128. Not relevant to key questions
174. Bayless TM, Rosensweig NS. A racial difference in incidence of lactase deficiency. A survey of milk intolerance and lactase deficiency in healthy adult males. JAMA 1966 Sep 19; 197(12):968–72. Not relevant to key questions
175. Bayless TM, Rosensweig NS, Christopher N, et al. Milk intolerance and lactose tolerance tests. Gastroenterology 1968 Mar; 54(3):475–7. Not relevant to key questions
176. Bayless TM, Rothfeld B, Massa C, et al. Lactose and milk intolerance: clinical implications. N Engl J Med 1975 May 29; 292(22):1156–9. Not eligible test for lactose malabsorption
177. Beal D, Gillis JS. Methylphenidate hydrochloride and judgmental behavior in hyperkinetic children. Curr Ther Res, Clin Exp Vol 26; 1979: 931–9. Not lactose intolerance study
178. Beau JP, Fontaine O, Garenne M. Management of malnourished children with acute diarrhoea and sugar intolerance. J Trop Pediatr 1989 Dec; 35(6):281–4. Not relevant to key questions
179. Beau JP, Fontaine O, Garenne M. Management of malnourished children with acute diarrhoea and sugar intolerance. J Trop Pediatr 1990 Apr; 36(2):86–9. Not relevant to key questions
180. Beck IT, Da Costa LR, Beck M. Sugar absorption by small bowel biopsy samples from patients with primary lactase deficiency and with adult celiac disease. Am J Dig Dis 1976 Nov; 21(11):946–52. Not relevant to key questions
181. Bedine MS, Bayless TM. Intolerance of small amounts of lactose by individuals with low lactase levels. Gastroenterology 1973 Nov; 65(5):735–43. Not relevant to key questions
182. Beeken WL. Remediable defects in Crohn disease: a prospective study of 63 patients. Archives of Internal Medicine 1975 May; 135(5):686–90. No prevalence data
183. Beeken WL, Kanich RE. Microbial flora of the upper small bowel in Crohn's disease. Gastroenterology 1973 Sep; 65(3):390–7. Not relevant to key questions
184. Beilin LJ, Burke V. Vegetarian diet components, protein and blood pressure: which nutrients are important? Clin Exp Pharmacol Physiol 1995 Mar; 22(3):195–8. Review
185. Bell RR, Draper HH, Bergan JG. Sucrose, lactose, and glucose tolerance in northern Alaskan Eskimos. Am J Clin Nutr 1973 Nov; 26(11):1185–90. Not relevant to key questions
186. Bellati U, Liberati M. [Experience regarding the use of arginine-lysine-lactose treatment in menopausal osteoporosis]. Minerva medica Vol 85; 1994: 327–32. Not lactose intolerance study
187. Benetos A, Xiao YY, Cuche JL, et al. Arterial effects of salt restriction in hypertensive patients. A 9-week, randomized, double-blind, crossover study. Journal of hypertension Vol 10; 1992: 355–60. Not lactose intolerance study
188. Bengtsson U, Knutson TW, Knutson L, et al. Increased levels of hyaluronan and albumin after intestinal challenge in adult patients with cow's milk intolerance. Clinical and experimental allergy : journal of the British Society for Allergy and Clinical Immunology Vol 26; 1996: 96–103. Not relevant to key questions
189. Ben-Yoseph Y, Momoi T, Baylerian MS, et al. Km defect in neuraminidase of dysmorphic type sialidosis with and without beta-galactosidase deficiency. Clin Chim Acta 1982 Aug 18; 123(3):233–40. Not relevant to key questions
190. Berezin S, Bhole A, Wu TC, et al. Abdominal distention associated with lactose malabsorption in a premature infant. N Y State J Med 1985 May; 85(5):227. Not relevant to key questions
191. Berezin S, Schwarz SM, Glassman M, et al. Gastrointestinal milk intolerance of infancy.[see comment]. American Journal of Diseases of Children 1989 Mar; 143(3):361–2. Ineligible number of subjects
192. Berg A, Eriksson M, Barany F, et al. Hydrogen concentration in expired air analyzed with a new hydrogen sensor, plasma glucose rise, and symptoms of lactose intolerance after oral administration of 100 gram lactose. Scand J Gastroenterol 1985 Sep; 20(7):814–22. Not relevant to key questions
193. Berg NO, Borulf S, Jakobsson I, et al. How to approach the child suspected of malabsorption. Experience from a prospective investigation of suspected malabsorption in children 1968‐1976 in Malmo. Acta Paediatr Scand 1978 Jul; 67(4):403–11. Not relevant to key questions
194. Berg NO, Dahlqvist A, Lindberg T. A boy with severe infantile gastrogen lactose intolerance and acquired lactase deficiency. Acta Paediatrica Scandinavica 1979 Sep; 68(5):751–8. Ineligible number of subjects
195. Berg SB. Think before you drink milk. Dent Assist 1986 Jul–Aug; 55(4):21–2. Comment
196. Bergoz R, Griessen M, Infante F, et al. Significance of duodenal disaccharidases. A comparative study of duodenal and jejunal values. Digestion 1981; 22(2):108–12. Not relevant to key questions
197. Berkey CS, Rockett HR, Willett WC, et al. Milk, dairy fat, dietary calcium, and weight gain: a longitudinal study of adolescents. Arch Pediatr Adolesc Med 2005 Jun; 159(6):543–50. Not eligible outcomes
198. Berlin CM, Jr., Tinker DE. Kwashiorker in a child in central Pennsylvania. A seven-year follow-up. American Journal of Diseases of Children 1982 Sep; 136(9):822–4. Not relevant to key questions
199. Bernardes-Silva CF, Pereira AC, de Fatima Alves da Mota G, et al. Lactase persistence/nonpersistence variants, C/T_13910 and G/A_22018, as a diagnostic tool for lactose intolerance in IBS patients. Clin Chim Acta 2007 Nov–Dec; 386(1–2):7–11. Not relevant to key questions
200. Bernhardt MK, Southard KA, Batterson KD, et al. The effect of preemptive and/or postoperative ibuprofen therapy for orthodontic pain. American journal of orthodontics and dentofacial orthopedics : official publication of the American Association of Orthodontists, its constituent societies, and the American Board of Orthodontics Vol 120; 2001: 20–7. Not lactose intolerance study
201. Bernier GM, Gunderman JR, Ruymann FB. Kappa-chain deficiency. Blood 1972 Dec; 40(6):795–805. Not relevant to key questions
202. Bernstein CN, Ament M, Artinian L, et al. Milk tolerance in adults with ulcerative colitis. Am J Gastroenterol 1994 Jun; 89(6):872–7. Not relevant to key questions
203. Bernstein JA, Bernstein DI, Stauder T, et al. A cross-sectional survey of sensitization to Aspergillus oryzae-derived lactase in pharmaceutical workers. Journal of Allergy & Clinical Immunology 1999 Jun; 103(6):1153–7. No prevalence data
204. Berry GT, Nissim I, Gibson JB, et al. Quantitative assessment of whole body galactose metabolism in galactosemic patients. European journal of pediatrics 1997 Aug; 156(Suppl 1):S43–9. Not relevant to key questions
205. Besigye E, Kajubi SK. Experience with a radiological method of diagnosing lactase deficiency. East Afr Med J 1969 Oct; 46(10):564–71. Not relevant to key questions
206. Bhan MK, Arora NK, Ghai OP, et al. Lactose and milk intolerance in recurrent abdominal pain of childhood. Indian J Pediatr 1982 Mar–Apr; 49(397):199–202. Not relevant to key questions
207. Bhan MK, Arora NK, Khoshoo V, et al. Comparison of a lactose-free cereal-based formula and cow's milk in infants and children with acute gastroenteritis. Journal of pediatric gastroenterology and nutrition Vol 7; 1988: 208–13. Not relevant to key questions
208. Bhatia BD, Banerjee D, Agarwal DK, et al. Dietary intakes of urban and rural pregnant, lactating and non-pregnant, non-lactating vegetarian women of Varanasi. Indian J Med Res 1981 Nov; 74:680–7. Not eligible outcomes
209. Bhatnagar R, Sharma YR, Vajpayee RB, et al. Does milk have a cataractogenic effect? Weighing of clinical evidence. Digestive Diseases & Sciences 1989 Nov; 34(11):1745–50. No prevalence data
210. Bhatnagar S, Bhan MK, Singh KD, et al. Efficacy of milk-based diets in persistent diarrhea: a randomized, controlled trial. Pediatrics Vol 98; 1996: 1122–6. Not relevant to key questions
211. Bhattacharya RD, Patel TS, Pandya CB. Reference values of urinary electrolyte excretion in respect of a vegetarian diet. A chronobiological study. Panminerva Med 1985 Apr–Jun; 27(2):83–7. Not eligible outcomes
212. Bhttacharyya AK, Chaudhuri AD, Chatterjee S, et al. Milk intolerance in irritable colon syndrome. Bull Calcutta Sch Trop Med 1971 Jul; 19(3):55–6. Not relevant to key questions
213. Bhutta ZA, Nizami SQ, Isani Z. Lactose intolerance in persistent diarrhoea during childhood: the role of a traditional rice-lentil (Khitchri) and yogurt diet in nutritional management. J Pak Med Assoc 1997 Jan; 47(1):20–4. Not relevant to key questions
214. Bianchi Porro G, Parente F, Sangaletti O. Lactose intolerance in adults with chronic unspecific abdominal complaints. Hepato-Gastroenterology 1983 Dec; 30(6):254–7. Not population based study
215. Bianchi Porro G, Petrillo M, Parente F, et al. Recurrent abdominal pain and lactose intolerance. Br Med J (Clin Res Ed) 1981 Aug 15; 283(6289):501. Not relevant to key questions
216. Biar J. Milk intolerance. J Med Liban 1969; 22(1):66–71. Not relevant to key questions
217. Biddulph J. Standardized management of diarrhoea in young children. Paediatr Indones 1971 Sep–Oct; 11(5):37–46. Not relevant to key questions
218. Bilir S. Acquired disaccharide intolerance in children with malnutrition. Am J Clin Nutr 1972 Jul; 25(7):664–71. Not relevant to key questions
219. Biller JA, King S, Rosenthal A, et al. Efficacy of lactase-treated milk for lactose-intolerant pediatric patients. J Pediatr 1987 Jul; 111(1):91–4. Not relevant to key questions
220. Binder HJ. The pathophysiology of diarrhea. Hosp Pract (Off Ed) 1984 Oct; 19(10):107–13, 16–8. Not lactose intolerance study
221. Binder JH, Gryboski JD, Thayer WR, Jr., et al. Intolerance to milk in ulcerative colitis. A preliminary report. Am J Dig Dis 1966 Nov; 11(11):858–64. Not relevant to key questions
222. Binnington HB, Keating JP, Ternberg JL. Proceedings: Gastroschisis. Arch Surg 1974 Apr; 108(4):455–9. Not relevant to key questions
223. Binns J, Stevens HNE, McEwen J, et al. The tolerability of multiple oral doses of Pulsincapregistered trade mark capsules in healthy volunteers. Journal of Controlled Release. Vol 38; 1996: 151–8. Not lactose intolerance study
224. Birch EE, Castan~eda YS, Wheaton DH, et al. Visual maturation of term infants fed long-chain polyunsaturated fatty acid-supplemented or control formula for 12 months. American Journal of Clinical Nutrition Vol 81; 2005: 871–9. Not lactose intolerance study
225. Bircher J, Haemmerli UP, Williams R. Lactulose in the treatment of portal-systemic encephalopathy. Report of a symposium. Gastroenterology Vol 58; 1970: 595–7. Not lactose intolerance study
226. Birkhed D, Fuchs G. Influence of sugar content in soft bread on pH of human dental plaque. Acta Odontologica Scandinavica Vol 33; 1975: 59–66. Not lactose intolerance study
227. Birkhed D, Imfeld T, Edwardsson S. pH changes in human dental plaque from lactose and milk before and after adaptation. Caries-Res Vol 27; 1993: 43–50. Not lactose intolerance study
228. Birlouez-Aragon I, Ravelontseheno L, Villate-Cathelineau B, et al. Disturbed galactose metabolism in elderly and diabetic humans is associated with cataract formation. J Nutr 1993 Aug; 123(8):1370–6. Not relevant to key questions
229. Biskup H, Heine WE, Wutzke KD. Gastric emptying and intestinal transit time of high- and low caloric formulas. Aktuelle Ernahrungsmedizin Vol 24; 1999: 238–41. Not lactose intolerance study
230. Bjarnason I. Intestinal permeability. Gut 1994 Jan; 35(1 Suppl):S18–22. Not relevant to key questions
231. Blair J, Fitzgerald JF. Non-specific infantile diarrhea. J Indiana State Med Assoc 1973 Sep; 65(9):791–3. Not relevant to key questions
232. Blair J, Fitzgerald JF. Treatment of nonspecific diarrhea in infants. Clin Pediatr (Phila) 1974 Apr; 13(4):333–4. Not relevant to key questions
233. Blaney DJ, Cook CH. Topical use of tetracycline in the treatment of acne: a double-blind study comparing topical and oral tetracycline therapy and placebo. Archives of dermatology Vol 112; 1976: 971–3. Not lactose intolerance study
234. Blankenship RM, Greenburg BR, Lucas RN, et al. Familial sea-blue histiocytes with acid phosphatemia. A syndrome resembling Gaucher disease: the Lewis variant. JAMA 1973 Jul 2; 225(1):54–6. Not eligible target population
235. Blass EM. Milk-induced hypoalgesia in human newborns. Pediatrics Vol 99; 1997: 825–9. Not relevant to key questions
236. Blum AL, Haemmerli UP, Lorenz-Meyer H. Is phlorizin or its aglycon the inhibitor of intestinal glucose transport? A study in normal and lactase deficient man. Eur J Clin Invest 1975 Jun 12; 5(3):285–8. Not relevant to key questions
237. Blumenthal I, Kelleher J, Littlewood JM. Recurrent abdominal pain and lactose intolerance in childhood. Br Med J (Clin Res Ed) 1981 Jun 20; 282(6281):2013–4. Not relevant to key questions
238. Bode JC. [Lactose enemas plus placebo tablets vs neomycin tablets plus starch enemas in acute portal systemic encephalopathy A double-blind randomized contolled study]. Zeitschrift für Gastroenterologie Vol 19; 1981: 744. Not lactose intolerance study
239. Bode S, Gudmand-Hoyer E. Incidence and clinical significance of lactose malabsorption in adult coeliac disease. Scand J Gastroenterol 1988 May; 23(4):484–8. Not relevant to key questions
240. Bodlaj G, Stocher M, Hufnagl P, et al. Genotyping of the lactase-phlorizin hydrolase -13910 polymorphism by LightCycler PCR and implications for the diagnosis of lactose intolerance. Clin Chem 2006 Jan; 52(1):148–51. Not relevant to key questions
241. Boellner SW, Beard AG, Panos TC. Impairment of intestinal hydrolysis of lactose in newborn infants. Pediatrics 1965 Oct; 36(4):542–50. Not relevant to key questions
242. Boey CC. Lactase deficiency among Malaysian children with recurrent abdominal pain. Journal of Paediatrics & Child Health 2001 Apr; 37(2):157–60. Ineligible number of subjects
243. Bohmer CJ, Tuynman HA. The clinical relevance of lactose malabsorption in irritable bowel syndrome. European Journal of Gastroenterology & Hepatology 1996 Oct; 8(10):1013–6. Ineligible number of subjects
244. Bojarski C, Epple HJ, Kirstein FW, et al. Patients with dyspepsia benefit from eradication of Helicobacter pylori if other organic causes for dyspepsia were carefully ruled out. Zeitschrift für Gastroenterologie Vol 38; 2000: 211–9. Not lactose intolerance study
245. Bolin TD. Use of oral sodium cromoglycate in persistent diarrhoea. Gut Vol 21; 1980: 848‐50. Not lactose intolerance study
246. Bolin TD, Crane GG, Davis AE. Lactose intolerance in various ethnic groups in South-East Asia. Australas Ann Med 1968 Nov; 17(4):300–6. Not relevant to key questions
247. Bolin TD, Davis AE. Asian lactose intolerance and its relation to intake of lactose. Nature 1969 Apr 26; 222(5191):382–3. Not relevant to key questions
248. Bolin TD, Davis AE. Lactose intolerance in Australian-born Chinese. Australas Ann Med 1970 Feb; 19(1):40–1. Not relevant to key questions
249. Bolin TD, Davis AE. Primary lactase deficiency: genetic or acquired? Gastroenterology 1972 Feb; 62(2):355–7. Not relevant to key questions
250. Bolin TD, Davis AE, Duncombe VM. A prospective study of persistent diarrhoea. Australian & New Zealand Journal of Medicine 1982 Feb; 12(1):22–6. No prevalence data
251. Bolin TD, Davis AE, Levey J, et al. Aboriginal health on Mornington Island, 1972. Med J Aust 1975 Feb 22; 1(3 Suppl):29–31. Not relevant to key questions
252. Bolin TD, Davis AE, Seah CS, et al. Lactose intolerance in Singapore. Gastroenterology 1970 Jul; 59(1):76–84. Not relevant to key questions
253. Bond JH, Levitt MD. Quantitative measurement of lactose absorption. Gastroenterology 1976 Jun; 70(6):1058–62. Not relevant to key questions
254. Bondesson E, Asking L, Borgström L, et al. In vitro and in vivo aspects of quantifying intrapulmonary deposition of a dry powder radioaerosol. International journal of pharmaceutics Vol 232; 2002: 149–56. Not lactose intolerance study
255. Bondesson E, Bengtsson T, Borgström L, et al. Dose delivery late in the breath can increase dry powder aerosol penetration into the lungs. Journal of aerosol medicine : the official journal of the International Society for Aerosols in Medicine Vol 18; 2005: 23–33. Not lactose intolerance study
256. Boner AL, Niero E, Grigolini C, et al. Inhibition of exercise-induced asthma by three forms of sodium cromoglycate. European journal of respiratory diseases Vol 66; 1985: 21–4. Not lactose intolerance study
257. Bongers ME, de LF, Reitsma JB, et al. The clinical effect of a new infant formula in term infants with constipation: a double-blind, randomized cross-over trial. Nutrition journal Vol 6; 2007: 8. Not lactose intolerance
258. Booth IW. Dietary management of acute diarrhoea in childhood. Lancet 1993 Apr 17; 341(8851):996–7. Not relevant to key questions
259. Borg M, Phillips AD, Smith MW, et al. Enteric disease in early childhood inhibits microvillus expression by potential stem cells. Clin Sci (Lond) 1993 Apr; 84(4):377–9. Not relevant to key questions
260. Born P, Sekatcheva M, Rosch T, et al. Carbohydrate malabsorption in clinical routine: a prospective observational study. Hepato-Gastroenterology 2006 Sep–Oct; 53(71):673–7. Ineligible number of subjects
261. Bosch S, Kalde S, Kuhlbusch R, et al. Treatment of lactose intolerance with a new aspergillus lactose preparation. Aktuelle Ernahrungsmedizin Klinik Und Praxis. Vol 20; 1995: 310–5. Not relevant to key questions
262. Bose DP, Welsh JD. Lactose malabsorption in Oklahoma Indians. Am J Clin Nutr 1973 Dec; 26(12):1320–2. Ineligible number of subjects
263. Bott C, Rudolph MW, Schneider AR, et al. In vivo evaluation of a novel pH- and time-based multiunit colonic drug delivery system. Alimentary pharmacology & therapeutics Vol 20; 2004: 347–53. Not lactose intolerance study
264. Boudraa G, Benbouabdellah M, Hachelaf W, et al. Effect of feeding yogurt versus milk in children with acute diarrhea and carbohydrate malabsorption. Journal of pediatric gastroenterology and nutrition Vol 33; 2001: 307–13. Not relevant to key questions
265. Boudraa G, Touhami M, Pochart P, et al. Effect of feeding yogurt versus milk in children with persistent diarrhea. Journal of pediatric gastroenterology and nutrition Vol 11; 1990: 509–12. Not relevant to key questions
266. Boudraa GBM, Soltana R, Touhami M. Effets compares du yaourt et du lait, au cours des diarrhees prolongees du nourrisson et de l'enfant, avec malabsorption ou intolerance au lactose. Arch Fr Pediatr Vol 49; 1992: 583-. Not relevant to key questions
267. Bourlioux P, Bouley C, Ashwell M. New aspects of the functionalities of probiotics. Forum Nutr 2003; 56:355–6. Not relevant to key questions
268. Bowen J, Noakes M, Trenerry C, et al. Energy intake, ghrelin, and cholecystokinin after different carbohydrate and protein preloads in overweight men. The Journal of clinical endocrinology and metabolism Vol 91; 2006: 1477–83. Not lactose intolerance study
269. Bowie MD. Effect of lactose-induced diarrhoea on absorption of nitrogen and fat. Arch Dis Child 1975 May; 50(5):363–6. Not relevant to key questions
270. Bowie MD, Hill ID, Mann MD. Response of severe infantile diarrhoea to soya-based feeds. South African medical journal = Suid-Afrikaanse tydskrif vir geneeskunde Vol 73; 1988: 343–5. Not relevant to key questions
271. Boyd LD, Palmer C, Dwyer JT. Managing oral health related nutrition issues of high risk infants and children. J Clin Pediatr Dent 1998 Fall; 23(1):31–6. Not relevant to key questions
272. Bozzani A, Penagini R, Velio P, et al. Lactose malabsorption and intolerance in Italians. Clinical implications. Dig Dis Sci 1986 Dec; 31(12):1313–6. Not relevant to key questions
273. Bradfield RB, Jelliffe DB, Ifekwunigwe A. Letter: Milk intolerance and mainutrition. Lancet 1975 Aug 16; 2(7929):325. Not relevant to key questions
274. Braham R, Dawson B, Goodman C. The effect of glucosamine supplementation on people experiencing regular knee pain. British journal of sports medicine Vol 37; 2003: 45–9; discussion 9. Not lactose intolerance study
275. Brand J, Mitchell JD. Faecal fat losses and cow's milk lactose. Lancet 1980 Jan 26; 1(8161):207. Not relevant to key questions
276. Brand JC, Darnton-Hill I. Lactase deficiency in Australian school children. Medical Journal of Australia 1986 Oct 6; 145(7):318–22. Ineligible number of subjects
277. Brand JC, Darnton-Hill I, Gracey MS, et al. Lactose malabsorption in Australian Aboriginal children. American Journal of Clinical Nutrition 1985 Mar; 41(3):620–2. Ineligible number of subjects
278. Brand JC, Gracey MS, Spargo RM, et al. Lactose malabsorption in Australian Aborigines. Am J Clin Nutr 1983 Mar; 37(3):449–52. Not relevant to key questions
279. Brand JC, Miller JJ, Vorbach EA, et al. A trial of lactose hydrolysed milk in Australian Aboriginal children. Med J Aust 1977 Nov 26; 2(4 Suppl):10–3. Not relevant to key questions
280. Brasseur D, Mandelbaum I, Vis HL. Effects of an episode of severe malnutrition and age on lactose absorption by recovered infants and children. Am J Clin Nutr 1980 Feb; 33(2):177–9. Not relevant to key questions
281. Brink EJ, van BEC, Dekker PR, et al. Urinary excretion of magnesium and calcium as an index of absorption is not affected by lactose intake in healthy adults. The British journal of nutrition Vol 69; 1993: 863–70. Not eligible target population
282. Brockis JG, Levitt AJ, Cruthers SM. The effects of vegetable and animal protein diets on calcium, urate and oxalate excretion. Br J Urol 1982 Dec; 54(6):590–3. Not eligible outcomes
283. Bronsky E, Bucholtz GA, Busse WW, et al. Comparison of inhaled albuterol powder and aerosol in asthma. The Journal of allergy and clinical immunology Vol 79; 1987: 741–7. Not lactose intolerance study
284. Broom J, Jones K. Causes and prevention of diarrhoea in patients receiving enteral nutritional support. J Hum Nutr 1981 Apr; 35(2):123–7. Not relevant to key questions
285. Brouwers FM, Van Der Werf S, Bleijenberg G, et al. The effect of a polynutrient supplement on fatigue and physical activity of patients with chronic fatigue syndrome: a double-blind randomized controlled trial. QJM 2002 Oct; 95(10):677–83. Not lactose intolerance
286. Brown KH. Dietary management of acute diarrheal disease: contemporary scientific issues. Journal of Nutrition 1994 Aug; 124(8 Suppl):1455S–60S. Not original research
287. Brown KH, Black RE, Parry L. The effect of diarrhea on incidence of lactose malabsorption among Bangladeshi children. Am J Clin Nutr 1980 Oct; 33(10):2226–7. Not relevant to key questions
288. Brown KH, Gastañaduy AS, Saavedra JM, et al. Effect of continued oral feeding on clinical and nutritional outcomes of acute diarrhea in children. The Journal of pediatrics Vol 112; 1988: 191–200. Not lactose intolerance study
289. Brown KH, Khatun M, Parry L, et al. Nutritional consequences of low dose milk supplements consumed by lactose-malabsorbing children. American Journal of Clinical Nutrition 1980 May; 33(5):1054–63. Ineligible number of subjects
290. Brown KH, Parry L, Khatun M, et al. Lactose malabsorption in Bangladeshi village children: relation with age, history of recent diarrhea, nutritional status, and breast feeding. American Journal of Clinical Nutrition 1979 Sep; 32(9):1962–9. Not eligible test for lactose malabsorption
291. Brown KH, Peerson JM, Fontaine O. Use of nonhuman milks in the dietary management of young children with acute diarrhea: a meta-analysis of clinical trials. Pediatrics 1994 Jan; 93(1):17–27. Not relevant to key questions
292. Brown KH, Perez F, Gastañaduy AS. Clinical trial of modified whole milk, lactose-hydrolyzed whole milk, or cereal-milk mixtures for the dietary management of acute childhood diarrhea. Journal of pediatric gastroenterology and nutrition Vol 12; 1991: 340–50. Not relevant to key questions
293. Brown KH, Perez F, Peerson JM, et al. Effect of dietary fiber (soy polysaccharide) on the severity, duration, and nutritional outcome of acute, watery diarrhea in children. Pediatrics Vol 92; 1993: 241–7. Not lactose intolerance study
294. Brown PT, Bergan JG. The dietary status of "new" vegetarians. J Am Diet Assoc 1975 Nov; 67(5):455–9. Not eligible outcomes
295. Brown RS, Di SPT, Beaver WT, et al. The administration of folic acid to institutionalized epileptic adults with phenytoin-induced gingival hyperplasia. A double-blind, randomized, placebo-controlled, parallel study. Oral surgery, oral medicine, and oral pathology Vol 71; 1991: 565–8. Not lactose intolerance study
296. Bruening K, Kemp FW, Simone N, et al. Dietary calcium intakes of urban children at risk of lead poisoning. Environ Health Perspect 1999 Jun; 107(6):431–5. Not eligible target population
297. Brummer RJ, Karibe M, Stockbrugger RW. Lactose malabsorption. Optimalization of investigational methods. Scandinavian Journal of Gastroenterology - Supplement 1993; 200:65–9. No prevalence data
298. Brunser O, Araya M, Espinoza J, et al. [Trial of milk with low-lactose contents in acute diarrhea]. Rev Chil Pediatr Vol 61; 1990: 94–9. Not English language
299. Bryant GD, Chu YK, Lovitt R. Incidence and aetiology of lactose intolerance. Med J Aust 1970 Jun 27; 1(26):1285–8. Not relevant to key questions
300. Buchanan GR, Martin V, Levine PH, et al. The effects of "anti-platelet" drugs on bleeding time and platelet aggregation in normal human subjects. American journal of clinical pathology Vol 68; 1977: 355–9. Not lactose intolerance study
301. Buchman AL, Moukarzel AA, Bhuta S, et al. Parenteral nutrition is associated with intestinal morphologic and functional changes in humans. Jpen: Journal of Parenteral & Enteral Nutrition Vol 19; 1995: 453–60. Not relevant to key questions
302. Bueno MA. Protriptyline: relationship between plasma concentrations and the clinical effect in depressed male patients. <ORIGINAL> PROTRIPTILINA: RELACION ENTRE LAS CONCENTRACIONES PLASMATICAS Y EL EFECTO CLINICO EN PACIENTES HOMBRES DEPRIMIDOS. Revcolombpsiquiatr Vol 5; 1976: 431–8. Not lactose intolerance study
303. Buhac I, Balint JA. Practical therapeutics. Diarrhea and constipation. Am Fam Physician 1975 Nov; 12(5):149–59. Not relevant to key questions
304. Bujanover Y, Schwartz G, Milbauer B, et al. Lactose malabsorption is not a cause of diarrhea during phototherapy. J Pediatr Gastroenterol Nutr 1985 Apr; 4(2):196–8. Not relevant to key questions
305. Bulhoes AC, Goldani HA, Oliveira FS, et al. Correlation between lactose absorption and the C/T-13910 and G/A-22018 mutations of the lactase-phlorizin hydrolase (LCT) gene in adult-type hypolactasia. Braz J Med Biol Res 2007 Nov; 40(11):1441–6. Not relevant to key questions
306. Bull NL, Barber SA. Food and nutrient intakes of vegetarians in Britain. Hum Nutr Appl Nutr 1984 Aug; 38(4):288–93. Not relevant to key questions
307. Buller HA, Grand RJ. Lactose intolerance. Annual Review of Medicine 1990; 41:141–8. Not original research
308. Buning C, Genschel J, Jurga J, et al. Introducing genetic testing for adult-type hypolactasia. Digestion 2005; 71(4):245–50. Not relevant to key questions
309. Buning C, Ockenga J, Kruger S, et al. The C/C(-13910) and G/G(-22018) genotypes for adult-type hypolactasia are not associated with inflammatory bowel disease. Scandinavian Journal of Gastroenterology 2003 May; 38(5):538–42. No prevalence data
310. Burger J, Kirchner M, Bramanti B, et al. Absence of the lactase-persistence-associated allele in early Neolithic Europeans. Proc Natl Acad Sci U S A 2007 Mar 6; 104(10):3736–41. Not eligible target population
311. Burgin-Wolff A, Bertele RM, Berger R, et al. A reliable screening test for childhood celiac disease: fluorescent immunosorbent test for gliadin antibodies. A prospective multicenter study. Journal of Pediatrics 1983 May; 102(5):655–60. No prevalence data
312. Burke V. Gastrointestinal symptoms and cow's milk allergy. Aust Paediatr J 1972 Oct; 8(5):231–2. Not relevant to key questions
313. Bursey RF. Burning issues. A guide for patients. Lactose intolerance. Can J Gastroenterol 1999 Mar; 13(2):107. Not relevant to key questions
314. Burton BK, Ben-Yoseph Y, Nadler HL. Lactosyl ceramidosis: deficient activity of neutral beta-galactosidase in liver and cultivated fibroblasts? Clin Chim Acta 1978 Sep 15; 88(3):483–93. Not relevant to key questions
315. Busk HE, Dahlerup B, Lytzen T, et al. The incidence of lactose malabsorption in ulcerative colitis. Scandinavian Journal of Gastroenterology 1975; 10(3):263–5. No prevalence data
316. Buttery JE, Ratnaike RN. Can ethanol be omitted from the lactose absorption test? Clin Biochem 1995 Dec; 28(6):599–601. Not relevant to key questions
317. Buttery JE, Ratnaike RN, Chamberlain BR. A visual screening method for lactose maldigestion. Ann Clin Biochem 1994 Nov; 31 ( Pt 6):566–7. Not relevant to key questions
318. Bye A, Kaasa S, Ose T, et al. The influence of low fat, low lactose diet on diarrhoea during pelvic radiotherapy. Clin-Nutr Vol 11; 1992: 147–53. Not relevant to key questions
319. Bye A, Ose T, Kaasa S. The effect of a low fat, low lactose diet on nutritional status during pelvic radiotherapy. Clin-Nutr Vol 12; 1993: 89–95. Not relevant to key questions
320. Bye A, Ose T, Kaasa S. Quality of life during pelvic radiotherapy. Acta obstetricia et gynecologica Scandinavica Vol 74; 1995: 147–52. Not eligible target population
321. Bye A, Ose T, Kaasa S. Food choice and nutrient intake among patients on a low-fat, low-lactose diet: Experience from a prospective randomized study. Journal of Human Nutrition & Dietetics Vol 12; 1999: 273–85. Not eligible target population
322. Bye A, Ose T, Sundfor K, et al. Effect of low-lactose/low-fat diet during pelvic radiotherapy [abstract]. Clin-Nutr Vol 10; 1991: 12–3. Not relevant to key questions
323. Bye A, Tropé C, Loge JH, et al. Health-related quality of life and occurrence of intestinal side effects after pelvic radiotherapy--evaluation of long-term effects of diagnosis and treatment. Acta oncologica (Stockholm, Sweden) Vol 39; 2000: 173–80. Not eligible target population
324. Bye C, Clubley M, Peck AW. Drowsiness, impaired performance and tricyclic antidepressants drugs. British journal of clinical pharmacology Vol 6; 1978: 155–62. Not lactose intolerance study
325. Bye CE, Claridge R, Peck AW, et al. Evidence for tolerance to the central nervous effects of the histamine antagonist, triprolidine, in man. Eur J Clin Pharmacol Vol 12; 1977: 181–6. Not lactose intolerance study
326. Bye CE, Clubley M, Henson T, et al. Changes in the human light reflex as a measure of the anticholinergic effects of drugs. A comparison with other measures. European journal of clinical pharmacology Vol 15; 1979: 21–5. Not lactose intolerance study
327. Byers KG, Savaiano DA. The myth of increased lactose intolerance in African-Americans. J Am Coll Nutr 2005 Dec; 24(6 Suppl):569S–73S. Review
328. Caballero B, Solomons NW, Torun B. Fecal reducing substances and breath hydrogen excretion as indicators of carbohydrate malabsorption. J Pediatr Gastroenterol Nutr 1983; 2(3):487–90. Not relevant to key questions
329. Caballero B, Solomons NW, Torun B, et al. Calcium metabolism in children recovering from severe protein-energy malnutrition. Journal of pediatric gastroenterology and nutrition Vol 5; 1986: 740–5. Not lactose intolerance study
330. Cade JE, Burley VJ, Greenwood DC. The UK Women's Cohort Study: comparison of vegetarians, fish-eaters and meat-eaters. Public Health Nutr 2004 Oct; 7(7):871–8. Not eligible outcomes
331. Caldwell EF, Mayor LR, Thomas MG, et al. Diet and the frequency of the alanine:glyoxylate aminotransferase Pro11Leu polymorphism in different human populations. Hum Genet 2004 Nov; 115(6):504–9. Not relevant to key questions
332. Caldwell JL, Prazinko BF, Rowe T, et al. Improving daytime sleep with temazepam as a countermeasure for shift lag. Aviation, space, and environmental medicine Vol 74; 2003: 153–63. Not lactose intolerance study
333. Calkins BM, Whittaker DJ, Nair PP, et al. Diet, nutrition intake, and metabolism in populations at high and low risk for colon cancer. Nutrient intake. Am J Clin Nutr 1984 Oct; 40(4 Suppl):896–905. Not eligible outcomes
334. Calloway DH, Chenoweth WL. Utilization of nutrients in milk- and wheat-based diets by men with adequate and reduced abilities to absorb lactose. I. Energy and nitrogen. Am J Clin Nutr 1973 Sep; 26(9):939–51. Not relevant to key questions
335. Calloway DH, Murphy EL, Bauer D. Determination of lactose intolerance by breath analysis. Am J Dig Dis 1969 Nov; 14(11):811–5. Not relevant to key questions
336. Cammà C, Fiorello F, Tinè F, et al. Lactitol in treatment of chronic hepatic encephalopathy. A meta-analysis. Digestive diseases and sciences Vol 38; 1993: 916–22. Not lactose intolerance study
337. Campbell AK, Waud JP, Matthews SB. The molecular basis of lactose intolerance. Sci Prog 2005; 88(Pt 3):157–202. Not relevant to key questions
338. Candan S, Sapci T, Turkmen M, et al. Sucralfate in accelerating post-tonsillectomy wound healing. Marmara Medical Journal Vol 10; 1997: 79–83. Not lactose intolerance study
339. Capano G, Guandalini S, Guarino A, et al. Enteric infections, cow's milk intolerance and parenteral infections in 118 consecutive cases of acute diarrhoea in children. Eur J Pediatr 1984 Sep; 142(4):281–5. Not relevant to key questions
340. Capel LH, McKelvie P. Disodium cromoglycate in hayfever. Lancet Vol 1; 1971: 575–6. Not lactose intolerance study
341. Cappello G, Spezzaferro M, Grossi L, et al. Peppermint oil (Mintoil) in the treatment of irritable bowel syndrome: a prospective double blind placebo-controlled randomized trial. Dig Liver Dis 2007 Jun; 39(6):530–6. Not lactose intolerance
342. Capristo E, Mingrone G, Addolorato G, et al. Effect of a vegetable-protein-rich polymeric diet treatment on body composition and energy metabolism in inactive Crohn's disease. Eur J Gastroenterol Hepatol 2000 Jan; 12(1):5–11. Not relevant to key questions
343. Cardinal BJ, Engels HJ. Ginseng does not enhance psychological well-being in healthy, young adults: results of a double-blind, placebo-controlled, randomized clinical trial. Journal of the American Dietetic Association Vol 101; 2001: 655–60. Not lactose intolerance study
344. Carey WB. "Colic"--primary excessive crying as an infant-environment interaction. Pediatric clinics of North America 1984 Oct; 31(5):993–1005. Review
345. Carlson SJ, Rogers RR, Lombard KA. Effect of a lactase preparation on lactose content and osmolality of preterm and term infant formulas. JPEN J Parenter Enteral Nutr 1991 Sep–Oct; 15(5):564–6. Not relevant to key questions
346. Carpentier G, D'Hondt F, Molla AM, et al. Lactose intolerance following measles. Lancet 1970 Oct 3; 2(7675):725–6. Not relevant to key questions
347. Carrera E, Nesheim MC, Crompton DW. Lactose maldigestion in Ascaris-infected preschool children. American Journal of Clinical Nutrition 1984 Feb; 39(2):255–64. Ineligible number of subjects
348. Carrier J, Fernandez-Bolanos M, Robillard R, et al. Effects of caffeine are more marked on daytime recovery sleep than on nocturnal sleep. Neuropsychopharmacology : official publication of the American College of Neuropsychopharmacology Vol 32; 2007: 964–72. Not lactose intolerance study
349. Carroccio A, Montalto G, Custro N, et al. Evidence of very delayed clinical reactions to cow's milk in cow's milk-intolerant patients. Allergy 2000 Jun; 55(6):574–9. Not lactose intolerance
350. Carroccio A, Scalici C, Maresi E, et al. Chronic constipation and food intolerance: a model of proctitis causing constipation. Scandinavian Journal of Gastroenterology 2005 Jan; 40(1):33‐42. Ineligible number of subjects
351. Carter JP, Furman T, Hutcheson HR. Preeclampsia and reproductive performance in a community of vegans. South Med J 1987 Jun; 80(6):692–7. Not relevant to key questions
352. Casaburi R, Briggs DD, Jr., Donohue JF, et al. The spirometric efficacy of once-daily dosing with tiotropium in stable COPD: A 13-week multicenter trial. Chest Vol 118; 2000: 1294‐302. Not lactose intolerance study
353. Casellas F, Malagelada JR. Applicability of short hydrogen breath test for screening of lactose malabsorption. Dig Dis Sci 2003 Jul; 48(7):1333–8. Not relevant to key questions
354. Caskey DA, Payne-Bose D, Welsh JD, et al. Effects of age on lactose malabsorption in Oklahoma Native Americans as determined by breath H2 analysis. Am J Dig Dis 1977 Feb; 22(2):113–6. Not relevant to key questions
355. Caspary WF. Breath tests. Clin Gastroenterol 1978 May; 7(2):351–74. Not relevant to key questions
356. Caspary WF. Diarrhoea associated with carbohydrate malabsorption. Clin Gastroenterol 1986 Jul; 15(3):631–55. Not relevant to key questions
357. Castiglia PT. Lactose intolerance. J Pediatr Health Care 1994 Jan–Feb; 8(1):36–8. Not relevant to key questions
358. Castillo-Durán C, Perales CG, Hertrampf ED, et al. Effect of zinc supplementation on development and growth of Chilean infants. The Journal of pediatrics Vol 138; 2001: 229–35. Not lactose intolerance study
359. Castillo-Duran C, Solomons NW. Studies on the bioavailability of zinc in humans. IX. Interaction of beef-zinc with iron, calcium and lactose. Nutrition Research Vol 11; 1991: 429‐38. Not lactose intolerance study
360. Castillo-Duran C, Venegas G, Villalobos JC, et al. Trace mineral balance in acute diarrhea of infants. Association to etiological agents and lactose content of formula. Nutrition Research Vol 18; 1998: 799–808. Not relevant to key questions
361. Cavaliere H, Medeiros-Neto G. The anorectic effect of increasing doses of L-tryptophan in obese patients. Eating and weight disorders : EWD Vol 2; 1997: 211–5. Not lactose intolerance study
362. Cavalli-Sforza LT, Menozzi P, Strata A. A model and program for study of a tolerance curve: application to lactose absorption tests. Int J Biomed Comput 1983 Jan; 14(1):31–41. Not relevant to key questions
363. Cavalli-Sforza LT, Strata A, Barone A, et al. Primary adult lactose malabsorption in Italy: regional differences in prevalence and relationship to lactose intolerance and milk consumption. American Journal of Clinical Nutrition 1987 Apr; 45(4):748–54. Not eligible test for lactose malabsorption
364. Ceriani R, Zuccato E, Fontana M, et al. Lactose malabsorption and recurrent abdominal pain in Italian children. J Pediatr Gastroenterol Nutr 1988 Nov–Dec; 7(6):852–7. Not relevant to key questions
365. Ceuterick C, Martin JJ. Diagnostic role of skin or conjunctival biopsies in neurological disorders. An update. J Neurol Sci 1984 Aug; 65(2):179–91. Not relevant to key questions
366. Chakrabarti AK, Johnson SC, Samantray SK, et al. Osteomalacia, myopathy and basilar impression. J Neurol Sci 1974 Oct; 23(2):227–35. Not eligible target population
367. Chalfin D, Holt PR. Lactase deficiency in ulcerative colitis, regional enteritis, and viral hepatitis. Am J Dig Dis 1967 Jan; 12(1):81–7. Not relevant to key questions
368. Challacombe DN, Richardson JM, Edkins S. Anaerobic bacteria and deconjugated bile salts in the upper small intestine of infants with gastrointestinal disorders. Acta Paediatr Scand 1974 Jul; 63(4):581–7. Not relevant to key questions
369. Chan GM, McMurry M, Westover K, et al. Effects of increased dietary calcium intake upon the calcium and bone mineral status of lactating adolescent and adult women. Am J Clin Nutr 1987 Aug; 46(2):319–23. Not eligible outcomes
370. Chandra RK, Pawa RR, Ghai OP. Sugar intolerance in malnourished infants and children. Br Med J 1968 Dec 7; 4(5631):611–3. Not relevant to key questions
371. Chandra RK, Pawa RR, Ghai OP. Disaccharide intolerance in the aetiology of chronic and-or recurrent diarrhoea in young children. Indian J Med Res 1969 Apr; 57(4):713–7. Not relevant to key questions
372. Chandra RK, Singh G, Shridhara B. Effect of feeding whey hydrolysate, soy and conventional cow milk formulas on incidence of atopic disease in high risk infants. Annals of allergy Vol 63; 1989: 102–6. Not relevant to key questions
373. Chandrasekaran R, Kumar V, Moorthy B. Combined lactose-D-xylose tolerance test in infancy. Digestion 1976; 14(3):281–4. Not relevant to key questions
374. Chang MH, Hsu HY, Chen CJ, et al. Lactose malabsorption and small-intestinal lactase in normal Chinese children. J Pediatr Gastroenterol Nutr 1987 May–Jun; 6(3):369–72. Not relevant to key questions
375. Chao CK, Sibley E. PCR-RFLP genotyping assay for a lactase persistence polymorphism upstream of the lactase-phlorizin hydrolase gene. Genet Test 2004 Summer; 8(2):190–3. Not relevant to key questions
376. Charney M, McCracken RD. Intestinal lactase deficiency in adult nonhuman primates: implications for selection pressures in man. Soc Biol 1971 Dec; 18(4):416–21. Not relevant to key questions
377. Cheetham PS. An explanation for variations in the clinical and biochemical symptoms of lysosomal-enzyme deficiency diseases such as GM1 gangliosidosis [proceedings]. Biochem Soc Trans 1979 Oct; 7(5):980–2. Not relevant to key questions
378. Cheetham PS, Dance NE, Robinson D. A benign deficiency of typeB beta-galactosidase in human liver. Clin Chim Acta 1978 Feb 1; 83(1–2):67–74. Not relevant to key questions
379. Chen F, Cole P, Mi Z, et al. Dietary trace elements and esophageal cancer mortality in Shanxi, China. Epidemiology 1992 Sep; 3(5):402–6. Not eligible outcomes
380. Chen ST, Domala Z. Milk tolerance among malnourished school children in Malaysia. Asia Pac J Public Health 1989; 3(4):274–7. Not relevant to key questions
381. Cherry FF, Cooper MD, Stewart RA, et al. Cow versus soy formulas. Comparative evaluation in normal infants. Am J Dis Child 1968 Jun; 115(6):677–92. Not relevant to key questions
382. Chesta J, Antezana C. [Effects of neomycin on intestinal digestion, absorption and fermentation of carbohydrates in patients with liver cirrhosis: evidence for an alternative therapeutic mechanism in hepatic encephalopathy]. Revista médica de Chile Vol 122; 1994: 365–71. Not lactose intolerance study
383. Chiang BL, Sheih YH, Wang LH, et al. Enhancing immunity by dietary consumption of a probiotic lactic acid bacterium (Bifidobacterium lactis HN019): optimization and definition of cellular immune responses. European journal of clinical nutrition Vol 54; 2000: 849–55. Not relevant to key questions
384. Chilson BD, Knickrehm ME. Nutrient intake of college students under two systems of board charges--a la carte vs. contract. J Am Diet Assoc 1973 Nov; 63(5):543–5. Not eligible outcomes
385. Chintu C, Simukoko RB, Snook CR. Lactose tolerance tests in normal healthy Zambian children--a preliminary report. J Trop Med Hyg 1978 Feb–Mar; 81(2–3):46–7. Not relevant to key questions
386. Cho E, Smith-Warner SA, Spiegelman D, et al. Dairy foods, calcium, and colorectal cancer: a pooled analysis of 10 cohort studies. J Natl Cancer Inst 2004 Jul 7; 96(13):1015–22. Not eligible outcomes
387. Cho YW, Oh SY, Han HC, et al. Comparative bronchodilatory activity of cetiedil citrate monohydrate, theophylline, orciprenaline and placebo in adult asthmatics. International journal of clinical pharmacology and biopharmacy Vol 16; 1978: 402–7. Not lactose intolerance study
388. Choi YK, Johlin FC, Jr., Summers RW, et al. Fructose intolerance: an under-recognized problem. American Journal of Gastroenterology 2003 Jun; 98(6):1348–53. No prevalence data
389. Choy EH, Scott DL, Kingsley GH, et al. Control of rheumatoid arthritis by oral tolerance. Arthritis and rheumatism Vol 44; 2001: 1993–7. Not lactose intolerance study
390. Christensen MF. Prevalence of lactose intolerance in children with recurrent abdominal pain. Archives of Disease in Childhood 1978 Aug; 53(8):693. Not original research
391. Christensen MF. Prevalence of lactose intolerance in children with recurrent abdominal pain. Pediatrics 1980 Mar; 65(3):681–2. No prevalence data
392. Christman NT, Hamilton LH. A new chromatographic instrument for measuring trace concentrations of breath-hydrogen. J Chromatogr 1982 May 14; 229(2):259–65. Not relevant to key questions
393. Christomanou H, Jaffe S, Martinius J, et al. Biochemical, genetic, psychometric, and neuropsychological studies in heterozygotes of a family with globoid cell leucodystrophy (Krabbe's disease). Hum Genet 1981; 58(2):179–83. Not relevant to key questions
394. Christopher NL, Bayless TM. Role of the small bowel and colon in lactose-induced diarrhea. Gastroenterology 1971 May; 60(5):845–52. Not relevant to key questions
395. Chua CP. A rational approach to infant feeding in the management of sugar intolerance associated with infantile enteritis. Med J Malaysia 1975 Dec; 30(2):98–101. Not relevant to key questions
396. Chua KL, Seah CS. Lactose intolerance: hereditary or acquired? Effect of prolonged milk feeding. Singapore Med J 1973 Mar; 14(1):29–33. Not relevant to key questions
397. Chugh JC, Dhatt PS, Singh H, et al. Disaccharide intolerance & ICC. VII. Effect of steroid therapy on lactosuria. Indian Pediatr 1987 Feb; 24(2):163–5. Not relevant to key questions
398. Chung CM, Kong YF. No evidence of lactase deficiency related to phototherapy of jaundiced infants. N Engl J Med 1976 Dec 23; 295(26):1483. Not relevant to key questions
399. Chung MH, McGill DB. Lactase deficiency in Orientals. Gastroenterology 1968 Feb; 54(2):225–6. Not relevant to key questions
400. Cicco R, Holzman IR, Brown DR, et al. Glucose polymer tolerance in premature infants. Pediatrics 1981 Apr; 67(4):498–501. Not relevant to key questions
401. Ciclitira PJ, Machell RJ, Farthing JG, et al. Double-blind controlled trial of cimetidine in the healing of gastric ulcer. Gut Vol 20; 1979: 730–4. Not lactose intolerance study
402. Cirla AM, Sforza N, Roffi GP, et al. Preseasonal intranasal immunotherapy in birch-alder allergic rhinitis. A double-blind study. Allergy Vol 51; 1996: 299–305. Not lactose intolerance study
403. Clarke AD, Podmore DA. The enzymatic determination of lactic acid in faeces in glycosidase deficiency. Clin Chim Acta 1966 Jun; 13(6):725–30. Not relevant to key questions
404. Clemente YF, Tapia CC, Comino AL, et al. [Lactose-free formula versus adapted formula in acute infantile diarrhea]. Anales españoles de pediatría Vol 39; 1993: 309–12. Not English language
405. Cline MJ, Williams HE, Smith LH, Jr. Lactose intolerance. Calif Med 1967 Oct; 107(4):350‐ 4. Not relevant to key questions
406. Clubley M, Bye CE, Henson T, et al. A technique for studying the effects of drugs on human sweat gland activity. Eur J Clin Pharmacol Vol 14; 1978: 221–6. Not lactose intolerance study
407. Cochet B, Jung A, Griessen M, et al. Effects of lactose on intestinal calcium absorption in normal and lactase-deficient subjects. Gastroenterology 1983 May; 84(5 Pt 1):935–40. Not eligible outcomes
408. Cochran M, Nordin BE. Panhypopituitarism, testicular atrophy, alactasia, corticosteroid-induced osteoporosis and systemic lupus erythematosus induced by methoin. Proc R Soc Med 1968 Jul; 61(7):656. Not eligible target population
409. Coda BA, Mackie A, Hill HF. Influence of alprazolam on opioid analgesia and side effects during steady-state morphine infusions. Pain Vol 50; 1992: 309–16. Not lactose intolerance study
410. Coello-Ramirez P, Gutierres-Topete G, Lifshitz F. Pneumatosis intestinalis. Am J Dis Child 1970 Jul; 120(1):3–9. Not relevant to key questions
411. Coello-Ramirez P, Larrosa-Haro A. Gastrointestinal occult hemorrhage and gastroduodenitis in cow's milk protein intolerance. J Pediatr Gastroenterol Nutr 1984 Mar; 3(2):215–8. Not relevant to key questions
412. Coello-Ramirez P, Lifshitz F. Enteric microflora and carbohydrate intolerance in infants with diarrhea. Pediatrics 1972 Feb; 49(2):233–42. Not relevant to key questions
413. Cohen L. Lactase deficiency: helping patients cope. J Pract Nurs 1991 Dec; 41(4):59–61. Not relevant to key questions
414. Cohen MB, Mezoff AG, Laney DW, et al. Use of a single solution for oral rehydration and maintenance therapy of infants with diarrhea and mild to moderate dehydration. Pediatrics Vol 95; 1995: 639–45. Not relevant to key questions
415. Cole ET, Scott RA, Connor AL, et al. Enteric coated HPMC capsules designed to achieve intestinal targeting. International journal of pharmaceutics Vol 231; 2002: 83–95. Not lactose intolerance study
416. Collomp K, Le PB, Portier H, et al. Effects of acute salbutamol intake during a Wingate test. International journal of sports medicine Vol 26; 2005: 513–7. Not lactose intolerance study
417. Colomina MJ, Puig L, Godet C, et al. Prevalence of asymptomatic cardiac valve anomalies in idiopathic scoliosis. Pediatric Cardiology 2002 Jul–Aug; 23(4):426–9. No prevalence data
418. Colton T, Gosselin RE, Smith RP. The tolerance of coffee drinkers to caffeine. Clinical pharmacology and therapeutics Vol 9; 1968: 31–9. Not lactose intolerance study
419. Condon JR, Nassim JR, Millard FJ, et al. Calcium and phosphorus metabolism in relation to lactose tolerance. Lancet 1970 May 16; 1(7655):1027–9. Not eligible outcomes
420. Condon JR, Westerholm P, Tanner NC. Lactose malabsorption and postgastrectomy milk intolerance, dumping, and diarrhoea. Gut 1969 Apr; 10(4):311–4. Not eligible target population
421. Conley ME, Anolik R. The baby who refused to walk. Hospital Practice (Office Edition) 1981 Dec; 16(12):109. Ineligible number of subjects
422. Cook GC. Jejunal disaccharidiases in Uganda. East Afr Med J 1966 Nov; 43(11):554–7. Not relevant to key questions
423. Cook GC. Malabsorption. Br Med J 1967 Mar 11; 1(5540):613–7. Not relevant to key questions
424. Cook GC. Lactase activity in newborn and infant Baganda. Br Med J 1967 Mar 4; 1(5539):527–30. Not relevant to key questions
425. Cook GC. Defects of sugar absorption. Some observations on racial lactase deficiency. Proc R Soc Med 1968 Nov; 61(11 Part 1):1102–4. Not relevant to key questions
426. Cook GC. Some factors influencing absorption rates of the digestion products of protein and carbohydrate from the proximal jejunum of man and their possible nutritional implications. Gut 1974 Mar; 15(3):239–45. Not relevant to key questions
427. Cook GC. Serum cholesterol concentration in Arabs in Riyadh Saudi Arabia, and its relation to adult hypolactasia. Trop Geogr Med 1976 Dec; 28(4):339–42. Not relevant to key questions
428. Cook GC. Breath hydrogen concentrations after oral lactose and lactulose in tropical malabsorption and adult hypolactasia. Trans R Soc Trop Med Hyg 1978; 72(3):277–81. Not relevant to key questions
429. Cook GC. Intestinal lactase status of adults in Papua New Guinea. Ann Hum Biol 1979 Jan–Feb; 6(1):55–8. Not relevant to key questions
430. Cook GC, Dahlqvist A. Jejunal hetero-beta-galactosidase activities in Ugandans with lactase deficiency. Gastroenterology 1968 Sep; 55(3):328–32. Not relevant to key questions
431. Cook GC, Howells GR. Lactosuria in the African with lactase deficiency. Am J Dig Dis 1968 Jul; 13(7):634–7. Not relevant to key questions
432. Cook GC, Kajubi SK. Tribal incidence of lactase deficiency in Uganda. Lancet 1966 Apr 2; 1(7440):725–9. Not relevant to key questions
433. Cook GC, Lakin A, Whitehead RG. Absorption of lactose and its digestion products i the normal and malnourished Ugandan. Gut 1967 Dec; 8(6):622–7. Not relevant to key questions
434. Cook GC, Lee FD. The jejunum after kwashiorkor. Lancet 1966 Dec 10; 2(7476):1263–7. Not relevant to key questions
435. Cooke WT. Common problems of malabsorption. Practitioner 1976 Jun; 216(1296):637–41. Not relevant to key questions
436. Cooke WT, Asquith P, Ruck N, et al. Rickets, growth, and alkaline phosphatase in urban adolescents. Br Med J 1974 May 11; 2(5914):293–7. Not eligible target population
437. Cooper BT. Lactase deficiency and lactose malabsorption. Dig Dis 1986; 4(2):72–82. Not relevant to key questions
438. Cooper GS, Busby MG, Fairchild AP. Measurement of lactose consumption reliability and comparison of two methods. Annals of Epidemiology Vol 5; 1995: 473–7. Not eligible outcomes
439. Corazza GR, Benati G, Sorge M, et al. beta-Galactosidase from Aspergillus niger in adult lactose malabsorption: a double-blind crossover study. Aliment Pharmacol Ther 1992 Feb; 6(1):61–6. Not relevant to key questions
440. Corazza GR, Ginaldi L, Furia N, et al. The impact of HIV infection on lactose absorptive capacity. Journal of Infection 1997 Jul; 35(1):31–5. Ineligible number of subjects
441. Corazza GR, Sorge M, Strocchi A, et al. Methodology of the H2 breath test. II. Importance of the test duration in the diagnosis of carbohydrate malabsorption. Ital J Gastroenterol 1990 Oct; 22(5):303–5. Not relevant to key questions
442. Cordano A, Grahma GG. Copper deficiency complicating severe chronic intestinal malabsorption. Pediatrics 1966 Oct; 38(4):596–604. Not eligible target population
443. Coremans G, Geypens B, Vos R, et al. Influence of continuous isobaric rectal distension on gastric emptying and small bowel transit in young healthy women. Neurogastroenterology and motility : the official journal of the European Gastrointestinal Motility Society Vol 16; 2004: 107–11. Not lactose intolerance
444. Coremans G, Vos R, Margaritis V, et al. Small doses of the unabsorbable substance polyethylene glycol 3350 accelerate oro-caecal transit, but slow gastric emptying in healthy subjects. Digestive and liver disease : official journal of the Italian Society of Gastroenterology and the Italian Association for the Study of the Liver Vol 37; 2005: 97–101. Not lactose intolerance
445. Corkey C, Mindorff C, Levison H, et al. Comparison of three different preparations of disodium cromoglycate in the prevention of exercise-induced bronchospasm: a double-blind study. The American review of respiratory disease Vol 125; 1982: 623–6. Not lactose intolerance study
446. Costongs GM, Bos LP, Engels LG, et al. A new method for chemical analysis of faeces. Clin Chim Acta 1985 Aug 30; 150(3):197–203. Not relevant to key questions
447. Cox JA, Elliott FG. Primary adult lactose intolerance in the Kivu Lake area: Rwanda and the Bushi. Am J Dig Dis 1974 Aug; 19(8):714–24. Not relevant to key questions
448. Coyne MJ, Rodriguez H. Carbohydrate malabsorption in black and Hispanic dialysis patients. Am J Gastroenterol 1986 Aug; 81(8):662–5. Not relevant to key questions
449. Craig O. The radiology of small bowel lesions. Postgrad Med J 1970 Jan; 46(531):44–51. Not relevant to key questions
450. Craig RP. The quantitative evaluation of the use of oral proteolytic enzymes in the treatment of sprained ankles. Injury Vol 6; 1975: 313–6. Not lactose intolerance study
451. Cramer DW, Xu H, Sahi T. Adult hypolactasia, milk consumption, and age-specific fertility. American Journal of Epidemiology 1994 Feb 1; 139(3):282–9. Not original research
452. Crawford MA. Lactase deficiency. Nature 1969 Aug 16; 223(5207):742. Not relevant to key questions
453. Creagan ET, Moertel CG, O'Fallon JR, et al. Failure of high-dose vitamin C (ascorbic acid) therapy to benefit patients with advanced cancer. A controlled trial. The New England journal of medicine Vol 301; 1979: 687–90. Not lactose intolerance study
454. Crisp J, Ostrander C, Giannini A, et al. Cromolyn sodium therapy for chronic perennial asthma. A double-blind study of 40 children. JAMA : the journal of the American Medical Association Vol 229; 1974: 787–9. Not lactose intolerance study
455. Crittenden RG, Bennett LE. Cow's milk allergy: a complex disorder. J Am Coll Nutr 2005 Dec; 24(6 Suppl):582S–91S. Not eligible target population
456. Croagh C, Shepherd SJ, Berryman M, et al. Pilot study on the effect of reducing dietary FODMAP intake on bowel function in patients without a colon. Inflammatory Bowel Diseases 2007 Dec; 13(12):1522–8. Ineligible number of subjects
457. Cuddenec Y, Delbruck H, Flatz G. Distribution of the adult lactase phenotypes--lactose absorber and malabsorber--in a group of 131 army recruits. Gastroenterol Clin Biol 1982 Oct; 6(10):776–9. Not relevant to key questions
458. Curtis JA, Kooh SW, Fraser D, et al. Nutritional rickets in vegetarian children. Can Med Assoc J 1983 Jan 15; 128(2):150–2. Not eligible target population
459. Cuvelier A, Muir JF, Benhamou D, et al. Dry powder ipratropium bromide is as safe and effective as metered-dose inhaler formulation: a cumulative dose-response study in chronic obstructive pulmonary disease patients. Respiratory care Vol 47; 2002: 159–66. Not lactose intolerance study
460. Czernichow B, Cui SW, Goldstein L, et al. Delayed effects of protracted or single yoghurt and saccharomyces boulaardii ingestion on lactose absorption in a lactase deficiency Chinese population [abstract]. Clin-Nutr Vol 12; 1993: 45. Not relevant to key questions
461. Czerwenka H, Maly J, Quatember R, et al. [Clinical and test psychological studies with a geriatric agent]. Wiener medizinische Wochenschrift (1946) Vol 120; 1970: 217–24. Not lactose intolerance study
462. Dady IM, Thomas AG, Miller V, et al. Inflammatory bowel disease in infancy: an increasing problem? Journal of Pediatric Gastroenterology & Nutrition 1996 Dec; 23(5):569–76. Ineligible number of subjects
463. Dagan R, Gorodischer R, Moses S, et al. Lactose-free formulae for infantile diarrhoea. Lancet Vol 1; 1980: 207. Not relevant to key questions
464. Dagnelie PC, van Staveren WA. Macrobiotic nutrition and child health: results of a population-based, mixed-longitudinal cohort study in The Netherlands. Am J Clin Nutr 1994 May; 59(5 Suppl):1187S–96S. Not eligible outcomes
465. Dagnelie PC, van Staveren WA, Roos AH, et al. Nutrients and contaminants in human milk from mothers on macrobiotic and omnivorous diets. Eur J Clin Nutr 1992 May; 46(5):355–66. Not relevant to key questions
466. Dagnelie PC, Vergote FJ, van Staveren WA, et al. High prevalence of rickets in infants on macrobiotic diets. Am J Clin Nutr 1990 Feb; 51(2):202–8. Not eligible target population
467. Dahlqvist A. Sugar malabsorption. Scand J Clin Lab Invest Suppl 1967; 100:96. Not relevant to key questions
468. Dahlqvist A. Assay of intestinal disaccharidases. Enzymol Biol Clin (Basel) 1970; 11(1):52‐66. Not relevant to key questions
469. Dahlqvist A. The role of enzymes in the digestive tract. Prog Clin Biol Res 1981; 77:883–91. Not relevant to key questions
470. Dahlqvist A, Asp NG. Accurate assay of low intestinal lactase activity with a fluorometric method. Anal Biochem 1971 Dec; 44(2):654–7. Not relevant to key questions
471. Dahlqvist A, Hammond JB, Crane RK, et al. Intestinal lactase deficiency and lactose intolerance in adults. Preliminary report. Gastroenterology 1968 Apr; 54(4):Suppl:807–10. Not relevant to key questions
472. Dahlqvist A, Lindberg T, Meeuwisse G, et al. Intestinal dipeptidases and disaccharidases in children with malabsorption. Acta Paediatr Scand 1970 Nov; 59(6):621–30. Not relevant to key questions
473. Dahlstrom KA, Danielsson L, Kalin M, et al. Chronic non-specific diarrhea of infancy successfully treated with trimethoprim-sulfamethoxazole. Scandinavian journal of gastroenterology 1989 Jun; 24(5):589–92. Not relevant to key questions
474. Dahlström KA, Danielsson L, Kalin M, et al. Chronic non-specific diarrhea of infancy successfully treated with trimethoprim-sulfamethoxazole. Scandinavian journal of gastroenterology Vol 24; 1989: 589–92. Not relevant to key questions
475. Danchaivijitr A, Nakornchai S, Thaweeboon B, et al. The effect of different milk formulas on dental plaque pH. International journal of paediatric dentistry / the British Paedodontic Society [and] the International Association of Dentistry for Children Vol 16; 2006: 192–8. Not eligible outcomes
476. Dandona P, Mohiuddin J, Weerakoon JW, et al. Persistence of parathyroid hypersecretion after vitamin D treatment in Asian vegetarians. J Clin Endocrinol Metab 1984 Sep; 59(3):535–7. Not eligible outcomes
477. Danovitch SH. Gastrointestinal function after forty. Am Fam Physician 1984 Feb; 29(2):205‐10. Not relevant to key questions
478. Darling P, Lepage G, Tremblay P, et al. Protein quality and quantity in preterm infants receiving the same energy intake. American journal of diseases of children (1960) Vol 139; 1985: 186–90. Not relevant to key questions
479. Davey GK, Spencer EA, Appleby PN, et al. EPIC-Oxford: lifestyle characteristics and nutrient intakes in a cohort of 33 883 meat-eaters and 31 546 non meat-eaters in the UK. Public Health Nutr 2003 May; 6(3):259–69. Not eligible outcomes
480. Davidson GP. Lactase deficiency. Diagnosis and management. Med J Aust 1984 Sep 29; 141(7):442–4. Not relevant to key questions
481. Davidson GP. Cow's milk protein intolerance: diagnosis and management. Aust Fam Physician 1986 Feb; 15(2):204, 7. Not relevant to key questions
482. Davidson GP, Goodwin D, Robb TA. Incidence and duration of lactose malabsorption in children hospitalized with acute enteritis: study in a well-nourished urban population. J Pediatr 1984 Oct; 105(4):587–90. Not relevant to key questions
483. Davidson GP, Robb TA. Value of breath hydrogen analysis in management of diarrheal illness in childhood: comparison with duodenal biopsy. J Pediatr Gastroenterol Nutr 1985 Jun; 4(3):381–7. Not relevant to key questions
484. Davie I, Masson AH. An assessment of the analgesic efficacy of oral pentazocine. British journal of anaesthesia Vol 42; 1970: 169–73. Not lactose intolerance study
485. Davis AE. Irritable colon syndrome and lactose intolerance. Aust N Z J Med 1971 Nov; 1(4):420–1. Not relevant to key questions
486. Davis AE. Alactasia. Med J Aust 1972 Aug 19; 2(8):431–2. Not relevant to key questions
487. Davis AE, Bolin T. Lactose intolerance in asians. Nature 1967 Dec 23; 216(5121):1244–5. Not relevant to key questions
488. Davis AE, Bolin TD. Lactose intolerance in Asians. Gut 1969 Jan; 10(1):78. Not relevant to key questions
489. Davis FA, Stefoski D, Rush J. Orally administered 4-aminopyridine improves clinical signs in multiple sclerosis. Annals of neurology Vol 27; 1990: 186–92. Not lactose intolerance study
490. Davis JW, Novotny R, Ross PD, et al. Anthropometric, lifestyle and menstrual factors influencing size-adjusted bone mineral content in a multiethnic population of premenopausal women. J Nutr 1996 Dec; 126(12):2968–76. Not eligible outcomes
491. Dawson B, Trapp RG. Basic & Clinical Biostatistics (LANGE Basic Science). 3rd ed. New York: Lange Medical Books-McGraw-Hill; 2004. Custom 3
492. D'Azzo A, Hoogeveen A, Reuser AJ, et al. Molecular defect in combined beta-galactosidase and neuraminidase deficiency in man. Proc Natl Acad Sci U S A 1982 Aug; 79(15):4535–9. Not relevant to key questions
493. de Gast-Bakker DA, van Vliet I, Alles M, et al. Intestinal permeability and lactase activity in premature infants receiving enteral IGF-I supplementation, a randomized controlled trial. Pediatric research Vol 55; 2004: 99. Not relevant to key questions
494. De Giorgio R, Barbara G, Stanghellini V, et al. Diagnosis and therapy of irritable bowel syndrome. Aliment Pharmacol Ther 2004 Jul; 20 Suppl 2:10–22. Not relevant to key questions
495. De Haan P, Lerk CF. The megaloporous system: A novel principle for zero-order drug delivery I. In vitro and in vivo performance. International Journal of Pharmaceutics Vol 31; 1986: 15–24. Not lactose intolerance study
496. De Preter V, Geboes K, Verbrugghe K, et al. The in vivo use of the stable isotope-labelled biomarkers lactose-[15N]ureide and [2H4]tyrosine to assess the effects of pro- and prebiotics on the intestinal flora of healthy human volunteers. The British journal of nutrition Vol 92; 2004: 439–46. Not lactose intolerance
497. De Preter V, Vanhoutte T, Huys G, et al. Effect of lactulose and Saccharomyces boulardii administration on the colonic urea-nitrogen metabolism and the bifidobacteria concentration in healthy human subjects. Alimentary pharmacology & therapeutics Vol 23; 2006: 963–74. Not lactose intolerance
498. De Ritis F, Balestrieri GG, Ruggiero G, et al. High incidence of lactase activity deficiency in small bowel of adults in the Naples area. Pol Arch Med Wewn 1970 Apr–May; 4(4):539–42. Not relevant to key questions
499. De Ritis F, Balestrieri GG, Ruggiero G, et al. High frequency of lactase activity deficiency in small bowel of adults in the Neapolitan area. Enzymol Biol Clin (Basel) 1970; 11(3):263–7. Not relevant to key questions
500. de Villiers FP. A standardized milk tolerance test. J Clin Gastroenterol 1987 Jun; 9(3):320–3. Not relevant to key questions
501. de Villiers FP. Relationship between milk lactose tolerance and body mass in teenage Tswana schoolchildren. South African Medical Journal Suid-Afrikaanse Tydskrif Vir Geneeskunde 1988 Nov 19; 74(10):499–501. Ineligible number of subjects
502. de Villiers FP. The effect of lactose maldigestion on the stools of young Tswana children. J Trop Pediatr 1995 Feb; 41(1):54–6. Not relevant to key questions
503. de Vizia B, Poggi V, Conenna R, et al. Iron absorption and iron deficiency in infants and children with gastrointestinal diseases. Journal of Pediatric Gastroenterology & Nutrition 1992 Jan; 14(1):21–6. No prevalence data
504. de Vrese M, Schrezenmeir J. Probiotics, prebiotics, and synbiotics. Adv Biochem Eng Biotechnol 2008; 111:1–66. Not relevant to key questions
505. de Vrese M, Stegelmann A, Richter B, et al. Probiotics--compensation for lactase insufficiency. Am J Clin Nutr 2001 Feb; 73(2 Suppl):421S–9S. Not relevant to key questions
506. De Vries HA, Adams GM. Electromyographic comparison of single doses of exercise and meprobamate as to effects on muscular relaxation. American journal of physical medicine Vol 51; 1972: 130–41. Not lactose intolerance study
507. de Vries TW, Wierdsma N, van Ede J, et al. Dieting in children referred to the paediatric outpatient clinic. European journal of pediatrics 2001 Oct; 160(10):595–8. Not relevant to key questions
508. Dearlove J, Dearlove B, Pearl K, et al. Dietary lactose and the child with abdominal pain. Br Med J (Clin Res Ed) 1983 Jun 18; 286(6382):1936. Not relevant to key questions
509. Dearlove J, Dearlove B, Pearl K, et al. A measure of aggression among working-class youths. Br-Med-J-Clin-Res-Ed Vol 286; 1983: 1936. Not relevant to key questions
510. Debongnie JC, Newcomer AD, McGill DB, et al. Absorption of nutrients in lactase deficiency. Dig Dis Sci 1979 Mar; 24(3):225–31. Not relevant to key questions
511. Degenhardt DP, Hodgkinson R. Ethaverine in the treatment of angina pectoris. British Heart Journal Vol 16; 1954: 142–6. Not lactose intolerance study
512. DeGrandpre RJ, Bickel WK, Higgins ST. Emergent equivalence relations between interoceptive (drug) and exteroceptive (visual) stimuli. Journal of the experimental analysis of behavior Vol 58; 1992: 9–18. Not lactose intolerance study
513. Dehkordi N, Rao DR, Warren AP, et al. Lactose malabsorption as influenced by chocolate milk, skim milk, sucrose, whole milk, and lactic cultures. J Am Diet Assoc 1995 Apr; 95(4):484–6. Not relevant to key questions
514. Demetree JW, Safer LF, Artis WM. The effect of zinc on the sebum secretion rate. Acta dermato-venereologica Vol 60; 1980: 166–69. Not lactose intolerance study
515. Den Tandt WR, Hooghwinkel GJ. Brain lysosomal enzymes in generalized gangliosidosis and metachromatic leukodystrophy. Acta Neurol (Napoli) 1980 Feb; 2(1):10–4. Not relevant to key questions
516. Densupsoontorn N, Jirapinyo P, Thamonsiri N, et al. Lactose intolerance in Thai adults. J Med Assoc Thai 2004 Dec; 87(12):1501–5. Not relevant to key questions
517. Dent CE, Gupta MM. Plasma 25-hydroxyvitamin-D-levels during pregnancy in Caucasians and in vegetarian and non-vegetarian Asians. Lancet 1975 Nov 29; 2(7944):1057–60. Not eligible outcomes
518. Dent CE, Round JM, Rowe DJ, et al. Effect of chapattis and ultraviolet irradiation on nutritional rickets in an Indian immigrant. Lancet 1973 Jun 9; 1(7815):1282–4. Not eligible target population
519. Dent CE, Smith R. Nutritional osteomalacia. Q J Med 1969 Apr; 38(150):195–209. Not eligible target population
520. Desai AB, Gandhi RA, Vani GB. Lactose intolerance. Indian Pediatr 1969 Jul; 6(7):457–62. Not relevant to key questions
521. Desai HG. Editorial: Intestinal disaccharidases. J Assoc Physicians India 1974 Dec; 22(12):918–20. Editorial
522. Desai HG, Antia FP. Lactose load and abdominal symptoms: should milk be withdrawn from healthy subjects with low lactase levels? Gastroenterology 1973 Jan; 64(1):136–8. Not relevant to key questions
523. Desai HG, Chitre AV, Jeejeebhoy KN. Lactose loading. A simple test for detecting intestinal lactase. Evaluation of different methods. Gastroenterologia 1967; 108(4):177–88. Not relevant to key questions
524. Desai HG, Gupte UV, Pradhan AG, et al. Incidence of lactase deficiency in control subjects from India. Role of hereditary factors. Indian J Med Sci 1970 Nov; 24(11):729–36. Not relevant to key questions
525. Desai HG, Pereira E, Jeejeebhoy KN. Disaccharidases in jejunal and ileal mucosa in Indian subjects. Indian J Med Sci 1969 Oct; 23(10):538–42. Not relevant to key questions
526. Deutschmann HA, Weger M, Weger W, et al. Search for occult secondary osteoporosis: impact of identified possible risk factors on bone mineral density. Journal of Internal Medicine 2002 Nov; 252(5):389–97. No prevalence data
527. Dewit O, Boudraa G, Touhami M, et al. Breath hydrogen test and stools characteristics after ingestion of milk and yogurt in malnourished children with chronic diarrhoea and lactase deficiency. J Trop Pediatr 1987 Aug; 33(4):177–80. Not relevant to key questions
528. Dhatt PS, Aggarwal RK, Saini AS, et al. Disaccharide intolerence and Indian childhood cirrhosis. IV. Relationship of melituria to lactose administration. Indian Pediatr 1982 Jul; 19(7):583–9. Not relevant to key questions
529. Dhonukshe-Rutten RA, van Dusseldorp M, Schneede J, et al. Low bone mineral density and bone mineral content are associated with low cobalamin status in adolescents. Eur J Nutr 2005 Sep; 44(6):341–7. Not eligible exposure
530. Dhume RR, Dhume RA. A comparative study of the driving effects of dextroamphetamine and yogic meditation on muscle control for the performance of balance on balance board. Indian journal of physiology and pharmacology Vol 35; 1991: 191–4. Not lactose intolerance study
531. Di Camillo M, Marinaro V, Argnani F, et al. Hydrogen breath test for diagnosis of lactose malabsorption: the importance of timing and the number of breath samples. Canadian Journal of Gastroenterology 2006 Apr; 20(4):265–8. No prevalence data
532. Di Nola F, Soranzo ML, Bosio G, et al. [Pharmacokinetic and clinical research on a new antibiotic combination (amoxicillin and flucloxacillin in equivalent-weight dose)]. Minerva medica Vol 68; 1977: 917–28. Not lactose intolerance study
533. Di Stefano M, Miceli E, Mazzocchi S, et al. Visceral hypersensitivity and intolerance symptoms in lactose malabsorption. Neurogastroenterol Motil 2007 Nov; 19(11):887–95. Not relevant to key questions
534. Di Stefano M, Missanelli A, Miceli E, et al. Hydrogen breath test in the diagnosis of lactose malabsorption: accuracy of new versus conventional criteria. J Lab Clin Med 2004 Dec; 144(6):313–8. Not relevant to key questions
535. Di Stefano M, Veneto G, Malservisi S, et al. Lactose malabsorption and intolerance in the elderly. Scandinavian Journal of Gastroenterology 2001 Dec; 36(12):1274–8. Ineligible number of subjects
536. Diamond S. Double-blind study of metaxalone; use as skeletal-muscle relaxant. JAMA : the journal of the American Medical Association Vol 195; 1966: 479–80. Not lactose intolerance study
537. Díaz S, Croxatto HB, Pavez M, et al. Clinical assessment of treatments for prolonged bleeding in users of Norplant implants. Contraception Vol 42; 1990: 97–109. Not lactose intolerance study
538. Díaz-Sánchez V, Antúnez O, Vargas L, et al. Absorption of oral ethinylestradiol is delayed by its eutectic mixture with cholesterol. Contraception Vol 43; 1991: 45–53. Not lactose intolerance study
539. Diestelhorst M, Grunthal S, Süverkrüp R. Dry Drops: a new preservative-free drug delivery system. Graefe's archive for clinical and experimental ophthalmology = Albrecht von Graefes Archiv für klinische und experimentelle Ophthalmologie Vol 237; 1999: 394–8. Not lactose intolerance study
540. Dill JE, Levy M, Wells RF, et al. Lactase deficiency in Mexican-American males. Am J Clin Nutr 1972 Sep; 25(9):869–70. Not relevant to key questions
541. Dinnerstein AJ, Halm J. Modification of placebo effects by means of drugs: effects of aspirin and placebos on self-rated moods. Journal of abnormal psychology Vol 75; 1970: 308–14. Not lactose intolerance study
542. DiPalma JA, Collins MS. Enzyme replacement for lactose malabsorption using a beta-D‐galactosidase. J Clin Gastroenterol 1989 Jun; 11(3):290–3. Not relevant to key questions
543. DiPalma JA, Narvaez RM. Prediction of lactose malabsorption in referral patients. Dig Dis Sci 1988 Mar; 33(3):303–7. Not relevant to key questions
544. Dissanayake AS, Truelove SC, Whitehead R. Jejunal mucosal recovery in coeliac disease in relation to the degree of adherence to a gluten-free diet. The Quarterly journal of medicine Vol 43; 1974: 161–85. Not relevant to key questions
545. Donaldson RM, Jr. The muddle of diets for gastrointestinal disorders. JAMA 1973 Sep 3; 225(10):1243. Not relevant to key questions
546. Donovan GK, Torres-Pinedo R. Chronic diarrhea and soy formulas. Inhibition of diarrhea by lactose. American journal of diseases of children (1960) Vol 141; 1987: 1069–71. Not relevant to key questions
547. Donovan UM, Gibson RS. Dietary intakes of adolescent females consuming vegetarian, semi-vegetarian, and omnivorous diets. J Adolesc Health 1996 Apr; 18(4):292–300. Not relevant to key questions
548. Doron S, Gorbach SL. Probiotics: their role in the treatment and prevention of disease. Expert Rev Anti Infect Ther 2006 Apr; 4(2):261–75. Not relevant to key questions
549. Dossetor JF, Whittle HC. Protein-losing enteropathy and malabsorption in acute measles enteritis. Br Med J 1975 Jun 14; 2(5971):592–3. Not relevant to key questions
550. Douwes AC, Fernandes J, Degenhart HJ. Improved accuracy of lactose tolerance test in children, using expired H2 measurement. Arch Dis Child 1978 Dec; 53(12):939–42. Not relevant to key questions
551. Douwes AC, Fernandes J, Jongbloed AA. Diagnostic value of sucrose tolerance test in children evaluated by breath hydrogen measurement. Acta Paediatr Scand 1980 Jan; 69(1):79–82. Not relevant to key questions
552. Douwes AC, Oosterkamp RF, Fernandes J, et al. Sugar malabsorption in healthy neonates estimated by breath hydrogen. Arch Dis Child 1980 Jul; 55(7):512–5. Not relevant to key questions
553. Douwes AC, Schaap C, van der Klei-van Moorsel JM. Hydrogen breath test in schoolchildren. Arch Dis Child 1985 Apr; 60(4):333–7. Not relevant to key questions
554. Doxiadis S, Papageorgiadis G. Lactose intolerance in Greeks. Lancet 1973 Feb 3; 1(7797):271. Not relevant to key questions
555. Drapeau C, Hamel-Hébert I, Robillard R, et al. Challenging sleep in aging: the effects of 200 mg of caffeine during the evening in young and middle-aged moderate caffeine consumers. Journal of sleep research Vol 15; 2006: 133–41. Not lactose intolerance study
556. Drewitt PN, Butterworth KR, Springall CD, et al. Toxicity threshold of quinine hydrochloride following low-level repeated dosing in healthy volunteers. Food and chemical toxicology : an international journal published for the British Industrial Biological Research Association Vol 31; 1993: 235–45. Not lactose intolerance study
557. Drube HC, Hansen HT, Klein UE, et al. Disaccharidase activity of the jejunal mucosa in normal subjects and patients after partial gastrectomy. Ger Med Mon 1967 Sep; 12(9):418–21. Not relevant to key questions
558. Duan LP, Braden B, Clement T, et al. Clinical evaluation of a miniaturized desktop breath hydrogen analyzer. Z Gastroenterol 1994 Oct; 32(10):575–8. Not relevant to key questions
559. Dufourmentel C, Pailheret JP, Raulo Y. [Double-blind trial of a new therapeutic agent with wound healing properties]. Annales de chirurgie plastique Vol 19; 1974: 139–46. Not lactose intolerance study
560. Dughera L, Elia C, Navino M, et al. Effects of symbiotic preparations on constipated irritable bowel syndrome symptoms. Acta Bio-Medica de l Ateneo Parmense 2007 Aug; 78(2):111–6. No prevalence data
561. Duncan A, Park RP, Lee FD, et al. A retrospective assessment of the clinical value of jejunal disaccharidase analysis. Scand J Gastroenterol 1994 Dec; 29(12):1111–6. Not relevant to key questions
562. Duncan IW, Scott EM. Lactose intolerance in Alaskan Indians and Eskimos. Am J Clin Nutr 1972 Sep; 25(9):867–8. Not relevant to key questions
563. Dupont C, Moreno JL, Barau E, et al. Effect of diosmectite on intestinal permeability changes in acute diarrhea: a double-blind placebo-controlled trial. Journal of pediatric gastroenterology and nutrition Vol 14; 1992: 413–9. Not eligible target population
564. Duteil L, Queille C, Poncet M, et al. Processing and statistical analysis of laser Doppler data applied to the assessment of systemic anti-inflammatory drugs. Journal of dermatological science Vol 2; 1991: 376–82. Not lactose intolerance study
565. Dwyer JT. Health aspects of vegetarian diets. Am J Clin Nutr 1988 Sep; 48(3 Suppl):712–38. Review
566. Dwyer JT, Dietz WH, Jr., Hass G, et al. Risk of nutritional rickets among vegetarian children. Am J Dis Child 1979 Feb; 133(2):134–40. Not eligible outcomes
567. Eaglstein WH, Feinstein RJ, Halprin KM, et al. Systemic antibiotic therapy of secondary infected dermatitis. Archives of dermatology Vol 113; 1977: 1378–9. Not lactose intolerance study
568. Eastham EJ, Walker WA. Effect of cow's milk on the gastrointestinal tract: a persistent dilemma for the pediatrician. Pediatrics 1977 Oct; 60(4):477–81. Not relevant to key questions
569. Easton CJ, Bauer LO. Beneficial effects of thiamine on recognition memory and P300 in abstinent cocaine-dependent patients. Psychiatry research Vol 70; 1997: 165–74. Not lactose intolerance study
570. Eastwood MA, Walton BA, Brydon WG, et al. Faecal weight, constituents, colonic motility, and lactose tolerance in the irritable bowel syndrome. Digestion 1984; 30(1):7–12. Not relevant to key questions
571. Ebbesen F, Edelsten D, Hertel J. Gut transit time and lactose malabsorption during phototherapy. II. A study using raw milk from the mothers of the infants. Acta Paediatr Scand 1980 Jan; 69(1):69–71. Not relevant to key questions
572. Ebbesen F, Edelsten D, Hertel J. Gut transit time and lactose malabsorption during phototherapy. I. A study using lactose-free human mature milk. Acta Paediatr Scand 1980 Jan; 69(1):65–8. Not relevant to key questions
573. Ebrahim S. The use of numbers needed to treat derived from systematic reviews and meta‐analysis. Caveats and pitfalls. Eval Health Prof 2001 Jun; 24(2):152–64. Not relevant to key questions
574. Eddington ND, Ashraf M, Augsburger LL, et al. Identification of formulation and manufacturing variables that influence in vitro dissolution and in vivo bioavailability of propranolol hydrochloride tablets. Pharm Dev Technol Vol 3; 1998: 535–47. Not lactose intolerance study
575. Edwards AM, Chambers A. Comparison of a lactose-free formulation of sodium cromoglycate and sodium cromoglycate plus lactose in the treatment of asthma. Current medical research and opinion Vol 11; 1989: 283–92. Not lactose intolerance study
576. Eerikainen S, Leino J, Harjula M, et al. Use of a hard gelatin capsule as a rectal dosage form. S.T.P. Pharma Pratiques. Vol 6; 1996: 435–40. Not lactose intolerance study
577. Egarter C, Eppel W, Vogel S, et al. A pilot study of hormone replacement therapy with tibolone in women with mastopathic breasts. Maturitas Vol 40; 2001: 165–71. Not lactose intolerance study
578. Egger M, Smith GD, Altman DG. Systematic Reviews in Health Care. London: NetLibrary, Inc. BMJ Books; 2001. Custom 3
579. Eichenberger JR, Hadorn B, Schmidt BJ. A semi-elemental diet with low osmolarity and high content of hydrolyzed lactalbumin in the treatment of acute diarrhea in malnourished children. Arquivos de gastroenterologia Vol 21; 1984: 130–5. Not relevant to key questions
580. Elbary AA, El-laithy HM, Tadros MI. Promising ternary dry powder inhaler formulations of cromolyn sodium: formulation and in vitro-in vivo evaluation. Archives of pharmacal research Vol 30; 2007: 785–92. Not lactose intolerance study
581. el-Ebrashy N, Shaheen MH, Wasfi AA, et al. Side effects of IV fructose load in diabetics. J Egypt Med Assoc 1974; 57(9–10):406–14. Not relevant to key questions
582. Eley B. Metabolic complications of antiretroviral therapy in HIV-infected children. Expert Opinion On Drug Metabolism & Toxicology 2008 Jan; 4(1):37–49. Not original research
583. Ellestad-Sayed JJ, Haworth JC. Disaccharide consumption and malabsorption in Canadian Indians. Am J Clin Nutr 1977 May; 30(5):698–703. Not relevant to key questions
584. Ellestad-Sayed JJ, Haworth JC, Hildes JA. Disaccharide malabsorption and dietary patterns in two Canadian Eskimo communities. Am J Clin Nutr 1978 Aug; 31(8):1473–8. Ineligible number of subjects
585. Ellestad-Sayed JJ, Levitt MD, Bond JH. Milk intolerance in Manitoba Indian school children. American Journal of Clinical Nutrition 1980 Oct; 33(10):2198–201. No prevalence data
586. Elliott RB, Maxwell GM. Predominance of lactase of small molecular size in duodenal and jejunal mucosa of Australian aboriginal children. Aust J Exp Biol Med Sci 1966 Dec; 44(6):709–13. Not relevant to key questions
587. Elliott RB, Maxwell GM, Vawser N. Lactose maldigestion in Australian Aboriginal children. Med J Aust 1967 Jan 14; 1(2):46–9. Not relevant to key questions
588. Ellis FR, Holesh S, Ellis JW. Incidence of osteoporosis in vegetarians and omnivores. Am J Clin Nutr 1972 Jun; 25(6):555–8. Not target population
589. Elwood PC, Pickering JE, Hughes J, et al. Milk drinking, ischaemic heart disease and ischaemic stroke II. Evidence from cohort studies. Eur J Clin Nutr 2004 May; 58(5):718–24. Not eligible outcomes
590. Emberlin JC, Lewis RA. A double blind, placebo-controlled cross over trial of cellulose powder by nasal provocation with Der p1 and Der f1. Current medical research and opinion Vol 23; 2007: 2423–31. Not lactose intolerance study
591. Enattah NS, Jensen TG, Nielsen M, et al. Independent introduction of two lactase-persistence alleles into human populations reflects different history of adaptation to milk culture. American Journal of Human Genetics 2008 Jan; 82(1):57–72. Ineligible number of subjects
592. Enattah NS, Sahi T, Savilahti E, et al. Identification of a variant associated with adult-type hypolactasia. Nature Genetics 2002 Feb; 30(2):233–7. No prevalence data
593. Enattah NS, Trudeau A, Pimenoff V, et al. Evidence of still-ongoing convergence evolution of the lactase persistence T-13910 alleles in humans. Am J Hum Genet 2007 Sep; 81(3):615‐25. Not relevant to key questions
594. Enck P, Kremer A, Kuhlbusch R, et al. Prevalence of lactose malabsorption among patients with functional bowel disorders. Zeitschrift fur Gastroenterologie 1990 May; 28(5):239–41. Ineligible number of subjects
595. Engels HJ, Fahlman MM, Wirth JC. Effects of ginseng on secretory IgA, performance, and recovery from interval exercise. Medicine and science in sports and exercise Vol 35; 2003: 690–6. Not lactose intolerance study
596. Englert DM, Guillory JA. For want of lactase. Am J Nurs 1986 Aug; 86(8):902–6. Not relevant to key questions
597. Epstein E, Ugel AR. Effects of topical mechlorethamine on skin lesions of psoriasis. Archives of dermatology Vol 102; 1970: 504–6. Not lactose intolerance study
598. Erasmus HD, Ludwig-Auser HM, Paterson PG, et al. Enhanced weight gain in preterm infants receiving lactase-treated feeds: a randomized, double-blind, controlled trial. The Journal of pediatrics Vol 141; 2002: 532–7. Not eligible target population
599. Ercan N, Nuttall FQ, Gannon MC, et al. Effects of glucose, galactose, and lactose ingestion on the plasma glucose and insulin response in persons with non-insulin-dependent diabetes mellitus. Metab. Clin. Exp. Vol 42; 1993: 1560–7. Not relevant to key questions
600. Erinoso HO, Hoare S, Spencer S, et al. Is cow's milk suitable for the dietary supplementation of rural Gambian children? 1. Prevalence of lactose maldigestion. Annals of Tropical Paediatrics 1992; 12(4):359–65. Subjects less than 4 years old
601. Escoboza PM, Fernandes MI, Peres LC, et al. Adult-type hypolactasia: clinical, morphologic and functional characteristics in Brazilian patients at a university hospital. Journal of Pediatric Gastroenterology & Nutrition 2004 Oct; 39(4):361–5. Not population based study
602. Eto Y, Owada M, Kitagawa T, et al. Neurochemical abnormality in I-cell disease: chemical analysis and a possible importance of beta-galactosidase deficiency. J Neurochem 1979 Feb; 32(2):397–405. Not relevant to key questions
603. Evans R. Therapeutic diets for children. Nursing (Lond) 1980 Apr; (12):527–30. Not relevant to key questions
604. Evans WO, Witt NF. The interaction of high altitude and psychotropic drug action. Psychopharmacologia Vol 10; 1966: 184–8. Not lactose intolerance study
605. Ewe K, Ueberschaer B, Press AG, et al. Effect of lactose, lactulose and bisacodyl on gastrointestinal transit studied by metal detector. Alimentary pharmacology & therapeutics Vol 9; 1995: 69–73. Not relevant to key questions
606. Fagundes-Neto U, Scaletsky IC. The gut at war: the consequences of enteropathogenic Escherichia coli infection as a factor of diarrhea and malnutrition. Sao Paulo medical journal = Revista paulista de medicina 2000 Jan 6; 118(1):21–9. Review
607. Fagundes-Neto U, Viaro T, Lifshitz F. Tolerance to glucose polymers in malnourished infants with diarrhea and disaccharide intolerance. Am J Clin Nutr 1985 Feb; 41(2):228–34. Not relevant to key questions
608. Fahr K, Nutzenadel W. Lactose-free diet by acute enteritis in infants. Monatsschrift fur Kinderheilkunde Vol 124; 1976: 389–90. Not relevant to key questions
609. Faiz S, Panunti B, Andrews S. The epidemic of vitamin D deficiency. Journal of the Louisiana State Medical Society 2007 Jan–Feb; 159(1):17–20; quiz Ineligible number of subjects
610. Fajardo O, Naim HY, Lacey SW. The polymorphic expression of lactase in adults is regulated at the messenger RNA level.[see comment]. Gastroenterology 1994 May; 106(5):1233–41. Ineligible number of subjects
611. Falcoz C, Oliver R, McDowall JE, et al. Bioavailability of orally administered micronised fluticasone propionate. Clinical pharmacokinetics Vol 39; 2000: 9–15. Not lactose intolerance study
612. Farnworth ER. The evidence to support health claims for probiotics. J Nutr 2008 Jun; 138(6):1250S–4S. Not relevant to key questions
613. Fayad IM, Hashem M, Hussein A, et al. Comparison of soy-based formulas with lactose and with sucrose in the treatment of acute diarrhea in infants. Archives of pediatrics & adolescent medicine Vol 153; 1999: 675–80. Not relevant to key questions
614. Fehily AM, Coles RJ, Evans WD, et al. Factors affecting bone density in young adults. Am J Clin Nutr 1992 Sep; 56(3):579–86. Not eligible outcomes
615. Feigenberg M, Sotman JW. A toddler with a malabsorption syndrome. Am J Nurs 1975 Jun; 75(6):978–9. Not relevant to key questions
616. Feitelson M, Fitz P, Rovezzi-Carroll S, et al. Enteral nutrition practices: similarities and differences between dietitians and physicians in Connecticut. Journal of the American Dietetic Association 1987 Oct; 87(10):1363–8. Not relevant to key questions
617. Ferencík M, Ebringer L, Mikes Z, et al. [Successful modification of human intestinal microflora with oral administration of lactic acid bacteria]. Bratislavské lekárske listy Vol 100; 1999: 238–45. Not English language
618. Ferguson A, Downie WW. Gastrointestinal amyloidosis in psoriatic arthritis. Ann Rheum Dis 1968 May; 27(3):245–8. Not relevant to key questions
619. Fernandes J, Vos CE, Douwes AC, et al. Respiratory hydrogen excretion as a parameter for lactose malabsorption in children. Am J Clin Nutr 1978 Apr; 31(4):597–602. Not relevant to key questions
620. Fernandez-Banares F, Rosinach M, Esteve M, et al. Sugar malabsorption in functional abdominal bloating: a pilot study on the long-term effect of dietary treatment. Clin Nutr 2006 Oct; 25(5):824–31. Not relevant to key questions
621. Ferrara M, Coppola L, Coppola A, et al. Iron deficiency in childhood and adolescence: retrospective review. Hematology 2006 Jun; 11(3):183–6. No prevalence data
622. Ferrari AM, Montano A, Ferolla MC, et al. [Acute diarrheal disease. Refeeding with a low lactose milk.]. Arch. Pediatr. Uruguay Vol 58; 1987: 221–3. Not English language
623. Ferris B, Green OC. Pregnanediol excretion by newly born infants. Am J Dis Child 1968 Jun; 115(6):693–7. Not relevant to key questions
624. Ficicioglu C, Thomas N, Yager C, et al. Duarte (DG) galactosemia: a pilot study of biochemical and neurodevelopmental assessment in children detected by newborn screening. Molecular Genetics & Metabolism 2008 Dec; 95(4):206–12. Not relevant to key questions
625. Fiddes PJ, Baume P. Disaccharidase deficiency in regional enteritis. Australas Ann Med 1967 Nov; 16(4):339–42. Not relevant to key questions
626. Fielding JF. The half-hour lactose "tolerance" test in adults. Ir Med J 1980 Jan; 73(1):21–2. Not relevant to key questions
627. Fielding JF. The value of a second oral lactose tolerance test in detecting hypolactasia. Ir J Med Sci 1981 Jul; 150(7):210–2. Not relevant to key questions
628. Fielding JF, Baynes S, Fottrell PJ. The lactose tolerance test and intestinal lactase activity. Ir J Med Sci 1983 May; 152(5):196–8. Not relevant to key questions
629. Fielding JF, Harrington MG, Fottrell PF. The incidence of primary hypolactasia amongst native Irish. Ir J Med Sci 1981 Sep; 150(9):276–7. Not relevant to key questions
630. Fielding JF, Harrington MG, Fottrell PF. Hypolactasia and the irritable bowel syndrome in Ireland. Ir Med J 1982 Oct; 75(10):377–8. Not relevant to key questions
631. Fields JZ, Turk A, Durkin M, et al. Increased gastrointestinal symptoms in chronic alcoholics. American Journal of Gastroenterology 1994 Mar; 89(3):382–6. No prevalence data
632. Figueroa RB, Melgar E, Jo N, et al. Intestinal lactase deficiency in an apparently normal Peruvian population. Am J Dig Dis 1971 Oct; 16(10):881–9. Not relevant to key questions
633. Filippski GK, Tsaplin I, Voznenko AA. [Urinary lactose determination]. Klinicheskaia laboratornaia diagnostika; 1994: 40. Not English language
634. Filippvski GK, Klimov L. [Glycoprotein hexoses in feces of infants with lactose intolerance]. Klinicheskaia laboratornaia diagnostika; 1995: 20–1. Not English language
635. Finch PJ, Ang L, Colston KW, et al. Blunted seasonal variation in serum 25-hydroxy vitamin D and increased risk of osteomalacia in vegetarian London Asians. Eur J Clin Nutr 1992 Jul; 46(7):509–15. Not eligible target population
636. Fine A, Willoughby E, McDonald GS, et al. A family with intolerance to lactose and cold milk. Ir J Med Sci 1968 Jul; 7(7):321–6. Not relevant to key questions
637. Finley DA, Dewey KG, Lonnerdal B, et al. Food choices of vegetarians and nonvegetarians during pregnancy and lactation. J Am Diet Assoc 1985 Jun; 85(6):678–85. Not relevant to key questions
638. Finley DA, Lonnerdal B, Dewey KG, et al. Inorganic constituents of breast milk from vegetarian and nonvegetarian women: relationships with each other and with organic constituents. J Nutr 1985 Jun; 115(6):772–81. Not relevant to key questions
639. Fiocchi A, Restani P, Leo G, et al. Clinical tolerance to lactose in children with cow's milk allergy. Pediatrics 2003 Aug; 112(2):359–62. Not relevant to key questions
640. Fischer TJ, Guilfoile TD, Kesarwala HH, et al. Adverse pulmonary responses to aspirin and acetaminophen in chronic childhood asthma. Pediatrics Vol 71; 1983: 313–8. Not lactose intolerance study
641. Fischer-Rasmussen W, Kjaer SK, Dahl C, et al. Ginger treatment of hyperemesis gravidarum. European journal of obstetrics, gynecology, and reproductive biology Vol 38; 1991: 19–24. Not lactose intolerance study
642. Fisher M. Vegan pregnancy. Midwifery Today Int Midwife 1999 Winter; (52):30–3. Not eligible outcomes
643. Fisher SE, Markowitz J, Lifshitz F. Food intolerance in childhood. Compr Ther 1984 May; 10(5):5–11. Not relevant to key questions
644. Flasch H, Asmussen B, Heinz N. [Enhanced bioavailability of digoxin from silica matrix formulations (author's transl)]. Arzneimittel-Forschung Vol 28; 1978: 326–30. Not lactose intolerance study
645. Flaten MA, Simonsen T, Olsen H. Drug-related information generates placebo and nocebo responses that modify the drug response. Psychosomatic Medicine Vol 61; 1999: 250–5. Not lactose intolerance study
646. Flaten MA, Simonsen T, Zahlsen K, et al. Stimulant and relaxant drugs combined with stimulant and relaxant information: a study of active placebo. Psychopharmacology Vol 176; 2004: 426–34. Not lactose intolerance study
647. Flatz G. Ethnic differences in reactions to drugs and xenobiotics. Problems perceived in Asia. Prog Clin Biol Res 1986; 214:55–7. Not relevant to key questions
648. Flatz G, Bernsau I, Behrens A. Lactose absorption and malabsorption in healthy German children: improved phenotypic resolution by simultaneous determination of breath hydrogen and carbon dioxide. Eur J Pediatr 1982 Jul; 138(4):304–6. Not relevant to key questions
649. Flatz G, Henze HJ, Palabiyikoglu E, et al. Distribution of the adult lactase phenotypes in Turkey. Trop Geogr Med 1986 Sep; 38(3):255–8. Not relevant to key questions
650. Flatz G, Howell JN, Doench J, et al. Distribution of physiological adult lactase phenotypes, lactose absorber and malabsorber, in Germany. Hum Genet 1982; 62(2):152–7. Not relevant to key questions
651. Flatz G, Kuhnau W, Naftali D. Breath hydrogen test for lactose absorption capacity: importance of timing of hydrogen excretion and of high fasting hydrogen concentration. Am J Clin Nutr 1984 May; 39(5):752–5. Not relevant to key questions
652. Flatz G, Lie GH. Effect of acetylsalicylic acid on symptoms and hydrogen excretion in the disaccharide tolerance test with lactose or lactulose. Am J Clin Nutr 1982 Feb; 35(2):273–6. Not relevant to key questions
653. Flatz G, Rotthauwe HW. Evidence against nutritional adaption of tolerance to lactose. Humangenetik 1971; 13(2):118–25. Not relevant to key questions
654. Flatz G, Rotthauwe HW. Lactose nutrition and natural selection. Lancet 1973 Jul 14; 2(7820):76–7. Comment
655. Flatz G, Rotthauwe HW. The human lactase polymorphism: physiology and genetics of lactose absorption and malabsorption. Prog Med Genet 1977; 2:205–49. Not relevant to key questions
656. Flatz G, Saengudom C. Lactose tolerance in Asians: a family study. Nature 1969 Nov 29; 224(5222):915–6. Not relevant to key questions
657. Flatz G, Saengudom C, Sanguanbhokhai T. Lactose intolerance in Thailand. Nature 1969 Feb 22; 221(5182):758–9. Not relevant to key questions
658. Flatz G, Schildge C, Sekou H. Distribution of adult lactase phenotypes in the Tuareg of Niger. Am J Hum Genet 1986 Apr; 38(4):515–9. Not relevant to key questions
659. Fleming SC. Evaluation of a hand-held hydrogen monitor in the diagnosis of intestinal lactase deficiency. Ann Clin Biochem 1990 Sep; 27 ( Pt 5):499–500. Not relevant to key questions
660. Fluge G, Aksnes L. Influence of cow's milk proteins and gluten on human duodenal mucosa in organ culture. J Pediatr Gastroenterol Nutr 1990 Nov; 11(4):481–8. Not relevant to key questions
661. Flynn MA, Irvin W, Krause G. The effect of folate and cobalamin on osteoarthritic hands. J. Am. Coll. Nutr. Vol 13; 1994: 351–6. Not lactose intolerance study
662. Forget P, Lombet J, Grandfils C, et al. Lactase insufficiency revisited. J Pediatr Gastroenterol Nutr 1985 Dec; 4(6):868–72. Not relevant to key questions
663. Förster H, Mehnert H, Beck J. [The effect of various orally administered carbohydrates on the blood sugar level]. Klinische Wochenschrift Vol 45; 1967: 50–1. Not lactose intolerance study
664. Fortner BR, Danziger RE, Rabinowitz PS, et al. The effect of ascorbic acid on cutaneous and nasal response to histamine and allergen. The Journal of allergy and clinical immunology Vol 69; 1982: 484–8. Not lactose intolerance study
665. Fosbrooke AD, Wharton BA. "Added lactose" and "added sucrose" cow's milk formulae in nutrition of low birthweight babies. Archives of disease in childhood Vol 50; 1975: 409–18. Not relevant to key questions
666. Foster DN. A proposed mechanism for acquired lactose tolerance in adults with hypolactasia. East Afr Med J 1974 Jan; 51(1):26–32. Not relevant to key questions
667. Fowkes FG, Ferguson A. Self-diagnosed irritable bowel syndrome and milk intolerance in white and non-white doctors. Scott Med J 1981 Jan; 26(1):41–4. Not relevant to key questions
668. Fowler W. Studies in non-gonococcal urethritis therapy. The long-term value of tetracycline. The British journal of venereal diseases Vol 46; 1970: 464–8. Not lactose intolerance study
669. Fox R, Leen CL, Dunbar EM, et al. Acute gastroenteritis in infants under 6 months old. Arch Dis Child 1990 Sep; 65(9):936–8. Not relevant to key questions
670. Fox ZR, Brickman HF, Beaudry PH, et al. Response to disodium cromoglycate in children with chronic asthma. Canadian Medical Association journal Vol 106; 1972: 975–9. Not lactose intolerance study
671. Fradkin A, Yahav J, Zemer D, et al. Colchicine-induced lactose malabsorption in patients with familial Mediterranean fever. Israel Journal of Medical Sciences 1995 Oct; 31(10):616‐20. Ineligible number of subjects
672. Fraser NG, Murray D, Alexander JO. Structure and function of the small intestine in dermatitis herpetiformis. Br J Dermatol 1967 Oct; 79(10):509–18. Not relevant to key questions
673. Fratello F, Curcio G, Ferrara M, et al. Can an inert sleeping pill affect sleep? Effects on polysomnographic, behavioral and subjective measures. Psychopharmacology Vol 181; 2005: 761–70. Not lactose intolerance study
674. Freedman DJ, Tacket CO, Delehanty A, et al. Milk immunoglobulin with specific activity against purified colonization factor antigens can protect against oral challenge with enterotoxigenic Escherichia coli. The Journal of infectious diseases Vol 177; 1998: 662–7. Not relevant to key questions
675. Freeland-Graves J. Mineral adequacy of vegetarian diets. Am J Clin Nutr 1988 Sep; 48(3 Suppl):859–62. Review
676. Freeland-Graves JH, Bodzy PW, Eppright MA. Zinc status of vegetarians. J Am Diet Assoc 1980 Dec; 77(6):655–61. Not eligible outcomes
677. Freeman HJ. Gene therapy for lactose intolerance. Can J Gastroenterol 1999 Apr; 13(3):209‐10. Not relevant to key questions
678. Freiburghaus AU, Schmitz J, Schindler M, et al. Protein patterns of brush-border fragments in congenital lactose malabsorption and in specific hypolactasia of the adult. N Engl J Med 1976 May 6; 294(19):1030–2. Not relevant to key questions
679. French AB, Cook HB, Pollard HM. Nutritional problems after gastrointestinal surgery. Med Clin North Am 1969 Nov; 53(6):1389–402. Not eligible target population
680. Friedland N. "Normal" lactose tolerance test. Arch Intern Med 1965 Dec; 116(6):886–8. Not relevant to key questions
681. Friedman LS. By the way, doctor. There seem to be many products, such as stool softeners, to help with constipation. But are there any remedies for loose, poorly formed stools--a problem my husband has? The first suggestion is always to eat more fiber, but that hasn't helped my husband. Harv Health Lett 2004 Feb; 29(4):8. Not relevant to key questions
682. Fries JH. Food allergy: current concerns. Ann Allergy 1981 May; 46(5):260–3. Not relevant to key questions
683. Frissora CL, Koch KL. Symptom overlap and comorbidity of irritable bowel syndrome with other conditions. Current Gastroenterology Reports 2005 Aug; 7(4):264–71. No prevalence data
684. Frith PA, Ruffin RE, Juniper EF, et al. Inhibition of allergen-induced asthma by three forms of sodium cromoglycate. Clinical allergy Vol 11; 1981: 67–77. Not lactose intolerance study
685. Frostell G. Effects of mouth rinses with sucrose, glucose, fructose, lactose, sorbitol and Lycasin on the pH of dental plaque. Odontologisk revy Vol 24; 1973: 217–26. Not lactose intolerance study
686. Fry AC, Kraemer WJ, Stone MH, et al. Endocrine and performance responses to high volume training and amino acid supplementation in elite junior weightlifters. International journal of sport nutrition Vol 3; 1993: 306–22. Not lactose intolerance study
687. Fryburg DA. N(G)-monomethyl-L-arginine inhibits the blood flow but not the insulin- like response of forearm muscle to IGF-I. Possible role of nitric oxide in muscle protein synthesis. Journal of Clinical Investigation Vol 97; 1996: 1319–28. Not lactose intolerance study
688. Fukuda M, Hirota M, Sato S. Bone lesions and dental caries after gastrectomy--evaluation of milk intolerance and operative procedure. Jpn J Surg 1986 Jan; 16(1):36–41. Not eligible target population
689. Fukuda M, Shibata H, Hatakeyama K, et al. Difference in calcium metabolism following Billroth-I and Billroth-II procedures for gastric and duodenal ulcers. Jpn J Surg 1979 Dec; 9(4):295–303. Not eligible target population
690. Fukuda M, Tamura T. A controlled clinical trial of adrenochrome monoaminoguanidine methansulfonate in diabetic retinopathy. Jpn J Clin Ophthal Vol 32; 1978: 1470–4. Not lactose intolerance study
691. Fukuda Y, et al. [Evaluation of the Antitussive Effect of Perocan: A Double-Blind Comparison with Lactose Placebo]. Rinsho to Kenkyu (The Japanese Journal of Clinical and Experimental Medicine) Vol 50; 1973: 882–92. Not lactose intolerance study
692. Fulton JR, Hutton CW, Stitt KR. Preschool vegetarian children. Dietary and anthropometric data. J Am Diet Assoc 1980 Apr; 76(4):360–5. Not relevant to key questions
693. Fung WP, Kho KM. The importance of milk intolerance in patients presenting with chronic (nervous) diarrhoea. Aust N Z J Med 1971 Nov; 1(4):374–6. Not relevant to key questions
694. Furuya T, Suzuki Y. GM1-Gangliosidosis: a molecular abnormality of acid beta-galactosidase in fibroblasts. J Inherit Metab Dis 1984; 7(3):145–6. Not relevant to key questions
695. Fusch C, Skopnik H, Wirth S, et al. Double-blind, randomised, placebo-controlled study to evaluate the nutritional efficacy of Omneo 1. Final study results. Pediatrika Vol 21; 2001: 49‐54. Not relevant to key questions
696. Gaab MR, Rode CP, Schakel EH, et al. [Effect of the Ca antagonist nimodipine on global and regional cerebrovascular circulation]. Klinische Wochenschrift Vol 63; 1985: 8–15. Not lactose intolerance study
697. Gabr M, El-Beheiry F, Soliman AA, et al. Lactose tolerance in normal Egyptian infants and children and in protein calorie malnutrition. Gaz Egypt Paediatr Assoc 1977 Jan; 26(1):27–33. Not relevant to key questions
698. Gaeini AA, Rahnama N, Hamedinia MR. Effects of vitamin E supplementation on oxidative stress at rest and after exercise to exhaustion in athletic students. The Journal of sports medicine and physical fitness Vol 46; 2006: 458–61. Not lactose intolerance study
699. Gaffney PT, Buttenshaw RL, Thomas MJ, et al. Faster assay of H2 in breath by dedicated instruments compared with conventional gas chromatography. Clin Chem 1986 Sep; 32(9):1784–8. Not relevant to key questions
700. Gallagher CR, Molleson AL, Caldwell JH. Lactose intolerance and fermented dairy products. J Am Diet Assoc 1974 Oct; 65(4):418–9. Not relevant to key questions
701. Gannage MH, Abikaram G, Nasr F, et al. Osteomalacia secondary to celiac disease, primary hyperparathyroidism, and Graves' disease. Am J Med Sci 1998 Feb; 315(2):136–9. Not eligible target population
702. Gao KP, Mitsui T, Fujiki K, et al. Effect of lactase preparations in asymptomatic individuals with lactase deficiency--gastric digestion of lactose and breath hydrogen analysis. Nagoya J Med Sci 2002 May; 65(1–2):21–8. Not relevant to key questions
703. Gao X, Wilde PE, Lichtenstein AH, et al. Meeting adequate intake for dietary calcium without dairy foods in adolescents aged 9 to 18 years (National Health and Nutrition Examination Survey 2001–2002). Journal of the American Dietetic Association 2006 Nov; 106(11):1759–65. Not relevant to key questions
704. Gaón D, Chekherdemian M, Harwicz R, et al. [Effect of cimetidine on lactose activity in patients with duodenal ulcer]. Acta gastroenterologica Latinoamericana Vol 11; 1981: 285‐90. Not English language
705. Gaón D, Doweck Y, Gómez ZA, et al. [Lactose digestion by milk fermented with Lactobacillus acidophilus and Lactobacillus casei of human origin]. Medicina Vol 55; 1995: 237–42. Not English language
706. Garcia-Paredes J, Truelove SC. Disaccharidase levels in the small intestine in patients with diarrhoea following vagotomy and pyloroplasty. Gut 1971 Feb; 12(2):107–9. Not relevant to key questions
707. Gardiner AJ, Tarlow MJ, Sutherland IT, et al. Lactose malabsorption during gastroenteritis, assessed by the hydrogen breath test. Arch Dis Child 1981 May; 56(5):364–7. Not relevant to key questions
708. Gearhart HL, Bose DP, Smith CA, et al. Determination of lactose malabsorption by breath analysis with gas chromatography. Anal Chem 1976 Feb; 48(2):393–8. Not relevant to key questions
709. Geboes KP, Luypaerts A, Rutgeerts P, et al. Inulin is an ideal substrate for a hydrogen breath test to measure the orocaecal transit time. Alimentary pharmacology & therapeutics Vol 18; 2003: 721–9. Not lactose intolerance
710. Gendrel D, Dupont C, Richard-Lenoble D, et al. Feeding lactose-intolerant children with a powdered fermented milk. Journal of Pediatric Gastroenterology & Nutrition 1990 Jan; 10(1):44–6. Ineligible number of subjects
711. Gendrel D, Dupont C, Richard-Lenoble D, et al. Milk lactose malabsorption in Gabon measured by the breath hydrogen test. Journal of Pediatric Gastroenterology & Nutrition 1989 May; 8(4):545–7. Ineligible number of subjects
712. Gendrel D, Richard-Lenoble D, Kombila M, et al. Influence of intestinal parasitism on lactose absorption in well-nourished African children. Am J Trop Med Hyg 1992 Feb; 46(2):137–40. Not relevant to key questions
713. Gerasimidis K, McGrogan P, Hassan K, et al. Dietary modifications, nutritional supplements and alternative medicine in paediatric patients with inflammatory bowel disease. Alimentary Pharmacology & Therapeutics 2008 Jan 15; 27(2):155–65. Not relevant to key questions
714. Gerstenfeld TS, Wing DA. Rectal misoprostol versus intravenous oxytocin for the prevention of postpartum hemorrhage after vaginal delivery. American journal of obstetrics and gynecology Vol 185; 2001: 878–82. Not lactose intolerance study
715. Ghadirian P, Shatenstein B, Verdy M, et al. The influence of dairy products on plasma uric acid in women. European journal of epidemiology 1995 Jun; 11(3):275–81. Not relevant to key questions
716. Ghahremani GG, Bowie JD. Volvulus of the splenic flexure: report of a case. Dis Colon Rectum 1974 Jan–Feb; 17(1):100–2. Not relevant to key questions
717. Ghai OP, Bhan MK, Arora NK, et al. Practical implication of milk intolerance in diarrhea. Indian Pediatr 1982 Jan; 19(1):89–93. Not relevant to key questions
718. Ghai OP, Kumar L, Kumar V. Disaccharide intolerance in malnutrition. Indian Pediatr 1969 Jun; 6(6):364–73. Not relevant to key questions
719. Ghoshal UC, Abraham P, Bhatt C, et al. Epidemiological and clinical profile of irritable bowel syndrome in India: report of the Indian Society of Gastroenterology Task Force.[see comment]. Indian Journal of Gastroenterology 2008 Jan–Feb; 27(1):22–8. No prevalence data
720. Gibbons IS. Disaccharides and cystic fibrosis of the pancreas. Arch Dis Child 1969 Feb; 44(233):63–8. Not relevant to key questions
721. Gibbs SE, D'Esposito M. A functional MRI study of the effects of bromocriptine, a dopamine receptor agonist, on component processes of working memory. Psychopharmacology Vol 180; 2005: 644–53. Not lactose intolerance study
722. Gibney SF, Munroe V, Nurse GT, et al. Lactose absorption in a Western Massim population. Ann Hum Biol 1981 Sep–Oct; 8(5):477–80. Not relevant to key questions
723. Gibson G. Human evolution: thrifty genes and the dairy queen. Curr Biol 2007 Apr 17; 17(8):R295–6. Not relevant to key questions
724. Gibson JB, Berry GT, Palmieri MJ, et al. Sugar nucleotide concentrations in red blood cells of patients on protein- and lactose-limited diets: effect of galactose supplementation. American Journal of Clinical Nutrition 1996 May; 63(5):704–8. Not relevant to key questions
725. Gibson RS, Donovan UM, Heath AL. Dietary strategies to improve the iron and zinc nutriture of young women following a vegetarian diet. Plant Foods Hum Nutr 1997; 51(1):1–16. Not relevant to key questions
726. Gilat T. Lactase--an adaptable enzyme? Gastroenterology 1971 Feb; 60(2):346–7. Not relevant to key questions
727. Gilat T. Lactase deficiency: the world pattern today. Isr J Med Sci 1979 Apr; 15(4):369–73. Not relevant to key questions
728. Gilat T, Benaroya Y, Gelman-Malachi E, et al. Genetics of primary adult lactase deficiency. Gastroenterology 1973 Apr; 64(4):562–8. Not relevant to key questions
729. Gilat T, Dolizky F, Gelman-Malachi E, et al. Lactase in childhood--a non-adaptable enzyme. Scand J Gastroenterol 1974; 9(4):395–8. Not relevant to key questions
730. Gilat T, Kuhn R, Gelman E, et al. Lactase deficiency in Jewish communities in Israel. Am J Dig Dis 1970 Oct; 15(10):895–904. Not relevant to key questions
731. Gilat T, Malachi EG, Shochet SB. Lactose tolerance in an Arab population. Am J Dig Dis 1971 Mar; 16(3):203–6. Not relevant to key questions
732. Gilat T, Russo S, Gelman-Malachi E, et al. Lactase in man: a nonadaptable enzyme. Gastroenterology 1972 Jun; 62(6):1125–7. Not relevant to key questions
733. Gill HS, Guarner F. Probiotics and human health: a clinical perspective. Postgrad Med J 2004 Sep; 80(947):516–26. Review
734. Gill HS, Rutherfurd KJ, Cross ML. Dietary probiotic supplementation enhances natural killer cell activity in the elderly: an investigation of age-related immunological changes. Journal of clinical immunology Vol 21; 2001: 264–71. Not relevant to key questions
735. Gilliland SE, Kim HS. Effect of viable starter culture bacteria in yogurt on lactose utilization in humans. J Dairy Sci 1984 Jan; 67(1):1–6. Not relevant to key questions
736. Giovannetti S, Barsotti G, Gretz N, et al. Treatment and prevention of uremic osteodystrophy. Contrib Nephrol 1989; 72:66–72. Not eligible target population
737. Gismondo MR, Drago L, Lombardi A. Review of probiotics available to modify gastrointestinal flora. Int J Antimicrob Agents 1999 Aug; 12(4):287–92. Not relevant to key questions
738. Glinghammar B, Venturi M, Rowland IR, et al. Shift from a dairy product-rich to a dairy product-free diet: influence on cytotoxicity and genotoxicity of fecal water--potential risk factors for colon cancer. American Journal of Clinical Nutrition 1997 Nov; 66(5):1277–82. Not eligible outcomes
739. Godard C, Bustos M, Muñoz M, et al. Value of a chicken-based formula for refeeding of children with protracted diarrhea and malnutrition in a developing country. Journal of pediatric gastroenterology and nutrition Vol 9; 1989: 473–80. Not relevant to key questions
740. Godfrey S, Konig P. Inhibition of exercise induced asthma by different pharmacological pathways. Thorax Vol 31; 1976: 137–43. Not lactose intolerance study
741. Godfrey S, Silverman M. Demonstration by placebo response in asthma by means of exercise testing. Journal of psychosomatic research Vol 17; 1973: 293–7. Not lactose intolerance study
742. Godfrey S, Zeidifard E, Brown K, et al. The possible site of action of sodium cromoglycate assessed by exercise challenge. Clinical science and molecular medicine Vol 46; 1974: 265‐72. Not lactose intolerance study
743. Goepp JG, Katz S, Cuervo E, et al. Comparison of two regimens of feeding and oral electrolyte solutions in infants with diarrhea. Journal of pediatric gastroenterology and nutrition Vol 24; 1997: 374–9. Not relevant to key questions
744. Goldberg D. A psychiatric study of patients with diseases of the small intestine. Gut 1970 Jun; 11(6):459–65. Not relevant to key questions
745. Goldberg DP. A one-year survey of the prevalence of psychiatric illness in patients with disease of the small intestine. Gut 1968 Dec; 9(6):725. No prevalence data
746. Goldberg JP, Folta SC, Must A. Milk: can a "good" food be so bad? Pediatrics 2002 Oct; 110(4):826–32. Comment
747. Goldfarb AH, Bloomer RJ, McKenzie MJ. Combined antioxidant treatment effects on blood oxidative stress after eccentric exercise. Medicine and science in sports and exercise Vol 37; 2005: 234–9. Not lactose intolerance study
748. Goldin BR. Health benefits of probiotics. Br J Nutr 1998 Oct; 80(4):S203–7. Not relevant to key questions
749. Goldstein R, Braverman D, Stankiewicz H. Carbohydrate malabsorption and the effect of dietary restriction on symptoms of irritable bowel syndrome and functional bowel complaints. Isr Med Assoc J 2000 Aug; 2(8):583–7. Not relevant to key questions
750. Gonzalez A, Neri M, Campollo O, et al. Treatment of acute portalsystemic encephalopathy (PSE) grades III and IV with sodium benzoate and lactose [AASLD abstract]. Hepatology Vol 16; 1992: 249a. Not lactose intolerance study
751. Gonzalez A, Neri M, Campollo O, et al. Treatment of acute portalsystemic encephalopathy (PSE) grades III and IV with sodium benzoate and lactose [IASL abstract]. Hepatology Vol 19; 1994: 67i. Not lactose intolerance study
752. Gonzalez de la Reguera I, Subira ML, Oehling A. The role of sensitizing proteins in milk allergy. Allergol Immunopathol (Madr) 1978 May–Jun; 6(3):225–30. Not relevant to key questions
753. Goodchild CS, Robinson A, Nadeson R. Antinociceptive properties of neurosteroids IV: pilot study demonstrating the analgesic effects of alphadolone administered orally to humans. British journal of anaesthesia Vol 86; 2001: 528–34. Not lactose intolerance study
754. Goodlin RC. Letter: Maternal nutrition. Obstet Gynecol 1974 Jan; 43(1):157–9. Not relevant to key questions
755. Goossens D, Jonkers D, Stobberingh E, et al. Probiotics in gastroenterology: indications and future perspectives. Scandinavian Journal of Gastroenterology - Supplement 2003; (239):15‐23. No prevalence data
756. Gorbach SL, Neale G, Levitan R, et al. Alterations in human intestinal microflora during experimental diarrhoea. Gut 1970 Jan; 11(1):1–6. Not relevant to key questions
757. Gorduza EV, Indrei LL, Gorduza VM. Nutrigenomics in postgenomic era. Revista medico‐chirurgicala a Societatii de Medici si Naturalisti din Iasi 2008 Jan–Mar; 112(1):152–64. Review
758. Gounder DS, Pullon HW, Ockelford PA, et al. Clinical manifestations of the thrombocytopenia and absent radii (TAR) syndrome. Aust N Z J Med 1989 Oct; 19(5):479‐82. Not eligible target population
759. Gozalo RF, Colas SC, Senent SC, et al. Long-term modification on histamine-induced bronchoconstriction by disodium cromoglycate and ketotifen versus placebo. Allergy Vol 40; 1985: 242–9. Not lactose intolerance study
760. Gracey M. Some paediatric problems of Australian Aborigines. Paediatr Indones 1973 Jan; 13(1):1–10. Not relevant to key questions
761. Graham GG. Letter: Protein advisory group's recommendations deplored. Pediatrics 1975 Feb; 55(2):295–6. Not relevant to key questions
762. Graham GG, Baertl JM, Cordano A, et al. Lactose-free, medium-chain triglyceride formulas in severe malnutrition. Am J Dis Child 1973 Sep; 126(3):330–5. Not relevant to key questions
763. Grange AO, Santosham M, Ayodele AK, et al. Evaluation of a maize-cowpea-palm oil diet for the dietary management of Nigerian children with acute, watery diarrhea. Acta paediatrica (Oslo, Norway : 1992) Vol 83; 1994: 825–32. Not relevant to key questions
764. Granot E, Simcha A, Tamir I, et al. Lactose breath hydrogen analysis in infants with congenital heart disease. Isr J Med Sci 1987 Nov; 23(11):1158–60. Not relevant to key questions
765. Grant JD, Bezerra JA, Thompson SH, et al. Assessment of lactose absorption by measurement of urinary galactose. Gastroenterology 1989 Oct; 97(4):895–9. Not relevant to key questions
766. Grases F, Costa-Bauza A, Prieto RM. Renal lithiasis and nutrition. Nutr J 2006; 5:23. Review
767. Gravelle IH, Marsden RT. Radiological assessment of hypolactasia in ulcerative colitis. Br J Radiol 1969 Jun; 42(498):416–8. Not relevant to key questions
768. Gray GM. Malabsorption of carbohydrate. Fed Proc 1967 Sep; 26(5):1415–9. Not relevant to key questions
769. Gray GM. Congenital and adult intestinal lactase deficiency. N Engl J Med 1976 May 6; 294(19):1057–8. Not relevant to key questions
770. Gray GM. Absorption and malabsorption of dietary carbohydrate. Curr Concepts Nutr 1980; 9:43–53. Not relevant to key questions
771. Gray GM, Conklin KA, Townley RR. Sucrase-isomaltase deficiency. Absence of an inactive enzyme variant. N Engl J Med 1976 Apr 1; 294(14):750–3. Not relevant to key questions
772. Gray GM, Santiago NA. Intestinal beta-galactosidases. I. Separation and characterization of three enzymes in normal human intestine. Journal of Clinical Investigation 1969 Apr; 48(4):716–28. No prevalence data
773. Gray GM, Santiago NA, Colver EH, et al. Intestinal beta-galactosidases. II. Biochemical alteration in human lactase deficiency. Journal of Clinical Investigation 1969 Apr; 48(4):729‐35. Ineligible number of subjects
774. Gray GM, Walter WM, Jr., Colver EH. Persistent deficiency of intestinal lactase in apparently cured tropical sprue. Gastroenterology 1968 Apr; 54(4):552–8. Not relevant to key questions
775. Grazioli B, Matera G, Laratta C, et al. Giardia lamblia infection in patients with irritable bowel syndrome and dyspepsia: a prospective study. World Journal of Gastroenterology 2006 Mar 28; 12(12):1941–4. No prevalence data
776. Green TJ, Issenman RM, Jacobson K. Patients' diets and preferences in a pediatric population with inflammatory bowel disease. Canadian Journal of Gastroenterology 1998 Nov–Dec; 12(8):544–9. Not relevant to key questions
777. Gregorio GV, Rogacion JM, Gabriel EP, et al. Nutritional intervention in acute diarrhea: is a lactose-free formula essential? Southeast Asian Journal of Tropical Medicine & Public Health 1992 Jun; 23(2):235–45. No prevalence data
778. Gremse DA, Nguyenduc GH, Sacks AI, et al. Irritable bowel syndrome and lactose maldigestion in recurrent abdominal pain in childhood. South Med J 1999 Aug; 92(8):778–81. Not relevant to key questions
779. Gribbin M, Walker-Smith J, Wood C. Delayed recovery following acute gastroenteritis. Acta Paediatrica Belgica 1976 Jul–Sep; 29(3):167–76. No prevalence data
780. Griessen M, Cochet B, Infante F, et al. Calcium absorption from milk in lactase-deficient subjects. Am J Clin Nutr 1989 Feb; 49(2):377–84. Not eligible outcomes
781. Griffin MP, Hansen JW. Can the elimination of lactose from formula improve feeding tolerance in premature infants?[see comment]. Journal of Pediatrics 1999 Nov; 135(5):587‐92. No prevalence data
782. Grimbacher B, Peters T, Peter HH. Lactose-intolerance may induce severe chronic eczema. Int Arch Allergy Immunol 1997 Aug; 113(4):516–8. Not relevant to key questions
783. Groothuis JR, Berman S, Chapman J. Effect of carbohydrate ingested on outcome in infants with mild gastroenteritis. Journal of Pediatrics 1986 Jun; 108(6):903–6. No prevalence data
784. Gross MD. Effect of sucrose on hyperkinetic children. Pediatrics Vol 74; 1984: 876–8. Not lactose intolerance study
785. Guarner F, Perdigon G, Corthier G, et al. Should yoghurt cultures be considered probiotic? Br J Nutr 2005 Jun; 93(6):783–6. Not relevant to key questions
786. Gudmand-Hoyer E. Lactose malabsorption in patients operated upon for peptic ulcer. Scand J Gastroenterol 1969; 4(8):705–11. Not relevant to key questions
787. Gudmand-Hoyer E. The clinical significance of disaccharide maldigestion. American Journal of Clinical Nutrition 1994 Mar; 59(3 Suppl):735S–41S. Not original research
788. Gudmand-Hoyer E, Asp NG, Skovbjerg H, et al. Lactose malabsorption after bypass operation for obesity. Scand J Gastroenterol 1978; 13(6):641–7. Not relevant to key questions
789. Gudmand-Hoyer E, Dahlqvist A, Jarnum S. Specific small-intestinal lactase deficiency in adults. Scand J Gastroenterol 1969; 4(4):377–86. Not relevant to key questions
790. Gudmand-Hoyer E, Dahlqvist A, Jarnum S. The clinical significance of lactose malabsorption. Am J Gastroenterol 1970 May; 53(5):460–73. Not relevant to key questions
791. Gudmand-Hoyer E, Folke K. Radiological detection of lactose malabsorption. Scand J Gastroenterol 1970; 5(7):565–71. Not relevant to key questions
792. Gudmand-Hoyer E, Jarnum S. Diagnosis of lactose malabsorption. Gastroenterology 1968 Feb; 54(2):323–4. Not relevant to key questions
793. Gudmand-Hoyer E, Jarnum S. Milk intolerance following gastric surgery. Scand J Gastroenterol 1969; 4(2):127–32. Not relevant to key questions
794. Gudmand-Hoyer E, Jarnum S. Incidence and clinical significance of lactose malabsorption in ulcerative colitis and Crohn's disease. Gut 1970 Apr; 11(4):338–43. Not relevant to key questions
795. Gudmand-Hoyer E, Riis P, Wulff HR. The significance of lactose malabsorption in the irritable colon syndrome. Scand J Gastroenterol 1973; 8(3):273–8. Not relevant to key questions
796. Gudmand-Hoyer E, Simony K. Individual sensitivity to lactose in lactose malabsorption. Am J Dig Dis 1977 Mar; 22(3):177–81. Not relevant to key questions
797. Gudmand-Hoyer E, Skovbjerg H. Disaccharide digestion and maldigestion. Scandinavian Journal of Gastroenterology - Supplement 1996; 216:111–21. Not original research
798. Gudmand-Hoyer E, Soeberg B. Disaccharidase activity in the small intestinal mucosa in cases with acute enteritis. Scand J Gastroenterol 1974; 9(4):405–9. Not relevant to key questions
799. Guevara G, Jiminez R, Kranz P, et al. Lactase enzyme-treated cow's milk based formula does not alter course of acute diarrheal illness in babies. Pediatric Research Vol 31/4; 1992: 107a. Not relevant to key questions
800. Guiheneuc P, Ginet J, Grolleau JY, et al. [Study of the effects of isaxonine on retrograde axon degeneration induced by vincristine in man (author's transl)]. La Nouvelle presse médicale Vol 11; 1982: 1257–61. Not lactose intolerance study
801. Gulati VK, Desai S, Khatri PK, et al. Aqueous penetration of orally administered ciprofloxacin in humans. International Ophthalmology Vol 18; 1994: 221–4. Not lactose intolerance study
802. Gulick EE, Johnson S. Infant health of mothers with multiple sclerosis. Western Journal of Nursing Research 2004 Oct; 26(6):632–49. No prevalence data
803. Gumand-Hoyer E, Simony K. [Individual sensitivity to lactose in lactose malabsorption]. Ugeskrift for laeger Vol 137; 1975: 2064–8. Not English language
804. Gunn TR, Stunzner D. A comparative trial of casein or whey-predominant formulae in healthy infants. The New Zealand medical journal Vol 99; 1986: 843–6. Not relevant to key questions
805. Gunther S, Patterson RE, Kristal AR, et al. Demographic and health-related correlates of herbal and specialty supplement use. Journal of the American Dietetic Association 2004 Jan; 104(1):27–34. No prevalence data
806. Gupta D, Ghoshal UC, Misra A, et al. Lactose intolerance in patients with irritable bowel syndrome from northern India: a case-control study. J Gastroenterol Hepatol 2007 Dec; 22(12):2261–5. Not relevant to key questions
807. Gupta I, Gupta V, Parihar A, et al. Effects of Boswellia serrata gum resin in patients with bronchial asthma: results of a double-blind, placebo-controlled, 6-week clinical study. European journal of medical research Vol 3; 1998: 511–4. Not lactose intolerance study
808. Gupta MM, Round JM, Stamp TC. Spontaneous cure of vitamin-D deficiency in Asians during summer in Britain. Lancet 1974 Apr 6; 1(7858):586–8. Not eligible outcomes
809. Gupta PS, Misra RC, Ramachandran KA, et al. Lactose intolerance in adults. J Assoc Physicians India 1970 Sep; 18(9):765–8. Not relevant to key questions
810. Gupta PS, Misra RC, Sacheti CK, et al. Lactase activity in irritable colon syndrome. J Assoc Physicians India 1971 Jul; 19(7):507–10. Not relevant to key questions
811. Gupta PS, Misra RC, Sarin GS, et al. Intestinal disaccharidases activity in normal adult population in tropics. J Trop Med Hyg 1971 Oct; 74(10):225–9. Not relevant to key questions
812. Gupta R, Gupta S. Dietary management of lactose intolerance--lactase treated milk versus soya milk. Indian J Med Sci 1993 Jan; 47(1):1–7. Not relevant to key questions
813. Gupta RC, Sarin GS, Misra RC, et al. Intestinal disaccharidases in intestinal tuberculosis. J Indian Med Assoc 1975 May 16; 64(10):262–4. Not relevant to key questions
814. Gupta SK, Chong SK, Fitzgerald JF. Disaccharidase activities in children: normal values and comparison based on symptoms and histologic changes. J Pediatr Gastroenterol Nutr 1999 Mar; 28(3):246–51. Not relevant to key questions
815. Gupta SK, Gupta RC, Seth AK, et al. Reversal of fluorosis in children. Acta paediatrica Japonica; Overseas edition Vol 38; 1996: 513–9. Not lactose intolerance study
816. Gwee KA, Graham JC, McKendrick MW, et al. Psychometric scores and persistence of irritable bowel after infectious diarrhoea.[see comment]. Lancet 1996 Jan 20; 347(8995):150‐ 3. No prevalence data
817. Habte D, Sterky G, Hjalmarsson B. Lactose malabsorption in Ethiopian children. Acta Paediatr Scand 1973 Nov; 62(6):649–54. Not relevant to key questions
818. Hackett PH, Rennie D, Levine HD. The incidence, importance, and prophylaxis of acute mountain sickness. Lancet Vol 2; 1976: 1149–55. Not lactose intolerance study
819. Haderstorfer B, Psycholgin D, Whitehead WE, et al. Intestinal gas production from bacterial fermentation of undigested carbohydrate in irritable bowel syndrome. Am J Gastroenterol 1989 Apr; 84(4):375–8. Not relevant to key questions
820. Haffejee IE. Persistent diarrhoea following gastroenteritis. Journal of diarrhoeal diseases research 1990 Dec; 8(4):143–6. Not relevant to key questions
821. Haffejee IE. Cow's milk-based formula, human milk, and soya feeds in acute infantile diarrhea: a therapeutic trial. Journal of pediatric gastroenterology and nutrition Vol 10; 1990: 193–8. Not relevant to key questions
822. Haider T, Husain Q. Concanavalin A layered calcium alginate-starch beads immobilized beta galactosidase as a therapeutic agent for lactose intolerant patients. Int J Pharm 2008 Jul 9; 359(1–2):1–6. Not relevant to key questions
823. Hajek P, Belcher M. Improved CO monitors for validating smoking abstinence by expired-air carbon monoxide levels. British Journal of Addiction 1991 Aug; 86(8):1029–30. No prevalence data
824. Hakala P, Karvetti RL. Weight reduction on lactovegetarian and mixed diets. Changes in weight, nutrient intake, skinfold thicknesses and blood pressure. Eur J Clin Nutr 1989 Jun; 43(6):421–30. Not relevant to key questions
825. Halimun EM, Sunoto, Suharjono. Sugar intolerance in post neonatal surgery. Paediatr Indones 1973 Nov; 13(11):289–92. Not relevant to key questions
826. Hall RT, Callenbach JC, Sheehan MB, et al. Comparison of calcium- and phosphorus-supplemented soy isolate formula with whey-predominant premature formula in very low birth weight infants. J Pediatr Gastroenterol Nutr Vol 3; 1984: 571–6. Not eligible target population
827. Halliday R, Callaway E, Lannon R. The effects of clonidine and yohimbine on human information processing. Psychopharmacology Vol 99; 1989: 563–6. Not lactose intolerance study
828. Halpern GM, Prindiville T, Blankenburg M, et al. Treatment of irritable bowel syndrome with Lacteol Fort: a randomized, double-blind, cross-over trial. The American journal of gastroenterology Vol 91; 1996: 1579–85. Not relevant to key questions
829. Halpern GM, Van de Water J, Delabroise AM, et al. Comparative uptake of calcium from milk and a calcium-rich mineral water in lactose intolerant adults: implications for treatment of osteoporosis. Am J Prev Med 1991 Nov–Dec; 7(6):379–83. Not eligible outcomes
830. Halpin TC, Byrne WJ, Ament ME. Colitis, persistent diarrhea, and soy protein intolerance. Journal of Pediatrics 1977 Sep; 91(3):404–7. No prevalence data
831. Halsas M, Hietala J, Veski P, et al. Morning versus evening dosing of ibuprofen using conventional and time-controlled release formulations. International Journal of Pharmaceutics Vol 189; 1999: 179–85. Not lactose intolerance study
832. Hamer S, Collinson G. Achieving Evidence-based Practice: A Handbook for Practitioners. 2nd ed. New York: Bailliere Tindall Elsevier; 2005. Custom 3
833. Hamilton I, Hill A, Bose B, et al. Small intestinal permeability in pediatric clinical practice. J Pediatr Gastroenterol Nutr 1987 Sep–Oct; 6(5):697–701. Not relevant to key questions
834. Hamilton M, Bush M, Bye C, et al. A comparison of triprolidine and cyclizine on histamine (H1) antagonism, subjective effects and performance tests in man. British journal of clinical pharmacology Vol 13; 1982: 441–4. Not lactose intolerance study
835. Hamilton MJ, Smith PR, Peck AW. Effects of bupropion, nomifensine and dexamphetamine on performance, subjective feelings, autonomic variables and electroencephalogram in healthy volunteers. British journal of clinical pharmacology Vol 15; 1983: 367–74. Not lactose intolerance study
836. Hamilton-Miller JM. Probiotics and prebiotics in the elderly. Postgrad Med J 2004 Aug; 80(946):447–51. Not relevant to key questions
837. Hamm LR, Sorrells SC, Harding JP, et al. Additional investigations fail to alter the diagnosis of irritable bowel syndrome in subjects fulfilling the Rome criteria. Am J Gastroenterol 1999 May; 94(5):1279–82. Not relevant to key questions
838. Hammer HF, Petritsch W, Pristautz H, et al. Evaluation of the pathogenesis of flatulence and abdominal cramps in patients with lactose malabsorption. Wien Klin Wochenschr 1996; 108(6):175–9. Not relevant to key questions
839. Hammer HF, Petritsch W, Pristautz H, et al. Assessment of the influence of hydrogen nonexcretion on the usefulness of the hydrogen breath test and lactose tolerance test. Wiener Klinische Wochenschrift 1996; 108(5):137–41. Ineligible number of subjects
840. Hanafy MM, Seddik Y, El-Khateeb S, et al. Lactose absorption in protein-calorie malnutrition. Gaz Egypt Paediatr Assoc 1973 Oct; 21(4):9–13. Not relevant to key questions
841. Hanger HC, Smart EJ, Merrilees MJ, et al. The prevalence of malnutrition in elderly hip fracture patients. New Zealand Medical Journal 1999 Mar 26; 112(1084):88–90. Letter
842. Hannington E. Preliminary report on tyramine headache. British medical journal Vol 2; 1967: 550–1. Not lactose intolerance study
843. Harland BF, Peterson M. Nutritional status of lacto-ovo vegetarian Trappist monks. J Am Diet Assoc 1978 Mar; 72(3):259–64. Not relevant to key questions
844. Harland BF, Smith SA, Howard MP, et al. Nutritional status and phytate:zinc and phytate x calcium:zinc dietary molar ratios of lacto-ovo vegetarian Trappist monks: 10 years later. J Am Diet Assoc 1988 Dec; 88(12):1562–6. Not target population
845. Harms HK, Bertele-Harms RM, Bruer-Kleis D. Enzyme-substitution therapy with the yeast Saccharomyces cerevisiae in congenital sucrase-isomaltase deficiency. N Engl J Med 1987 May 21; 316(21):1306–9. Not relevant to key questions
846. Harris RP, Helfand M, Woolf SH, et al. Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med 2001 Apr; 20(3 Suppl):21–35. Not relevant to key questions
847. Harrison GG, Graver EJ, Vargas M, et al. Growth and adiposity of term infants fed whey-predominant or casein-predominant formulas or human milk. Journal of pediatric gastroenterology and nutrition Vol 6; 1987: 739–47. Not relevant to key questions
848. Harrison M. Letter: Sugar malabsorption in cow's milk protein intolerance. Lancet 1974 Mar 2; 1(7853):360–1. Not relevant to key questions
849. Harrison M, Kilby A, Walker-Smith JA, et al. Cows' milk protein intolerance: a possible association with gastroenteritis, lactose intolerance, and IgA deficiency. Br Med J 1976 Jun 19; 1(6024):1501–4. Not relevant to key questions
850. Harrison M, Walker-Smith JA. Reinvestigation of lactose intolerant children: lack of correlation between continuing lactose intolerance and small intestinal morphology, disaccharidase activity, and lactose tolerance tests. Gut 1977 Jan; 18(1):48–52. Not relevant to key questions
851. Harrison V, Fawcus S, Jordaan E. Magnesium supplementation and perinatal hypoxia: outcome of a parallel group randomised trial in pregnancy. BJOG : an international journal of obstetrics and gynaecology Vol 114; 2007: 994–1002. Not lactose intolerance study
852. Hart J, Hill HM, Bye CE, et al. The effects of low doses of amylobarbitone sodium and diazepam on human performance. British journal of clinical pharmacology Vol 3; 1976: 289‐98. Not lactose intolerance study
853. Harvey CB, Hollox EJ, Poulter M, et al. Lactase haplotype frequencies in Caucasians: association with the lactase persistence/non-persistence polymorphism. Ann Hum Genet 1998 May; 62(Pt 3):215–23. Not relevant to key questions
854. Harvey-Berino J, Gold BC, Lauber R, et al. The impact of calcium and dairy product consumption on weight loss. Obesity research 2005 Oct; 13(10):1720–6. Not relevant to key questions
855. Harzer G, Dieterich I, Haug M. Effects of the diet on the composition of human milk. Ann Nutr Metab Vol 28; 1984: 231–9. Not relevant to key questions
856. Harzer K. The two human lactosylceramidases and their respective enzyme activity deficiency diseases: inhibition studies using p-nitrophenyl-beta-D-galactoside. Hum Genet 1978 Apr 24; 41(3):341–5. Not relevant to key questions
857. Hass CJ, Collins MA, Juncos JL. Resistance training with creatine monohydrate improves upper-body strength in patients with Parkinson disease: a randomized trial. Neurorehabilitation and neural repair Vol 21; 2007: 107–15. Not lactose intolerance study
858. Hassan NA, al-Ani MR, Lafta AM, et al. Value of breath hydrogen test in detection of hypolactasia in patients with chronic diarrhoea. J Chromatogr 1990 Aug 24; 530(1):102–7. Not relevant to key questions
859. Hastings K, Hilker DM. An investigation of milk-drinking habits of University of Hawaii students as a possible indication of lactose intolerance. Hawaii Med J 1976 Jul; 35(7):197–9. Not relevant to key questions
860. Havala S, Dwyer J. Position of the American Dietetic Association: vegetarian diets. J Am Diet Assoc 1993 Nov; 93(11):1317–9. Guideline
861. He M, Antoine JM, Yang Y, et al. [Influence of live flora on lactose digestion in male adult lactose-malabsorbers after dairy products intake]. Wei sheng yan jiu = Journal of hygiene research Vol 33; 2004: 603–5. Not English language
862. He T, Priebe MG, Harmsen HJ, et al. Colonic fermentation may play a role in lactose intolerance in humans. J Nutr 2006 Jan; 136(1):58–63. Not relevant to key questions
863. He T, Priebe MG, Vonk RJ, et al. Identification of bacteria with beta-galactosidase activity in faeces from lactase non-persistent subjects. FEMS Microbiol Ecol 2005 Nov 1; 54(3):463–9. Not relevant to key questions
864. He T, Priebe MG, Welling GW, et al. Effect of lactose on oro-cecal transit in lactose digesters and maldigesters. Eur J Clin Invest 2006 Oct; 36(10):737–42. Not relevant to key questions
865. He T, Priebe MG, Zhong Y, et al. Effects of yogurt and bifidobacteria supplementation on the colonic microbiota in lactose-intolerant subjects. Journal of Applied Microbiology 2008 Feb; 104(2):595–604. Ineligible number of subjects
866. He T, Roelofsen H, Alvarez-Llamas G, et al. Differential analysis of protein expression of Bifidobacterium grown on different carbohydrates. J Microbiol Methods 2007 May; 69(2):364–70. Not relevant to key questions
867. Heather DJ, Howell L, Montana M, et al. Effect of a bulk-forming cathartic on diarrhea in tube-fed patients. Heart Lung 1991 Jul; 20(4):409–13. Not relevant to key questions
868. Heckmann SM, Hujoel P, Habiger S, et al. Zinc gluconate in the treatment of dysgeusia--a randomized clinical trial. Journal of dental research Vol 84; 2005: 35–8. Not lactose intolerance study
869. Heiss H. [Clinical and experimental contribution on the question of the lactogenic effect of Galega officinalis]. Wiener medizinische Wochenschrift (1946) Vol 118; 1968: 546–8. Not English language
870. Heizer WD. Normal and abnormal intestinal absorption by humans. Environmental Health Perspectives 1979 Dec; 33:101–6. No prevalence data
871. Hendrickse RG, Wooldridge MA, Russell A. Lactulose in baby milks causing diarrhoea simulating lactose intolerance. Br Med J 1977 May 7; 1(6070):1194–5. Not relevant to key questions
872. Henriksson R, Franzén L, Sandström K, et al. Effects of active addition of bacterial cultures in fermented milk to patients with chronic bowel discomfort following irradiation. Supportive care in cancer : official journal of the Multinational Association of Supportive Care in Cancer Vol 3; 1995: 81–3. Not eligible target population
873. Heresbach D, Flourie B, Briet F, et al. Effect of colonic fermentation on respiratory gas exchanges measured in the postabsorptive state. American Journal of Clinical Nutrition Vol 62; 1995: 973–8. Not relevant to key questions
874. Hermann J, Arquitt A, Stoecker B. Effects of chromium supplementation on plasma lipids, apolipoproteins, and glucose in elderly subjects. Nutr Res Vol 14; 1994: 671–4. Not relevant to key questions
875. Hernandez-Rauda R, Martinez-Garcia S. Osteoporosis-related life habits and knowledge about osteoporosis among women in El Salvador: a cross-sectional study. BMC Musculoskelet Disord 2004 Aug 26; 5:29. Not eligible outcomes
876. Hernell O, West C. Do we need personalized recommendations for infants at risk of developing disease? Nestle Nutrition Workshop Series Paediatric Programme 2008; 62:239‐49; discussion 49–52. Not original research
877. Herrera JA, Arevalo-Herrera M, Herrera S. Prevention of preeclampsia by linoleic acid and calcium supplementation: a randomized controlled trial. Obstetrics and gynecology Vol 91; 1998: 585–90. Not lactose intolerance study
878. Herrera JA, Arévalo-Herrera M, Shahabuddin AK, et al. Calcium and conjugated linoleic acid reduces pregnancy-induced hypertension and decreases intracellular calcium in lymphocytes. American journal of hypertension : journal of the American Society of Hypertension Vol 19; 2006: 381–7. Not lactose intolerance study
879. Herskovic T. Protein malnutrition and the small intestine. Am J Clin Nutr 1969 Mar; 22(3):300–4. Not relevant to key questions
880. Hertzler SR, Clancy S. Kefir improves lactose digestion and tolerance in adult lactose maldigesters. Journal of Parenteral and Enteral Nutrition Vol 27; 2003: S26–s7. Not relevant to key questions
881. Hertzler SR, Clancy SM. Kefir improves lactose digestion and tolerance in adults with lactose maldigestion. J Am Diet Assoc 2003 May; 103(5):582–7. Not relevant to key questions
882. Hertzler SR, Savaiano DA, Levitt MD. Fecal hydrogen production and consumption measurements. Response to daily lactose ingestion by lactose maldigesters. Dig Dis Sci 1997 Feb; 42(2):348–53. Not relevant to key questions
883. Hessels J, Eidhof HH, Steggink J, et al. Assessment of hypolactasia and site-specific intestinal permeability by differential sugar absorption of raffinose, lactose, sucrose and mannitol. Clin Chem Lab Med 2003 Aug; 41(8):1056–63. Not relevant to key questions
884. Heubi J, Karasov R, Reisinger K, et al. Randomized multicenter trial documenting the efficacy and safety of a lactose-free and a lactose-containing formula for term infants. Journal of the American Dietetic Association Vol 100; 2000: 212–7. Not relevant to key questions
885. Hewson P, Oberklaid F, Menahem S. Infant colic, distress, and crying. Clin Pediatr (Phila) 1987 Feb; 26(2):69–76. Not relevant to key questions
886. Heyman M. Effect of lactic acid bacteria on diarrheal diseases. J Am Coll Nutr 2000 Apr; 19(2 Suppl):137S–46S. Not relevant to key questions
887. Heyman MB. Lactose intolerance in infants, children, and adolescents. Pediatrics 2006 Sep; 118(3):1279–86. Review
888. Hicks SM, Walker AF, Gallagher J, et al. The significance of "nonsignificance" in randomized controlled studies: a discussion inspired by a double-blinded study on St. John's wort (Hypericum perforatum L.) for premenstrual symptoms. Journal of alternative and complementary medicine (New York, N.Y.) Vol 10; 2004: 925–32. Not lactose intolerance study
889. Hiele M. Georges Brohee Prize 1988–1989. Assimilation of nutritional carbohydrates: influence of hydrolysis. Acta Gastroenterol Belg 1991 Jan–Feb; 54(1):3–11. Not relevant to key questions
890. Hiele M, Ghoos Y, Rutgeerts P, et al. 13CO2 breath test using naturally 13C-enriched lactose for detection of lactase deficiency in patients with gastrointestinal symptoms. Journal of Laboratory & Clinical Medicine 1988 Aug; 112(2):193–200. Ineligible number of subjects
891. Higgins EA, Chiles WD, McKenzie JM, et al. Effects of altitude and two decongestant-antihistamine preparations on physiological functions and performance. Aviation, space, and environmental medicine Vol 50; 1979: 154–8. Not lactose intolerance study
892. Higgins ST, Roll JM, Bickel WK. Alcohol pretreatment increases preference for cocaine over monetary reinforcement. Psychopharmacology Vol 123; 1996: 1–8. Not lactose intolerance study
893. Higham MA, Sharara AM, Magee RP, et al. Determination of the minimum dose of lactose that can be sensed during inhalation [abstract]. European Respiratory Journal. Supplement. Vol 8; 1995: 97s. Not lactose intolerance study
894. Higham MA, Sharara AM, Magee RP, et al. Determination of the minimum dose of lactose drug carrier that can be sensed during inhalation. British journal of clinical pharmacology Vol 40; 1995: 281–2. Not lactose intolerance study
895. Hijazi S, El-Khateeb M, Abdulatif D. Lactose malabsorption in Jordanian infants and young children. Acta Paediatr Scand 1981 Sep; 70(5):759–60. Not relevant to key questions
896. Hijazi SS, Abulaban A, Ammarin Z, et al. Distribution of adult lactase phenotypes in Bedouins and in urban and agricultural populations of Jordan. Trop Geogr Med 1983 Jun; 35(2):157–61. Not relevant to key questions
897. Hilb A. Metabolic study on a patient with nutritional vitamin D deficiency. J Hum Nutr 1977 Oct; 31(5):359–61. Not eligible target population
898. Hildebrandt J, Herrmann U. [Selective proximal vagotomy with and without pyloroplasty in uncomplicated chronic duodenal ulcer. Results of a randomized clinical study 5 and 10 years following surgery]. Zentralblatt für Chirurgie Vol 117; 1992: 36–40. Not lactose intolerance study
899. Hildebrandt J, Lauschke G, Wolff H, et al. [Selective proximal vagotomy with and without pyloroplasty--results of a randomized clinical study of duodenal ulcer 5 and 8 years after surgery]. Zentralblatt für Chirurgie Vol 113; 1988: 827–36. Not lactose intolerance study
900. Hill AM, Coates AM, Buckley JD, et al. Can EGCG reduce abdominal fat in obese subjects? Journal of the American College of Nutrition Vol 26; 2007: 396s–402s. Not lactose intolerance study
901. Hines C, Jr. Milk intolerance--mimic of the irritable bowel syndrome. J La State Med Soc 1977 May; 129(5):125–7. Not relevant to key questions
902. Hirota N, Sone Y, Tokura H. Effect of post-prandial posture on orocecal transit time and digestion of milk lactose in humans. Journal of physiological anthropology and applied human science Vol 23; 2004: 75–80. Not lactose intolerance
903. Hirota T, Nara M, Ohguri M, et al. Effect of diet and lifestyle on bone mass in Asian young women. Am J Clin Nutr 1992 Jun; 55(6):1168–73. Not eligible outcomes
904. Hirschhorn N, Molla A, Molla AM. Reversible jejunal disaccharidase deficiency in cholera and other acute diarrheal diseases. Johns Hopkins Med J 1969 Dec; 125(6):291–300. Not relevant to key questions
905. Hjelt K, Paerregaard A, Krasilnikoff PA. Giardiasis causing chronic diarrhoea in suburban Copenhagen: incidence, physical growth, clinical symptoms and small intestinal abnormality. Acta Paediatrica 1992 Nov; 81(11):881–6. Ineligible number of subjects
906. Hjelt K, Paerregaard A, Petersen W, et al. Rapid versus gradual refeeding in acute gastroenteritis in childhood: energy intake and weight gain. Journal of pediatric gastroenterology and nutrition Vol 8; 1989: 75–80. Not relevant to key questions
907. Ho MW, Povey S, Swallow D. Lactase polymorphism in adult British natives: estimating allele frequencies by enzyme assays in autopsy samples. Am J Hum Genet 1982 Jul; 34(4):650–7. Not relevant to key questions
908. Hobbs SH. Attitudes, practices, and beliefs of individuals consuming a raw foods diet. Explore (NY) 2005 Jul; 1(4):272–7. Not relevant to key questions
909. Hodgson JM, Puddey IB, Beilin LJ, et al. Effects of isoflavonoids on blood pressure in subjects with high-normal ambulatory blood pressure levels: a randomized controlled trial. Am J Hypertens 1999 Jan; 12(1 Pt 1):47–53. Not eligible target population
910. Hoeksema HL, De Wit J, Westerveld A. The genetic defect in the various types of human beta-galactosidase deficiency. Hum Genet 1980 Feb; 53(2):241–7. Not relevant to key questions
911. Hoeksema HL, van Diggelen OP, Galjaard H. Intergenic complementation after fusion of fibroblasts from different patients with beta-galactosidase deficiency. Biochim Biophys Acta 1979 Jan 12; 566(1):72–9. Not relevant to key questions
912. Hoffman JJ. A double-blind crossover clinical trial of an OTC diuretic in the treatment of premenstrual tension and weight gain. Curr-Ther-Res,-Clin-Exp Vol 26; 1979: 575–80. Not lactose intolerance study
913. Hogarth FW. Should zinc be added to textured vegetable protein? J Hum Nutr 1981 Oct; 35(5):379–82. Comment
914. Hogenauer C, Hammer HF, Mellitzer K, et al. Evaluation of a new DNA test compared with the lactose hydrogen breath test for the diagnosis of lactase non-persistence. Eur J Gastroenterol Hepatol 2005 Mar; 17(3):371–6. Not relevant to key questions
915. Hoghton MA, Mittal NK, Sandhu BK, et al. Effects of immediate modified feeding on infantile gastroenteritis. The British journal of general practice : the journal of the Royal College of General Practitioners Vol 46; 1996: 173–5. Not relevant to key questions
916. Hohenauer L. [Dietary treatment of acute gastroenteritis in infants]. Monatsschrift Kinderheilkunde : Organ der Deutschen Gesellschaft für Kinderheilkunde Vol 131; 1983: 729–32. Not English language
917. Holtug K, Clausen MR, Hove H, et al. The colon in carbohydrate malabsorption: short-chain fatty acids, pH, and osmotic diarrhoea. Scand J Gastroenterol 1992 Jul; 27(7):545–52. Not relevant to key questions
918. Holzel A. Defects of sugar absorption. Sugar malabsorption and sugar intolerance in childhood. Proc R Soc Med 1968 Nov; 61(11 Part 1):1095–9. Not relevant to key questions
919. Holzel A. Malabsorption. Midwife Health Visit Community Nurse 1978 Mar; 14(3):79–81. Not relevant to key questions
920. Hongladarom GC, Russell M. An ethnic difference--lactose intolerance. Nurs Outlook 1976 Dec; 24(12):764–5. Not relevant to key questions
921. Honkanen O, Nordberg M, Eerikainen S, et al. Bioavailability of metoclopramide from orally and rectally administered novel hydroxypropyl methylcellulose capsules containing different diluents: A comparison with corresponding gelatine capsules. S.T.P. Pharma Sciences Vol 12; 2002: 299–307. Not lactose intolerance study
922. Honkanen O, Seppa H, Eerikainen S, et al. Bioavailability of ibuprofen from orally and rectally administered hydroxypropyl methyl cellulose capsules compared to corresponding gelatine capsules. S.T.P. Pharma Sciences Vol 11; 2001: 181–5. Not lactose intolerance study
923. Hoogeveen A, d'Azzo A, Brossmer R, et al. Correction of combined beta-galactosidase/neuraminidase deficiency in human fibroblasts. Biochem Biophys Res Commun 1981 Nov 16; 103(1):292–300. Not relevant to key questions
924. Hoogeveen AT, Verheijen FW, d'Azzo A, et al. Genetic heterogeneity in human neuraminidase deficiency. Nature 1980 Jun 12; 285(5765):500–2. Not relevant to key questions
925. Hoogeveen AT, Verheijen FW, Galjaard H. The relation between human lysosomal beta-galactosidase and its protective protein. J Biol Chem 1983 Oct 25; 258(20):12143–6. Not relevant to key questions
926. Horak F, Matthes H. The protective action of fluocortin butylester (FCB) in the nasal antigen provocation test: a controlled double-blind, crossover study. Annals of allergy Vol 48; 1982: 305–8. Not lactose intolerance study
927. Horsmans Y, Solbreux PM, Daenens C, et al. Lactulose improves psychometric testing in cirrhotic patients with subclinical encephalopathy. Alimentary pharmacology & therapeutics Vol 11; 1997: 165–70. Not lactose intolerance study
928. Horton GE, Wruble LD. Lactose intolerance syndrome mimicking milk--allergy and/or functional bowel disorders: four cases. Ann Allergy 1966 Dec; 24(12):698–704. Not relevant to key questions
929. Hosny M, Eldin SG, Hosny H. Combined lidocaine 1% and hydroxypropyl methylcellulose 2.25% as a single anesthetic/ viscoelastic agent in phacoemulsification. Journal of cataract and refractive surgery Vol 28; 2002: 834–6. Not lactose intolerance study
930. Host A, Husby S, Osterballe O. A prospective study of cow's milk allergy in exclusively breast-fed infants. Incidence, pathogenetic role of early inadvertent exposure to cow's milk formula, and characterization of bovine milk protein in human milk. Acta Paediatrica Scandinavica 1988 Sep; 77(5):663–70. Ineligible number of subjects
931. Hove H, Nordgaard-Andersen I, Mortensen PB. Effect of lactic acid bacteria on the intestinal production of lactate and short-chain fatty acids, and the absorption of lactose. Am J Clin Nutr 1994 Jan; 59(1):74–9. Not relevant to key questions
932. Hove H, Norgaard H, Mortensen PB. Lactic acid bacteria and the human gastrointestinal tract. Eur J Clin Nutr 1999 May; 53(5):339–50. Not relevant to key questions
933. Howard FM, O'Halloran ET, Creagh A. Diarrhoea: after rehydration, what next? Human Nutrition - Applied Nutrition 1985 Feb; 39(1):53–61. Not relevant to key questions
934. Howell JN, Mellmann J, Ehlers P, et al. Intestinal disaccharidase activities and activity ratios in a group of 60 adult German subjects. Hepatogastroenterology 1980 Jun; 27(3):208–12. Not relevant to key questions
935. Howell JN, Schockenhoff T, Flatz G. Population screening for the human adult lactase phenotypes with a multiple breath version of the breath hydrogen test. Hum Genet 1981; 57(3):276–8. Not relevant to key questions
936. Howell JN, Von der Fecht R, Flatz G. Hydrogen breath test for lactose tolerance adapted to population screening. Clin Chim Acta 1980 Apr 25; 103(2):229–31. Not relevant to key questions
937. Hrboticky N, Leiter LA, Anderson GH. Effects of L-tryptophan on short term food intake in lean men. Nutr Res Vol 5; 1985: 595–607. Not lactose intolerance study
938. Hrboticky N, Leiter LA, Anderson GH. Menstrual cycle effects on the metabolism of tryptophan loads. The American journal of clinical nutrition Vol 50; 1989: 46–52. Not lactose intolerance study
939. Hu JF, Zhao XH, Jia JB, et al. Dietary calcium and bone density among middle-aged and elderly women in China. Am J Clin Nutr 1993 Aug; 58(2):219–27. Not eligible outcomes
940. Huang SS, Bayless TM. Lactose intolerance in healthy children. N Engl J Med 1967 Jun 8; 276(23):1283–7. Not relevant to key questions
941. Huang SS, Bayless TM. Milk and lactose intolerance in healthy Orientals. Science 1968 Apr 5; 160(823):83–4. Not relevant to key questions
942. Huempel M, Wendt H, Dogs G, et al. Intraindividual comparison of pharmacokinetic parameters of d norgestrel, lynestrenol and cyproterone acetate in 6 women. Contraception Vol 16; 1977: 199–215. Not lactose intolerance study
943. Huncharek M, Muscat J, Kupelnick B. Impact of dairy products and dietary calcium on bone-mineral content in children: results of a meta-analysis. Bone 2008 Aug; 43(2):312–21. Not relevant to key questions
944. Hunt IF, Murphy NJ, Henderson C, et al. Bone mineral content in postmenopausal women: comparison of omnivores and vegetarians. Am J Clin Nutr 1989 Sep; 50(3):517–23. Not eligible outcomes
945. Hunt JR, Matthys LA, Johnson LK. Zinc absorption, mineral balance, and blood lipids in women consuming controlled lactoovovegetarian and omnivorous diets for 8 wk. Am J Clin Nutr 1998 Mar; 67(3):421–30. Not relevant to key questions
946. Hunt T, Geetha R, Warga E. The bioavailability of desogestrel/ethinyl estradiol tablets relative to the oral solution. Clinical Drug Investigation Vol 15; 1998: 507–14. Not lactose intolerance study
947. Hurlemann R, Matusch A, Hawellek B, et al. Emotion-induced retrograde amnesia varies as a function of noradrenergic-glucocorticoid activity. Psychopharmacology Vol 194; 2007: 261‐ 9. Not lactose intolerance study
948. Hursh LM. Milk has something for every body? JAMA 1975 May 5; 232(5):539–40. Comment
949. Hussein L, Ezzilarab A. The frequency distribution of lactose malabsorption among adult populations from the eastern and western Egyptian deserts. Biochemical Genetics 1994 Oct; 32(9–10):331–42. No prevalence data
950. Hussein L, Flatz SD, Kuhnau W, et al. Distribution of human adult lactose phenotypes in Egypt. Human Heredity 1982; 32(2):94–9. Not eligible test for lactose malabsorption
951. Hutt MS. Epidemiology of chronic intestinal disease in middle Africa. Isr J Med Sci 1979 Apr; 15(4):314–7. Not relevant to key questions
952. Hyams JS, Krause PJ, Gleason PA. Lactose malabsorption following rotavirus infection in young children. J Pediatr 1981 Dec; 99(6):916–8. Not relevant to key questions
953. Hyams JS, Stafford RJ, Grand RJ, et al. Correlation of lactose breath hydrogen test, intestinal morphology, and lactase activity in young children. J Pediatr 1980 Oct; 97(4):609–12. Not relevant to key questions
954. Hyams JS, Treem WR, Justinich CJ, et al. Characterization of symptoms in children with recurrent abdominal pain: resemblance to irritable bowel syndrome.[see comment]. Journal of Pediatric Gastroenterology & Nutrition 1995 Feb; 20(2):209–14. No prevalence data
955. Hyman FC, Collins WE, Taylor HL, et al. Instrument flight performance under the influence of certain combinations of antiemetic drugs. Aviation, space, and environmental medicine Vol 59; 1988: 533–9. Not lactose intolerance study
956. Hyo S, Fujieda S, Kawada R, et al. The efficacy of short-term administration of 3 antihistamines vs placebo under natural exposure to Japanese cedar pollen. Annals of allergy, asthma & immunology : official publication of the American College of Allergy, Asthma, & Immunology Vol 94; 2005: 457–64. Not lactose intolerance study
957. Iancu T, Elian E. The intestinal microvillus. Ultrastructural variability in coeliac disease and cow's milk intolerance. Acta Paediatr Scand 1976 Jan; 65(1):65–73. Not relevant to key questions
958. Ibrahim SA, O'Sullivan DJ. Use of chemical mutagenesis for the isolation of food grade beta-galactosidase overproducing mutants of bifidobacteria, lactobacilli and Streptococcus thermophilus. J Dairy Sci 2000 May; 83(5):923–30. Not relevant to key questions
959. Imokawa S, Satou A, Taniguchi M, et al. [Amlexanox has an acute bronchodilator effect in patients with aspirin-induced asthma (AIA)]. Nihon Ky?bu Shikkan Gakkai zasshi Vol 31; 1993: 976–82. Not lactose intolerance study
960. Imtiaz F, Savilahti E, Sarnesto A, et al. The T/G 13915 variant upstream of the lactase gene (LCT) is the founder allele of lactase persistence in an urban Saudi population. Journal of Medical Genetics 2007 Oct; 44(10):e89. Subjects less than 4 years old
961. Ingram CJ, Elamin MF, Mulcare CA, et al. A novel polymorphism associated with lactose tolerance in Africa: multiple causes for lactase persistence? Human Genetics 2007 Feb; 120(6):779–88. No prevalence data
962. Ingram CJ, Mulcare CA, Itan Y, et al. Lactose digestion and the evolutionary genetics of lactase persistence. Hum Genet 2009 Jan; 124(6):579–91. Not relevant to key questions
963. Inui K, Wenger DA. Biochemical, immunological, and structural studies on a sphingolipid activator protein (SAP-1). Arch Biochem Biophys 1984 Sep; 233(2):556–64. Not relevant to key questions
964. Iqbal TH, Wood GM, Lewis KO, et al. Prevalence of primary lactase deficiency in adult residents of west Birmingham. BMJ 1993 May 15; 306(6888):1303. Not population based study
965. Isbell RG, Carlson HC, Hoffman HN, 2nd. Roentgenologic-pathologic correlation in malabsorption syndromes. Am J Roentgenol Radium Ther Nucl Med 1969 Sep; 107(1):158‐69. Not relevant to key questions
966. Ish-Horowicz M, Korman SH, Shapiro M, et al. Asymptomatic giardiasis in children. Pediatric Infectious Disease Journal 1989 Nov; 8(11):773–9. No prevalence data
967. Ishimori A. Safety experience with sucralfate in Japan. Journal of clinical gastroenterology Vol 3; 1981: 169–73. Not lactose intolerance study
968. Isokoski M, Jussila J, Sarna S. A simple screening method for lactose malabsorption. Gastroenterology 1972 Jan; 62(1):28–32. Not relevant to key questions
969. Isokoski M, Sahi T, Villako K, et al. Epidemiology and genetics of lactose malabsorption. Ann Clin Res 1981 Jun; 13(3):164–8. Not relevant to key questions
970. Isselbacher KJ. Malabsorption syndromes including disease of pancreatic and biliary origin. Curr Concepts Nutr 1980; 9:93–104. Not relevant to key questions
971. Itoh H, Naito T, Takeyama M. Effects of histamine H_2_-receptor antagonists on human plasma levels of calcitonin gene-related peptide, substance P and vasoactive intestinal peptide. Journal of Pharmacy & Pharmacology Vol 54; 2002: 1559–63. Not lactose intolerance study
972. Iyngkaran N, Davis K, Robinson MJ, et al. Cows' milk protein-sensitive enteropathy: an important contributing cause of secondary sugar intolerance in young infants with acute infective enteritis. Arch Dis Child 1979 Jan; 54(1):39–43. Not relevant to key questions
973. Iyngkaran N, Yadav M, Boey CG, et al. Effect of continued feeding of cows' milk on asymptomatic infants with milk protein sensitive enteropathy. Archives of Disease in Childhood 1988 Aug; 63(8):911–5. Subjects less than 4 years old
974. Jackson AA, Golden MH. The human rumen. Lancet 1978 Oct 7; 2(8093):764–7. Not relevant to key questions
975. Jackson KA, Savaiano DA. Lactose maldigestion, calcium intake and osteoporosis in African-, Asian-, and Hispanic-Americans. J Am Coll Nutr 2001 Apr; 20(2 Suppl):198S‐207S. review
976. Jackson RT, Latham MC. Lactose and milk intolerance in Tanzania. East Afr Med J 1978 Jul; 55(7):298–302. Not relevant to key questions
977. Jackson RT, Latham MC. Lactose malabsorption among Masai children of East Africa. Am J Clin Nutr 1979 Apr; 32(4):779–82. Not relevant to key questions
978. Jacobsen ST, Hull CK, Crawford AH. Nutritional rickets. Journal of pediatric orthopedics 1986 Nov–Dec; 6(6):713–6. Not eligible target population
979. Jahn HU, Ullrich R, Schneider T, et al. Immunological and trophical effects of Saccharomyces boulardii on the small intestine in healthy human volunteers. Digestion 1996; 57(2):95–104. Ineligible number of subjects
980. James JA, Clark C, Ward PS. Screening Rastafarian children for nutritional rickets. Br Med J (Clin Res Ed) 1985 Mar 23; 290(6472):899–900. Not eligible outcomes
981. James JE. The influence of user status and anxious disposition on the hypertensive effects of caffeine. International journal of psychophysiology : official journal of the International Organization of Psychophysiology Vol 10; 1990: 171–9. Not lactose intolerance study
982. James WP. Intestinal absorption in protein-calorie malnutrition. Lancet Vol 1; 1968: 333–5. Not relevant to key questions
983. James WP. Sugar absorption and intestinal motility in children when malnourished and after treatment. Clin Sci 1970 Aug; 39(2):305–18. Not relevant to key questions
984. James WP. Comparison of three methods used in assessment of carbohydrate absorption in malnourished children. Arch Dis Child 1972 Aug; 47(254):531–6. Not relevant to key questions
985. Jamison JR, Davies NJ. Chiropractic management of cow's milk protein intolerance in infants with sleep dysfunction syndrome: a therapeutic trial. Journal of Manipulative & Physiological Therapeutics 2006 Jul–Aug; 29(6):469–74. Not relevant to key questions
986. Janas LM, Picciano MF, Hatch TF. Indices of protein metabolism in term infants fed either human milk or formulas with reduced protein concentration and various whey/casein ratios. The Journal of pediatrics Vol 110; 1987: 838–48. Not relevant to key questions
987. Janelle KC, Barr SI. Nutrient intakes and eating behavior scores of vegetarian and nonvegetarian women. J Am Diet Assoc 1995 Feb; 95(2):180–6, 9, quiz 7–8. Not relevant to key questions
988. Janket SJ, Manson JE, Sesso H, et al. A prospective study of sugar intake and risk of type 2 diabetes in women. Diabetes care Vol 26; 2003: 1008–15. Not lactose intolerance study
989. Jardini L, Findlay R, Burgi E, et al. Auditory changes associated with moderate blood salicylate levels. Rheumatology and rehabilitation Vol 17; 1978: 233–6. Not lactose intolerance study
990. Jarnum S, Kristensen M. Lactose malabsorption and lactose-induced enteric loss of protein in regional enteritis. Nucl Med (Stuttg) 1967:223–9. Not relevant to key questions
991. Jarrett EC, Holman GH. Lactose absorption in the premature infant. Archives of Disease in Childhood Vol 41; 1966: 525–7. Not relevant to key questions
992. Jarvela I, Enattah NS, Kokkonen J, et al. Assignment of the locus for congenital lactase deficiency to 2q21, in the vicinity of but separate from the lactase-phlorizin hydrolase gene. Am J Hum Genet 1998 Oct; 63(4):1078–85. Not relevant to key questions
993. Jarvela IE. Molecular genetics of adult-type hypolactasia. Annals of Medicine 2005; 37(3):179–85. No prevalence data
994. Jarvis JK, Miller GD. Overcoming the barrier of lactose intolerance to reduce health disparities. J Natl Med Assoc 2002 Feb; 94(2):55–66. Review
995. Jasani MK, Downie WW, Samuels BM, et al. Ibuprofen in rheumatoid arthritis. Clinical study of analgesic and anti-inflammatory activity. Annals of the rheumatic diseases Vol 27; 1968: 457–62. Not lactose intolerance study
996. Jeans WD. An evaluation of radiological signs in small bowel examinations in children. Clin Radiol 1972 Jan; 23(1):78–86. Not relevant to key questions
997. Jelliffe DB. Intolerance to lactose in mother's milk? Lancet 1972 Oct 7; 2(7780):760. Not relevant to key questions
998. Jenista JA, Chapman D. Medical problems of foreign-born adopted children. Am J Dis Child 1987 Mar; 141(3):298–302. Not relevant to key questions
999. Jenkins C, Breslin AB, Marlin GE. The role of alpha and beta adrenoceptors in airway hyperresponsiveness to histamine. The Journal of allergy and clinical immunology Vol 75; 1985: 364–72. Not lactose intolerance study
1000. Jenkins T, Gibney SF, Nurse GT, et al. Persistent high intestinal lactase activity in Papua New Guinea. Lactose absorption curves in two populations. Ann Hum Biol 1981 Sep–Oct; 8(5):447–51. Not relevant to key questions
1001. Jenkins T, Lehmann H, Nurse GT. Public health and genetic constitution of the San ("Bushmen"): carbohydrate metabolism and acetylator status of the Kung of Tsumkwe in the North-western Kalahari. Br Med J 1974 Apr 6; 2(5909):23–6. Not relevant to key questions
1002. Jenkins T, Nurse GT. Biomedical studies on the desert dwelling huntergatherers of Southern Africa. Prog Med Genet 1976; 1:211–81. Not relevant to key questions
1003. Jennings W, Rowland R, Hecker R, et al. The significance of lowered jejunal disaccharidase levels. Aust N Z J Med 1976 Dec; 6(6):556–60. Not relevant to key questions
1004. Jersky J, Kinsley RH. Lactose deficiency in the South African Bantu. S Afr Med J 1967 Dec 16; 41(46):1194–6. Not relevant to key questions
1005. Jewell DP, Truelove SC. Circulating antibodies to cow's milk proteins in ulcerative colitis. Gut 1972 Oct; 13(10):796–801. Not relevant to key questions
1006. Jiang TA, Ye RY. Studies on small intestinal mucosal morphology lactase activity and lactose hydrolysis rate in childhood with diarrhea. Chin Med J (Engl) 1991 Jun; 104(6):476‐ 9. Not relevant to key questions
1007. Johansson G, Callmer E, Gustafsson JA. Validity of repeated dietary measurements in a dietary intervention study. Eur J Clin Nutr 1992 Oct; 46(10):717–28. Not eligible outcomes
1008. Johansson G, Holmen A, Persson L, et al. Long-term effects of a change from a mixed diet to a lacto-vegetarian diet on human urinary and faecal mutagenic activity. Mutagenesis 1998 Mar; 13(2):167–71. Not relevant to key questions
1009. Johansson G, Holmen A, Persson L, et al. The effect of a shift from a mixed diet to a lacto‐vegetarian diet on human urinary and fecal mutagenic activity. Carcinogenesis 1992 Feb; 13(2):153–7. Not eligible outcomes
1010. Johnson AO, Semenya JG, Buchowski MS, et al. Adaptation of lactose maldigesters to continued milk intakes. Am J Clin Nutr 1993 Dec; 58(6):879–81. Not relevant to key questions
1011. Johnson JD, Simoons FJ, Hurwitz R, et al. Lactose malabsorption among the Pima indians of Arizona. Gastroenterology 1977 Dec; 73(6):1299–304. Not eligible test for lactose malabsorption
1012. Johnson RC, Ayau EP, Ching CA, et al. Environmental influences on lactose tolerance. Behav Genet 1987 Jul; 17(4):313–30. Not relevant to key questions
1013. Johnson RC, Bowman KS, Schwitters SY, et al. Ethnic, familial, and environmental influences on lactose tolerance. Hum Biol 1984 May; 56(2):307–16. Not relevant to key questions
1014. Johnson RC, Cole RE, Ahern FM. Genetic interpretation of racial/ethnic differences in lactose absorption and tolerance: a review. Hum Biol 1981 Feb; 53(1):1–13. Not relevant to key questions
1015. Johnson RC, Schwitters SY, Cole RE, et al. A family study of lactose tolerance. Behav Genet 1981 Jul; 11(4):369–72. Not relevant to key questions
1016. Johnson RM, Brummett R, Schleuning A. Use of alprazolam for relief of tinnitus. A double-blind study. Archives of otolaryngology--head & neck surgery Vol 119; 1993: 842–5. Not lactose intolerance study
1017. Johnston PK. Getting enough to grow on. Am J Nurs 1984 Mar; 84(3):336–9. Comment
1018. Jones DV, Latham MC. Lactose intolerance in young children and their parents. Am J Clin Nutr 1974 Jun; 27(6):547–9. Not relevant to key questions
1019. Jones DV, Latham MC. The implications of lactose intolerance in children. J Trop Pediatr Environ Child Health 1974 Oct; 20(5):261–71. Not relevant to key questions
1020. Jones VA, McLaughlan P, Shorthouse M, et al. Food intolerance: a major factor in the pathogenesis of irritable bowel syndrome. Lancet 1982 Nov 20; 2(8308):1115–7. Not relevant to key questions
1021. Jonkers D, Stockbrugger R. Review article: Probiotics in gastrointestinal and liver diseases. Aliment Pharmacol Ther 2007 Dec; 26 Suppl 2:133–48. Not relevant to key questions
1022. Jonsson B, Gardsell P, Johnell O, et al. Life-style and different fracture prevalence: a cross-sectional comparative population-based study. Calcif Tissue Int 1993 Jun; 52(6):425–33. Not eligible outcomes
1023. Joos G, Vincken W, Aumann J, et al. Comparison of the bronchodilator effect of fenoterol‐ipratropium bromide delivered as lactose powder capsule to metered dose inhaler in asthma [abstract]. European Respiratory Journal. Supplement. Vol 8; 1995: 426s. Not lactose intolerance study
1024. Joseph F, Jr., Rosenberg AJ. Low breath hydrogen production in post-diarrheic infants. Acta Paediatr Scand 1991 Aug–Sep; 80(8–9):792–4. Not relevant to key questions
1025. Josephson RV, Rupp JW, Chambers JF. Needs assessment of enteral nutrition support products. Journal of the American Dietetic Association 1985 Nov; 85(11):1485–7. Not relevant to key questions
1026. Juambeltz JC, Kula K, Perman J. Nursing caries and lactose intolerance. Journal of Dentistry for Children 1993 Nov–Dec; 60(4):377–84. No prevalence data
1027. Jung AL, Carr SL. A soy protein formula and a milk-based formula. A comparative evaluation in milk-tolerant infants showed no significant nutritional differences. Clin Pediatr (Phila) 1977 Nov; 16(11):982–5. Not relevant to key questions
1028. Jussila J. Milk intolerance and lactose malabsorption in hospital patients and young servicemen in Finland. Ann Clin Res 1969 Nov; 1(3):199–207. Not relevant to key questions
1029. Jussila J. The lactose tolerance test with intravenous administration of ethanol. Ann Clin Res 1969 May; 1(1):50–6. Not relevant to key questions
1030. Jussila J. Diagnosis of lactose malabsorption by the lactose tolerance test with peroral ethanol administration. Scand J Gastroenterol 1969; 4(4):361–8. Not relevant to key questions
1031. Jussila J, Isokoski M, Launiala K. Prevalence of lactose malabsorption in a Finnish rural population. Scandinavian Journal of Gastroenterology 1970; 5(1):49–56. Not eligible test for lactose malabsorption
1032. Jussila J, Launiala K, Gorbatow O. Lactase deficiency and a lactose-free diet in patients with "unspecific abdominal complaints". Acta Med Scand 1969 Sep; 186(3):217–22. Not relevant to key questions
1033. Jussila J, Mattila MJ, Takki S. Drug absorption during lactose-induced intestinal symptoms in patients with selective lactose malabsorption. Ann Med Exp Biol Fenn 1970; 48(1):33–7. Not relevant to key questions
1034. Jussila J, Sivula A, Salmi HJ. Effect of ulcer surgery on disaccharidase activities of the small bowel and on lactose absorption. Scandinavian Journal of Gastroenterology 1972; 7(4):315–20. No prevalence data
1035. Jutzy RV. Clinical studies of Norpace (Part IV). Angiology 1975 Jan; 26(1 Pt 2):138–9. Not relevant to key questions
1036. Kagaya M, Iwata M, Toda Y, et al. Circadian rhythm of breath hydrogen in young women. J Gastroenterol 1998 Aug; 33(4):472–6. Not relevant to key questions
1037. Kahn A, Francois G, Sottiaux M, et al. Sleep characteristics in milk-intolerant infants. Sleep 1988 Jun; 11(3):291–7. Not relevant to key questions
1038. Kahn A, Mozin MJ, Rebuffat E, et al. Milk intolerance in children with persistent sleeplessness: a prospective double-blind crossover evaluation.[see comment]. Pediatrics 1989 Oct; 84(4):595–603. Ineligible number of subjects
1039. Kahn HA, Sempos CT. Statistical Methods in Epidemiology (Monographs in Epidemiology and Biostatistics). USA: Oxford University Press; 1989. Custom 3
1040. Kailasapathy K, Chin J. Survival and therapeutic potential of probiotic organisms with reference to Lactobacillus acidophilus and Bifidobacterium spp. Immunol Cell Biol 2000 Feb; 78(1):80–8. Not relevant to key questions
1041. Kalis B. [Assessment by transcutaneous PO2 measurement of the treatment of venous ulcers with naftidrofuryl]. Journal Des Maladies Vasculaires Vol 9; 1984: 133–6. Not lactose intolerance study
1042. Kaminski M, Boal R. An effect of ascorbic acid on delayed-onset muscle soreness. Pain Vol 50; 1992: 317–21. Not lactose intolerance study
1043. Kammann J, Dornbach G, Vollenberg C, et al. [Controlled clinical study of two viscoelastic substances]. Fortschritte der Ophthalmologie : Zeitschrift der Deutschen Ophthalmologischen Gesellschaft Vol 88; 1991: 438–41. Not lactose intolerance study
1044. Kanabar D. Infantile colic. J Fam Health Care 2004; 14(2):suppl 1–2. Review
1045. Kanabar D, Randhawa M, Clayton P. Improvement of symptoms in infant colic following reduction of lactose load with lactase. J Hum Nutr Diet 2001 Oct; 14(5):359–63. Not eligible target population
1046. Kanaghinis T, Hatzioannou J, Deliargyris N, et al. Primary lactase deficiency in Greek adults. Am J Dig Dis 1974 Nov; 19(11):1021–7. Not relevant to key questions
1047. Kaplan NM. Non-drug treatment of hypertension. Ann Intern Med 1985 Mar; 102(3):359‐73. Not eligible target population
1048. Kaplan NM. Dietary aspects of the treatment of hypertension. Annu Rev Public Health 1986; 7:503–19. Not eligible target population
1049. Kar P, Tandon RK. Lactose intolerance in Nagaland. Indian J Med Res 1985 Sep; 82:254‐ 6. Not relevant to key questions
1050. Karhu M, Kuikka J, Kauppinen T, et al. Pulmonary deposition of lactose carriers used in inhalation powders. International journal of pharmaceutics Vol 196; 2000: 95–103. Not lactose intolerance study
1051. Karlowski TR, Chalmers TC, Frenkel LD, et al. Ascorbic acid for the common cold. A prophylactic and therapeutic trial. JAMA : the journal of the American Medical Association Vol 231; 1975: 1038–42. Not lactose intolerance study
1052. Karofsky PS. Infantile colic. J Fam Pract 1984 Jul; 19(1):107–8, 11–2, 14 passim. Not relevant to key questions
1053. Kasper H, Kuhn HA. The small-intestinal function in ulcerative colitis. Am J Proctol 1970 Aug; 21(4):253–7. Not relevant to key questions
1054. Katch VL, Moorehead CP, Becque MD, et al. Reduced short-term thermic effects of a meal in obese adolescent girls. European journal of applied physiology and occupational physiology Vol 65; 1992: 535–40. Not lactose intolerance study
1055. Kato T, Okada S, Yutaka T, et al. beta-Galactosidase deficient-type mucolipidosis: a complementation study of neuraminidase in somatic cell hybrids. Biochem Biophys Res Commun 1979 Nov 14; 91(1):114–7. Not relevant to key questions
1056. Kato T, Okada S, Yutaka T, et al. Induction of beta-galactosidase in beta-galactosidase‐alpha-neuraminidase deficiency: effects of leupeptin and sucrose. Biochem Int 1983 Feb; 6(2):267–73. Not relevant to key questions
1057. Katz AJ, Falchuk ZM. Definitive diagnosis of gluten-sensitive enteropathy. Use of an in vitro organ culture model. Gastroenterology 1978 Oct; 75(4):695–700. Not relevant to key questions
1058. Kaur K, Mahmood S, Mahmood A. Hypolactasia as a molecular basis of lactose intolerance. Indian Journal of Biochemistry & Biophysics 2006 Oct; 43(5):267–74. No prevalence data
1059. Kay CD, Morrison JD. The effects of ingestion of 60 mg pyridostigmine bromide on contrast sensitivity in man. Human toxicology Vol 7; 1988: 347–52. Not lactose intolerance study
1060. Keet MP, Moodie AD, Wittmann W, et al. Kwashiorkor: a prospective ten-year follow-up study. S Afr Med J 1971 Dec 25; 45(49):1427–49. Not eligible target population
1061. Kefenie H, Berhane R. Lactose tolerance test in 193 subjects in Ethiopia. Ethiop Med J 1987 Apr; 25(2):65–9. Not relevant to key questions
1062. Kelsay JL, Frazier CW, Prather ES, et al. Impact of variation in carbohydrate intake on mineral utilization by vegetarians. Am J Clin Nutr 1988 Sep; 48(3 Suppl):875–9. Not relevant to key questions
1063. Kemp JP, Hill MR, Vaughan LM, et al. Pilot study of bronchodilator response to inhaled albuterol delivered by metered-dose inhaler and a novel dry powder inhaler. Annals of allergy, asthma & immunology : official publication of the American College of Allergy, Asthma, & Immunology Vol 79; 1997: 322–6. Not lactose intolerance study
1064. Keohane PP, Attrill H, Jones BJ, et al. The roles of lactose and clostridium difficile in the pathogenesis of enteral feeding associated diarrhoea. Clin-Nutr Vol 1; 1983: 259–64. Not relevant to key questions
1065. Kerber M, Oberkanins C, Kriegshauser G, et al. Hydrogen breath testing versus LCT genotyping for the diagnosis of lactose intolerance: a matter of age? Clin Chim Acta 2007 Aug; 383(1–2):91–6. Not relevant to key questions
1066. Kerr FA, Szabadi E. Comparison of the effects of chronic administration of ciclazindol and desipramine on pupillary responses to tyramine, methoxamine and pilocarpine in healthy volunteers. British journal of clinical pharmacology Vol 19; 1985: 639–47. Not lactose intolerance study
1067. Keshavarzian A, Iber FL, Dangleis MD, et al. Intestinal-transit and lactose intolerance in chronic alcoholics. Am J Clin Nutr 1986 Jul; 44(1):70–6. Not relevant to key questions
1068. Keusch GT. Subclinical malabsorption in Thailand. I. Intestinal absorption in Thai children. Am J Clin Nutr 1972 Oct; 25(10):1062–6. Not relevant to key questions
1069. Keusch GT, Plaut AG, Troncale FJ. Subclinical malabsorption in Thailand. II. Intestinal absorption in American military and Peace Corps personnel. Am J Clin Nutr 1972 Oct; 25(10):1067–79. Not relevant to key questions
1070. Keusch GT, Troncale FJ, Miller LH, et al. Acquired lactose malabsorption in Thai children. Pediatrics 1969 Apr; 43(4):540–5. Not relevant to key questions
1071. Keusch GT, Troncale FJ, Thavaramara B, et al. Lactase deficiency in Thailand: effect of prolonged lactose feeding. Am J Clin Nutr 1969 May; 22(5):638–41. Not relevant to key questions
1072. Khan NA, McAlister FA, Rabkin SW, et al. The 2006 Canadian Hypertension Education Program recommendations for the management of hypertension: Part II - Therapy. Canadian Journal of Cardiology 2006 May 15; 22(7):583–93. Not relevant to key questions
1073. Khoshoo V, Bhan MK, Arora NK, et al. Leucocyte migration inhibition in cow's milk protein intolerance. Acta Paediatr Scand 1986 Mar; 75(2):308–12. Not relevant to key questions
1074. Kien CL, Liechty EA. Effects of lactose intake on nutrient absorption and nutritional status in premature infants (PI). Pediatric Research Vol 25; 1989: 117a. Not relevant to key questions
1075. Kien CL, Liechty EA, Mullett MD. Contribution of low-molecular-weight compounds to the fecal excretion of carbohydrate energy in premature infants. Gastroenterology Vol 99; 1990: 165–74. Not relevant to key questions
1076. Kien CL, Liechty EA, Mullett MD. Effects of lactose intake on nutritional status in premature infants. Journal of Pediatrics Vol 116; 1990: 446–9. Not relevant to key questions
1077. Kien CL, Liechty EA, Myerberg DZ, et al. Dietary carbohydrate assimilation in the premature infant: evidence for a nutritionally significant bacterial ecosystem in the colon. The American journal of clinical nutrition Vol 46; 1987: 456–60. Not relevant to key questions
1078. Kien CL, Liechty EA, Myerberg DZ, et al. Effects in premature infants of normalizing breath H2 concentrations with CO2: increased H2 concentration and reduced interaliquot variation. J Pediatr Gastroenterol Nutr 1987 Mar–Apr; 6(2):286–9. Not relevant to key questions
1079. Kien CL, McClead RE, Cordero L. Effects of lactose intake on lactose digestion and colonic fermentation in preterm infants. The Journal of pediatrics Vol 133; 1998: 401–5. Not relevant to key questions
1080. Kien CL, Sumners JE, Stetina JS, et al. A method for assessing carbohydrate energy absorption and its application to premature infants. The American journal of clinical nutrition Vol 36; 1982: 910–6. Not relevant to key questions
1081. Kies CV. Mineral utilization of vegetarians: impact of variation in fat intake. Am J Clin Nutr 1988 Sep; 48(3 Suppl):884–7. Not eligible target population
1082. Kikuchi K, Matahira Y. Oral N-acetylglucosamine supplementation improves skin conditions of female volunteers: Clinical evaluation by a microscopic three-dimensional skin surface analyzer. Journal of Applied Cosmetology Vol 20; 2002: 143–52. Not lactose intolerance study
1083. Kim HS, Gilliland SE. Lactobacillus acidophilus as a dietary adjunct for milk to aid lactose digestion in humans. J Dairy Sci 1983 May; 66(5):959–66. Not relevant to key questions
1084. King F. Intolerance to lactose in mother's milk? Lancet 1972 Aug 12; 2(7772):335. Not relevant to key questions
1085. King T. Comparison of symptoms after the consumption of milk or lactose-hydrolysed milk by people with self-reported severe lactose intolerance. Clin Nutr 1996 Apr; 15(2):97–8. Not relevant to key questions
1086. Kingfisher CP, Millard AV. "Milk makes me sick but my body needs it": conflict and contradiction in the establishment of authoritative knowledge. Med Anthropol Q 1998 Dec; 12(4):447–66. Not relevant to key questions
1087. Kirkpatrick C, Buck H, Ellis S. Assessment of adrenal suppression from two new dry powder inhaler formulations of budesonide delivered by Clickhaler compared with the Pulmicort Turbuhaler. Journal of aerosol medicine : the official journal of the International Society for Aerosols in Medicine Vol 16; 2003: 31–6. Not lactose intolerance study
1088. Kirschner BS, DeFavaro MV, Jensen W. Lactose malabsorption in children and adolescents with inflammatory bowel disease. Gastroenterology 1981 Nov; 81(5):829–32. No prevalence data
1089. Kirsner JB. Clinical observations on malabsorption. Med Clin North Am 1969 Sep; 53(5):1169–94. Not relevant to key questions
1090. Klauser AG, Voderholzer WA, Schindlbeck NE, et al. Functional diagnostic work-up in patients with irritable bowel syndrome. Zeitschrift fur Gastroenterologie 1996 May; 34(5):273–8. Not population based study
1091. Kleerekoper M, Peterson E, Nelson D, et al. Identification of women at risk for developing postmenopausal osteoporosis with vertebral fractures: role of history and single photon absorptiometry. Bone Miner 1989 Sep; 7(2):171–86. Not eligible outcomes
1092. Kleessen B, Sykura B, Zunft H, et al. Effects of insulin and lactose on fecal microflora, microbial activity, and bowel habit in elderly constipated persons. American Journal of Clinical Nutrition Vol 65; 1997: 1397–402. Not relevant to key questions
1093. Klein UE, Walpurger G. Biochemical and enzyme-cytochemical findings in the human small intestinal mucosa in malabsorption syndromes. Digestion 1971; 4(4):205–15. Not relevant to key questions
1094. Klesges RC, Harmon-Clayton K, Ward KD, et al. Predictors of milk consumption in a population of 17- to 35-year-old military personnel. J Am Diet Assoc 1999 Jul; 99(7):821–6; quiz 7–8. Not relevant to key questions
1095. Kline AH, Assemi M. Lactose intolerance with lactosuria. Tex Med 1968 Jul; 64(7):36–9. Not relevant to key questions
1096. Klorman R, Brumaghim JT, Salzman LF, et al. Effects of methylphenidate on processing negativities in patients with attention-deficit hyperactivity disorder. Psychophysiology Vol 27; 1990: 328–37. Not lactose intolerance study
1097. Klotz AP, Lubos MC. Gastrointestinal symptoms and intestinal lactase deficiencies--a word of caution. Am J Dig Dis 1967 Apr; 12(4):421–3. Not relevant to key questions
1098. Klug RM. AIDS beyond the hospital. 2. Children with AIDS. Am J Nurs 1986 Oct; 86(10):1126–32. Not relevant to key questions
1099. Kneepkens CM, Hoekstra JH. Malabsorption of carbohydrates. Nestle Nutr Workshop Ser Pediatr Program 2005; 56:57–69; discussion -71. Not relevant to key questions
1100. Knodell RG, Tate MA, Akl BF, et al. Vitamin C prophylaxis for posttransfusion hepatitis: lack of effect in a controlled trial. The American journal of clinical nutrition Vol 34; 1981: 20–3. Not lactose intolerance study
1101. Knopp RH, Brandt K, Arky RA. Effects of aspartame in young persons during weight reduction. Journal of toxicology and environmental health Vol 2; 1976: 417–28. Not lactose intolerance study
1102. Knudsen KB, Welsh JD, Kronenberg RS, et al. Effect of a nonlactose diet on human intestinal disaccharidase activity. Am J Dig Dis 1968 Jul; 13(7):593–7. Not relevant to key questions
1103. Kobayashi A, Kawai S, Obe Y, et al. Effects of dietary lactose and lactase preparation on the intestinal absorption of calcium and magnesium in normal infants. The American journal of clinical nutrition Vol 28; 1975: 681–3. Not eligible target population
1104. Kochhar R, Mehta SK, Goenka MK, et al. Lactose intolerance in idiopathic ulcerative colitis in north Indians. Indian J Med Res 1993 Apr; 98:79–82. Not relevant to key questions
1105. Kocian J, Skala I, Bakos K. Calcium absorption from milk and lactose-free milk in healthy subjects and patients with lactose intolerance. Digestion 1973 Nov; 9(4):317–24. Not eligible outcomes
1106. Kocian J, Vulterinova M, Bejblova O, et al. Influence of lactose intolerance on the bones of patients after partial gastrectomy. Digestion 1973; 8(4):324–35. Not eligible target population
1107. Koetse HA, Klaassen D, van der Molen AR, et al. Combined LDI/SAT test to evaluate intestinal lactose digestion and mucosa permeability. Eur J Clin Invest 2006 Oct; 36(10):730‐ 6. Not relevant to key questions
1108. Koetse HA, Vonk RJ, Gonera-De Jong GB, et al. Low lactase activity in a small-bowel biopsy specimen: should dietary lactose intake be restricted in children with small intestinal mucosal damage? Scand J Gastroenterol 2006 Jan; 41(1):37–41. Not relevant to key questions
1109. Kohlenberg-Mueller K, Raschka L. Calcium balance in young adults on a vegan and lactovegetarian diet. J Bone Miner Metab 2003; 21(1):28–33. not eligible outcomes
1110. Kokke FT, van ERM, van OFM, et al. [A new biscuit free of cow's milk, chicken egg protein, lactose and gluten for children with food hypersensitivity]. Nederlands tijdschrift voor geneeskunde Vol 138; 1994: 2549–52. Not English language
1111. Kokkonen J, Haapalahti M, Tikkanen S, et al. Gastrointestinal complaints and diagnosis in children: a population-based study. Acta Paediatr 2004 Jul; 93(7):880–6. Not relevant to key questions
1112. Kokkonen J, Mottonen M, Karttunen TJ, et al. Mucosal pathology of the upper gastrointestinal tract associated with intensive chemotherapy in children: vitamin A supplements do not prevent lesions. Pediatric Hematology & Oncology 2002 Apr–May; 19(3):181–92. Ineligible number of subjects
1113. Kokkonen J, Simila S. Cow's milk intolerance with melena. Eur J Pediatr 1980 Dec; 135(2):189–94. Not relevant to key questions
1114. Kolars JC, Levitt MD, Aouji M, et al. Yogurt--an autodigesting source of lactose. N Engl J Med 1984 Jan 5; 310(1):1–3. Not relevant to key questions
1115. Koller WC, Block GA, Ahlskog JE, et al. Effect of MK-458 (HPMC) in Parkinson's disease previously untreated with dopaminergic drugs. A double-blind, placebo-controlled multicenter study. Clinical neuropharmacology Vol 14; 1991: 322–9. Not lactose intolerance study
1116. Kondo T, Liu F, Toda Y. Milk is a useful test meal for measurement of small bowel transit time. J Gastroenterol 1994 Dec; 29(6):715–20. Not relevant to key questions
1117. Konstantynowicz J, Nguyen TV, Kaczmarski M, et al. Fractures during growth: potential role of a milk-free diet. Osteoporos Int 2007 Dec; 18(12):1601–7. Not relevant to key questions
1118. Kopp-Hoolihan L. Prophylactic and therapeutic uses of probiotics: a review. Journal of the American Dietetic Association 2001 Feb; 101(2):229–38; quiz 39–41. Not original research
1119. Kordansky D, Adkinson NF, Jr., Norman PS, et al. Asthma improved by nonsteroidal anti‐inflammatory drugs. Annals of Internal Medicine Vol 88; 1978: 508–11. Not lactose intolerance study
1120. Kordansky DW, Rosenthal RR, Norman PS. The effect of vitamin C on antigen-induced bronchospasm. The Journal of allergy and clinical immunology Vol 63; 1979: 61–4. Not lactose intolerance study
1121. Korede O. Effect of supplementation with water-soluble vitamins on erythrocyte alanine aminotransferase activity of healthy adolescents. Annals of nutrition & metabolism Vol 35; 1991: 77–81. Not lactose intolerance study
1122. Koskinen S. Long-term follow-up of health in blood donors with primary selective IgA deficiency. Journal of Clinical Immunology 1996 May; 16(3):165–70. No prevalence data
1123. Kosnai I, Kuitunen P, Savilahti E, et al. Mast cells and eosinophils in the jejunal mucosa of patients with intestinal cow's milk allergy and celiac disease of childhood. J Pediatr Gastroenterol Nutr 1984 Jun; 3(3):368–72. Not relevant to key questions
1124. Kosonen H, Rimpela A, Rauma AL, et al. Consumption of special diet among Finnish adolescents in 1979–2001: repeated national cross-sectional surveys. Sozial- und Praventivmedizin 2005; 50(3):142–50. No prevalence data
1125. Kowalski R. Lactose intolerance how widespread? Nurs Care 1977 May; 10(5):30, 4. Not relevant to key questions
1126. Kozlov AI. Hypolactasia in the indigenous populations of northern Russia. Int J Circumpolar Health 1998 Jan; 57(1):18–21. Not relevant to key questions
1127. Krasilnikoff PA, Gudman-Hoyer E, Moltke HH. Diagnostic value of disaccharide tolerance tests in children. Acta Paediatr Scand 1975 Sep; 64(5):693–8. Not relevant to key questions
1128. Krawczyk M, Wolska M, Schwartz S, et al. Concordance of genetic and breath tests for lactose intolerance in a tertiary referral centre. Journal of Gastrointestinal & Liver Diseases 2008 Jun; 17(2):135–9. Ineligible number of subjects
1129. Kresse H, von Figura K, Klein U, et al. Enzymic diagnosis of the genetic mucopolysaccharide storage disorders. Methods Enzymol 1982; 83:559–72. Not relevant to key questions
1130. Kretchmer N. Lactose and lactase. Sci Am 1972 Oct; 227(4):71–8. Not relevant to key questions
1131. Kretchmer N. The geography and biology of lactose digestion and malabsorption. Postgrad Med J 1977; 53 Suppl 2:65–72. Not relevant to key questions
1132. Kretchmer N, Ransome-Kuti O. Lactose intolerance: an international problem. Proc Inst Med Chic 1970 Nov; 28(6):213–7. Not relevant to key questions
1133. Kretchmer N, Ransome-Kuti O, Hurwitz R, et al. Intestinal absorption of lactose in Nigerian ethnic groups. Lancet 1971 Aug 21; 2(7721):392–5. Not relevant to key questions
1134. Kretchmer N, Sunshine P. Intestinal disaccharidase deficiency in the sea lion. Gastroenterology 1967 Jul; 53(1):123–9. Not relevant to key questions
1135. Krishnaswamy K, Prasad MP, Krishna TP, et al. A case study of nutrient intervention of oral precancerous lesions in India. European journal of cancer. Part B, Oral oncology Vol 31b; 1995: 41–8. Not lactose intolerance study
1136. Kristinsson JO, Valdimarsson O, Steingrimsdottir L, et al. Relation between calcium intake, grip strength and bone mineral density in the forearms of girls aged 13 and 15. J Intern Med 1994 Oct; 236(4):385–90. Not eligible exposure
1137. Kromhout D. Epidemiology of cardiovascular diseases in Europe. Public Health Nutr 2001 Apr; 4(2B):441–57. Review
1138. Kromhout D. Diet and cardiovascular diseases. J Nutr Health Aging 2001; 5(3):144–9. Review
1139. Kudoh A, Ishihara H, Matsuki A. Effect of carbamazepine on pain scores of unipolar depressed patients with chronic pain: a trial of off-on-off-on design. The Clinical journal of pain Vol 14; 1998: 61–5. Not lactose intolerance study
1140. Kudoh T, Wenger DA. Diagnosis of metachromatic leukodystrophy, Krabbe disease, and Farber disease after uptake of fatty acid-labeled cerebroside sulfate into cultured skin fibroblasts. J Clin Invest 1982 Jul; 70(1):89–97. Not relevant to key questions
1141. Kuitunen P, Kosnai I, Savilahti E. Morphometric study of the jejunal mucosa in various childhood enteropathies with special reference to intraepithelial lymphocytes. Journal of Pediatric Gastroenterology & Nutrition 1982; 1(4):525–31. Ineligible number of subjects
1142. Kukuruzovic RH, Brewster DR. Milk formulas in acute gastroenteritis and malnutrition: a randomized trial. J Paediatr Child Health 2002 Dec; 38(6):571–7. Not eligible target population
1143. Kulaputana O, Thanakomsirichot S, Anomasiri W. Ginseng supplementation does not change lactate threshold and physical performances in physically active Thai men. Journal of the Medical Association of Thailand = Chotmaihet thangphaet Vol 90; 2007: 1172–9. Not lactose intolerance study
1144. Kullisaar T, Songisepp E, Mikelsaar M, et al. Antioxidative probiotic fermented goats' milk decreases oxidative stress-mediated atherogenicity in human subjects. British Journal of Nutrition Vol 90; 2003: 449–56. Not relevant to key questions
1145. Kulski JK, Hartmann PE, Martin JD, et al. Effects of bromocriptine mesylate on the composition of the mammary secretion in non-breast-feeding women. Obstetrics and gynecology Vol 52; 1978: 38–42. Not lactose intolerance study
1146. Kumar V, Chandrasekaran R, Bhaskar R. Carbohydrate intolerance associated with acute gastroenteritis. A prospective study of 90 well-nourished indian infants. Clinical Pediatrics 1977 Dec; 16(12):1123–7. No prevalence data
1147. Kuokkanen M, Butzow R, Rasinpera H, et al. Lactase persistence and ovarian carcinoma risk in Finland, Poland and Sweden. International Journal of Cancer 2005 Oct 20; 117(1):90‐ 4. No prevalence data
1148. Kuokkanen M, Kokkonen J, Enattah NS, et al. Mutations in the translated region of the lactase gene (LCT) underlie congenital lactase deficiency. Am J Hum Genet 2006 Feb; 78(2):339–44. Not relevant to key questions
1149. Kuokkanen M, Myllyniemi M, Vauhkonen M, et al. A biopsy-based quick test in the diagnosis of duodenal hypolactasia in upper gastrointestinal endoscopy. Endoscopy 2006 Jul; 38(7):708–12. Not relevant to key questions
1150. Kuriyama M, Ariga T, Ando S, et al. Urinary sialyloligosaccharides in adult type sialidosis: occurrence of two positional isomers. Jpn J Exp Med 1981 Apr; 51(2):129–32. Not relevant to key questions
1151. Kuriyama M, Someya F, Yamada T, et al. Radioassay method of neuraminidase towards N-acetylneuraminosyl hexasaccharides. Clin Chim Acta 1982 Feb 26; 119(1–2):73–80. Not relevant to key questions
1152. Kwinta P, Mitkowska Z, Kruczek P, et al. [Influence of the lactose free and lactose containing diet on prevalence of gram-negative sepsis and feeding intolerance in very low birth weight infants: double-blind randomized trial]. Przegla?d lekarski Vol 59; 2002: 63–6. Not English language
1153. Kwok T, Woo J, Kwan M. Does low lactose milk powder improve the nutritional intake and nutritional status of frail older Chinese people living in nursing homes? Journal of Nutrition, Health & Aging 2001; 5(1):17–21. Ineligible number of subjects
1154. Kwok TC, Chan TY, Woo J. Relationship of urinary sodium/potassium excretion and calcium intake to blood pressure and prevalence of hypertension among older Chinese vegetarians. Eur J Clin Nutr 2003 Feb; 57(2):299–304. not eligible outcomes
1155. Labayen I, Forga L, Gonzalez A, et al. Relationship between lactose digestion, gastrointestinal transit time and symptoms in lactose malabsorbers after dairy consumption. Aliment Pharmacol Ther 2001 Apr; 15(4):543–9. Not relevant to key questions
1156. Lacassie Y, Weinberg R, Monckeberg F. Poor predictability of lactose malabsorption from clinical symptoms for Chilean populations. Am J Clin Nutr 1978 May; 31(5):799–804. Not relevant to key questions
1157. Ladas S, Papanikos J, Arapakis G. Lactose malabsorption in Greek adults: correlation of small bowel transit time with the severity of lactose intolerance. Gut 1982 Nov; 23(11):968‐73. No prevalence data
1158. Ladas SD, Grammenos I, Tassios PS, et al. Low-dose lactose, fructose and sorbitol malabsorption and intolerance does not often coexist in normal adults [abstract]. Gut Vol 45; 1999: A290. Not relevant to key questions
1159. Ladas SD, Grammenos I, Tassios PS, et al. Coincidental malabsorption of lactose, fructose, and sorbitol ingested at low doses is not common in normal adults. Dig Dis Sci 2000 Dec; 45(12):2357–62. Not relevant to key questions
1160. Ladas SD, Haritos DN, Raptis SA. Honey may have a laxative effect on normal subjects because of incomplete fructose absorption. The American journal of clinical nutrition Vol 62; 1995: 1212–5. Not relevant to key questions
1161. Lader M. Comparison of amphetamine sulphate and caffeine citrate in man. Psychopharmacologia Vol 14; 1969: 83–94. Not lactose intolerance study
1162. Lagarde D, Chappuis B, Billaud PF, et al. Evaluation of pharmacological aids on physical performance after a transmeridian flight. Medicine and science in sports and exercise Vol 33; 2001: 628–34. Not lactose intolerance study
1163. Lamberg-Allardt C, Karkkainen M, Seppanen R, et al. Low serum 25-hydroxyvitamin D concentrations and secondary hyperparathyroidism in middle-aged white strict vegetarians. Am J Clin Nutr 1993 Nov; 58(5):684–9. Not eligible target population
1164. Lami F, Callegari C, Tatali M, et al. Efficacy of addition of exogenous lactase to milk in adult lactase deficiency. Am J Gastroenterol 1988 Oct; 83(10):1145–9. Not relevant to key questions
1165. Langlais PJ, Mair RG, Whalen PJ, et al. Memory effect of DL-threo-3,4‐dihydroxyphenylserine (DOPS) in human Korsakoff's disease. Psychopharmacology Vol 95; 1988: 250–4. Not lactose intolerance study
1166. Lanng C, Mortensen D, Friis M, et al. Gastrointestinal dysfunction in a community sample of subjects with symptoms of irritable bowel syndrome. Digestion 2003; 67(1–2):14–9. No prevalence data
1167. Lanzkowsky P, Karayalcin G, Miller F, et al. Disaccharidase values in iron-deficient infants. J Pediatr 1981 Oct; 99(4):605–8. Not relevant to key questions
1168. Larsson CL, Johansson GK. Dietary intake and nutritional status of young vegans and omnivores in Sweden. Am J Clin Nutr 2002 Jul; 76(1):100–6. Not relevant to key questions
1169. Larsson CL, Johansson GK. Young Swedish vegans have different sources of nutrients than young omnivores. J Am Diet Assoc 2005 Sep; 105(9):1438–41. Not relevant to key questions
1170. Larsson SC, Orsini N, Wolk A. Milk, milk products and lactose intake and ovarian cancer risk: a meta-analysis of epidemiological studies. Int J Cancer 2006 Jan 15; 118(2):431–41. Not eligible outcomes
1171. Launiala K. The mechanism of diarrhoea in congenital disaccharide malabsorption. Acta Paediatr Scand 1968 Sep; 57(5):425–32. Not relevant to key questions
1172. Launiala K, Kuitunen P, Visakorpi JK. Disaccharidases and histology of duodenal mucosa in congenital lactose malabsorption. Acta Paediatr Scand 1966 May; 55(3):257–63. Not relevant to key questions
1173. Launiala K, Sahi T, Isokoski M, et al. Lactose malabsorption in school-children. Acta Paediatr Scand 1971 May; 60(3):365–6. Not relevant to key questions
1174. Lawlor-Smith C, Lawlor-Smith L. Lactose intolerance. Breastfeed Rev 1998 May; 6(1):29‐30. Review
1175. Lawriw B, I, Barbee JG. Effect of diazepam upon verbal recall associated with simple picture recognition. Psychol Rep Vol 60; 1987: 1139–49. Not lactose intolerance study
1176. Laws HF, 2nd. Effect of lactase on infantile colic.[comment]. Journal of Pediatrics 1991 Jun; 118(6):993–4. No prevalence data
1177. Leahy SC, Higgins DG, Fitzgerald GF, et al. Getting better with bifidobacteria. J Appl Microbiol 2005; 98(6):1303–15. Not relevant to key questions
1178. Lebenthal E. Lactose malabsorption and milk consumption in infants and children. Am J Dis Child 1979 Jan; 133(1):21–3. Not relevant to key questions
1179. Lebenthal E. Impact of digestion and absorption in the weaning period on infant feeding practices. Pediatrics 1985 Jan; 75(1 Pt 2):207–13. Not relevant to key questions
1180. Lebenthal E, Antonowicz I, Shwachman H. Correlation of lactase activity, lactose tolerance and milk consumption in different age groups. Am J Clin Nutr 1975 Jun; 28(6):595‐600. Not relevant to key questions
1181. Lebenthal E, Tsuboi K, Kretchmer N. Characterization of human intestinal lactase and hetero-beta-galactosidases of infants and adults. Gastroenterology 1974 Dec; 67(6):1107–13. Not relevant to key questions
1182. Leblanc JC, Yoon H, Kombadjian A, et al. Nutritional intakes of vegetarian populations in France. Eur J Clin Nutr 2000 May; 54(5):443–9. Not relevant to key questions
1183. Lechin F, Van Der Dijs B, Bentolila A, et al. Antidiarrheal effects of dihydroergotamine. J Clin Pharmacol 1977 May–Jun; 17(5–6):339–49. Not relevant to key questions
1184. Ledochowski M, Murr C, Lass-Florl C, et al. Increased serum amylase and lipase in fructose malabsorbers. Clin Chim Acta 2001 Sep 25; 311(2):119–23. Not relevant to key questions
1185. Ledochowski M, Sperner-Unterweger B, Fuchs D. Lactose malabsorption is associated with early signs of mental depression in females: a preliminary report. Dig Dis Sci 1998 Nov; 43(11):2513–7. Not relevant to key questions
1186. Lee CK. Disaccharidase deficiency and malabsorption of carbohydrates. Singapore Med J 1984 Feb; 25(1):6–13. Not relevant to key questions
1187. Lee CM, Hardy CM. Cocoa feeding and human lactose intolerance. Am J Clin Nutr 1989 May; 49(5):840–4. Not relevant to key questions
1188. Lee JH, Griffiths WJ, Zantout I, et al. Adequacy of endoscopic biopsy specimens for disaccharidase assays. Am J Dig Dis 1978 Dec; 23(12):1129–31. Not relevant to key questions
1189. Lee MF, Krasinski SD. Human adult-onset lactase decline: an update. Nutr Rev 1998 Jan; 56(1 Pt 1):1–8. Review
1190. Lee WS, Boey CC. Chronic diarrhoea in infants and young children: causes, clinical features and outcome. Journal of Paediatrics & Child Health 1999 Jun; 35(3):260–3. Ineligible number of subjects
1191. Leese PT, White KD, Frampton M, et al. Absence of increased fecal blood loss in adult volunteers after oral administration of conventional tablets and osmotic tablets of albuterol. Curr Ther Res Clin Exp Vol 48; 1990: 440–50. Not lactose intolerance study
1192. Leffler DA, Dennis M, Hyett B, et al. Etiologies and predictors of diagnosis in nonresponsive celiac disease. Clin Gastroenterol Hepatol 2007 Apr; 5(4):445–50. Not relevant to key questions
1193. Lehtimaki T, Hutri-Kahonen N, Kahonen M, et al. Adult-type hypolactasia is not a predisposing factor for the early functional and structural changes of atherosclerosis: the Cardiovascular Risk in Young Finns Study. Clinical science 2008 Nov; 115(9):265–71. Not relevant to key questions
1194. Lehtniemi A, Lindholm R. [The effect of Lactobacillus products on lactose intolerance]. Duodecim; lääketieteellinen aikakauskirja Vol 111; 1995: 1027–31. Not English language
1195. Lehtniemi A, Lindholm RK. Alleviation of symptoms of lactase-deficient patients during lactose challenge after administration of enteric coated lactobacilli- preparation.[abstract]. Scand J of Gastroenterol Vol 30; 1995: 114. Not relevant to key questions
1196. Leichter J. Lactose tolerance in a Jewish population. Am J Dig Dis 1971 Dec; 16(12):1123‐ 6. Not relevant to key questions
1197. Leichter J. Lactose tolerance in a Slavic population. Am J Dig Dis 1972 Jan; 17(1):73–6. Not relevant to key questions
1198. Leichter J. Comparison of whole milk and skim milk with aqueous lactose solution in lactose tolerance testing. Am J Clin Nutr 1973 Apr; 26(4):393–6. Not relevant to key questions
1199. Leichter J, Lee M. Lactose intolerance in Canadian West Coast Indians. Am J Dig Dis 1971 Sep; 16(9):809–13. Not relevant to key questions
1200. Leino J, Honkanen O, Kokkonen M, et al. Evaluation of hard gelatin capsules as a rectal dosage form for a freely water-soluble model drug, metoclopramide hydrochloride. S.T.P Pharma Sciences Vol 13; 2003: 141–5. Not lactose intolerance study
1201. Leitzmann C. Vegetarian diets: what are the advantages? Forum Nutr 2005; (57):147–56. Review
1202. Leitzmann P, Heine W, Wutzke KD, et al. Blood glucose, gastric emptying and orocoecal transit time after a conventional breakfast vs. a Kollath breakfast. Zeitschrift fur Ernahrungswissenschaft Vol 37; 1998: 31–7. Not lactose intolerance study
1203. Lembcke B, Fölsch UR, Caspary WF, et al. Influence of metronidazole on the breath hydrogen response and symptoms in acarbose-induced malabsorption of sucrose. Digestion Vol 25; 1982: 186–93. Not relevant to key questions
1204. Lembcke B, Kraus B, Lankisch PG. Small intestinal function in chronic relapsing pancreatitis. Hepato-Gastroenterology 1985 Jun; 32(3):149–51. Ineligible number of subjects
1205. Lembcke B, Schneider H, Lankisch PG. Is the assay of disaccharidase activity in small bowel mucosal biopsy relevant for clinical gastroenterologists? Klin Wochenschr 1989 Jun 1; 67(11):568–75. Not relevant to key questions
1206. Lember M, Tamm A, Piirsoo A, et al. Lactose malabsorption in Khants in western Siberia. Scandinavian Journal of Gastroenterology 1995 Mar; 30(3):225–7. Ineligible number of subjects
1207. Lemire I, Cartier A, Malo JL, et al. Effect of sodium cromoglycate on histamine inhalation tests. The Journal of allergy and clinical immunology Vol 73; 1984: 234–9. Not lactose intolerance study
1208. Lerch MM, Rieband HC, Feldberg W, et al. Concordance of indirect methods for the detection of lactose malabsorption in diabetic and nondiabetic subjects. Digestion 1991; 48(2):81–8. No prevalence data
1209. Lerebours E, N'Djitoyap C, Lavoine A, et al. [Absorption of lactose and intestinal lactosic activities after acute and chronic intake of yoghourt in subjects with lactasis deficiency]. Gastroenterologie Clinique et Biologique Vol 11; 1987: 24a. Not relevant to key questions
1210. Leslie J, MacLean WC, Jr., Graham GG. Effect of an episode of severe malnutrition and age on lactose absorption by recovered infants and children. Am J Clin Nutr 1979 May; 32(5):971–4. Not relevant to key questions
1211. Leung SS, Lee RH, Sung RY, et al. Growth and nutrition of Chinese vegetarian children in Hong Kong. J Paediatr Child Health 2001 Jun; 37(3):247–53. not eligible outcomes
1212. Leveille GA. United States food and nutrition issues--roles of dairy foods. J Dairy Sci 1979 Oct; 62(10):1665–72. Not relevant to key questions
1213. Levenson DI, Bockman RS. A review of calcium preparations. Nutr Rev 1994 Jul; 52(7):221–32. Review
1214. Levin B, Abraham JM, Burgess EA, et al. Congenital lactose malabsorption. Arch Dis Child 1970 Apr; 45(240):173–7. Not relevant to key questions
1215. Levin N, Rattan J, Gilat T. Mineral intake and blood levels in vegetarians. Isr J Med Sci 1986 Feb; 22(2):105–8. Not relevant to key questions
1216. Levitt MD. Intestinal gas. Postgrad Med 1975 Jan; 57(1):77–81. Not relevant to key questions
1217. Levitt MD, Donaldson RM. Use of respiratory hydrogen (H2) excretion to detect carbohydrate malabsorption. J Lab Clin Med 1970 Jun; 75(6):937–45. Not relevant to key questions
1218. Levri KM, Ketvertis K, Deramo M, et al. Do probiotics reduce adult lactose intolerance? A systematic review. J Fam Pract 2005 Jul; 54(7):613–20. Review
1219. Lewindon PJ, Robb TA, Moore DJ, et al. Bowel dysfunction in cystic fibrosis: importance of breath testing. Journal of Paediatrics & Child Health 1998 Feb; 34(1):79–82. No prevalence data
1220. Lewinsky RH, Jensen TG, Moller J, et al. T-13910 DNA variant associated with lactase persistence interacts with Oct-1 and stimulates lactase promoter activity in vitro. Hum Mol Genet 2005 Dec 15; 14(24):3945–53. Not relevant to key questions
1221. Lewith G, Brown PK, Tyrell DA. Controlled study of the effects of a homoeopathic dilution of influenza vaccine on antibody titres in man. Complementary medical research Vol 3; 1989: 22–4. Not lactose intolerance study
1222. Liebman WM. Recurrent abdominal pain in children: lactose and sucrose intolerance, a prospective study. Pediatrics 1979 Jul; 64(1):43–5. Ineligible number of subjects
1223. Liebman WM. Infantile colic. Association with lactose and milk intolerance. JAMA 1981 Feb 20; 245(7):732–3. Not relevant to key questions
1224. Lifschitz CH, Abrams SA. Addition of rice cereal to formula does not impair mineral bioavailability. Journal of pediatric gastroenterology and nutrition Vol 26; 1998: 175–8. Not eligible target population
1225. Lifschitz CH, Bautista A, Gopalakrishna GS, et al. Absorption and tolerance of lactose in infants recovering from severe diarrhea. J Pediatr Gastroenterol Nutr 1985 Dec; 4(6):942–8. Not relevant to key questions
1226. Lifschitz CH, Smith EO, Garza C. Delayed complete functional lactase sufficiency in breast-fed infants. J Pediatr Gastroenterol Nutr 1983; 2(3):478–82. Not relevant to key questions
1227. Lifshitz F. Carbohydrate problems in paediatric gastroenterology. Clin Gastroenterol 1977 May; 6(2):415–29. Not relevant to key questions
1228. Lifshitz F, Coello-Ramirez P, Contreras-Gutierrez ML. The response of infants to carbohydrate oral loads after recovery from diarrhea. J Pediatr 1971 Oct; 79(4):612–7. Not relevant to key questions
1229. Lifshitz F, Coello-Ramirez P, Gutierrez-Topete G, et al. Carbohydrate intolerance in infants with diarrhea. J Pediatr 1971 Nov; 79(5):760–7. Not relevant to key questions
1230. Lifshitz F, Fagundes-Neto U, Ferreira VC, et al. The response to dietary treatment of patients with chronic post-infectious diarrhea and lactose intolerance. Journal of the American College of Nutrition 1990 Jun; 9(3):231–40. Ineligible number of subjects
1231. Lim E, Ali ZA, Attaran R, et al. Evaluating routine diuretics after coronary surgery: a prospective randomized controlled trial. The Annals of thoracic surgery Vol 73; 2002: 153–5. Not lactose intolerance study
1232. Lin CL, Fang TC, Gueng MK. Vascular dilatory functions of ovo-lactovegetarians compared with omnivores. Atherosclerosis 2001 Sep; 158(1):247–51. Not relevant to key questions
1233. Lin LH, See M, Wang NK. Breath hydrogen test for assessment of lactose malabsorption following rotavirus gastroenteritis. J Formos Med Assoc 1990 Dec; 89(12):1072–6. Not relevant to key questions
1234. Lin MY, Savaiano D, Harlander S. Influence of nonfermented dairy products containing bacterial starter cultures on lactose maldigestion in humans. J Dairy Sci 1991 Jan; 74(1):87‐95. Not relevant to key questions
1235. Lingström P, Birkhed D. Effect of buccal administration of a lactose-containing nitroglycerin tablet (Suscard) on plaque pH. Scandinavian journal of dental research Vol 102; 1994: 324–8. Not lactose intolerance study
1236. Liong MT. Probiotics: a critical review of their potential role as antihypertensives, immune modulators, hypocholesterolemics, and perimenopausal treatments. Nutr Rev 2007 Jul; 65(7):316–28. Not relevant to key questions
1237. Lisker R, Aguilar L, Lares I, et al. Double blind study of milk lactose intolerance in a group of rural and urban children. Am J Clin Nutr 1980 May; 33(5):1049–53. Not relevant to key questions
1238. Lisker R, Aguilar L, Zavala C. Intestinal lactase deficiency and milk drinking capacity in the adult. Am J Clin Nutr 1978 Sep; 31(9):1499–503. Not relevant to key questions
1239. Lisker R, Amador A, Meza-Calix A. Intestinal lactase deficiency and milk drinking habits. Rev Invest Clin 1976 Apr–Jun; 28(02):109–12. Not relevant to key questions
1240. Lisker R, Cervantes G, Pérez-Briceño R, et al. Lack of relationship between lactose absorption and senile cataracts. Annals of ophthalmology Vol 20; 1988: 436–8. Not relevant to key questions
1241. Lisker R, Gonzalez B, Daltabuit M. Recessive inheritance of the adult type of intestinal lactase deficiency. Am J Hum Genet 1975 Sep; 27(5):662–4. Not relevant to key questions
1242. Lisker R, Lopez HG, Mora MA, et al. Correlation in the diagnosis of intestinal lactase deficiency between the radiological method and the lactose tolerance test. Rev Invest Clin 1975 Jan–Mar; 27(1):1–5. Not relevant to key questions
1243. Lisker R, Lopez-Habib G, Daltabuit M, et al. Lactase deficiency in a rural area of Mexico. Am J Clin Nutr 1974 Jul; 27(7):756–9. Not relevant to key questions
1244. Lisker R, Moreno-Terrazas O. [Double blind study of milk lactose intolerance in a group of rural children]. Revista de Investigacion Clinica Vol 32; 1980: 363–8. Not relevant to key questions
1245. Lisker R, Solomons NW, Perez Briceno R, et al. Lactase and placebo in the management of the irritable bowel syndrome: a double-blind, cross-over study. American Journal of Gastroenterology 1989 Jul; 84(7):756–62. Ineligible number of subjects
1246. Littman A. Isolated lactase deficit in the adult: a present view. JAMA 1966 Mar 14; 195(11):954–5. Not relevant to key questions
1247. Littman A, Cady AB, Rhodes J. Lactase and other disaccharidase deficiencies in a hospital population. Isr J Med Sci 1968 Jan–Feb; 4(1):110–6. Not relevant to key questions
1248. Liu HY, Tsao MU, Moore B, et al. Bovine milk protein-induced intestinal malabsorption of lactose and fat in infants. Gastroenterology 1968 Jan; 54(1):27–34. Not relevant to key questions
1249. Lloyd B, Halter RJ, Kuchan MJ, et al. Formula tolerance in postbreastfed and exclusively formula-fed infants. Pediatrics Vol 103; 1999: E7. Not relevant to key questions
1250. Lloyd T, Schaeffer JM, Walker MA, et al. Urinary hormonal concentrations and spinal bone densities of premenopausal vegetarian and nonvegetarian women. Am J Clin Nutr 1991 Dec; 54(6):1005–10. not eligible exposure
1251. Lloyd-Still J. Gastroenteritis with secondary disaccharide intolerance. An outbreak in a premature unit. Acta Paediatr Scand 1969 Mar; 58(2):147–50. Not relevant to key questions
1252. Lobley RW, Burrows PC, Warwick R, et al. Simultaneous assessment of intestinal permeability and lactose tolerance with orally administered raffinose, lactose and L-arabinose. Clin Sci (Lond) 1990 Aug; 79(2):175–83. Not relevant to key questions
1253. Lojda Z. Suitability of the azocoupling reaction with 1-naphthyl-beta-D-glucoside for the histochemical demonstration of lactase (lactase-beta-glucosidase complex) in human enterobiopsies. Histochemistry 1975 Jun 9; 43(4):349–53. Not relevant to key questions
1254. London DR, Cuatrecasas P, Birge SJ, Jr., et al. Metabolism of lactose by intestinal mucosa from normal and lactase-deficient subjects. Br Med J 1967 Mar 4; 1(5539):524–6. Not relevant to key questions
1255. Longmore J, Szabadi E, Bradshaw CM. Comparison of the effects of binodaline and amitriptyline on peripheral autonomic functions in healthy volunteers. British journal of clinical pharmacology Vol 19; 1985: 295–300. Not lactose intolerance study
1256. Lopez-Gonzalez MA, Moliner-Peiro F, Alfaro-Garcia J, et al. Sulpiride plus hydroxyzine decrease tinnitus perception. Auris, nasus, larynx Vol 34; 2007: 23–7. Not lactose intolerance study
1257. Lopez-Gonzalez MA, Santiago AM, Esteban-Ortega F. Sulpiride and melatonin decrease tinnitus perception modulating the auditolimbic dopaminergic pathway. The Journal of otolaryngology Vol 36; 2007: 213–9. Not lactose intolerance study
1258. Lorenz-Meyer H, Blum AL, Haemmerli HP, et al. A second enzyme defect in acquired lactase deficiency: lack of small-intestinal phlorizin-hydrolase. Eur J Clin Invest 1972 Aug; 2(5):326–31. Not relevant to key questions
1259. Loriaux SM, Deijen JB, Orlebeke JF, et al. The effects of nicotinic acid and xanthinol nicotinate on human memory in different categories of age. A double blind study. Psychopharmacology Vol 87; 1985: 390–5. Not lactose intolerance study
1260. Lorist MM, Snel J. Caffeine effects on perceptual and motor processes. Electroencephalography and clinical neurophysiology Vol 102; 1997: 401–13. Not lactose intolerance study
1261. Lorist MM, Snel J, Kok A. Influence of caffeine on information processing stages in well rested and fatigued subjects. Psychopharmacology Vol 113; 1994: 411–21. Not lactose intolerance study
1262. Lorist MM, Snel J, Kok A, et al. Acute effects of caffeine on selective attention and visual search processes. Psychophysiology Vol 33; 1996: 354–61. Not lactose intolerance study
1263. Lovelace HY, Barr SI. Diagnosis, symptoms, and calcium intakes of individuals with self-reported lactose intolerance. J Am Coll Nutr 2005 Feb; 24(1):51–7. Not relevant to key questions
1264. Low-Beer TS. Chronic diarrhoea: diagnosis, mechanisms and treatment. Ir J Med Sci 1973 May; 142(3 Suppl):67–73. Not relevant to key questions
1265. Lowe JC, Garrison RL, Reichman AJ, et al. Effectiveness and safety of T3 (Triiodothyronine) therapy for euthyroid fibromyalgia: A double-blind placebo-controlled response-driven crossover study. Clinical Bulletin of Myofascial Therapy Vol 2; 1997: 31–57. Not lactose intolerance study
1266. Lowe JC, Reichman AJ, Yellin J. The process of change during T3 treatment for euthyroid fibromyalgia: A double-blind placebo-controlled crossover study. Clinical Bulletin of Myofascial Therapy Vol 2; 1997: 91–124. Not lactose intolerance study
1267. Lozano JM, Cespedes JA. Lactose vs. lactose free regimen in children with acute diarrhoea: a randomized controlled trial. Archivos Latinoamericanos de Nutricion 1994 Mar; 44(1):6–11. Not relevant to key questions
1268. Lubos MC, Gerrard JW, Buchan DJ. Disaccharidase activities in milk-sensitive and celiac patients. J Pediatr 1967 Mar; 70(3):325–31. Not relevant to key questions
1269. Lucassen PL, Assendelft WJ, Gubbels JW, et al. Effectiveness of treatments for infantile colic: systematic review. Bmj Vol 316; 1998. Not relevant to key questions
1270. Ludan AC. Current management of acute diarrheas in the Philippines. J Singapore Paediatr Soc 1987; 29 Suppl 1:153–8. Not relevant to key questions
1271. Ludvigsson JF. Effect of gastroenteritis during pregnancy on neonatal outcome. European Journal of Clinical Microbiology & Infectious Diseases 2001 Dec; 20(12):843–9. No prevalence data
1272. Luke B. Lactose intolerance during pregnancy: significance and solutions. MCN Am J Matern Child Nurs 1977 Mar–Apr; 2(2):93–6. Not relevant to key questions
1273. Lund-Hansen T, Hoyer PE, Andersen H. A quantitative cytochemical assay of beta-galactosidase in single cultured human skin fibroblasts. Histochemistry 1984; 81(4):321–30. Not relevant to key questions
1274. Lundquist G, Hedenstedt S. Jejunal transposition in stomach surgery: indications and results. Acta Chirurgica Scandinavica - Supplementum 1975; 457:1–83. No prevalence data
1275. Luyken R. Studies on milk intolerance. A review of literature for Latin America. Paediatr Indones 1971 Nov–Dec; 11(6):233–50. Not relevant to key questions
1276. Luyken R. Medical research in Kenya. III. Nutrition. Trop Geogr Med 1977 Jun; 29(2):S25–30. Not relevant to key questions
1277. Luyken R, Luyken-Koning FW. Lactose intolerance in Kenya. Proc Nutr Soc 1972 May; 31(1):6A. Not relevant to key questions
1278. Luyken R, Luyken-Koning FW, Immikhuizen MJ. Lactose intolerance in Surinam. Trop Geogr Med 1971 Mar; 23(1):54–8. Not relevant to key questions
1279. Lyytikainen A, Lamberg-Allardt C, Kannas L, et al. Food consumption and nutrient intakes with a special focus on milk product consumption in early pubertal girls in Central Finland. Public health nutrition 2005 May; 8(3):284–9. Not relevant to key questions
1280. Macdonald MJ, Horowitz R, Duncan TG. Use of the lactose-ethanol tolerance test in diabetes. Am J Med Sci 1975 Mar–Apr; 269(2):193–9. Not relevant to key questions
1281. Machiels F, De Maeseneer M, Van Snick A, et al. A rare cause of rickets in a young child. J Belge Radiol 1995 Oct; 78(5):276–7. Case Reports
1282. MacLean WC, Jr., Graham GC. Evaluation of a low-lactose nutritional supplement in malnourished children. J Am Diet Assoc 1975 Dec; 67(6):558–64. Not relevant to key questions
1283. MacPhee IT, Sircus W, Farmer ED, et al. Use of steroids in treatment of aphthous ulceration. British medical journal Vol 2; 1968: 147–9. Not lactose intolerance study
1284. Madsen PO, Pedersen JF, Knuth OE. Endocrine treatment of cancer of the prostate. Wisconsin medical journal Vol 69; 1970: 177–81. Not lactose intolerance study
1285. Madzarovova N. Activity of intestinal disaccharidases. Rev Czech Med 1969; 15(4):212‐34. Review
1286. Maesen FP, Smeets JJ, Sledsens TJ, et al. Tiotropium bromide, a new long-acting antimuscarinic bronchodilator: a pharmacodynamic study in patients with chronic obstructive pulmonary disease (COPD). Dutch Study Group. The European respiratory journal : official journal of the European Society for Clinical Respiratory Physiology Vol 8; 1995: 1506–13. Not lactose intolerance study
1287. Maffei HV, Daher SR, Moreira FL. Carbohydrate malabsorption in infants with diarrhea: diagnostic and evolutive aspects. Arq Gastroenterol 1984 Jul–Sep; 21(3):136–42. Not relevant to key questions
1288. Maffei HV, Metz G, Bampoe V, et al. Lactose intolerance, detected by the hydrogen breath test, in infants and children with chronic diarrhoea. Arch Dis Child 1977 Oct; 52(10):766–71. Not relevant to key questions
1289. Mahé S, Marteau P, Huneau JF, et al. Intestinal nitrogen and electrolyte movements following fermented milk ingestion in man. The British journal of nutrition Vol 71; 1994: 169–80. Not eligible target population
1290. Maki KC, Davidson MH, Malik KC, et al. Cholesterol lowering with high-viscosity hydroxypropylmethylcellulose. The American journal of cardiology Vol 84; 1999: 1198–203. Not lactose intolerance study
1291. Maldonado J, Gil A, Narbona E, et al. Special formulas in infant nutrition: a review. Early Hum Dev 1998 Dec; 53 Suppl:S23–32. Not relevant to key questions
1292. Malik GM, Khuroo MS, Ahmed SZ. Incidence of lactose intolerance in Kashmir. J Assoc Physicians India 1977 Sep; 25(9):623–5. Not relevant to key questions
1293. Mallinson CN. Effect of pancreatic insufficiency and intestinal lactase deficiency on the gastric emptying of starch and lactose. Gut 1968 Dec; 9(6):737. Not relevant to key questions
1294. Maluenda C, Phillips AD, Briddon A, et al. Quantitative analysis of small intestinal mucosa in cow's milk-sensitive enteropathy. J Pediatr Gastroenterol Nutr 1984 Jun; 3(3):349‐56. Not relevant to key questions
1295. Mandell HN. Lactose intolerance--a case of bovine revenge? Med Times 1978 Apr; 106(4):71–7. Not relevant to key questions
1296. Mann MD, Hill ID, Bowie MD. Absorption and retention in acute diarrhoea. European journal of clinical nutrition Vol 44; 1990: 629–35. Not relevant to key questions
1297. Marangella M, Bianco O, Martini C, et al. Effect of animal and vegetable protein intake on oxalate excretion in idiopathic calcium stone disease. Br J Urol 1989 Apr; 63(4):348–51. Not eligible target population
1298. Mardirossian G, Cooper SA. Comparison of the analgesic efficacy of flurbiprofen and aspirin for postsurgical dental pain. Journal of oral and maxillofacial surgery : official journal of the American Association of Oral and Maxillofacial Surgeons Vol 43; 1985: 106–9. Not lactose intolerance study
1299. Margetts BM, Beilin LJ, Vandongen R, et al. Vegetarian diet in mild hypertension: a randomised controlled trial. Br Med J (Clin Res Ed) 1986 Dec 6; 293(6560):1468–71. Not eligible outcomes
1300. Marien P, Molla AM, Eggermont E. Coeliac disease in childhood. Problems in differential diagnosis. Acta Gastroenterol Belg 1986 Jul–Aug; 49(4):387–92. Not relevant to key questions
1301. Marino DD, King JC. Nutritional concerns during adolescence. Pediatr Clin North Am 1980 Feb; 27(1):125–39. Review
1302. Mark LC. Letter: Avoiding the pain of veinpuncture. N Engl J Med 1976 Mar 11; 294(11):614. Not relevant to key questions
1303. Marrs DC. Milk drinking by the elderly of three races. J Am Diet Assoc 1978 May; 72(5):495–8. Not relevant to key questions
1304. Marsh AA, Finger EC, Buzas B, et al. Impaired recognition of fear facial expressions in 5‐HTTLPR S-polymorphism carriers following tryptophan depletion. Psychopharmacology Vol 189; 2006: 387–94. Not lactose intolerance study
1305. Marsh AG, Ford DL, Christensen DK. Metabolic response of adolescent girls to a lacto‐ovo-vegetarian diet. J Am Diet Assoc 1967 Nov; 51(5):441–6. Not eligible outcomes
1306. Marsh AG, Sanchez TV, Midkelsen O, et al. Cortical bone density of adult lacto-ovo‐vegetarian and omnivorous women. J Am Diet Assoc 1980 Feb; 76(2):148–51. Not target population
1307. Marteau P, Boutron-Ruault MC. Nutritional advantages of probiotics and prebiotics. Br J Nutr 2002 May; 87 Suppl 2:S153–7. Not relevant to key questions
1308. Marteau P, Flourie B, Pochart P, et al. Effect of the microbial lactase (EC 3.2.1.23) activity in yoghurt on the intestinal absorption of lactose: An in vivo study in lactase-deficient humans. British Journal of Nutrition Vol 64; 1990: 71–9. Not relevant to key questions
1309. Marteau P, Messing B, Arrigoni E, et al. Do patients with short-bowel syndrome need a lactose-free diet? Nutrition 1997 Jan; 13(1):13–6. Not relevant to key questions
1310. Marteau P, Seksik P, Jian R. Probiotics and intestinal health effects: a clinical perspective. Br J Nutr 2002 Sep; 88 Suppl 1:S51–7. Not relevant to key questions
1311. Marteau PR. Probiotics in clinical conditions. Clin Rev Allergy Immunol 2002 Jun; 22(3):255–73. Not relevant to key questions
1312. Martini MC, Bollweg GL, Levitt MD, et al. Lactose digestion by yogurt beta-galactosidase: influence of pH and microbial cell integrity. Am J Clin Nutr 1987 Feb; 45(2):432–6. Not relevant to key questions
1313. Martini MC, Kukielka D, Savaiano DA. Lactose digestion from yogurt: influence of a meal and additional lactose. Am J Clin Nutr 1991 May; 53(5):1253–8. Not relevant to key questions
1314. Martini MC, Lerebours EC, Lin WJ, et al. Strains and species of lactic acid bacteria in fermented milks (yogurts): effect on in vivo lactose digestion. Am J Clin Nutr Vol 54; 1991: 1041–6. Not relevant to key questions
1315. Martini MC, Savaiano DA. Reduced intolerance symptoms from lactose consumed during a meal. Am J Clin Nutr 1988 Jan; 47(1):57–60. Not relevant to key questions
1316. Marvel ME, Bertino JS. Comparative effects of an elemental and a complex enteral feeding formulation on the absorption of phenytoin suspension. JPEN. Journal of parenteral and enteral nutrition Vol 15; 1991: 316–8. Not relevant to key questions
1317. Mascart-Lemone F, Van Pachterbeek T, Duchateau J, et al. Serum IgA anti-gliadin antibodies (monomeric versus dimeric) in childhood coeliac disease. Acta Gastroenterol Belg 1986 Jul–Aug; 49(4):415–22. Not relevant to key questions
1318. Mascolo R, Saltzman JR. Lactose intolerance and irritable bowel syndrome. Nutrition Reviews 1998 Oct; 56(10):306–8. Not original research
1319. Massler M. Geriatric nutrition. I: Osteoporosis. Calcif Tissue Int 1979 Sep; 42(3):252–4. Comment
1320. Mathur GP, Gandhi KK, Mathur S, et al. Lactobacillus therapy. Indian Pediatr 1991 Feb; 28(2):199–204. Not relevant to key questions
1321. Matsumura T, Kuroume T, Amada K. Close relationship between lactose intolerance and allergy to milk protein. J Asthma Res 1971 Sep; 9(1):13–29. Not relevant to key questions
1322. Mattar R, Monteiro Mdo S, Villares CA, et al. Single nucleotide polymorphism C/T(‐13910), located upstream of the lactase gene, associated with adult-type hypolactasia: validation for clinical practice. Clin Biochem 2008 May; 41(7–8):628–30. Not relevant to key questions
1323. Matthews SB, Waud JP, Roberts AG, et al. Systemic lactose intolerance: a new perspective on an old problem. Postgrad Med J 2005 Mar; 81(953):167–73. Not relevant to key questions
1324. Mattila MJ, Palva E, Seppälä T, et al. Actions and interactions with alcohol of drugs on psychomotor skills: comparison of diazepam and gamma-hydroxybutyric acid. Archives internationales de pharmacodynamie et de thérapie Vol 234; 1978: 236–46. Not lactose intolerance study
1325. Maulén-Radován I, Brown KH, Acosta MA, et al. Comparison of a rice-based, mixed diet versus a lactose-free, soy-protein isolate formula for young children with acute diarrhea. The Journal of pediatrics Vol 125; 1994: 699–706. Not relevant to key questions
1326. Mavromichalis J, Brueton MJ, McNeish AS, et al. Evaluation of the intraepithelial lymphocyte count in the jejunum in childhood enteropathies. Gut 1976 Aug; 17(8):600–3. Not relevant to key questions
1327. Max MB, Schafer SC, Culnane M, et al. Amitriptyline, but not lorazepam, relieves postherpetic neuralgia. Neurology Vol 38; 1988: 1427–32. Not lactose intolerance study
1328. Maxwell GM, Elliott RB. Nutritional state of Australian aboriginal children. Am J Clin Nutr 1969 Jun; 22(6):716–24. Not relevant to key questions
1329. Maxwell JD, McKiddie MT, Ferguson A, et al. Plasma insulin response to oral carbohydrate in patients with glucose and lactose malabsorption. Gut 1970 Nov; 11(11):962–5. Not relevant to key questions
1330. May DC, Jarboe CH, Ellenburg DT, et al. The effects of erythromycin on theophylline elimination in normal males. Journal of clinical pharmacology Vol 22; 1982: 125–30. Not lactose intolerance study
1331. Mayer PJ, Beeken WL. The role of urinary indican as a predictor of bacterial colonization in the human jejunum. Am J Dig Dis 1975 Nov; 20(11):1003–9. Not relevant to key questions
1332. Mayne AJ, Brown GA, Sule D, et al. Postnatal development of disaccharidase activities in jejunal fluid of preterm neonates. Gut 1986 Nov; 27(11):1357–61. Ineligible number of subjects
1333. McBean LD, Miller GD. Allaying fears and fallacies about lactose intolerance. Journal of the American Dietetic Association 1998 Jun; 98(6):671–6. Not original research
1334. McCarthy OR. The prevention of exercise induced asthma. British journal of diseases of the chest Vol 66; 1972: 133–40. Not lactose intolerance study
1335. McCarty MF. A moderately low phosphate intake may provide health benefits analogous to those conferred by UV light - a further advantage of vegan diets. Med Hypotheses 2003 Nov–Dec; 61(5–6):543–60. Not eligible exposure
1336. McCarty MF. Sub-optimal taurine status may promote platelet hyperaggregability in vegetarians. Med Hypotheses 2004; 63(3):426–33. Not relevant to key questions
1337. McClean P, Lynch AB, Dodge JA. Comparison of three regimens in the management of acute gastroenteritis in infants. Alimentary pharmacology & therapeutics Vol 4; 1990: 457‐64. Not relevant to key questions
1338. McClure RJ, Newell SJ. Randomized controlled study of digestive enzyme activity following trophic feeding. Acta Paediatrica 2002; 91(3):292–6. No prevalence data
1339. McConnell EA. Myths & facts ... about lactose intolerance. Nursing 1999 Mar; 29(3):71. Not relevant to key questions
1340. McCracken RD. Adult lactose tolerance. JAMA 1970 Sep 28; 213(13):2257–60. Not relevant to key questions
1341. McCracken RD. Origins and implications of the distribution of adult lactase deficiency in human populations. J Trop Pediatr Environ Child Health 1971 Mar; 17(1):7–10. Not relevant to key questions
1342. McDonagh TJ. Lactose intolerance: a newly recognized cause of gastrointestinal symptoms seen in the practice of occupational medicine. J Occup Med 1969 Feb; 11(2):57–64. Not relevant to key questions
1343. McDonald GS, Willoughby E, Weir DG. The incidence of lactase deficiency following partial gastrectomy. Ir J Med Sci 1969 Oct; 8(10):481–8. Not relevant to key questions
1344. McDonald GS, Willoughby E, Weir DG, et al. Milk intolerance in clinical practice. J Ir Med Assoc 1966 Dec; 59(354):179–83. Not relevant to key questions
1345. McDonough FE, Hitchins AD, Wong NP, et al. Modification of sweet acidophilus milk to improve utilization by lactose-intolerant persons. Am J Clin Nutr 1987 Mar; 45(3):570–4. Not relevant to key questions
1346. McGee T. For parents. Planning a vegetarian diet. Diabetes Self Manag 2002 Jul–Aug; 19(4):53–4, 6, 9. Parent education
1347. McGill CR, Fulgoni VL, 3rd, DiRienzo D, et al. Contribution of dairy products to dietary potassium intake in the United States population. Journal of the American College of Nutrition 2008 Feb; 27(1):44–50. Not relevant to key questions
1348. McGill DB, Newcomer AD. Comparison of venous and capillary blood samples in lactose tolerance testing. Gastroenterology 1967 Sep; 53(3):371–4. Not relevant to key questions
1349. McGrath PJ, Feldman W. Clinical approach to recurrent abdominal pain in children. J Dev Behav Pediatr 1986 Feb; 7(1):56–63. Not relevant to key questions
1350. McGrath PJ, Goodman JT, Firestone P, et al. Recurrent abdominal pain: a psychogenic disorder? Arch Dis Child 1983 Nov; 58(11):888–90. Not relevant to key questions
1351. McIntyre BA, Philp RB, Inwood MJ. Effect of ibuprofen on platelet function in normal subjects and hemophiliac patients. Clinical pharmacology and therapeutics Vol 24; 1978: 616–21. Not lactose intolerance study
1352. McMahan S, South C, Crespin S. Lactose intolerance. Strategies for symptom management. Adv Nurse Pract 2002 Jun; 10(6):71–4. Not relevant to key questions
1353. McMahon FG, Vargas R, Leese P, et al. Controlled-release dosage forms and gastrointestinal blood loss: Four clinical studies. Int. J. Pharm. Vol 91; 1993: 75–84. Not lactose intolerance study
1354. McMichael HB. The irrelevancies of disaccharidase assays. Acta Hepatogastroenterol (Stuttg) 1972 Jul–Aug; 19(4):281–90. Not relevant to key questions
1355. McMichael HB, Webb J, Dawson AM. Jejunal disaccharidases and some observations on the cause of lactase deficiency. Br Med J 1966 Oct 29; 2(5521):1037–41. Not relevant to key questions
1356. McMichael HB, Webb J, Dawson AM. The absorption of maltose and lactose in man. Clin Sci 1967 Aug; 33(1):135–45. Not relevant to key questions
1357. McNair A, Olsen J. Disaccharidase activity in chronic renal failure. Acta Med Scand 1974 Jan–Feb; 195(1–2):93–6. Not relevant to key questions
1358. McNeill AD, Owen LA, Belcher M, et al. Abstinence from smoking and expired-air carbon monoxide levels: lactose intolerance as a possible source of error. Am J Public Health 1990 Sep; 80(9):1114–5. Not relevant to key questions
1359. McNeish AS, Sweet EM. Lactose intolerance in childhood coeliac disease. Assessment of its incidence and importance. Arch Dis Child 1968 Aug; 43(230):433–7. Not relevant to key questions
1360. Meador KJ, Nichols ME, Franke P, et al. Evidence for a central cholinergic effect of high-dose thiamine. Annals of neurology Vol 34; 1993: 724–6. Not lactose intolerance study
1361. Medow MS, Glassman MS, Schwarz SM, et al. Respiratory methane excretion in children with lactose intolerance. Dig Dis Sci 1993 Feb; 38(2):328–32. Not relevant to key questions
1362. Medow MS, Thek KD, Newman LJ, et al. Beta-galactosidase tablets in the treatment of lactose intolerance in pediatrics. Am J Dis Child 1990 Nov; 144(11):1261–4. Not relevant to key questions
1363. Meeusen R, Piacentini MF, Van DES, et al. Exercise performance is not influenced by a 5‐HT reuptake inhibitor. International journal of sports medicine Vol 22; 2001: 329–36. Not lactose intolerance study
1364. Mehuys E, Remon JP, Korst A, et al. Human bioavailability of propranolol from a matrix‐in-cylinder system with a HPMC-Gelucire core. Journal of controlled release : official journal of the Controlled Release Society Vol 107; 2005: 523–36. Not lactose intolerance study
1365. Meloni G, Ogana A, Mannazzu MC, et al. High prevalence of lactose absorbers in patients with presenile cataract from northern Sardinia. British Journal of Ophthalmology 1995 Jul; 79(7):709. No prevalence data
1366. Meloni GF, Colombo C, La Vecchia C, et al. High prevalence of lactose absorbers in Northern Sardinian patients with type 1 and type 2 diabetes mellitus. American Journal of Clinical Nutrition 2001 Mar; 73(3):582–5. No prevalence data
1367. Meloni GF, Colombo C, La Vecchia C, et al. Lactose absorption in patients with ovarian cancer. Am J Epidemiol 1999 Jul 15; 150(2):183–6. Not eligible target population
1368. Meloni T, Colombo C, Ogana A, et al. Lactose absorption in patients with glucose 6‐phosphate dehydrogenase deficiency with and without favism. Gut 1996 Aug; 39(2):210–3. Ineligible number of subjects
1369. Meloni T, Colombo C, Ruggiu G, et al. Primary lactase deficiency and past malarial endemicity in Sardinia.[see comment]. Italian Journal of Gastroenterology & Hepatology 1998 Oct; 30(5):490–3. Ineligible number of subjects
1370. Mendis BL, Wijesiriwardena BC, Sheriff MH, et al. Irritable bowel syndrome. Ceylon Medical Journal 1982 Dec; 27(4):171–81. No prevalence data
1371. Menon MPS, Sharma VC, Shivpuri DN. Effect of cromolyn sodium (DSCG) on allergen induced asthma. Indjchest Disallied Sci Vol 18; 1976: 83–9. Not lactose intolerance study
1372. Meretoja J. Inherited syndrome with corneal snowflake dystrophy, oculocutaneous pigmentary disturbances, pseudoexfoliation and malabsorption. Statistical data of some symptoms. Ophthalmic Research 1987; 19(5):245–54. No prevalence data
1373. Mermelstein NH. Food allergies and other food sensitivities. ASDC J Dent Child 1986 Jul–Aug; 53(4):296–9. Not relevant to key questions
1374. Meshitsuka K. Intranasal administration of antihistamine for nasal allergy. Otolaryngology (Tokyo) Vol 54; 1982: 213–7. Not lactose intolerance study
1375. Messina V, Mangels AR. Considerations in planning vegan diets: children. J Am Diet Assoc 2001 Jun; 101(6):661–9. Review
1376. Messina V, Melina V, Mangels AR. A new food guide for North American vegetarians. Can J Diet Pract Res 2003 Summer; 64(2):82–6. Not relevant to key questions
1377. Metalidis C, Knockaert DC, Bobbaers H, et al. Involuntary weight loss. Does a negative baseline evaluation provide adequate reassurance? European Journal of Internal Medicine 2008 Jul; 19(5):345–9. No prevalence data
1378. Metneki J, Czeizel A, Flatz SD, et al. A study of lactose absorption capacity in twins. Hum Genet 1984; 67(3):296–300. Not relevant to key questions
1379. Metz G, Blendis LM, Jenkins DJ. Letter: H2 breath test for lactase deficiency. N Engl J Med 1976 Mar 25; 294(13):730. Not relevant to key questions
1380. Metz G, Jenkins DJ, Peters TJ, et al. Breath hydrogen as a diagnostic method for hypolactasia. Lancet 1975 May 24; 1(7917):1155–7. Not relevant to key questions
1381. Metz GL, Blendis LM, Jenkins JA. Proceedings: Alveolar H2 in the diagnosis of carbohydrate malabsorption. Gut 1975 May; 16(5):398. Not relevant to key questions
1382. Miadonna A, Cottini M, Candiani C, et al. Modulation of allergen-induced nasal symptoms and mediator release by treatment with N-acetyl-aspartyl-glutamate (ZY15106). European journal of clinical pharmacology Vol 46; 1994: 127–31. Not lactose intolerance study
1383. Miadonna A, Milazzo N, Salmaso C, et al. N-acetyl-aspartyl-glutamic acid inhibits cellular recruitment and mediator release during the late allergen-induced nasal reaction. European journal of clinical pharmacology Vol 54; 1998: 515–20. Not lactose intolerance study
1384. Micallef J, Gavaudan G, Burle B, et al. A study of a topiramate pre-treatment on the effects induced by a subanaesthetic dose of ketamine on human reaction time. Neuroscience letters Vol 369; 2004: 99–103. Not lactose intolerance study
1385. Michaelsson K, Holmberg L, Ljunghall S, et al. Effect of prefracture versus postfracture dietary assessment on hip fracture risk estimates. Int J Epidemiol 1996 Apr; 25(2):403–10. not eligible outcomes
1386. Miettinen P, Pasanen P, Lahtinen J, et al. The long-term outcome after negative appendix operation. Annales Chirurgiae et Gynaecologiae 1995; 84(3):267–70. No prevalence data
1387. Mihatsch WA, von SP, Fahnenstich H, et al. Randomized, multicenter trial of two different formulas for very early enteral feeding advancement in extremely-low-birth-weight infants. Journal of pediatric gastroenterology and nutrition Vol 33; 2001: 155–9. Not relevant to key questions
1388. Milla PJ, Moynahan EJ. Acrodermatitis enteropathica with lactose intolerance. Proc R Soc Med 1972 Jul; 65(7):600–1. Not relevant to key questions
1389. Miller JJ, McVeagh P, Fleet GH, et al. Effect of yeast lactase enzyme on "colic" in infants fed human milk. J Pediatr 1990 Aug; 117(2 Pt 1):261–3. Not relevant to key questions
1390. Miller TL, Orav EJ, Martin SR, et al. Malnutrition and carbohydrate malabsorption in children with vertically transmitted human immunodeficiency virus 1 infection. Gastroenterology 1991 May; 100(5 Pt 1):1296–302. Not relevant to key questions
1391. Milne MD. Hereditary disorders of intestinal transport. Biomembranes 1974; 4B(0):961‐1013. Not relevant to key questions
1392. Minami R, Wagatsuma K, Ishikawa Y, et al. Complementation analysis of beta-galactosidase deficiency by means of histochemical method. Tohoku J Exp Med 1985 Jun; 146(2):181–7. Not relevant to key questions
1393. Minenna MF, Palieri A, Panella C, et al. Gastro-oesophageal reflux disease and lactose malabsorption: Casual comorbidity or neglected association? Digestive & Liver Disease 2006 Jun; 38(6):437–8. Not original research
1394. Minoia C, Apostoli P, Maranelli G, et al. Urinary chromium levels in subjects living in two north Italy regions. Sci Total Environ 1988 Jun 1; 71(3):527–31. Not relevant to key questions
1395. Mishkin B, Yalovsky M, Mishkin S. Increased prevalence of lactose malabsorption in Crohn's disease patients at low risk for lactose malabsorption based on ethnic origin. American Journal of Gastroenterology 1997 Jul; 92(7):1148–53. No prevalence data
1396. Mishkin D, Sablauskas L, Yalovsky M, et al. Fructose and sorbitol malabsorption in ambulatory patients with functional dyspepsia: comparison with lactose maldigestion/malabsorption. Digestive Diseases & Sciences 1997 Dec; 42(12):2591–8. No prevalence data
1397. Mishkin S. Dairy sensitivity, lactose malabsorption, and elimination diets in inflammatory bowel disease. American Journal of Clinical Nutrition 1997 Feb; 65(2):564–7. Not original research
1398. Misra S, Sabui TK, Basu S, et al. A prospective study of rotavirus diarrhea in children under 1 year of age. Clinical Pediatrics 2007 Oct; 46(8):683–8. Ineligible number of subjects
1399. Missmer SA, Smith-Warner SA, Spiegelman D, et al. Meat and dairy food consumption and breast cancer: a pooled analysis of cohort studies. Int J Epidemiol 2002 Feb; 31(1):78–85. Not eligible outcomes
1400. Mitchell JD, Brand J, Halbisch J. Weight-gain inhibition by lactose in Australian Aboriginal children. A controlled trial of normal and lactose hydrolysed milk. Lancet 1977 Mar 5; 1(8010):500–2. Not relevant to key questions
1401. Mitchell KJ, Bayless TM, Paige DM, et al. Intolerance of eight ounces of milk in healthy lactose-intolerant teen-agers. Pediatrics 1975 Nov; 56(5):718–21. Ineligible number of subjects
1402. Mittal SK, Mital HS, Dwivedi KK, et al. Lactose malabsorption in irritable colon syndrome. J Assoc Physicians India 1981 Sep; 29(9):751–6. Not relevant to key questions
1403. Mittal SK, Mittal HS, Dwivvedi KK, et al. Lactose malabsorption in healthy adults. J Assoc Physicians India 1979 Feb; 27(2):95–8. Not relevant to key questions
1404. Mobassaleh M, Montgomery RK, Biller JA, et al. Development of carbohydrate absorption in the fetus and neonate. Pediatrics 1985 Jan; 75(1 Pt 2):160–6. Not relevant to key questions
1405. Mokhtar NA, Ghaly IM. Lactose intolerance, a cause of recurrent diarrhea in Kuwait. Gazette of the Egyptian Paediatric Association 1974 Apr; 22(2):113–8. Subjects less than 4 years old
1406. Mombelli B, Gismondo MR. The use of probiotics in medical practice. Int J Antimicrob Agents 2000 Dec; 16(4):531–6. Not relevant to key questions
1407. Montalto M, Curigliano V, Santoro L, et al. Management and treatment of lactose malabsorption. World J Gastroenterol 2006 Jan 14; 12(2):187–91. Not relevant to key questions
1408. Montalto M, Gallo A, Santoro L, et al. Low-dose lactose in drugs neither increases breath hydrogen excretion nor causes gastrointestinal symptoms. Aliment Pharmacol Ther 2008 Oct 15; 28(8):1003–12. Not relevant to key questions
1409. Montaño GML, Orea M. [Frequency of urticaria and angioedema induced by food additives]. Revista alergia México Vol 36; 1989: 15–8. Not relevant to key questions
1410. Montes RG, Bayless TM, Saavedra JM, et al. Effect of milks inoculated with Lactobacillus acidophilus or a yogurt starter culture in lactose-maldigesting children. J Dairy Sci 1995 Aug; 78(8):1657–64. Not relevant to key questions
1411. Montes RG, Perman JA. Lactose intolerance. Pinpointing the source of nonspecific gastrointestinal symptoms. Postgraduate Medicine 1991 Jun; 89(8):175–8. No prevalence data
1412. Moodie PM. Medical aspects of Aboriginal health. Aust Fam Physician 1977 Oct; 6(10):1309–17. Not relevant to key questions
1413. Moore DJ, Robb TA, Davidson GP. Breath hydrogen response to milk containing lactose in colicky and noncolicky infants.[see comment]. Journal of Pediatrics 1988 Dec; 113(6):979‐84. No prevalence data
1414. Moore LG, Cymerman A, Huang SY, et al. Propranolol does not impair exercise oxygen uptake in normal men at high altitude. Journal of applied physiology (Bethesda, Md. : 1985) Vol 61; 1986: 1935–41. Not lactose intolerance study
1415. Moore TJ, McKnight JA. Dietary factors and blood pressure regulation. Endocrinol Metab Clin North Am 1995 Sep; 24(3):643–55. Review
1416. Morales C, Peñarrocha M, Bagán JV, et al. Immunological study of Melkersson-Rosenthal syndrome. Lack of response to food additive challenge. Clinical and experimental allergy : journal of the British Society for Allergy and Clinical Immunology Vol 25; 1995: 260–4. Not lactose intolerance study
1417. Morley D, Woodland M, Cuthbertson WF. Controlled trial of pyrimethamine in pregnant women in an african village. Bmj Vol 1; 1964: 667–8. Not lactose intolerance study
1418. Morrison WJ, Christopher NL, Bayless TM, et al. Low lactase levels: evaluation of the radiologic diagnosis. Radiology 1974 Jun; 111(3):513–8. Not relevant to key questions
1419. Moscato G, Rossi G, Dellabianca A, et al. Local immunotherapy by inhalation of a powder extract in asthma due to house dust mite Dermatophagoides pteronyssinus: a double-blind comparison with parenteral immunotherapy. Journal of investigational allergology & clinical immunology : official organ of the International Association of Asthmology (INTERASMA) and Sociedad Latinoamericana de Alergia e Inmunología Vol 1; 1991: 383–94. Not lactose intolerance study
1420. Moskovitz M, Curtis C, Gavaler J. Does oral enzyme replacement therapy reverse intestinal lactose malabsorption? Am J Gastroenterol 1987 Jul; 82(7):632–5. Not relevant to key questions
1421. Mota-Hernandez F, Gordillo-Paniagua G, Muñoz-Arizpe R, et al. Prednisone versus placebo in membranoproliferative glomerulonephritis: long-term clinicopathological correlations. The International journal of pediatric nephrology Vol 6; 1985: 25–8. Not lactose intolerance study
1422. Mottes M, Belpinati F, Milani M, et al. Genetic testing for adult-type hypolactasia in Italian families. Clin Chem Lab Med 2008; 46(7):980–4. Not relevant to key questions
1423. Motulsky AG. Human genetic variation and nutrition. Am J Clin Nutr 1987 May; 45(5 Suppl):1108–13. Not relevant to key questions
1424. Moukarzel AA, Lesicka H, Ament ME. Irritable bowel syndrome and nonspecific diarrhea in infancy and childhood--relationship with juice carbohydrate malabsorption. Clinical Pediatrics 2002 Apr; 41(3):145–50. Ineligible number of subjects
1425. Moya M, Cortés E, Juste M, et al. [Absorptive pattern of individual fatty acids and total fat in full term babies. Its stability in the absence of lactose]. Anales españoles de pediatría Vol 48; 1998: 515–21. Not relevant to key questions
1426. Moya M, Cortes E, Vento M, et al. Impaired absorption of calcium in term babies on lactose free formula (LFF) with vitamin D repletion [abstract]. Pediatric Research Vol 28; 1990: 309. Not relevant to key questions
1427. Moya M, Lifschitz C, Ameen V, et al. A metabolic balance study in term infants fed lactose-containing or lactose-free formula. Acta Paediatrica 1999 Nov; 88(11):1211–5. Ineligible number of subjects
1428. Moynahan EJ, Barnes PM. Zinc deficiency and a synthetic diet for lactose intolerance. Lancet 1973 Mar 24; 1(7804):676–7. Not relevant to key questions
1429. Moynihan P. Dietary therapy in chronically sick children: dental health considerations. Quintessence Int 2006 Jun; 37(6):444–8. Not relevant to key questions
1430. Moynihan PJ, Wright WG, Walton AG. A comparison of the relative acidogenic potential of infant milk and soya infant formula: a plaque pH study. International journal of paediatric dentistry / the British Paedodontic Society [and] the International Association of Dentistry for Children Vol 6; 1996: 177–81. Not eligible outcomes
1431. Mueller OT, Shows TB. Human beta-galactosidase and alpha-neuraminidase deficient mucolipidosis: genetic complementation analysis of the neuraminidase deficiency. Hum Genet 1982; 60(2):158–62. Not relevant to key questions
1432. Mujika I, Chatard JC, Lacoste L, et al. Creatine supplementation does not improve sprint performance in competitive swimmers. Medicine and science in sports and exercise Vol 28; 1996: 1435–41. Not lactose intolerance study
1433. Munck LK, Kjeldsen J, Philipsen E, et al. Incomplete remission with short-term prednisolone treatment in collagenous colitis: a randomized study. Scandinavian journal of gastroenterology Vol 38; 2003: 606–10. Not lactose intolerance study
1434. Munir M. Protracted diarrhea in infants and young children. A clinical evaluation with special reference to the role of infection. Paediatr Indones 1982 May–Jun; 22(5–6):89–98. Not relevant to key questions
1435. Munir M. Determinants of chronic diarrhea in infants in Manado. Paediatr Indones 1985 Jan–Feb; 25(1–2):22–32. Not relevant to key questions
1436. Munir M. Infantile diarrhoea: breast and bottle feeding compared with special reference to their clinical role. Paediatrica Indonesiana 1985 May–Jun; 25(5–6):100–6. No prevalence data
1437. Murphy MS, Sood M, Johnson T. Use of the lactose H2 breath test to monitor mucosal healing in coeliac disease. Acta Paediatr 2002; 91(2):141–4. Not relevant to key questions
1438. Murphy S, Khaw KT, May H, et al. Milk consumption and bone mineral density in middle aged and elderly women. Bmj 1994 Apr 9; 308(6934):939–41. not eligible outcomes
1439. Murray RD, Boutton TW, Klein PD, et al. Comparative absorption of [13C]glucose and [13C]lactose by premature infants. Am J Clin Nutr 1990 Jan; 51(1):59–66. Not relevant to key questions
1440. Murtagh J. Test for lactose intolerance. Aust Fam Physician 1993 Jul; 22(7):1272. Not relevant to key questions
1441. Murthy MS, Haworth JC. Intestinal lactase deficiency among east Indians. An adaptive rather than a genetically inherited phenomenon? Am J Gastroenterol 1970 Mar; 53(3):246–51. Not relevant to key questions
1442. Mustadjab I, Munir M. Lactose intolerance in pateints with gastroenteritis between 0--2 years of age. Paediatr Indones 1976 Nov–Dec; 16(11–12):415–29. Not relevant to key questions
1443. Mutalik S, Naha A, Usha AN, et al. Preparation, in vitro, preclinical and clinical evaluations of once daily sustained release tablets of aceclofenac. Archives of pharmacal research Vol 30; 2007: 222–34. Not lactose intolerance study
1444. Mutch PB. Food guides for the vegetarian. Am J Clin Nutr 1988 Sep; 48(3 Suppl):913–9. Review
1445. Myers VH, Champagne CM. Nutritional effects on blood pressure. Curr Opin Lipidol 2007 Feb; 18(1):20–4. Not relevant to key questions
1446. Myles S, Bouzekri N, Haverfield E, et al. Genetic evidence in support of a shared Eurasian-North African dairying origin. Hum Genet 2005 Jun; 117(1):34–42. Not relevant to key questions
1447. Myo K, Bolin TD, Khin Mar O, et al. Ineffectiveness of breath methane excretion as a diagnostic test for lactose malabsorption. Journal of Pediatric Gastroenterology & Nutrition 1999 May; 28(5):474–9. No prevalence data
1448. Nacey KA. Infant colic. J Emerg Nurs 1993 Feb; 19(1):65–6. Not relevant to key questions
1449. Nadasdi M. Tolerance of a milk-based formula by infants. Clin Ther 1992 Mar–Apr; 14(2):242–6. Not relevant to key questions
1450. Nadasdi M. Tolerance of a soy formula by infants and children. Clin Ther 1992 Mar–Apr; 14(2):236–41. Not relevant to key questions
1451. Nagano T, Itoh H, Hayashi T, et al. Effect of pilocarpine on levels of substance P and alpha-calcitonin gene-related peptide in human saliva. Pharmacy & Pharmacology Communications Vol 5; 1999: 571–4. Not lactose intolerance study
1452. Nagy L, Mozsik G, Garamszegi M, et al. Lactose-poor milk in adult lactose intolerance. Acta Med Hung 1983; 40(4):239–45. Not relevant to key questions
1453. Nagy L, Tapsonyi Z, Mozsik G, et al. Efficacy testing of beta-galactosidase with H2 breath test in patients with carbohydrate malabsorption. Acta Med Hung 1987; 44(1):31–42. Not relevant to key questions
1454. Nahum LH. Lactose deficiency and the "irritable-colon syndrome". Conn Med 1966 Mar; 30(3):153–4. Not relevant to key questions
1455. Naidoo BT, Chunterpurshad I, Mahyoodeen AB, et al. The use of a soy isolate based formula in the treatment of infantile diarrhoea. J Int Med Res 1981; 9(3):232–5. Not relevant to key questions
1456. Nakade S, Komaba J, Ohno T, et al. Bioequivalence study of two limaprost alfadex 5 microg tablets in healthy subjects: moisture-resistant tablet (dextran formulation) versus standard tablet (lactose formulation). International journal of clinical pharmacology and therapeutics Vol 46; 2008: 42–7. Not lactose intolerance study
1457. Nakamoto K, Watanabe S, Kudo H, et al. Nutritional characteristics of middle-aged Japanese vegetarians. J Atheroscler Thromb 2008 Jun; 15(3):122–9. Not relevant to key questions
1458. Nakamura K, Takahashi H, Shimai S, et al. Effects of immersion in tepid bath water on recovery from fatigue after submaximal exercise in man. Ergonomics Vol 39; 1996: 257–66. Not lactose intolerance study
1459. Nakate T, Yoshida H, Ohike A, et al. Formulation development of inhalation powders for FK888 with carrier lactose using Spinhaler and its absorption in healthy volunteers. Journal of controlled release : official journal of the Controlled Release Society Vol 97; 2004: 19–29. Not lactose intolerance study
1460. Nandi NA, Parham ES. Milk drinking by the lactose intolerant. Comparison of Caucasian and Oriental adults. J Am Diet Assoc 1972 Sep; 61(3):258–61. Not relevant to key questions
1461. Nanji AA, Denardi FG. Primary adult lactose intolerance protects against development of inflammatory bowel disease. Medical Hypotheses 1986 Jan; 19(1):1–6. No prevalence data
1462. Nasrallah SM. Lactose intolerance in the Lebanese population and in "Mediterranean lymphoma". American Journal of Clinical Nutrition 1979 Oct; 32(10):1994–6. Ineligible number of subjects
1463. Neale G. Defects of sugar absorption. The diagnosis, incidence and significance of disaccharidase deficiency in adults. Proc R Soc Med 1968 Nov; 61(11 Part 1):1099–102. Not relevant to key questions
1464. Neale G. The geographical incidence of lactase deficiency. Pathol Microbiol (Basel) 1973; 39(3):238–47. Not relevant to key questions
1465. Neaverson MA. The clinical significance of lactose intolerance. Aust Fam Physician 1980 Oct; 9(10):747–50. Not relevant to key questions
1466. Nedkova-Bratanova N. Radiologic changes of the small intestine in combined enzymic deficiency (gluten intolerance and lactase deficiency). Digestion 1968; 1(1):43–51. Not relevant to key questions
1467. Nei M, Saitou N. Genetic relationship of human populations and ethnic differences in reaction to drugs and food. Prog Clin Biol Res 1986; 214:21–37. Not relevant to key questions
1468. Nelson CD, Waggoner DD, Donnell GN, et al. Verbal dyspraxia in treated galactosemia. Pediatrics 1991 Aug; 88(2):346–50. Not relevant to key questions
1469. Neumeister A, Hu XZ, Luckenbaugh DA, et al. Differential effects of 5-HTTLPR genotypes on the behavioral and neural responses to tryptophan depletion in patients with major depression and controls. Archives of general psychiatry Vol 63; 2006: 978–86. Not lactose intolerance study
1470. Neumeister A, Nugent AC, Waldeck T, et al. Neural and behavioral responses to tryptophan depletion in unmedicated patients with remitted major depressive disorder and controls. Archives of general psychiatry Vol 61; 2004: 765–73. Not lactose intolerance study
1471. New SA. Do vegetarians have a normal bone mass? Osteoporos Int 2004 Sep; 15(9):679‐88. Review
1472. New SA, Bolton-Smith C, Grubb DA, et al. Nutritional influences on bone mineral density: a cross-sectional study in premenopausal women. Am J Clin Nutr 1997 Jun; 65(6):1831–9. not eligible outcomes
1473. Newcomer AD. Disaccharidase deficiencies. Mayo Clin Proc 1973 Sep; 48(9):648–52. Not relevant to key questions
1474. Newcomer AD. Lactase deficiency. J Med Soc N J 1980 Feb; 77(2):127–8. Not relevant to key questions
1475. Newcomer AD, Gordon H, Thomas PJ, et al. Family studies of lactase deficiency in the American Indian. Gastroenterology 1977 Nov; 73(5):985–8. Not relevant to key questions
1476. Newcomer AD, Hodgson SF, McGill DB, et al. Lactase deficiency: prevalence in osteoporosis. Annals of Internal Medicine 1978 Aug; 89(2):218–20. Ineligible number of subjects
1477. Newcomer AD, McGill DB. Incidence of lactase deficiency in ulcerative colitis. Gastroenterology 1967 Dec; 53(6):890–3. Not relevant to key questions
1478. Newcomer AD, McGill DB, Thomas PJ, et al. Prospective comparison of indirect methods for detecting lactase deficiency. New England Journal of Medicine 1975 Dec 11; 293(24):1232–6. Ineligible number of subjects
1479. Newcomer AD, Thomas PJ, McGill DB, et al. Lactase deficiency: a common genetic trait of the American Indian. Gastroenterology 1977 Feb; 72(2):234–7. Not relevant to key questions
1480. Newman S, Malik S, Hirst R, et al. Lung deposition of salbutamol in healthy human subjects from the MAGhaler dry powder inhaler. Respiratory medicine Vol 96; 2002: 1026‐32. Not lactose intolerance study
1481. Ngan P, Wilson S, Shanfeld J, et al. The effect of ibuprofen on the level of discomfort in patients undergoing orthodontic treatment. American journal of orthodontics and dentofacial orthopedics : official publication of the American Association of Orthodontists, its constituent societies, and the American Board of Orthodontics Vol 106; 1994: 88–95. Not lactose intolerance study
1482. Nguyen KN, Welsh JD, Manion CV, et al. Effect of fiber on breath hydrogen response and symptoms after oral lactose in lactose malabsorbers. Am J Clin Nutr 1982 Jun; 35(6):1347‐51. Not relevant to key questions
1483. Nguyen MT. Effect of cow milk on pulmonary function in atopic asthmatic patients. Annals of Allergy, Asthma, & Immunology 1997 Jul; 79(1):62–4. No prevalence data
1484. Nicolaescu T, Stoiculescu P, Bittman E, et al. Chronic dysenzymatic enteropathy; its relationship to chronic functional colopathy. Rom Med Rev 1970 Oct–Dec; 14(4):18–23. Review
1485. Nielsen FH, Milne DB, Gallagher S, et al. Moderate magnesium deprivation results in calcium retention and altered potassium and phosphorus excretion by postmenopausal women. Magnesium research : official organ of the International Society for the Development of Research on Magnesium Vol 20; 2007: 19–31. Not lactose intolerance study
1486. Nielsen FH, Penland JG. Boron supplementation of peri-menopausal women affects boron metabolism and indices associated with macromineral metabolism, hormonal status and immune function. Journal of Trace Elements in Experimental Medicine Vol 12; 1999: 251‐61. Not lactose intolerance study
1487. Nilsson M, Stenberg M, Frid AH, et al. Glycemia and insulinemia in healthy subjects after lactose-equivalent meals of milk and other food proteins: the role of plasma amino acids and incretins. Am J Clin Nutr Vol 80; 2004: 1246–53. Not relevant to key questions
1488. Nilsson TK, Johansson CA. A novel method for diagnosis of adult hypolactasia by genotyping of the -13910 C/T polymorphism with Pyrosequencing technology. Scand J Gastroenterol 2004 Mar; 39(3):287–90. Not relevant to key questions
1489. Nilsson TK, Olsson LA. Simultaneous genotyping of the three lactose tolerance-linked polymorphisms LCT -13907C>G, LCT -13910C>T and LCT -13915T>G with Pyrosequencing technology. Clin Chem Lab Med 2008; 46(1):80–4. Not relevant to key questions
1490. Nin F, Fukui T, Sakai K, et al. Effects of bromazepam (Lexotan(Reg.trademark)) as a premedicant in the preoperative night. Hiroshima J. Anesth. Vol 16; 1980: 29–34. Not lactose intolerance study
1491. Nizami SQ, Bhutta ZA, Molla AM. Efficacy of traditional rice-lentil-yogurt diet, lactose free milk protein-based formula and soy protein formula in management of secondary lactose intolerance with acute childhood diarrhoea. Journal of Tropical Pediatrics 1996 Jun; 42(3):133–7. Ineligible number of subjects
1492. Nordio S, Lamedica GM, Berio A, et al. Disaccharidase activities of duodenal mucosa in children. (Normal subjects, coeliac DISEASE, malnutrition, cystic fibrosis of pancreas, other chronic enteropathies). Ann Paediatr 1966; 206(4):287–312. Review
1493. Nordstrom C, Dahlqvist A. Quantitative distribution of some enzymes along the villi and crypts of human small intestine. Scand J Gastroenterol 1973; 8(5):406–16. Not relevant to key questions
1494. Northrop-Clewes CA, Lunn PG, Downes RM. Lactose maldigestion in breast-feeding Gambian infants. J Pediatr Gastroenterol Nutr 1997 Mar; 24(3):257–63. Not relevant to key questions
1495. Nose O, Iida Y, Kai H, et al. Breath hydrogen test for detecting lactose malabsorption in infants and children. Prevalence of lactose malabsorption in Japanese children and adults. Archives of Disease in Childhood 1979 Jun; 54(6):436–40. Ineligible number of subjects
1496. Nurse GT, Jenkins T. Letter: Lactose intolerance in San populations. Br Med J 1974 Sep 28; 3(5934):809. Not relevant to key questions
1497. Nurse GT, Jenkins T. Health and the Hunter-Gatherer. Biomedical studies on the hunting and gathering populations of Southern Africa. Monogr Hum Genet 1977; 8:1–126. Not relevant to key questions
1498. Nyulasi IB, Metz G. Methods of introducing nasoenteric feeding. A prospective randomized study. Medical Journal of Australia 1984 Oct 13; 141(8):496–8. Not relevant to key questions
1499. Oberlander TF, Barr RG, Young SN, et al. Short-term effects of feed composition on sleeping and crying in newborns. Pediatrics Vol 90; 1992: 733–40. Not relevant to key questions
1500. Ochs HD, Ament ME, Davis SD. Giardiasis with malabsorption in X-linked agammaglobulinemia. N Engl J Med 1972 Aug 17; 287(7):341–2. Not relevant to key questions
1501. Ochs HD, Ament ME, Davis SD. Structure and function of the gastrointestinal tract in primary immunodeficiency syndromes (IDS) and in granulocyte dysfunction. Birth Defects Orig Artic Ser 1975; 11(1):199–207. Not relevant to key questions
1502. O'Connell S, Walsh G. Physicochemical characteristics of commercial lactases relevant to their application in the alleviation of lactose intolerance. Appl Biochem Biotechnol 2006 Aug; 134(2):179–91. Not relevant to key questions
1503. Ohler J, Grinspoon L, Shader R, et al. Behavioral correlates of the guessing game. Side effects and double-blind studies. Archives of general psychiatry Vol 15; 1966: 279–87. Not lactose intolerance study
1504. Ohura T, Kobayashi K, Tazawa Y, et al. Clinical pictures of 75 patients with neonatal intrahepatic cholestasis caused by citrin deficiency (NICCD). Journal of inherited metabolic disease 2007 Apr; 30(2):139–44. Not relevant to key questions
1505. Ojantakanen S, Hannula AM, Marvola M. Bioavailability of ibuprofen from hard gelatin capsules containing sodium bicarbonate, lactose or dicalcium phosphate. Acta Pharmaceutica Fennica Vol 99; 1990: 119–27. Not lactose intolerance study
1506. Ojetti V, Gabrielli M, Migneco A, et al. Regression of lactose malabsorption in coeliac patients after receiving a gluten-free diet. Scandinavian journal of gastroenterology 2008; 43(2):174–7. Not relevant to key questions
1507. Ojetti V, La Mura R, Zocco MA, et al. Quick test: a new test for the diagnosis of duodenal hypolactasia. Dig Dis Sci 2008 Jun; 53(6):1589–92. Not relevant to key questions
1508. Ojetti V, Nucera G, Migneco A, et al. High prevalence of celiac disease in patients with lactose intolerance. Digestion 2005; 71(2):106–10. No prevalence data
1509. Okada S, Kato T, Miura S, et al. Hypersialyloligosacchariduria in mucolipidoses: a method for diagnosis. Clin Chim Acta 1978 Jun; 86(2):159–67. Not relevant to key questions
1510. Okada S, Kato T, Yabuuchi H, et al. The complementation of beta-galactosidase in fused cells of mucolipidosis II with another variants of beta-galactosidase deficiency using new single cell enzyme assay. Biochem Biophys Res Commun 1979 May 28; 88(2):559–62. Not relevant to key questions
1511. O'Keefe SJ, Adam JK. Primary lactose intolerance in Zulu adults. S Afr Med J 1983 May 14; 63(20):778–80. Not relevant to key questions
1512. O'Keefe SJ, Adam JK, Cakata E, et al. Nutritional support of malnourished lactose intolerant African patients. Gut 1984 Sep; 25(9):942–7. Not relevant to key questions
1513. O'Keefe SJ, O'Keefe EA, Burke E, et al. Milk-induced malabsorption in malnourished African patients. Am J Clin Nutr 1991 Jul; 54(1):130–5. Not relevant to key questions
1514. O'Keefe SJ, Young GO, Rund J. Milk tolerance and the malnourished African. Eur J Clin Nutr 1990 Jul; 44(7):499–504. Not relevant to key questions
1515. Olafsdottir E, Aksnes L, Fluge G, et al. Faecal calprotectin levels in infants with infantile colic, healthy infants, children with inflammatory bowel disease, children with recurrent abdominal pain and healthy children. Acta Paediatrica 2002; 91(1):45–50. Ineligible number of subjects
1516. Olatunbosun DA, Adadevoh BK. Lactose intolerance in Nigerian children. Acta Paediatr Scand 1972 Nov; 61(6):715–9. Not relevant to key questions
1517. Olatunbosun DA, Adadevoh BK. Plasma insulin response to oral lactose and glucose-galactose in patients with lactose intolerance. Ghana Med J 1973 Dec; 12(4):370–4. Not relevant to key questions
1518. Olatunbosun DA, Kwaku Adadevoh B. Lactase deficiency in Nigerians. Am J Dig Dis 1971 Oct; 16(10):909–14. Not relevant to key questions
1519. Olden KW. Diagnosis of irritable bowel syndrome. Gastroenterology 2002 May; 122(6):1701–14. Not original research
1520. Olds LC, Sibley E. Lactase persistence DNA variant enhances lactase promoter activity in vitro: functional role as a cis regulatory element. Hum Mol Genet 2003 Sep 15; 12(18):2333‐40. Not relevant to key questions
1521. Oliver MF. Thrombosis and oestrogens. Lancet Vol 2; 1967: 510–1. Not lactose intolerance study
1522. Olives JP, Mundelengolo JM, Le TO, et al. Diarrhees aigues communes du nourrisson: faut-il avoir peur du lactose? Arch Fr Pediatr Vol 45; 1988: 591-. Not relevant to key questions
1523. Olsen WA. Carbohydrate digestion and absorption. Clinically significant abnormalities. Postgrad Med 1972 Apr; 51(4):149–52. Not relevant to key questions
1524. O'Malley BW, Li D, McQuone SJ, et al. Combination nonviral interleukin-2 gene immunotherapy for head and neck cancer: from bench top to bedside. The Laryngoscope Vol 115; 2005: 391–404. Not lactose intolerance study
1525. Onbasi K, Gunsar F, Sin AZ, et al. Common variable immunodeficiency (CVID) presenting with malabsorption due to giardiasis. Turkish Journal of Gastroenterology 2005 Jun; 16(2):111–3. No prevalence data
1526. Onwulata CI, Rao DR, Vankineni P. Relative efficiency of yogurt, sweet acidophilus milk, hydrolyzed-lactose milk, and a commercial lactase tablet in alleviating lactose maldigestion. Am J Clin Nutr 1989 Jun; 49(6):1233–7. Not relevant to key questions
1527. Ooms ME, Lips P, Van Lingen A, et al. Determinants of bone mineral density and risk factors for osteoporosis in healthy elderly women. J Bone Miner Res 1993 Jun; 8(6):669–75. not eligible exposure
1528. Orrego F, Quintana C. Darwin's illness: a final diagnosis. Notes Rec R Soc Lond 2007 Jan 22; 61(1):23–9. Not relevant to key questions
1529. Orris L, Shalita AR, Sibulkin D, et al. Oral zinc therapy of acne. Absorption and clinical effect. Archives of dermatology Vol 114; 1978: 1018–20. Not lactose intolerance study
1530. Osterlund P, Ruotsalainen T, Peuhkuri K, et al. Lactose intolerance associated with adjuvant 5-fluorouracil-based chemotherapy for colorectal cancer. Clin Gastroenterol Hepatol 2004 Aug; 2(8):696–703. Not eligible target population
1531. Osterwalder P, Bircher AJ, Wuthrich B. Cow's milk allergy as delayed-type reaction. Allergologie Vol 21; 1998: 73–7. Not relevant to key questions
1532. Osvaath P, Kerese I, Szendrey A. Use of chestnut in the feeding of infants allergic to cow's milk or intolerant to lactose. Allergol Immunopathol (Madr) 1976 Nov–Dec; 4(6):413–8. Not relevant to key questions
1533. Outila TA, Karkkainen MU, Seppanen RH, et al. Dietary intake of vitamin D in premenopausal, healthy vegans was insufficient to maintain concentrations of serum 25‐hydroxyvitamin D and intact parathyroid hormone within normal ranges during the winter in Finland. J Am Diet Assoc 2000 Apr; 100(4):434–41. Not eligible exposure
1534. Ouwehand A, Vesterlund S. Health aspects of probiotics. IDrugs 2003 Jun; 6(6):573–80. Not relevant to key questions
1535. Ouwehand AC, Salminen S, Isolauri E. Probiotics: an overview of beneficial effects. Antonie Van Leeuwenhoek 2002 Aug; 82(1–4):279–89. Not relevant to key questions
1536. Ozkaya O, Sezik M, Kaya H, et al. Placebo-controlled randomized comparison of vaginal with rectal misoprostol in the prevention of postpartum hemorrhage. The journal of obstetrics and gynaecology research Vol 31; 2005: 389–93. Not lactose intolerance study
1537. Ozmen S, Turhan NO, Seckin NC. Gardnerella-associated vaginitis: Comparison of three treatment modalities. Turkish Journal of Medical Sciences Vol 28; 1998: 171–3. Not lactose intolerance study
1538. Ozolek JA, Cook LA, Mimouni FB, et al. Bone mineralization over the first eight months of life in infants fed a lactose free formula. Pediatric Research Vol 2; 1995: 315. Not eligible target population
1539. Paajanen L, Tuure T, Poussa T, et al. No difference in symptoms during challenges with homogenized and unhomogenized cow's milk in subjects with subjective hypersensitivity to homogenized milk. The Journal of dairy research Vol 70; 2003: 175–9. Not lactose intolerance
1540. Paerregaard A, Hjelt K, Christiansen L, et al. Postenteritis enteropathy in infancy. A prospective study of 10 patients with special reference to growth pattern, long-term outcome and incidence. Acta Paediatrica Scandinavica 1990 Nov; 79(11):1045–51. Not relevant to key questions
1541. Paerregaard A, Vilien M, Krasilnikoff PA, et al. Supposed coeliac disease during childhood and its presentation 14–38 years later. Scandinavian Journal of Gastroenterology 1988 Jan; 23(1):65–70. Ineligible number of subjects
1542. Paes IC, Searl P, Rubert MW, et al. Intestinal lactase deficiency and saccharide malabsorption during oral neomycin administration. Gastroenterology 1967 Jul; 53(1):49–58. Not relevant to key questions
1543. Paganini-Hill A, Chao A, Ross RK, et al. Exercise and other factors in the prevention of hip fracture: the Leisure World study. Epidemiology 1991 Jan; 2(1):16–25. not eligible outcomes
1544. Paige DM, Bayless TM, Dellinger WS, Jr. Relationship of milk consumption to blood glucose rise in lactose intolerant individuals. Am J Clin Nutr 1975 Jul; 28(7):677–80. Not relevant to key questions
1545. Paige DM, Bayless TM, Ferry GD, et al. Lactose malabsorption and milk rejection in Negro children. Johns Hopkins Med J 1971 Sep; 129(3):163–9. Not relevant to key questions
1546. Paige DM, Bayless TM, Graham GG. Milk programs: helpful or harmful to Negro children? Am J Public Health 1972 Nov; 62(11):1486–8. Not relevant to key questions
1547. Paige DM, Bayless TM, Graham GG. Pregnancy and lactose intolerance. Am J Clin Nutr 1973 Mar; 26(3):238–40. Not relevant to key questions
1548. Paige DM, Bayless TM, Mellitis ED, et al. Lactose malabsorption in preschool black children. Am J Clin Nutr 1977 Jul; 30(7):1018–22. Not relevant to key questions
1549. Paige DM, Bayless TM, Mellits ED, et al. Effects of age and lactose tolerance on blood glucose rise with whole cow and lactose-hydrolyzed milk. J Agric Food Chem 1979 Jul–Aug; 27(4):677–80. Not relevant to key questions
1550. Paige DM, Graham GG. Etiology of lactase deficiency: another perspective. Gastroenterology 1971 Nov; 61(5):798–9. Not relevant to key questions
1551. Paige DM, Graham GG. School milk programs and Negro children: a nutritional dilemma. J Sch Health 1974 Jan; 44(1):8–10. Not relevant to key questions
1552. Paige DM, Leonardo E, Cordano A, et al. Lactose intolerance in Peruvian children: effect of age and early nutrition. Am J Clin Nutr 1972 Mar; 25(3):297–301. Not relevant to key questions
1553. Paige DM, Leonardo E, Nakashima J, et al. Response of lactose-intolerant children to different lactose levels. Am J Clin Nutr 1972 May; 25(5):467–9. Not relevant to key questions
1554. Paige DM, Mellits ED, Chiu FY, et al. Blood glucose rise after lactose tolerance testing in infants. Am J Clin Nutr 1978 Feb; 31(2):222–5. Not relevant to key questions
1555. Paige DM, Witter FR, Bronner YL, et al. Lactose digestion in pregnant African-Americans. Public Health Nutrition 2003 Dec; 6(8):801–7. Secondary lactose intolerance
1556. Palacios S, Castelo-Branco C, Cifuentes I, et al. Changes in bone turnover markers after calcium-enriched milk supplementation in healthy postmenopausal women: a randomized, double-blind, prospective clinical trial. Menopause (New York, N.Y.) Vol 12; 2005: 63–8. Not lactose intolerance study
1557. Palma D, Oliva CA, Taddei JA, et al. [Acute diarrhea: stool water loss in hospitalized infants and its correlation with etiologic agents and lactose content in the diet]. Arquivos de gastroenterologia Vol 34; 1997: 186–95. Not relevant to key questions
1558. Palma M, Rosado JL, López P, et al. [Lactose intolerance. Its definition, its prevalence in Mexico, and its implications in milk consumption]. Revista de investigación clínica; organo del Hospital de Enfermedades de la Nutrición Vol 48; 1996: 25–31. Not English language
1559. Pan J, Takeshita T, Morimoto K. Acute caffeine effect on repeatedly measured P300. Environmental Health & Preventive Medicine Vol 5; 2000: 13–7. Not lactose intolerance study
1560. Papadaki A, Vardavas C, Hatzis C, et al. Calcium, nutrient and food intake of Greek Orthodox Christian monks during a fasting and non-fasting week. Public Health Nutr 2008 Oct; 11(10):1022–9. Not eligible outcomes
1561. Park RH, Duncan A, Russell RI. Hypolactasia and Crohn's disease: a myth. American Journal of Gastroenterology 1990 Jun; 85(6):708–10. Ineligible number of subjects
1562. Parker TJ, Woolner JT, Prevost AT, et al. Irritable bowel syndrome: is the search for lactose intolerance justified? Eur J Gastroenterol Hepatol 2001 Mar; 13(3):219–25. Not relevant to key questions
1563. Parnes HL, Fung E, Schiffer CA. Chemotherapy-induced lactose intolerance in adults. Cancer 1994 Sep 1; 74(5):1629–33. Ineligible number of subjects
1564. Parra D, Martinez JA. Amino acid uptake from a probiotic milk in lactose intolerant subjects. Br J Nutr 2007 Oct; 98 Suppl 1:S101–4. Not relevant to key questions
1565. Parra MD, Martinez de Morentin BE, Cobo JM, et al. Acute calcium assimilation from fresh or pasteurized yoghurt depending on the lactose digestibility status. J Am Coll Nutr 2007 Jun; 26(3):288–94. Not eligible outcomes
1566. Parrott AC, Golding JF, Pethybridge RJ. The effects of single and repeated doses of oral scopolamine, cinnarizine, and placebo upon psychological performance and physiological functioning. Hum Psychopharmacol Vol 5; 1990: 207–16. Not lactose intolerance study
1567. Parry SD, Barton JR, Welfare MR. Is lactose intolerance implicated in the development of post-infectious irritable bowel syndrome or functional diarrhoea in previously asymptomatic people? European Journal of Gastroenterology & Hepatology 2002 Nov; 14(11):1225–30. No prevalence data
1568. Parsons TJ, van Dusseldorp M, Seibel MJ, et al. Are levels of bone turnover related to lower bone mass of adolescents previously fed a macrobiotic diet? Exp Clin Endocrinol Diabetes 2001; 109(5):288–93. not eligible outcomes
1569. Parvez S, Malik KA, Ah Kang S, et al. Probiotics and their fermented food products are beneficial for health. Journal of Applied Microbiology 2006 Jun; 100(6):1171–85. No prevalence data
1570. Patel Y, Boyd PA, Chamberlain P, et al. Follow-up of children with isolated fetal echogenic bowel with particular reference to bowel-related symptoms. Prenatal Diagnosis 2004 Jan; 24(1):35–7. No prevalence data
1571. Patel YT, Minocha A. Lactose intolerance: diagnosis and management. Comprehensive Therapy 2000; 26(4):246–50. Not original research
1572. Patil DH, Grimble GK, Silk DB. Lactitol, a new hydrogenated lactose derivative: intestinal absorption and laxative threshold in normal human subjects. The British journal of nutrition Vol 57; 1987: 195–9. Not relevant to key questions
1573. Patrick MK. Vomiting and diarrhoea. Aust Fam Physician 1994 Oct; 23(10):1913, 6–9. Not relevant to key questions
1574. Patwari AK, Anand VK, Aneja S, et al. Persistent diarrhea: management in a diarrhea treatment unit. Indian Pediatrics 1995 Mar; 32(3):277–84. No prevalence data
1575. Paul VK, Singh M, Srivastava LM, et al. Macronutrient and energy content of breast milk of mothers delivering prematurely. Indian journal of pediatrics Vol 64; 1997: 379–82. Not relevant to key questions
1576. Pauwels S, Fiasse R, Tome G, et al. A simplified method of measuring breath hydrogen by end-expiratory sampling for diagnosis of lactose malabsorption. Acta Clin Belg 1985; 40(3):174–8. Not relevant to key questions
1577. Payne DL, Welsh JD, Manion CV, et al. Effectiveness of milk products in dietary management of lactose malabsorption. Am J Clin Nutr 1981 Dec; 34(12):2711–5. Not relevant to key questions
1578. Payne-Bose D, Welsh JD, Gearhart HL, et al. Milk and lactose-hydrolyzed milk. Am J Clin Nutr 1977 May; 30(5):695–7. Not relevant to key questions
1579. Pearson AD, Craft AW, Pledger JV, et al. Small bowel function in acute lymphoblastic leukaemia. Arch Dis Child 1984 May; 59(5):460–5. Not relevant to key questions
1580. Peck AW, Adams R, Bye C, et al. Residual effects of hypnotic drugs: evidence for individual differences on vigilance. Psychopharmacologia Vol 47; 1976: 213–6. Not lactose intolerance study
1581. Pederzini F, Faraguna D, Giglio L, et al. Development of a screening system for cystic fibrosis: meconium or blood spot trypsin assay or both? Acta Paediatrica Scandinavica 1990 Oct; 79(10):935–42. No prevalence data
1582. Pei J, Yang T, Liu Z. [Study on effect of acupoint sticker of TTS-ST93–1 in treating motion sickness]. Zhongguo Zhong xi yi jie he za zhi Zhongguo Zhongxiyi jiehe zazhi = Chinese journal of integrated traditional and Western medicine / Zhongguo Zhong xi yi jie he xue hui, Zhongguo Zhong yi yan jiu yuan zhu ban Vol 18; 1998: 464–7. Not lactose intolerance study
1583. Pelchat ML, Rozin P. The special role of nausea in the acquisition of food dislikes by humans. Appetite 1982 Dec; 3(4):341–51. Not relevant to key questions
1584. Pelletier X, Laure-Boussuge S, Donazzolo Y. Hydrogen excretion upon ingestion of dairy products in lactose-intolerant male subjects: importance of the live flora. Eur J Clin Nutr 2001 Jun; 55(6):509–12. Not relevant to key questions
1585. Pelto L, Impivaara O, Salminen S, et al. Milk hypersensitivity in young adults. European Journal of Clinical Nutrition 1999 Aug; 53(8):620–4. No prevalence data
1586. Pelto L, Salminen S, Lilius EM, et al. Milk hypersensitivity--key to poorly defined gastrointestinal symptoms in adults. Allergy 1998 Mar; 53(3):307–10. Not relevant to key questions
1587. Pena AS, Truelove SC. Hypolactasia and the irritable colon syndrome. Scand J Gastroenterol 1972; 7(5):433–8. Not relevant to key questions
1588. Pena AS, Truelove SC. Hypolactasia and ulcerative colitis. Gastroenterology 1973 Mar; 64(3):400–4. Not relevant to key questions
1589. Pena AS, Truelove SC, Lumsden K, et al. Hypolactasia and the irritable colon syndrome. Gut 1969 Dec; 10(12):1052–3. Not relevant to key questions
1590. Penny ME, Brown KH. Lactose feeding during persistent diarrhoea. Acta Paediatr Suppl 1992 Sep; 381:133–8. Not relevant to key questions
1591. Penny ME, Paredes P, Brown KH. Clinical and nutritional consequences of lactose feeding during persistent postenteritis diarrhea. Pediatrics Vol 84; 1989: 835–44. Not relevant to key questions
1592. Perlow W, Baraona E, Lieber CS. Symptomatic intestinal disaccharidase deficiency in alcoholics. Gastroenterology 1977 Apr; 72(4 Pt 1):680–4. Not relevant to key questions
1593. Perman JA, Modler S, Olson AC. Role of pH in production of hydrogen from carbohydrates by colonic bacterial flora. Studies in vivo and in vitro. J Clin Invest 1981 Mar; 67(3):643–50. Not relevant to key questions
1594. Perrin B, Malo JL, Cartier A, et al. Occupational asthma in a pharmaceutical worker exposed to hydralazine. Thorax 1990 Dec; 45(12):980–1. Not relevant to key questions
1595. Pesola GR, Hogg JE, Eissa N, et al. Hypertonic nasogastric tube feedings: do they cause diarrhea? Critical care medicine 1990 Dec; 18(12):1378–82. Not eligible target population
1596. Peters TJ, Batt RM, Heath JR, et al. The micro-assay of intestinal disaccharidases. Biochem Med 1976 Apr; 15(2):145–8. Not relevant to key questions
1597. Petrarulo M, Marangella M, Bianco O, et al. Ion-chromatographic determination of L-tartrate in urine samples. Clin Chem 1991 Jan; 37(1):90–3. Not relevant to key questions
1598. Petrella RJ, DiSilvestro MD, Hildebrand C. Effects of hyaluronate sodium on pain and physical functioning in osteoarthritis of the knee: a randomized, double-blind, placebo-controlled clinical trial. Archives of internal medicine Vol 162; 2002: 292–8. Not lactose intolerance study
1599. Pettersson R, Dahlqvist A, Hattevig G, et al. Borderline galactosemia. Acta Paediatr Scand 1980 Nov; 69(6):735–9. Not relevant to key questions
1600. Pettersson T, Wegelius O, Skrifvars B. Gastro-intestinal disturbances in patients with severe rheumatoid arthritis. Acta Med Scand 1970 Jul–Aug; 1–2(1):139–44. Not relevant to key questions
1601. Pettifor JM, Hansen JD. Letter: Lactose intolerance in San populations. Br Med J 1974 Jul 20; 3(5924):173. Not relevant to key questions
1602. Pettoello Mantovani M, Guandalini S, Ecuba P, et al. Lactose malabsorption in children with symptomatic Giardia lamblia infection: feasibility of yogurt supplementation. J Pediatr Gastroenterol Nutr 1989 Oct; 9(3):295–300. Not relevant to key questions
1603. Pettoello-Mantovani M, Guandalini S, diMartino L, et al. Prospective study of lactose absorption during cancer chemotherapy: feasibility of a yogurt-supplemented diet in lactose malabsorbers. Journal of Pediatric Gastroenterology & Nutrition 1995 Feb; 20(2):189–95. Ineligible number of subjects
1604. Peuhkuri K, Nevala R, Vapaatalo H, et al. Ibuprofen augments gastrointestinal symptoms in lactose maldigesters during a lactose tolerance test. Aliment Pharmacol Ther 1999 Sep; 13(9):1227–33. Not relevant to key questions
1605. Peuhkuri K, Poussa T, Korpela R. Comparison of a portable breath hydrogen analyser (Micro H2) with a Quintron MicroLyzer in measuring lactose maldigestion, and the evaluation of a Micro H2 for diagnosing hypolactasia. Scand J Clin Lab Invest 1998 May; 58(3):217–24. Not relevant to key questions
1606. Peuhkuri K, Vapaatalo H, Korpela R. Wide variations in the testing of lactose tolerance: results of a questionnaire study in Finnish health care centres. Scand J Clin Lab Invest 2000 Jul; 60(4):291–7. Not relevant to key questions
1607. Peuhkuri K, Vapaatalo H, Nevala R, et al. Influence of the pharmacological modification of gastric emptying on lactose digestion and gastrointestinal symptoms. Aliment Pharmacol Ther 1999 Jan; 13(1):81–6. Not relevant to key questions
1608. Peuhkuri K, Vapaatalo H, Nevala R, et al. Temperature of a test solution influences abdominal symptoms in lactose tolerance tests. Scand J Clin Lab Invest 2000 Feb; 60(1):75‐80. Not relevant to key questions
1609. Phillips MC, Briggs GM. Milk and its role in the American diet. J Dairy Sci 1975 Nov; 58(11):1739–63. Not relevant to key questions
1610. Phillips SF. Relationship of diarrhea to maldigestion and malabsorption. Mayo Clin Proc 1973 Sep; 48(9):660–2. Not relevant to key questions
1611. Phillips T, Macdonald I, Keyser A. Some metabolic effects of ingesting galactose, before and after a high-lactose diet. Proc Nutr Soc 1978 May; 37(1):24A. Not relevant to key questions
1612. Piacentini MF, Meeusen R, Buyse L, et al. Hormonal responses during prolonged exercise are influenced by a selective DA/NA reuptake inhibitor. British journal of sports medicine Vol 38; 2004: 129–33. Not lactose intolerance study
1613. Piccirillo JF, Finnell J, Vlahiotis A, et al. Relief of idiopathic subjective tinnitus: is gabapentin effective? Archives of otolaryngology--head & neck surgery Vol 133; 2007: 390‐ 7. Not lactose intolerance study
1614. Piche T, Zerbib F, Bruley DVS, et al. Modulation by colonic fermentation of LES function in humans. American Journal of Physiology - Gastrointestinal & Liver Physiology Vol 278; 2000: G578–g84. Not lactose intolerance study
1615. Pickett CK, Regensteiner JG, Woodard WD, et al. Progestin and estrogen reduce sleep-disordered breathing in postmenopausal women. Journal of applied physiology (Bethesda, Md. : 1985) Vol 66; 1989: 1656–61. Not lactose intolerance study
1616. Pieters JJ, van Rens R. Lactose malabsorption and milk tolerance in Kenyan school-age children. Trop Geogr Med 1973 Dec; 25(4):365–71. Not relevant to key questions
1617. Pimentel M, Kong Y, Park S. Breath testing to evaluate lactose intolerance in irritable bowel syndrome correlates with lactulose testing and may not reflect true lactose malabsorption. American Journal of Gastroenterology 2003 Dec; 98(12):2700–4. Ineligible number of subjects
1618. Piper DW. Milk in treatment of gastric disease. Am J Clin Nutr 1969 Feb; 22(2):191–5. Not relevant to key questions
1619. Pirk F, Skala I. Functional response of the digestive tract to the ingestion of milk in subjects suffering from lactose intolerance. Digestion 1972; 5(2):89–99. Not relevant to key questions
1620. Pirk F, Skala I, Vulterinova M. Milk intolerance after gastrectomy. Digestion 1973; 9(2):130–7. Not relevant to key questions
1621. Pironi L, Callegari C, Cornia GL, et al. Lactose malabsorption in adult patients with Crohn's disease. American Journal of Gastroenterology 1988 Nov; 83(11):1267–71. Ineligible number of subjects
1622. Pitcairn G, Lunghetti G, Ventura P, et al. A comparison of the lung deposition of salbutamol inhaled from a new dry powder inhaler, at two inhaled flow rates. Int J Pharm Vol 102; 1994: 11–8. Not lactose intolerance study
1623. Placzek M, Walker-Smith JA. Comparison of two feeding regimens following acute gastroenteritis in infancy. J Pediatr Gastroenterol Nutr 1984 Mar; 3(2):245–8. Not relevant to key questions
1624. Pochart P, Dewit O, Desjeux JF, et al. Viable starter culture, beta-galactosidase activity, and lactose in duodenum after yogurt ingestion in lactase-deficient humans. Am J Clin Nutr 1989 May; 49(5):828–31. Not relevant to key questions
1625. Pock-Steen OC. The role of gluten, milk, and other dietary proteins in chronic or intermittent dyspepsia. Clin Allergy 1973 Dec; 3(4):373–83. Not relevant to key questions
1626. Pollack RL, Mueller DH. Nutritionally speaking. Pa Dent J (Harrisb) 1983 May–Jun; 50(3):28. Not relevant to key questions
1627. Ponz dLM, Roncucci L, Di DP, et al. Lactose and vitamin A,E,C on prevention of relapse of adenomatous polyps of the large intestine. Tumori Vol 75; 1989: 72. Not lactose intolerance study
1628. Poon WB, Ho WL, Yeo CL. Survey on parenting practices among Chinese in Singapore. Singapore Med J 2007 Nov; 48(11):1006–11. Not relevant to key questions
1629. Popescu CM. Experimental use of prostaglandin E2 (Dinoprost) in the treatment of duodenal ulcer in humans. Prostaglandins, leukotrienes, and medicine Vol 21; 1986: 97–105. Not lactose intolerance study
1630. Portincasa P, Di Ciaula A, Vacca M, et al. Beneficial effects of oral tilactase on patients with hypolactasia. Eur J Clin Invest 2008 Nov; 38(11):835–44. Not relevant to key questions
1631. Portnoy J, Bagstad K, Kanarek H, et al. Premedication reduces the incidence of systemic reactions during inhalant rush immunotherapy with mixtures of allergenic extracts. Annals of allergy Vol 73; 1994: 409–18. Not lactose intolerance study
1632. Potter NL, Lazarus JA, Johnson JM, et al. Correlates of language impairment in children with galactosaemia. Journal of inherited metabolic disease 2008 Aug; 31(4):524–32. Not relevant to key questions
1633. Powell GK. Enterocolitis in low-birth-weight infants associated with milk and soy protein intolerance. Journal of Pediatrics 1976 May; 88(5):840–4. Ineligible number of subjects
1634. Powell ML, Weisberger M, Gural R, et al. Comparative bioavailability and pharmacokinetics of three formulations of albuterol. Journal of pharmaceutical sciences Vol 74; 1985: 217–9. Not lactose intolerance study
1635. Preger L, Amberg JR. Sweet diarrhea. Roentgen diagnosis of disaccharidase deficiency. Am J Roentgenol Radium Ther Nucl Med 1967 Oct; 101(2):287–95. Not relevant to key questions
1636. Premchander KV, Sundaravalli N, Panchatcharam M, et al. Pattern of sugar intolerance in children following chronic or recurrent diarrhoea: a preliminary report. Indian Pediatr 1976 Mar; 13(3):177–86. Not relevant to key questions
1637. Prentice A. Diet, nutrition and the prevention of osteoporosis. Public Health Nutr 2004 Feb; 7(1A):227–43. Review
1638. Pribila BA, Hertzler SR, Martin BR, et al. Improved lactose digestion and intolerance among African-American adolescent girls fed a dairy-rich diet. J Am Diet Assoc 2000 May; 100(5):524–8; quiz 9–30. Not relevant to key questions
1639. Priebe MG, Wachters-Hagedoorn RE, Stellaard F, et al. Oro-cecal transit time: influence of a subsequent meal. European Journal of Clinical Investigation Vol 34; 2004: 417–21. Not lactose intolerance study
1640. Prieto L, Juyol M, Paricio A, et al. Oral challenge test with sodium metabisulfite in steroid-dependent asthmatic patients. Allergologia et immunopathologia Vol 16; 1988: 393–6. Not lactose intolerance study
1641. Prieto L, Pastor A, Palop A, et al. [Rhinitis with intolerance to non-steroidal anti‐inflammatory agents. Report of 3 cases]. Allergologia et immunopathologia Vol 14; 1986: 147–53. Not lactose intolerance study
1642. Prince R, Devine A, Dick I, et al. The effects of calcium supplementation (milk powder or tablets) and exercise on bone density in postmenopausal women. J Bone Miner Res 1995 Jul; 10(7):1068–75. not eligible outcomes
1643. Prinsloo JG, Laubscher NF, Kruger H, et al. The effect of different sugars and two levels of fat intake on diarrhoea in Bantu children. South African medical journal = Suid-Afrikaanse tydskrif vir geneeskunde Vol 47; 1973: 821–8. Not relevant to key questions
1644. Prinsloo JG, Wittmann W, Pretorius PJ, et al. Effect of different sugars on diarrhoea of acute kwashiorkor. Arch Dis Child 1969 Oct; 44(237):593–9. Not relevant to key questions
1645. Puche RC, Feldman S. Relative importance of urinary sulfate and net acid excretion as determinants of calciuria in normal subjects. Medicina (B Aires) 1992; 52(3):220–4. Not eligible outcomes
1646. Qin LQ, Xu JY, Wang PY, et al. Milk consumption is a risk factor for prostate cancer: meta-analysis of case-control studies. Nutr Cancer 2004; 48(1):22–7. Not eligible outcomes
1647. Qin LQ, Xu JY, Wang PY, et al. Milk consumption is a risk factor for prostate cancer in Western countries: evidence from cohort studies. Asia Pac J Clin Nutr 2007; 16(3):467–76. Not eligible outcomes
1648. Quak SH. Lactose intolerance in Asian children. J Paediatr Child Health 1994 Apr; 30(2):91–2. Not relevant to key questions
1649. Quak SH, Low PS, Quah TC, et al. Oral refeeding following acute gastro-enteritis: a clinical trial using four refeeding regimes. Annals of tropical paediatrics Vol 9; 1989: 152–5. Not relevant to key questions
1650. Quak SH, Raman GV, Low PS, et al. Lactase insufficiency in Chinese children detected by oral milk and lactose challenge. Ann Trop Paediatr 1987 Jun; 7(2):100–3. Not relevant to key questions
1651. Quak SH, Tan SP. Use of soy-protein formulas and soyfood for feeding infants and children in Asia. American Journal of Clinical Nutrition 1998 Dec; 68(6 Suppl):1444S–6S. No prevalence data
1652. Raadal M, Coldwell SE, Kaakko T, et al. A randomized clinical trial of triazolam in 3- to 5-year-olds. Journal of dental research Vol 78; 1999: 1197–203. Not lactose intolerance study
1653. Rab SM, Baseer A. High intestinal lactase concentration in adult Pakistanis. Br Med J 1976 Feb 21; 1(6007):436. Not relevant to key questions
1654. Rachelefsky GS, Coulson A, Siegel SC, et al. Aspirin intolerance in chronic childhood asthma: Detected by oral challenge. Pediatrics Vol 56; 1975: 443–8. Not lactose intolerance study
1655. Rachlis A, Gill J, Baril JG, et al. Effectiveness of step-wise intervention plan for managing nelfinavir-associated diarrhea: a pilot study. HIV clinical trials Vol 6; 2005: 203–12. Not lactose intolerance
1656. Radomyska B. [Effectiveness of the screening programme for galactosemia. New strategy in Poland]. Medycyna wieku rozwojowego 2001 Jan–Mar; 5(1):51–8. Not relevant to key questions
1657. Rahimi AG, Delbruck H, Haeckel R, et al. Persistence of high intestinal lactase activity (lactose tolerance) in Afghanistan. Human Genetics 1976 Sep 10; 34(1):57–62. Not eligible test for lactose malabsorption
1658. Raimondi F, Indrio F, Crivaro V, et al. Neonatal hyperbilirubinemia increases intestinal protein permeability and the prevalence of cow's milk protein intolerance. Acta Paediatrica 2008 Jun; 97(6):751–3. Ineligible number of subjects
1659. Rajah R, Pettifor JM, Noormohamed M, et al. The effect of feeding four different formulae on stool weights in prolonged dehydrating infantile gastroenteritis. Journal of pediatric gastroenterology and nutrition Vol 7; 1988: 203–7. Not relevant to key questions
1660. Rana S, Bhasin DK, Gupta D, et al. Assessment of optimal dose of lactose for lactose hydrogen breath test in Indian adults. Indian J Gastroenterol 1995 Jan; 14(1):13–4. Not relevant to key questions
1661. Rana SV, Bhasin DK, Naik N. Lactose malabsorption in apparently healthy adults in northern India, assessed using lactose hydrogen breath test. Indian Journal of Gastroenterology 2004 Mar–Apr; 23(2):78. Ineligible number of subjects
1662. Rana SV, Bhasin DK, Naik N, et al. Lactose maldigestion in different age groups of north Indians. Trop Gastroenterol 2004 Jan–Mar; 25(1):18–20. Not relevant to key questions
1663. Rana SV, Bhasin DK, Vinayak VK. Prospective evaluation of lactose malabsorption by lactose hydrogen breath test in individuals infected with Entamoeba histolytica and passing cysts. British Journal of Nutrition 2004 Aug; 92(2):207–8. Ineligible number of subjects
1664. Rana SV, Bhasin DK, Vinayak VK. Lactose hydrogen breath test in Giardia lamblia‐positive patients. Dig Dis Sci 2005 Feb; 50(2):259–61. Not relevant to key questions
1665. Rana SV, Mandal AK, Kochhar R, et al. Lactose intolerance in different types of irritable bowel syndrome in north Indians. Tropical Gastroenterology 2001 Oct–Dec; 22(4):202–4. Ineligible number of subjects
1666. Rangecroft L, de San Lazaro C, Scott JE. A comparison of the feeding of the postoperative newborn with banked breast-milk or cow's-milk feeds. J Pediatr Surg 1978 Feb; 13(1):11–2. Not relevant to key questions
1667. Ransome OJ, Roode H. Early introduction of milk feeds in acute infantile gastro-enteritis. A controlled study. South African Medical Journal Suid-Afrikaanse Tydskrif Vir Geneeskunde 1984 Jan 28; 65(4):127–8. Ineligible number of subjects
1668. Ransome-Kuti O. Lactose intolerance--a review. Postgrad Med J 1977; 53 Suppl 2:73–87. Not relevant to key questions
1669. Ransome-Kuti O, Kretchmer N, Johnson JD, et al. A genetic study of lactose digestion in Nigerian families. Gastroenterology 1975 Mar; 68(3):431–6. Not relevant to key questions
1670. Rao RM, Reddy GP, Grim CE. Relative role of genes and environment on BP: twin studies in Madras, India. J Hum Hypertens 1993 Oct; 7(5):451–5. Not relevant to key questions
1671. Raper NR, Hill MM. Vegetarian diets. Nutr Rev 1974 Jul; 32(0):suppl 1:29–33. Comment
1672. Rasinpera H, Saarinen K, Pelkonen A, et al. Molecularly defined adult-type hypolactasia in school-aged children with a previous history of cow's milk allergy. World Journal of Gastroenterology 2006 Apr 14; 12(14):2264–8. Secondary lactose intolerance
1673. Rasmussen DD, Ishizuka B, Quigley ME, et al. Effects of tyrosine and tryptophan ingestion on plasma catecholamine and 3,4-dihydroxyphenylacetic acid concentrations. J Clin Endocrinol Metab Vol 57; 1983: 760–3. Not lactose intolerance study
1674. Rasmussen M, Michalsen H, Lie SO, et al. Intestinal retinol esterification and serum retinol in children with cystic fibrosis. J Pediatr Gastroenterol Nutr 1986 May–Jun; 5(3):397–403. Not relevant to key questions
1675. Rastogi M, Misra RC, Srivastava PN, et al. Intestinal disaccharidases in primary protein malnutrition in adults. Trop Geogr Med 1974 Jun; 26(2):133–6. Not relevant to key questions
1676. Ratner D, Schneeyour A, Eshel E, et al. Does milk intolerance affect seronegative arthritis in lactase-deficient women? Isr J Med Sci 1985 Jun; 21(6):532–4. Not relevant to key questions
1677. Ratner D, Shneyour A, Eshel E, et al. Elevated IgM in dietary migraine with lactase deficiency. Isr J Med Sci 1984 Aug; 20(8):717–9. Not relevant to key questions
1678. Ratner D, Shoshani E, Dubnov B. Milk protein-free diet for nonseasonal asthma and migraine in lactase-deficient patients. Isr J Med Sci 1983 Sep; 19(9):806–9. Not relevant to key questions
1679. Rautio M, Eerola E, Vaisanen-Tunkelrott ML, et al. Reclassification of Bacteroides putredinis (Weinberg et al., 1937) in a new genus Alistipes gen. nov., as Alistipes putredinis comb. nov., and description of Alistipes finegoldii sp. nov., from human sources. Syst Appl Microbiol 2003 Jun; 26(2):182–8. Not relevant to key questions
1680. Read NW, Davies RJ, Holdsworth CD, et al. Electrical assessment of functional lactase activity in conscious man. Gut 1977 Aug; 18(8):640–3. Not relevant to key questions
1681. Read NW, Krejs GJ, Read MG, et al. Chronic diarrhea of unknown origin. Gastroenterology 1980 Feb; 78(2):264–71. Not relevant to key questions
1682. Rebello T, Hodges RE, Smith JL. Short-term effects of various sugars on antinatriuresis and blood pressure changes in normotensive young men. The American journal of clinical nutrition Vol 38; 1983: 84–94. Not lactose intolerance study
1683. Recker RR, Heaney RP. The effect of milk supplements on calcium metabolism, bone metabolism and calcium balance. Am J Clin Nutr 1985 Feb; 41(2):254–63. Not eligible outcomes
1684. Reddy V, Bhaskaram P. Treatment of severe protein energy malnutrition. Indian Pediatr 1982 Mar; 19(3):243–8. Not relevant to key questions
1685. Reddy V, Pershad J. Lactase deficiency in Indians. Am J Clin Nutr 1972 Jan; 25(1):114–9. Not relevant to key questions
1686. Reed JA, Anderson JJ, Tylavsky FA, et al. Comparative changes in radial-bone density of elderly female lacto-ovovegetarians and omnivores. Am J Clin Nutr 1994 May; 59(5 Suppl):1197S–202S. Not target population
1687. Regan PT, DiMagno EP. The medical management of malabsorption. Mayo Clin Proc 1979 Apr; 54(4):267–74. Not relevant to key questions
1688. Register UD, Sonnenberg LM. The vegetarian diet. Scientific and practical considerations. J Am Diet Assoc 1973 Mar; 62(3):253–61. Review
1689. Rehnberg O. Antrectomy and gastroduodenostomy with or without vagotomy in peptic ulcer disease. A prospective study with a 5-year follow-up. Acta Chirurgica Scandinavica - Supplementum 1983; 515:1–63. No prevalence data
1690. Rehnberg O, Olbe L. Early dumping reaction after partial gastrectomy and its relation to preoperative apomorphine testing. Acta Chirurgica Scandinavica 1985; 151(6):565–9. No prevalence data
1691. Reiner EB, 2nd, Patterson M. Intestinal disaccharidase content. South Med J 1966 Mar; 59(3):311–4. Not relevant to key questions
1692. Rejman F. Postgastrectomy syndrome. EFFECTS OF PARTIAL GASTRECTOMY ON BONE METABOLISM. Ann Chir Gynaecol Fenn Suppl 1970; 170:45–50. Not eligible target population
1693. Renaud J, Bourassa M, Douglas VI, et al. Methylphenidate and motor organization in children with ADHD [abstract]. 150th Annual Meeting of the American Psychiatric Association; 1997 May 17–22; San Diego, CA; 1997. Not lactose intolerance study
1694. Resbeut M, Marteau P, Cowen D, et al. A randomized double blind placebo controlled multicenter study of mesalazine for the prevention of acute radiation enteritis. Radiotherapy & Oncology 1997 Jul; 44(1):59–63. Not eligible target population
1695. Retta TM, Afre GM, Randall OS. Dietary management of blood pressure. J Assoc Acad Minor Phys 1994; 5(4):147–51. Review
1696. Reusser ME, DiRienzo DB, Miller GD, et al. Adequate nutrient intake can reduce cardiovascular disease risk in African Americans. J Natl Med Assoc 2003 Mar; 95(3):188–95. Review
1697. Rey J, Schmitz J, Rey F, et al. Cellular differentiation and enzymatic deficits. Lancet 1971 Jul 24; 2(7717):218. Not relevant to key questions
1698. Rhee YS, Hermann JR, Burnham K, et al. The effects of chromium and copper supplementation on mitogen-stimulated T cell proliferation in hypercholesterolaemic postmenopausal women. Clinical and experimental immunology Vol 127; 2002: 463–9. Not lactose intolerance study
1699. Rhoades RB, Leifer KN, Cohan R, et al. Suppression of histamine-induced pruritus by three antihistaminic drugs. The Journal of allergy and clinical immunology Vol 55; 1975: 180–5. Not lactose intolerance study
1700. Ribeiro JHC, Lifshitz F. Alanine-based oral rehydration therapy for infants with acute diarrhea. The Journal of pediatrics Vol 118; 1991: S86–90. Not lactose intolerance study
1701. Richards AJ, Condon JR, Mallinson CN. Lactose intolerance following extensive small intestinal resection. Br J Surg 1971 Jul; 58(7):493–4. Not relevant to key questions
1702. Rickett JW, Jackson BT. Topical ampicillin in the appendicectomy wound: report of double-blind trial. British medical journal Vol 4; 1969: 206–7. Not lactose intolerance study
1703. Ridefelt P, Hakansson LD. Lactose intolerance: lactose tolerance test versus genotyping. Scandinavian Journal of Gastroenterology 2005 Jul; 40(7):822–6. Ineligible number of subjects
1704. Rider JA. Placebo gastric analysis. The American journal of gastroenterology Vol 56; 1971: 364–70. Not lactose intolerance study
1705. Rinaldi E, Albini L, Costagliola C, et al. High frequency of lactose absorbers among adults with idiopathic senile and presenile cataract in a population with a high prevalence of primary adult lactose malabsorption. Lancet 1984 Feb 18; 1(8373):355–7. Secondary lactose intolerance
1706. Ringrose RE, Thompson JB, Welsh JD. Lactose malabsorption and steatorrhea. Am J Dig Dis 1972 Jun; 17(6):533–8. Not relevant to key questions
1707. Risch HA, Jain M, Marrett LD, et al. Dietary lactose intake, lactose intolerance, and the risk of epithelial ovarian cancer in southern Ontario (Canada). Cancer Causes Control 1994 Nov; 5(6):540–8. Not eligible outcomes
1708. Ritschel WA, Johnson RD, Young DG. Evaluation of a controlled release osmotic pump type of dosage form for chlorpheniramine maleate. Eur J Pharm Biopharm Vol 40; 1994: 122–7. Not lactose intolerance study
1709. Rittmann LS, Tennant LL, O'Brien JS. Dog GM1 gangliosidosis: characterization of the residual liver acid beta-galactosidase. Am J Hum Genet 1980 Nov; 32(6):880–9. Not relevant to key questions
1710. Ritzenthaler KL, McGuire MK, McGuire MA, et al. Consumption of conjugated linoleic acid (CLA) from CLA-enriched cheese does not alter milk fat or immunity in lactating women. Journal of Nutrition Vol 135; 2005: 422–30. Not lactose intolerance study
1711. Rizkalla SW, Luo J, Kabir M, et al. Chronic consumption of fresh but not heated yogurt improves breath-hydrogen status and short-chain fatty acid profiles: a controlled study in healthy men with or without lactose maldigestion. Am J Clin Nutr 2000 Dec; 72(6):1474–9. Not relevant to key questions
1712. Robb TA, Goodwin DA, Davidson GP. Faecal hydrogen production in vitro as an indicator for in vivo hydrogen producing capability in the breath hydrogen test. Acta Paediatr Scand 1985 Nov; 74(6):942–4. Not relevant to key questions
1713. Roberfroid MB. Prebiotics and probiotics: are they functional foods? Am J Clin Nutr 2000 Jun; 71(6 Suppl):1682S–7S; discussion 8S–90S. Not relevant to key questions
1714. Roberson CM. Lactose intolerance. Ala Nurse 2004 Dec–2005 Feb; 31(4):23–4; quiz 4. Comment
1715. Roberts SB, Hajduk CL, Howarth NC, et al. Dietary variety predicts low body mass index and inadequate macronutrient and micronutrient intakes in community-dwelling older adults. J Gerontol A Biol Sci Med Sci 2005 May; 60(5):613–21. Not relevant to key questions
1716. Robertson WG, Peacock M, Heyburn PJ, et al. Should recurrent calcium oxalate stone formers become vegetarians? Br J Urol 1979 Dec; 51(6):427–31. Not eligible outcomes
1717. Rodgers AL, Lewandowski S. Effects of 5 different diets on urinary risk factors for calcium oxalate kidney stone formation: evidence of different renal handling mechanisms in different race groups. J Urol 2002 Sep; 168(3):931–6. Not eligible outcomes
1718. Rodriguez M, Daniels B, Gunawardene S, et al. High frequency of vitamin D deficiency in ambulatory HIV-Positive patients. AIDS Research & Human Retroviruses 2009 Jan; 25(1):9‐14. No prevalence data
1719. Rodriguez-Rodriguez E, Aparicio A, Perea JM, et al. [Aproximation of the diet to the Mediterranean profile and repercusion in the body weight control]. Nutricion Clinica y Dietetica Hospitalaria Vol 26; 2006: 9–17. Not lactose intolerance study
1720. Roe DA. Prediction of the cause, effects, and prevention of drug-nutrient interactions using attributes and attribute values. Drug Nutr Interact 1985; 3(4):187–9. Not relevant to key questions
1721. Roelofs RI, de AGS, Law PK, et al. Treatment of Duchenne's muscular dystrophy with penicillamine. Results of a double-blind trial. Archives of neurology Vol 36; 1979: 266–8. Not lactose intolerance study
1722. Roggero P, Offredi ML, Mosca F, et al. Lactose absorption and malabsorption in healthy Italian children: do the quantity of malabsorbed sugar and the small bowel transit time play roles in symptom production? Journal of Pediatric Gastroenterology & Nutrition 1985 Feb; 4(1):82–6. Ineligible number of subjects
1723. Rolfe RD. The role of probiotic cultures in the control of gastrointestinal health. J Nutr 2000 Feb; 130(2S Suppl):396S–402S. Not relevant to key questions
1724. Romer H, Olivero E, Gomez-rodriguez G, et al. Effect of carbohydrate composition of semi-elemental diets on the nutritional recovery of children with chronic diarrhea. Nutr Rep Int Vol 40; 1989: 843–52. Not relevant to key questions
1725. Ropert A, Cherbut C, Rozé C, et al. Colonic fermentation and proximal gastric tone in humans. Gastroenterology Vol 111; 1996: 289–96. Not relevant to key questions
1726. Rosado JL. [Importance of nutritional status in digestion capacity and lactose tolerance]. Revista de investigación clínica; organo del Hospital de Enfermedades de la Nutrición Vol 48; 1996: 45–50. Not relevant to key questions
1727. Rosado JL, Allen LH, Solomons NW. Milk consumption, symptom response, and lactose digestion in milk intolerance. Am J Clin Nutr 1987 Jun; 45(6):1457–60. Not relevant to key questions
1728. Rosado JL, Deodhar AD, Bourges H, et al. The effect of the digestion products of lactose (glucose and galactose) on its intraintestinal, in vivo hydrolysis by exogenous microbial beta-D-galactosidase. J Am Coll Nutr 1986; 5(3):281–90. Not relevant to key questions
1729. Rosado JL, López P, Palma M. [Poor digestion and intolerance to lactose in Mexican adults. Importance of evaluating them with regular doses of milk]. Revista de investigación clínica; organo del Hospital de Enfermedades de la Nutrición Vol 46; 1994: 203–8. Not relevant to key questions
1730. Rosado JL, Morales M, Pasquetti A. Lactose digestion and clinical tolerance to milk, lactose-prehydrolyzed milk and enzyme-added milk: a study in undernourished continuously enteral-fed patients. JPEN J Parenter Enteral Nutr 1989 Mar–Apr; 13(2):157–61. Not relevant to key questions
1731. Rosado JL, Morales M, Pasquetti A, et al. Nutritional evaluation of a lactose-hydrolyzed milk-based enteral formula diet. I. A comparative study of carbohydrate digestion and clinical tolerance. Rev Invest Clin 1988 Apr–Jun; 40(2):141–7. Not relevant to key questions
1732. Rosado JL, Solomons NW. Sensitivity and specificity of the hydrogen breath-analysis test for detecting malabsorption of physiological doses of lactose. Clin Chem 1983 Mar; 29(3):545–8. Not relevant to key questions
1733. Rosado JL, Solomons NW, Allen LH. Lactose digestion from unmodified, low-fat and lactose-hydrolyzed yogurt in adult lactose-maldigesters. Eur J Clin Nutr 1992 Jan; 46(1):61‐ 7. Not relevant to key questions
1734. Rosanelli K, Hofler K. [Comparative studies on the rearing of premature infants with various milk mixtures]. Wiener Medizinische Wochenschrift Vol 115; 1965: 160–4. Not relevant to key questions
1735. Rosenberg IH, Solomons NW, Schneider RE. Malabsorption associated with diarrhea and intestinal infections. Am J Clin Nutr 1977 Aug; 30(8):1248–53. Not relevant to key questions
1736. Rosenkranz W, Hadorn B, Muller W, et al. Distribution of human adult lactase phenotypes in the population of Austria. Hum Genet 1982; 62(2):158–61. Not relevant to key questions
1737. Rosenquist CJ. Lactose-barium study as a screening test for lactase deficiency. West J Med 1975 Apr; 122(4):319. Not relevant to key questions
1738. Rosenquist CJ, Heaton JW, Jr., Friedland GW, et al. Assessment of a radiographic method for diagnosis of intestinal lactase deficiency: a prospective study. Investigative Radiology 1971 Jan–Feb; 6(1):40–3. Ineligible number of subjects
1739. Rosenquist CJ, Heaton JW, Jr., Gray GM, et al. Intestinal lactase deficiency. Diagnosis by routine upper gastrointestinal radiography. Radiology 1972 Feb; 102(2):275–7. Not relevant to key questions
1740. Rosensweig NS. Adult human milk intolerance and intestinal lactase deficiency. A review. J Dairy Sci 1969 May; 52(5):585–7. Not relevant to key questions
1741. Rosensweig NS. Adult lactase deficiency: genetic control or adaptive response? Gastroenterology 1971 Mar; 60(3):464–7. Not relevant to key questions
1742. Rosensweig NS. Lactose feeding and lactase deficiency. Am J Clin Nutr 1973 Nov; 26(11):1166–7. Not relevant to key questions
1743. Rosensweig NS. Other carbohydrate intolerances. Curr Concepts Nutr 1979; 8:91–6. Not relevant to key questions
1744. Rosensweig NS, Dawkins AT, Jr., Bayless TM. Lactase activity before and after acute febrile bacterial illness. Gastroenterology 1967 Jan; 52(1):50–3. Not relevant to key questions
1745. Rossi E, Hadorn B. Congenital enzyme deficiencies of the small intestine: molecular basis and nutritional and therapeutic implications. J Pediatr Gastroenterol Nutr 1983; 2 Suppl 1:S321–7. Not relevant to key questions
1746. Rossiter MA, Palmer T, Evans K, et al. The short-term response to a drink of milk, lactose or casein in children with apparently normal gastrointestinal tracts. The British journal of nutrition Vol 32; 1974: 605–13. Not relevant to key questions
1747. Rothman D, Habte D, Latham M. The effect of lactose on diarrhoea in the treatment of kwashiorkor. J Trop Pediatr 1980 Oct; 26(5):193–7. Not relevant to key questions
1748. Rotthauwe HW, el-Schallah MO, Flatz G. Lactose intolerance in Arabs. Humangenetik 1971; 13(4):344–6. Not relevant to key questions
1749. Rouse IL, Beilin LJ, Armstrong BK, et al. Vegetarian diet, blood pressure and cardiovascular risk. Aust N Z J Med 1984 Aug; 14(4):439–43. Not relevant to key questions
1750. Rouse IL, Beilin LJ, Mahoney DP, et al. Nutrient intake, blood pressure, serum and urinary prostaglandins and serum thromboxane references.r2 in a controlled trial with a lacto-ovo-vegetarian diet. J Hypertens 1986 Apr; 4(2):241–50. Not relevant to key questions
1751. Rowland I. Probiotics and benefits to human health--the evidence in favour. Environ Microbiol 1999 Oct; 1(5):375–6. Not relevant to key questions
1752. Roy P, Aubert-Jacquin C, Avart C, et al. [Benefits of a thickened infant formula with lactase activity in the management of benign digestive disorders in newborns]. Archives de pédiatrie : organe officiel de la Sociéte française de pédiatrie Vol 11; 2004: 1546–54. Not English language
1753. Roy PK, Venzon DJ, Shojamanesh H, et al. Zollinger-Ellison syndrome. Clinical presentation in 261 patients. Medicine 2000 Nov; 79(6):379–411. No prevalence data
1754. Rozen GS, Rennert G, Rennert HS, et al. Calcium intake and bone mass development among Israeli adolescent girls. J Am Coll Nutr 2001 Jun; 20(3):219–24. Not eligible outcomes
1755. Rozen P, Shafrir E. Behavior of serum free fatty acids and glucose during lactose tolerance tests. Isr J Med Sci 1968 Jan–Feb; 4(1):100–9. Not relevant to key questions
1756. Rudolf M, Arulanantham K, Greenstein RM. Unsuspected nutritional rickets. Pediatrics 1980 Jul; 66(1):72–6. Not eligible target population
1757. Rudzeviciene O, Narkeviciute I, Eidukevicius R. Lactose malabsorption in young Lithuanian children with atopic dermatitis. Acta Paediatrica 2004 Apr; 93(4):482–6. Secondary lactose intolerance
1758. Rugg GAJ, Roberts GJ, Wright WG. Effect of human milk on plaque pH in situ and enamel dissolution in vitro compared with bovine milk, lactose, and sucrose. Caries-Res Vol 19; 1985: 327–34. Not eligible outcomes
1759. Rugg-Gunn AJ, Wright WG. The effect of human milk on plaque pH and enamel dissolution compared with cow's milk, lactose and sucrose (JDR Divisional Abstract). Journal of Dental Research Vol 62; 1983: 426 (Abs 105). Not relevant to key questions
1760. Ruijter J, Lorist MM, Snel J. The influence of different doses of caffeine on visual task performance. Journal of Psychophysiology Vol 13; 1999: 37–48. Not lactose intolerance study
1761. Rumessen JJ, Gudmand-Hoyer E, Bachmann E, et al. Diagnosis of bacterial overgrowth of the small intestine. Comparison of the 14C-D-xylose breath test and jejunal cultures in 60 patients. Scand J Gastroenterol 1985 Dec; 20(10):1267–75. Not relevant to key questions
1762. Russo F, De Carne M, Buonsante A, et al. Hypolactasia and metabolic changes in post‐menopausal women. Maturitas 1997 Apr; 26(3):193–202. Ineligible number of subjects
1763. Russo G, Mollica F, Mazzone D, et al. Congenital lactose intolerance of gastrogen origin associated with cataracts. Acta Paediatr Scand 1974 May; 63(3):457–60. Not relevant to key questions
1764. Rutherford PJ, Davidson DC, Matthai SM. Dietary calcium in galactosaemia. Journal of Human Nutrition & Dietetics 2002 Feb; 15(1):39–42. Not relevant to key questions
1765. Saavedra JM. Clinical applications of probiotic agents. Am J Clin Nutr 2001 Jun; 73(6):1147S–51S. Not relevant to key questions
1766. Saavedra JM, Perman JA. Current concepts in lactose malabsorption and intolerance. Annu Rev Nutr 1989; 9:475–502. Not relevant to key questions
1767. Sacerdote C, Guarrera S, Smith GD, et al. Lactase persistence and bitter taste response: instrumental variables and mendelian randomization in epidemiologic studies of dietary factors and cancer risk. Am J Epidemiol 2007 Sep 1; 166(5):576–81. Not relevant to key questions
1768. Sadre M, Ghassemi H. Milk intolerance among Iranian school children. J Trop Pediatr 1981 Dec; 27(6):312–4. Not relevant to key questions
1769. Sadre M, Karbasi K. Lactose intolerance in Iran. American Journal of Clinical Nutrition 1979 Sep; 32(9):1948–54. Ineligible number of subjects
1770. Sahi T. Lactose malabsorption in Finnish-speaking and Swedish-speaking populations in Finland. Scand J Gastroenterol 1974; 9(3):303–8. Not relevant to key questions
1771. Sahi T. The inheritance of selective adult-type lactose malabsorption. Scand J Gastroenterol Suppl 1974; 30:1–73. Not relevant to key questions
1772. Sahi T. Intestinal lactase polymorphisms and dairy foods. Hum Genet Suppl 1978; (1):115‐23. Not relevant to key questions
1773. Sahi T. Genetics and epidemiology of adult-type hypolactasia. Scandinavian Journal of Gastroenterology - Supplement 1994; 202:7–20. Not original research
1774. Sahi T, Isokoski M, Jussila J, et al. Population surveys of lactose malabsorption. Preliminary report. Acta Sociomed Scand 1970; 2(2):161–5. Not relevant to key questions
1775. Sahi T, Isokoski M, Jussila J, et al. Lactose malabsorption in Finnish children of school age. Acta Paediatr Scand 1972 Jan; 61(1):11–6. Not relevant to key questions
1776. Sahi T, Isokoski M, Jussila J, et al. Recessive inheritance of adult-type lactose malabsorption. Lancet 1973 Oct 13; 2(7833):823–6. Not relevant to key questions
1777. Sahi T, Jussila J, Penttila IM, et al. Serum lipids and proteins in lactose malabsorption. Am J Clin Nutr 1977 Apr; 30(4):476–81. Not relevant to key questions
1778. Sahi T, Launiala K. More evidence for the recessive inheritance of selective adult type lactose malabsorption. Gastroenterology 1977 Aug; 73(2):231–2. Ineligible number of subjects
1779. Sahi T, Launiala K. Manifestation and occurrence of selective adult-type lactose malabsorption in Finnish teenagers. A follow-up study. American Journal of Digestive Diseases 1978 Aug; 23(8):699–704. Not original research
1780. Sahi T, Launiala K, Laitinen H. Hypolactasia in a fixed cohort of young Finnish adults. A follow-up study. Scandinavian Journal of Gastroenterology 1983 Oct; 18(7):865–70. Not original research
1781. Sakuraba H, Aoyagi T, Suzuki Y. Galactosialidosis (beta-galactosidase-neuraminidase deficiency): a possible role of serine-thiol proteases in the degradation of beta-galactosidase molecules. Clin Chim Acta 1982 Nov 10; 125(3):275–82. Not relevant to key questions
1782. Sakuraba H, Suzuki Y, Fukuoka K, et al. beta-Galactosidase--neuraminidase deficiency. Deficiency of a freeze-labile neuraminidase in leukocytes and fibroblasts. J Inherit Metab Dis 1982; 5(2):79–80. Not relevant to key questions
1783. Salazar de Sousa J, da Silva A, Pereira MV, et al. Cow's milk protein-sensitive enteropathy: number and timing of biopsies for diagnosis. J Pediatr Gastroenterol Nutr 1986 Mar–Apr; 5(2):207–9. Not relevant to key questions
1784. Salazar-Lindo E, Figueroa-Quintanilla D, Caciano MI, et al. Effectiveness and safety of Lactobacillus LB in the treatment of mild acute diarrhea in children. Journal of pediatric gastroenterology and nutrition Vol 44; 2007: 571–6. Not lactose intolerance
1785. Salazar-Lindo E, Miranda-Langschwager P, Campos-Sanchez M, et al. Lactobacillus casei strain GG in the treatment of infants with acute watery diarrhea: a randomized, double-blind, placebo controlled clinical trial [ISRCTN67363048]. BMC Pediatrics 2004 Sep 2; 4:18. No prevalence data
1786. Salminen E, Karonen SL, Salminen S. Blood glucose and plasma insulin responses to fat free milk and low-lactose fat free milk in healthy human volunteers. Z Ernahrungswiss 1987 Mar; 26(1):52–5. Not relevant to key questions
1787. Salmon PR, Read AE, McCarthy CF. An isotope technique for measuring lactose absorption. Gut 1969 Aug; 10(8):685–9. Ineligible number of subjects
1788. Saltzman JR, Russell RM, Golner B, et al. A randomized trial of Lactobacillus acidophilus BG2FO4 to treat lactose intolerance. Am J Clin Nutr 1999 Jan; 69(1):140–6. Not relevant to key questions
1789. Salvioli G, Lugli R, Pradelli JM. Relationships between squalene and cholesterol in bile: Effect of ursodeoxycholic acid administration in patients with radiolucent gallstones. Metab Clin Exp Vol 33; 1984: 641–5. Not lactose intolerance study
1790. Sandberg DH. Intolerance to lactose in Negro children. Pediatrics 1970 Oct; 46(4):646. Not relevant to key questions
1791. Sanders ME, Klaenhammer TR. Invited review: the scientific basis of Lactobacillus acidophilus NCFM functionality as a probiotic. Journal of dairy science 2001 Feb; 84(2):319‐31. Review
1792. Sanders SW, Tolman KG, Reitberg DP. Effect of a single dose of lactase on symptoms and expired hydrogen after lactose challenge in lactose-intolerant subjects. Clin Pharm 1992 Jun; 11(6):533–8. Not relevant to key questions
1793. Sanders T. Good nutrition for the vegetarian mother. Mod Midwife 1994 Apr; 4(4):23–6. Not relevant to key questions
1794. Sanders TA. Growth and development of British vegan children. Am J Clin Nutr 1988 Sep; 48(3 Suppl):822–5. Not relevant to key questions
1795. Sanders TA, Key TJ. Blood pressure, plasma renin activity and aldosterone concentrations in vegans and omnivore controls. Hum Nutr Appl Nutr 1987 Jun; 41(3):204–11. Not relevant to key questions
1796. Sanders TA, Purves R. An anthropometric and dietary assessment of the nutritional status of vegan preschool children. J Hum Nutr 1981 Oct; 35(5):349–57. Not relevant to key questions
1797. Sandhu BK, Isolauri E, Walker-Smith JA, et al. A multicentre study on behalf of the European Society of Paediatric Gastroenterology and Nutrition Working Group on Acute Diarrhoea. Early feeding in childhood gastroenteritis. Journal of Pediatric Gastroenterology & Nutrition 1997 May; 24(5):522–7. No prevalence data
1798. Sandler RB, Slemenda CW, LaPorte RE, et al. Postmenopausal bone density and milk consumption in childhood and adolescence. Am J Clin Nutr 1985 Aug; 42(2):270–4. Not eligible outcomes
1799. Sannolo N, Vajro P, Dioguardi G, et al. Gas chromatographic quantitation of breath hydrogen and carbon monoxide for clinical investigation in adults and in children. J Chromatogr 1983 Sep 9; 276(2):257–65. Not relevant to key questions
1800. Santosham M, Fayad IM, Hashem M, et al. A comparison of rice-based oral rehydration solution and "early feeding" for the treatment of acute diarrhea in infants. The Journal of pediatrics Vol 116; 1990: 868–75. Not relevant to key questions
1801. Santosham M, Foster S, Reid R, et al. Role of soy-based, lactose-free formula during treatment of acute diarrhea. Pediatrics Vol 76; 1985: 292–8. Not relevant to key questions
1802. Santosham M, Goepp J, Burns B, et al. Role of a soy-based lactose-free formula in the outpatient management of diarrhea. Pediatrics Vol 87; 1991: 619–22. Not relevant to key questions
1803. Sarri K, Linardakis M, Codrington C, et al. Does the periodic vegetarianism of Greek Orthodox Christians benefit blood pressure? Prev Med 2007 Apr; 44(4):341–8. Not relevant to key questions
1804. Sasaki Y, Iio M, Kameda H, et al. Measurement of 14C-lactose absorption in the diagnosis of lactase deficiency. J Lab Clin Med 1970 Nov; 76(5):824–35. Not relevant to key questions
1805. Sastre J, Lluch-Bernal M, Quirce S, et al. A double-blind, placebo-controlled oral challenge study with lyophilized larvae and antigen of the fish parasite, Anisakis simplex. Allergy Vol 55; 2000: 560–4. Not lactose intolerance study
1806. Sategna-Guidetti C, Cruto E, Capobianco P. Breath hydrogen excretion after lactose and whole milk ingestion. A prospective comparison in lactase deficiency. Journal of Clinical Gastroenterology 1989 Jun; 11(3):287–9. Ineligible number of subjects
1807. Savaiano D. Lactose intolerance: a self-fulfilling prophecy leading to osteoporosis? Nutr Rev 2003 Jun; 61(6 Pt 1):221–3. Review
1808. Savaiano DA, Boushey CJ, McCabe GP. Lactose intolerance symptoms assessed by meta‐analysis: a grain of truth that leads to exaggeration. J Nutr Vol 136; 2006: 1107–13. Not eligible outcomes
1809. Savaiano DA, Kotz C. Recent advances in the management of lactose intolerance. ASDC J Dent Child 1989 May–Jun; 56(3):228–33. Not relevant to key questions
1810. Savilahti E, Launiala K, Kuitunen P. Jejunal disaccharidases in children with selective IgA deficiency. Scand J Gastroenterol 1973; 8(5):417–9. Not relevant to key questions
1811. Savilahti E, Launiala K, Kuitunen P. Congenital lactase deficiency. A clinical study on 16 patients. Archives of Disease in Childhood 1983 Apr; 58(4):246–52. Ineligible number of subjects
1812. Savilahti E, Pelkonen P, Visakorpi JK. IgA deficiency in children. A clinical study with special reference to intestinal findings. Arch Dis Child 1971 Oct; 46(249):665–70. Not relevant to key questions
1813. Savino F. Focus on infantile colic. Acta Paediatr 2007 Sep; 96(9):1259–64. Not relevant to key questions
1814. Sawicki W. Pharmacokinetics of verapamil and norverapamil from controlled release floating pellets in humans. European Journal of Pharmaceutics & Biopharmaceutics Vol 53; 2002: 29–35. Not lactose intolerance study
1815. Scaglione F, Ferrara F, Dugnani S, et al. Immunomodulatory effects of two extracts of Panax ginseng C.A. Meyer. Drugs under experimental and clinical research Vol 16; 1990: 537–42. Not lactose intolerance study
1816. Schachter EN, Brown S, Lach E, et al. Histamine blocking agents in healthy and asthmatic subjects. Chest Vol 82; 1982: 143–7. Not lactose intolerance study
1817. Schade DS, Eaton RP, George S, et al. Metabolic effects of clofibrate in insulin-dependent ketosis-prone diabetic man. Metabolism: clinical and experimental Vol 27; 1978: 461–8. Not lactose intolerance study
1818. Schaefer O. Adverse reactions to drugs and metabolic problems perceived in Northern Canadian Indians and Eskimos. Progress in Clinical & Biological Research 1986; 214:77–83. No prevalence data
1819. Scharff L. Recurrent abdominal pain in children: a review of psychological factors and treatment. Clinical Psychology Review 1997; 17(2):145–66. Not original research
1820. Schirru E, Corona V, Usai-Satta P, et al. Genetic testing improves the diagnosis of adult type hypolactasia in the Mediterranean population of Sardinia. European Journal of Clinical Nutrition 2007 Oct; 61(10):1220–5. Ineligible number of subjects
1821. Schlimmer P. Formoterol Turbuhaler 6 mug vs. Formoterol Aerolizer 12 mug. Atemwegs- und Lungenkrankheiten Vol 26; 2000: 263–8. Not lactose intolerance study
1822. Schmidt BJ, Costa CVD, Oshiro CGS, et al. [Evaluation of a low lactose formula food in children with diahrreic syndrome]. Rev Paul Pediatr Vol 8; 1990: 91–6. Not relevant to key questions
1823. Schmidt P, Freund E, de MC, et al. Bronchodilatory response to three batches of fenoterol/ipratropium lactose based powder capsules with different fine particle fractions in asthmatic patients [abstract]. European Respiratory Journal. Supplement. Vol 9; 1996: 204s. Not lactose intolerance study
1824. Schmidt W, Schneider T, Heise W, et al. Mucosal abnormalities in microsporidiosis. AIDS 1997 Nov; 11(13):1589–94. No prevalence data
1825. Schneider RE, Corona E, Rosales F, et al. Effect of temperature on the lactose hydrolytic capacity of a lactase derived from Kluyveromyces lactis. Am J Clin Nutr 1990 Feb; 51(2):197–201. Not relevant to key questions
1826. Schnuth ML. You and your vegetarian patients. RDH 1994 Apr; 14(4):12–4, 6, 8 passim. Comment
1827. Schramm P. [Clinical experiences with collagenase powder on ulcers of different origin]. Aktuelle Dermatologie Vol 15; 1989: 146–9. Not lactose intolerance study
1828. Schrander JJ, Dellevoet JJ, Arends JW, et al. Small intestinal mucosa IgE plasma cells and specific anti-cow milk IgE in children with cow milk protein intolerance. Annals of Allergy 1993 May; 70(5):406–9. Subjects less than 4 years old
1829. Schrander JJ, Oudsen S, Forget PP, et al. Follow up study of cow's milk protein intolerant infants. European Journal of Pediatrics 1992 Oct; 151(10):783–5. No prevalence data
1830. Schrander JJ, Unsalan-Hooyen RW, Forget PP, et al. [51Cr]EDTA intestinal permeability in children with cow's milk intolerance. J Pediatr Gastroenterol Nutr 1990 Feb; 10(2):189–92. Not relevant to key questions
1831. Schrander JJ, van den Bogart JP, Forget PP, et al. Cow's milk protein intolerance in infants under 1 year of age: a prospective epidemiological study. European Journal of Pediatrics 1993 Aug; 152(8):640–4. Subjects less than 4 years old
1832. Schroeder DJ, Collins WE, Elam GW. Effects of some motion sickness suppressants on static and dynamic tracking performance. Aviation, space, and environmental medicine Vol 56; 1985: 344–50. Not lactose intolerance study
1833. Schuette SA, Yasillo NJ, Thompson CM. The effect of carbohydrates in milk on the absorption of calcium by postmenopausal women. Journal of the American College of Nutrition Vol 10; 1991: 132–9. Not eligible outcomes
1834. Schuh KJ, Schubiner H, Johanson CE. Discrimination of intranasal cocaine. Behavioural Pharmacology Vol 11; 2000: 511–5. Not lactose intolerance study
1835. Schulpis KH, Papassotiriou I, Tsakiris S. 8-hydroxy-2-desoxyguanosine serum concentrations as a marker of DNA damage in patients with classical galactosaemia. Acta Paediatrica 2006 Feb; 95(2):164–9. Not relevant to key questions
1836. Schwachman H, Lebenthal E. Letter: Lactose tolerance in children. N Engl J Med 1975 Aug 7; 293(6):305–6. Not relevant to key questions
1837. Schwartz RH, Puglese J, Schwartz DM. Use of a short course of prednisone for treating middle ear effusion. A double-blind crossover study. The Annals of otology, rhinology & laryngology. Supplement Vol 89; 1980: 296–300. Not lactose intolerance study
1838. Sciarretta G, Giacobazzi G, Verri A, et al. Hydrogen breath test quantification and clinical correlation of lactose malabsorption in adult irritable bowel syndrome and ulcerative colitis. Digestive Diseases & Sciences 1984 Dec; 29(12):1098–104. Ineligible number of subjects
1839. See MC, Birnbaum AH, Schechter CB, et al. Double-blind, placebo-controlled trial of famotidine in children with abdominal pain and dyspepsia: global and quantitative assessment. Digestive diseases and sciences Vol 46; 2001: 985–92. Not lactose intolerance study
1840. Seetharam B, Perrillo R, Alpers DH. Effect of pancreatic proteases on intestinal lactase activity. Gastroenterology 1980 Nov; 79(5 Pt 1):827–32. Not relevant to key questions
1841. Segall JJ. Hypothesis is lactose a dietary risk factor for ischaemic heart disease?[see comment][reprint in Int J Epidemiol. 2008 Dec;37(6):1204–8; discussion 1209–16; PMID: 18725363]. International Journal of Epidemiology 1980 Sep; 9(3):271–6. Not original research
1842. Segall JJ. Hypothesis is lactose a dietary risk factor for ischaemic heart disease? International Journal of Epidemiology 1980 Sep; 9(3):271–6. Duplicate listing
1843. Segall JJ. Dietary lactose as a possible risk factor for ischaemic heart disease: review of epidemiology.[see comment]. International Journal of Cardiology 1994 Oct; 46(3):197–207. Not original research
1844. Segall JJ. Digestive and nutritional factors may explain lower prevalence of coronary disease in indigenous peoples. BMJ 2003 Aug 23; 327(7412):449–50. No prevalence data
1845. Senewiratne B, Thambipillai S, Perera H. Intestinal lactase deficiency in Ceylon (Sri Lanka). Gastroenterology 1977 Jun; 72(6):1257–9. Not eligible test for lactose malabsorption
1846. Seppanen S, Niittynen L, Poussa T, et al. Removing lactose from milk does not delay bowel function or harden stool consistency in lactose-tolerant women. European journal of clinical nutrition 2008 Jun; 62(6):727–32. Not relevant to key questions
1847. Seppo L, Tuure T, Korpela R, et al. Can primary hypolactasia manifest itself after the age of 20 years? A two-decade follow-up study. Scandinavian Journal of Gastroenterology 2008; 43(9):1082–7. No prevalence data
1848. Seriki O, Adcock KJ. Lactose intolerance in infancy as a cuase for failure to thrive. West Afr Med J Niger Pract 1968 Feb; 17(1):14–6. Not relevant to key questions
1849. Sethi SK, Khuffash FA, al-Nakib W. Microbial etiology of acute gastroenteritis in hospitalized children in Kuwait. Pediatric Infectious Disease Journal 1989 Sep; 8(9):593–7. No prevalence data
1850. Sewell AC. Simple laboratory determination of excess oligosacchariduria. Clin Chem 1981 Feb; 27(2):243–5. Not relevant to key questions
1851. Sewell AC. The simple detection of neuraminic acid-containing urinary oligosaccharides in patients with glycoprotein storage diseases. J Inherit Metab Dis 1983; 6(4):153–7. Not relevant to key questions
1852. Sewell AC, Gehler J, Spranger J. Urinary oligosaccharide screening in patients with beta-galactosidase deficiency. Eur J Pediatr 1980 May; 133(3):269–71. Not relevant to key questions
1853. Shah KA, Needham TE. Correlation of urinary excretion with in vitro dissolution using several dissolution methods for hydrochlorothiazide formulations. J Pharm Sci Vol 68; 1979: 1486–90. Not lactose intolerance study
1854. Shahani KM, Chandan RC. Nutritional and healthful aspects of cultured and culture-containing dairy foods. J Dairy Sci 1979 Oct; 62(10):1685–94. Not relevant to key questions
1855. Shakur BH, Kemhadjian EL, Myers JD, et al. Minimum dose of inhaled lactose sensed by asthmatic patients. American Journal of Respiratory and Critical Care Medicine Vol 157; 1998: A637. Not lactose intolerance study
1856. Shane AL. Applications of probiotics for neonatal enteric diseases. J Perinat Neonatal Nurs 2008 Jul–Sep; 22(3):238–43. Not relevant to key questions
1857. Sharma AD. Disulfiram and low nickel diet in the management of hand eczema: a clinical study. Indian journal of dermatology, venereology and leprology Vol 72; 2006: 113–8. Not lactose intolerance study
1858. Shatin R. Evolution and lactase deficiency. Gastroenterology 1968 May; 54(5):992. Not relevant to key questions
1859. Shaw AD, Davies GJ. Lactose intolerance: problems in diagnosis and treatment. J Clin Gastroenterol 1999 Apr; 28(3):208–16. Not relevant to key questions
1860. Sheih YH, Chiang BL, Wang LH, et al. Systemic immunity-enhancing effects in healthy subjects following dietary consumption of the lactic acid bacterium Lactobacillus rhamnosus HN001. Journal of the American College of Nutrition Vol 20; 2001: 149–56. Not lactose intolerance study
1861. Sheppard D, Nadel JA, Boushey HA. Inhibition of sulfur dioxide-induced bronchoconstriction by disodium cromoglycate in asthmatic subjects. The American review of respiratory disease Vol 124; 1981: 257–9. Not lactose intolerance study
1862. Shermak MA, Saavedra JM, Jackson TL, et al. Effect of yogurt on symptoms and kinetics of hydrogen production in lactose-malabsorbing children. Am J Clin Nutr 1995 Nov; 62(5):1003–6. Not relevant to key questions
1863. Sherr HP. When diarrhea persists. Med Times 1980 Aug; 108(8):76–89. Not relevant to key questions
1864. Shibata Y, Yamamoto Y, Fujii M, et al. A novel method for predicting disintegration time in the mouth of rapidly disintegrating tablet by compaction analysis using TabAll. Chemical & pharmaceutical bulletin Vol 52; 2004: 1394–5. Not lactose intolerance study
1865. Shimomura Y, Maeda K, Nagasaki M, et al. Attenuated response of the serum triglyceride concentration to ingestion of a chocolate containing polydextrose and lactitol in place of sugar. Bioscience, biotechnology, and biochemistry Vol 69; 2005: 1819–23. Not lactose intolerance study
1866. Shiner M. Ultrastructural features of allergic manifestations in the small intestine of children. Scand J Gastroenterol Suppl 1981; 70:49–64. Not relevant to key questions
1867. Shishehbor F, Roche HM, Gibney MJ. The effect of acute carbohydrate load on the monophasic or biphasic nature of the postprandial lipaemic response to acute fat ingestion in human subjects. The British journal of nutrition Vol 80; 1998: 411–8. Not lactose intolerance study
1868. Shore L. Disodium cromoglycate (Rynacrom) in the treatment of nasal allergy in children. South African medical journal = Suid-Afrikaanse tydskrif vir geneeskunde Vol 46; 1972: 279–81. Not lactose intolerance study
1869. Shows TB, Mueller OT, Honey NK, et al. Genetic heterogeneity of I-cell disease is demonstrated by complementation of lysosomal enzyme processing mutants. Am J Med Genet 1982 Jul; 12(3):343–53. Not relevant to key questions
1870. Shrier I, Szilagyi A, Correa JA. Impact of lactose containing foods and the genetics of lactase on diseases: an analytical review of population data. Nutrition & Cancer 2008 May–Jun; 60(3):292–300. Not original research
1871. Shulman, R J, Schanler, et al. Early feeding in preterm infants increases lactase activity. Pediatric Research Vol 39; 1996: 320a. Not eligible target population
1872. Shulman RJ, Feste A, Ou C. Absorption of lactose, glucose polymers, or combination in premature infants. The Journal of pediatrics Vol 127; 1995: 626–31. Not relevant to key questions
1873. Shulman RJ, Lifschitz CH, Langston C, et al. Human milk and the rate of small intestinal mucosal recovery in protracted diarrhea. The Journal of pediatrics Vol 114; 1989: 218–24. Not relevant to key questions
1874. Shulman RJ, Schanler RJ, Lau C, et al. Early feeding, feeding tolerance, and lactase activity in preterm infants. Journal of Pediatrics 1998 Nov; 133(5):645–9. No prevalence data
1875. Shulman RJ, Wong WW, Smith EO. Influence of changes in lactase activity and small-intestinal mucosal growth on lactose digestion and absorption in preterm infants. American Journal of Clinical Nutrition 2005 Feb; 81(2):472–9. Ineligible number of subjects
1876. Shuster S, Marks J. Dermatitis herpetiformis and the coeliac syndrome. Proc R Soc Med 1969 Oct; 62(10):985–6. Not relevant to key questions
1877. Shwachman H, Lloyd-Still JD, Khaw KT, et al. Protracted diarrhea of infancy treated by intravenous alimentation. II. Studies of small intestinal biopsy results. American Journal of Diseases of Children 1973 Mar; 125(3):365–8. Subjects less than 4 years old
1878. Sicherer SH. I've always thought I was allergic to milk, but now I'm told that I have a food intolerance, not an allergy. What's the difference? Health News 2002 Jun; 8(6):12. Not relevant to key questions
1879. Siegel M, Krantz B, Lebenthal E. Effect of fat and carbohydrate composition on the gastric emptying of isocaloric feedings in premature infants. Gastroenterology Vol 89; 1985: 785–90. Not relevant to key questions
1880. Siener R, Hesse A. Influence of a mixed and a vegetarian diet on urinary magnesium excretion and concentration. Br J Nutr 1995 May; 73(5):783–90. Not eligible outcomes
1881. Sill V, Bartuschka B, Villiger B, et al. [Changes in specific airway resistance after powder inhalation of formoterol or salmeterol in moderate bronchial asthma]. Pneumologie (Stuttgart, Germany) Vol 53; 1999: 4–9. Not lactose intolerance study
1882. Silvennoinen J, Lamberg-Allardt C, Karkkainen M, et al. Dietary calcium intake and its relation to bone mineral density in patients with inflammatory bowel disease. Journal of internal medicine 1996 Nov; 240(5):285–92. Not eligible target population
1883. Silverman M, Connolly NM, Balfour-Lynn L, et al. Long-term trial of disodium cromoglycate and isoprenaline in children with asthma. British medical journal Vol 3; 1972: 378–81. Not lactose intolerance study
1884. Silvestre MA, Morbach CA, Brans YW, et al. A prospective randomized trial comparing continuous versus intermittent feeding methods in very low birth weight neonates. The Journal of pediatrics Vol 128; 1996: 748–52. Not lactose intolerance study
1885. Simakachorn N, Tongpenyai Y, Tongtan O, et al. Randomized, double-blind clinical trial of a lactose-free and a lactose-containing formula in dietary management of acute childhood diarrhea. Journal of the Medical Association of Thailand = Chotmaihet thangphaet Vol 87; 2004: 641–9. Not eligible target population
1886. Simila S, Kokkonen J, Kouvalainen K. Use of lactose-hydrolyzed human milk in congenital lactase deficiency. J Pediatr 1982 Oct; 101(4):584–5. Not relevant to key questions
1887. Simons FE. A comparison of beclomethasone, salmeterol, and placebo in children with asthma. Canadian Beclomethasone Dipropionate-Salmeterol Xinafoate Study Group. The New England journal of medicine Vol 337; 1997: 1659–65. Not lactose intolerance study
1888. Simoons FJ. Primary adult lactose intolerance and the milking habit: a problem in biological and cultural interrelations. I. Review of the medical research. Am J Dig Dis 1969 Dec; 14(12):819–36. Not relevant to key questions
1889. Simoons FJ. Primary adult lactose intolerance and the milking habit: a problem in biologic and cultural interrelations. II. A culture historical hypothesis. Am J Dig Dis 1970 Aug; 15(8):695–710. Not relevant to key questions
1890. Simoons FJ. Progress report. New light on ethnic differences in adult lactose intolerance. Am J Dig Dis 1973 Jul; 18(7):595–611. Not relevant to key questions
1891. Simoons FJ. The geographic hypothesis and lactose malabsorption. A weighing of the evidence. American Journal of Digestive Diseases 1978 Nov; 23(11):963–80. Not original research
1892. Simoons FJ. A geographic approach to senile cataracts: possible links with milk consumption, lactase activity, and galactose metabolism. Digestive Diseases & Sciences 1982 Mar; 27(3):257–64. No prevalence data
1893. Simoons FJ, Johnson JD, Kretchmer N. Perspective on milk-drinking and malabsorption of lactose. Pediatrics 1977 Jan; 59(1):98–108. Not relevant to key questions
1894. Sipski M, Alexander C, Guo X, et al. Cardiovascular effects of sildenafil in men with SCIs at and above T6. Topics in Spinal Cord Injury Rehabilitation Vol 8; 2003: 26–34. Not lactose intolerance study
1895. Skala I, Lamacova V. Diets in lactose intolerance. Nutr Metab 1971; 13(3):200–6. Review
1896. Skala I, Lamacova V, Pirk F. Lactose-free milk as a solution of problems associated with dietetic treatment of lactose intolerance. Digestion 1971; 4(6):326–32. Not relevant to key questions
1897. Skogsdal Y, Eriksson M, Schollin J. Analgesia in newborns given oral glucose. Acta paediatrica (Oslo, Norway : 1992) Vol 86; 1997: 217–20. Not lactose intolerance study
1898. Skovbjerg H, Gudmand-Hoyer E, Fenger HJ. Immunoelectrophoretic studies on human small intestinal brush border proteins--amount of lactase protein in adult-type hypolactasia. Gut 1980 May; 21(5):360–4. Not relevant to key questions
1899. Slapke J, Hummel S, Wischnewsky GG, et al. Protease inhibitor prevents bronchoconstriction in man. European journal of respiratory diseases Vol 68; 1986: 29–34. Not lactose intolerance study
1900. Smith A, Sturgess W, Rich N, et al. The effects of idazoxan on reaction times, eye movements and the mood of healthy volunteers and patients with upper respiratory tract illnesses. Journal of psychopharmacology (Oxford, England) Vol 13; 1999: 148–51. Not lactose intolerance study
1901. Smith AH, Pearce NE, Joseph JG. Major colorectal cancer aetiological hypotheses do not explain mortality trends among Maori and non-Maori New Zealanders. Int J Epidemiol 1985 Mar; 14(1):79–85. Not eligible outcomes
1902. Smith AM. Veganism and osteoporosis: a review of the current literature. Int J Nurs Pract 2006 Oct; 12(5):302–6. Review
1903. Smith GD, Ebrahim S. Mendelian randomization: prospects, potentials, and limitations. Int J Epidemiol 2004 Feb; 33(1):30–42. Review
1904. Smith TC. That villain milk. T. C. G. Smith, MB, ChB, describes the problem of milk intolerance in babies. Nurs Mirror Midwives J 1976 Apr 22; 142(17):67–8. Not relevant to key questions
1905. Smith TM, Kolars JC, Savaiano DA, et al. Absorption of calcium from milk and yogurt. American Journal of Clinical Nutrition 1985 Dec; 42(6):1197–200. No prevalence data
1906. Snook CR, Mahmoud JN, Chang WP. Lactose tolerance in adult Jordanian Arabs. Trop Geogr Med 1976 Dec; 28(4):333–5. Not relevant to key questions
1907. Soenarto Y, Suprapto, Sutrisno DS, et al. Milk lactose: the amount tolerated in post diarrheal children. J Trop Pediatr Environ Child Health 1979 Aug; 25(4):104–6. Not relevant to key questions
1908. Soeparto P, Noerasid H, Subianto, et al. Disaccharide intolerance in infants during the diarrheal stage of acute gastroenteritis. Paediatr Indones 1977 May–Jun; 17(5–6):161–7. Not relevant to key questions
1909. Soeparto P, Stobo E, Walker-Smith JA. Stool chromatography for sugar in children with diarrhoea. Gut 1970 Nov; 11(11):980. Not relevant to key questions
1910. Soeparto P, Subijanto MS, Noerasid H. Prolonged diarrhoea following acute gastro enteritis. Paediatr Indones 1982 May–Jun; 22(5–6):83–8. Not relevant to key questions
1911. Soeparto P, Subijanto MS, Satjadibrata K. Low lactose milk (L.L.M.) on refeeding infants with gastroenteritis. Paediatr Indones 1977 Mar–Apr; 17(3–4):85–94. Not relevant to key questions
1912. Solomons NW. The hydrogen breath test and gastrointestinal disorders. Compr Ther 1981 Aug; 7(8):7–15. Not relevant to key questions
1913. Solomons NW, Barillas C. The cut-off criterion for a positive hydrogen breath test in children: a reappraisal. Journal of Pediatric Gastroenterology & Nutrition 1986 Nov–Dec; 5(6):920–5. No prevalence data
1914. Solomons NW, Garcia-Ibanez R, Viteri FE. Reduced rate of breath hydrogen excretion with lactose tolerance tests in young children using whole milk. Am J Clin Nutr 1979 Apr; 32(4):783–6. Not relevant to key questions
1915. Solomons NW, Garcia-Ibanez R, Viteri FE. Hydrogen breath test of lactose absorption in adults: the application of physiological doses and whole cow's milk sources. Am J Clin Nutr 1980 Mar; 33(3):545–54. Not relevant to key questions
1916. Solomons NW, Garcia-Ibañez R, Viteri FE. Reduced rate of breath hydrogen excretion with lactose tolerance tests in young children using whole milk. The American journal of clinical nutrition Vol 32; 1979: 783–6. Not relevant to key questions
1917. Solomons NW, Guerrero AM, Torun B. Effective in vivo hydrolysis of milk lactose by beta-galactosidases in the presence of solid foods. Am J Clin Nutr 1985 Feb; 41(2):222–7. Not relevant to key questions
1918. Solomons NW, Guerrero AM, Torun B. Dietary manipulation of postprandial colonic lactose fermentation: II. Addition of exogenous, microbial beta-galactosidases at mealtime. Am J Clin Nutr 1985 Feb; 41(2):209–21. Not relevant to key questions
1919. Solomons NW, Guerrero AM, Torun B. Dietary manipulation of postprandial colonic lactose fermentation: I. Effect of solid foods in a meal. Am J Clin Nutr 1985 Feb; 41(2):199‐208. Not relevant to key questions
1920. Solomons NW, Rosenthal A. Intestinal metabolism of a random-bonded polyglucose bulking agent in humans: In vitro and in vivo studies of hydrogen evolution. J. Lab. Clin. Med. Vol 105; 1985: 585–92. Not relevant to key questions
1921. Solomons NW, Torun B, Caballero B, et al. The effect of dietary lactose on the early recovery from protein-energy malnutrition. I. Clinical and anthropometric indices. Am J Clin Nutr 1984 Sep; 40(3):591–600. Not relevant to key questions
1922. Solomons NW, Viteri F, Rosenberg IH. Development of an interval sampling hydrogen (H2) breath test for carbohydrate malabsorption in children: evidence for a circadian pattern of breath H2 concentration. Pediatr Res 1978 Aug; 12(8):816–23. Not relevant to key questions
1923. Solomons NW, Viteri FE, Hamilton LH. Application of a simple gas chromatographic technique for measuring breath hydrogen. J Lab Clin Med 1977 Nov; 90(5):856–62. Not relevant to key questions
1924. Somayaji BN. Functional and metabolic effects of vagotomy and pyloroplasty. Q J Med 1970 Jul; 39(155):441–60. Not relevant to key questions
1925. Soontornchai S, Sirichakwal P, Puwastien P, et al. Lactitol tolerance in healthy Thai adults. European Journal of Nutrition 1999 Oct; 38(5):218–26. Ineligible number of subjects
1926. Southgate DA, Barrett IM. The intake and excretion of calorific constituents of milk by babies. The British journal of nutrition Vol 20; 1966: 363–72. Not relevant to key questions
1927. Sowers MF, Winterfeldt E. Lactose intolerance among Mexican Americans. Am J Clin Nutr 1975 Jul; 28(7):704–5. Not relevant to key questions
1928. Spanidou EP, Petrakis NL. Lactose intolerance in Greeks. Lancet 1972 Oct 21; 2(7782):872–3. Not relevant to key questions
1929. Sparks JW, Avery GB, Fletcher AB, et al. Parenteral galactose therapy in the glucose-intolerant premature infant. The Journal of pediatrics Vol 100; 1982: 255–9. Not lactose intolerance study
1930. Specker BL. Nutritional concerns of lactating women consuming vegetarian diets. Am J Clin Nutr 1994 May; 59(5 Suppl):1182S–6S. Not eligible target population
1931. Specker BL, Tsang RC, Ho M, et al. Effect of vegetarian diet on serum 1,25‐dihydroxyvitamin D concentrations during lactation. Obstet Gynecol 1987 Dec; 70(6):870–4. Not eligible outcomes
1932. Spencer J, Welbourn RB. Milk intolerance following gastric operations with special reference to lactase deficiency. Br J Surg 1968 Apr; 55(4):261–4. Not relevant to key questions
1933. Sperotto G, Barison EM, Baldacci ER, et al. Use of undiluted whole cow's milk is effective for the routine treatment of children with acute diarrhea and severe dehydration. Arq Gastroenterol Vol 35; 1998: 132–7. Not relevant to key questions
1934. Spicher T, Orgül S, Gugleta K, et al. The effect of losartan potassium on choroidal hemodynamics in healthy subjects. Journal of glaucoma Vol 11; 2002: 177–82. Not lactose intolerance study
1935. Spollett GR. Nutritional management of common gastrointestinal problems. Nurse practitioner forum 1994 Mar; 5(1):24–7. Not relevant to key questions
1936. Spoor TC, Hammer M, Belloso H. Traumatic hyphema. Failure of steroids to alter its course: a double-blind prospective study. Archives of ophthalmology Vol 98; 1980: 116–9. Not lactose intolerance study
1937. Srinivasan R, Minocha A. When to suspect lactose intolerance. Symptomatic, ethnic, and laboratory clues. Postgraduate Medicine 122–3, 1998 Sep; 104(3):109–11. Not original research
1938. St James-Roberts I. Infant crying and sleeping: helping parents to prevent and manage problems. Primary Care; Clinics in Office Practice 2008 viii; Sep; 35(3):547–67. Review
1939. Ståhlberg MR, Savilahti E. Infantile colic and feeding. Archives of disease in childhood Vol 61; 1986: 1232–3. Not relevant to key questions
1940. Stallings VA. Calcium and bone health in children: a review. Am J Ther 1997 Jul–Aug; 4(7–8):259–73. Review
1941. Stanfield JP. The diarrhoea--malnutrition circle. J Trop Pediatr Afr Child Health 1966 Dec; 12(3):53–4. Not relevant to key questions
1942. Stanley ED, Jackson GG, Dirda VA, et al. Effect of a topical interferon inducer on rhinovirus infections in volunteers. The Journal of infectious diseases Vol 133; 1976: A121‐ 7. Not lactose intolerance study
1943. Stanton C, Gardiner G, Meehan H, et al. Market potential for probiotics. Am J Clin Nutr 2001 Feb; 73(2 Suppl):476S–83S. Not relevant to key questions
1944. Steen KH, Reeh PW, Kreysel HW. Topical acetylsalicylic, salicylic acid and indomethacin suppress pain from experimental tissue acidosis in human skin. Pain Vol 62; 1995: 339–47. Not lactose intolerance study
1945. Steen LSL, Southard KA, Law AS, et al. An evaluation of preoperative ibuprofen for treatment of pain associated with orthodontic separator placement. American journal of orthodontics and dentofacial orthopedics : official publication of the American Association of Orthodontists, its constituent societies, and the American Board of Orthodontics Vol 118; 2000: 629–35. Not lactose intolerance study
1946. Stegmann H, Kindermann W. Comparison of prolonged exercise tests at the individual anaerobic threshold and the fixed anaerobic threshold of 4 mmol.l(-1) lactate. International journal of sports medicine Vol 3; 1982: 105–10. Not lactose intolerance study
1947. Stemmermann GN, Nomura A, Chyou PH. The influence of dairy and nondairy calcium on subsite large-bowel cancer risk. Dis Colon Rectum 1990 Mar; 33(3):190–4. Not eligible exposure
1948. Stenström B. Oral contraception using a sequential method. A clinical investigation. Acta obstetricia et gynecologica Scandinavica Vol 47; 1968: 443–50. Not lactose intolerance study
1949. Stephenson LS. Helminth parasites, a major factor in malnutrition. World Health Forum 1994; 15(2):169–72. No prevalence data
1950. Stephenson LS, Latham MC. Rapid and portable methods of lactose tolerance test administration. Am J Clin Nutr 1975 Aug; 28(8):888–93. Not relevant to key questions
1951. Stephenson LS, Latham MC. Letter: Lactose tolerance tests as a predictor of milk tolerance. Am J Clin Nutr 1975 Feb; 28(2):86–8. Not relevant to key questions
1952. Stephenson LS, Latham MC, Jones DV. Milk consumption by black and by white pupils in two primary schools. J Am Diet Assoc 1977 Sep; 71(3):258–62. Not relevant to key questions
1953. Sterchi EE, Mills PR, Fransen JA, et al. Biogenesis of intestinal lactase-phlorizin hydrolase in adults with lactose intolerance. Evidence for reduced biosynthesis and slowed-down maturation in enterocytes. J Clin Invest 1990 Oct; 86(4):1329–37. Not relevant to key questions
1954. Sterky G, Freij L, Gobezi A, et al. Milk intolerance in young Ethiopian school children. Ethiop Med J 1973 Jan; 11(1):25–32. Not relevant to key questions
1955. Stoopler M, Frayer W, Alderman MH. Prevalence and persistence of lactose malabsorption among young jamaican children. American Journal of Clinical Nutrition 1974 Jul; 27(7):728‐32. Subjects less than 4 years old
1956. Storer EH. Postvagotomy diarrhea. Surg Clin North Am 1976 Dec; 56(6):1461–8. Not relevant to key questions
1957. Stott JR, Barnes GR, Wright RJ, et al. The effect on motion sickness and oculomotor function of GR 38032F, a 5-HT3-receptor antagonist with anti-emetic properties. British journal of clinical pharmacology Vol 27; 1989: 147–57. Not lactose intolerance study
1958. Strand FT. Primary prevention of insulin-dependent diabetes mellitus: simple approaches using thermal modification of milk. Med Hypotheses 1994 Feb; 42(2):110–4. Not relevant to key questions
1959. Strandhagen E, Lia A, Lindstrand S, et al. Fermented milk (ropy milk) replacing regular milk reduces glycemic response and gastric emptying in healthy subjects. Scand. J. Nutr. Naringsforsk. Vol 38; 1994: 117–21. Not relevant to key questions
1960. Stratiki Z, Costalos C, Sevastiadou S, et al. The effect of a bifidobacter supplemented bovine milk on intestinal permeability of preterm infants. Early human development Vol 83; 2007: 575–9. Not lactose intolerance
1961. Strisciuglio P, Creek KE, Sly WS. Complementation, cross correction, and drug correction studies of combined beta-galactosidase neuraminidase deficiency in human fibroblasts. Pediatr Res 1984 Feb; 18(2):167–71. Not relevant to key questions
1962. Strocchi A, Corazza GR, Anania C, et al. Quality control study of H2 breath testing for the diagnosis of carbohydrate malabsorption in Italy. The "Tenue Club" Group.[see comment]. Italian Journal of Gastroenterology & Hepatology 1997 Apr; 29(2):122–7. No prevalence data
1963. Stryker JA, Bartholomew M. Failure of lactose-restricted diets to prevent radiation-induced diarrhea in patients undergoing whole pelvis irradiation. Int J Radiat Oncol Biol Phys 1986 May; 12(5):789–92. Not relevant to key questions
1964. Suarez F, Levitt M. Assessing food intolerance: don't lose control. Gut 1997 Nov; 41(5):715–6. Not relevant to key questions
1965. Suarez FL, Savaiano DA. Lactose digestion and tolerance in adult and elderly Asian-Americans. Am J Clin Nutr 1994 May; 59(5):1021–4. Not relevant to key questions
1966. Suarez FL, Savaiano DA, Levitt MD. Review article: the treatment of lactose intolerance. Aliment Pharmacol Ther 1995 Dec; 9(6):589–97. Not relevant to key questions
1967. Suarez FL, Springfield J, Furne JK, et al. Gas production in human ingesting a soybean flour derived from beans naturally low in oligosaccharides. The American journal of clinical nutrition Vol 69; 1999: 135–9. Not lactose intolerance study
1968. Suarez FL, Zumarraga LM, Furne JK, et al. Nutritional supplements used in weight-reduction programs increase intestinal gas in persons who malabsorb lactose. J Am Diet Assoc 2001 Dec; 101(12):1447–52. Not relevant to key questions
1969. Sudarmo SM, Ranuh RG, Rochim A, et al. Management of infant diarrhea with high-lactose probiotic-containing formula. The Southeast Asian journal of tropical medicine and public health Vol 34; 2003: 845–8. Not eligible target population
1970. Suharjono. Intestinal biopsy and coeliac disease. Paediatrica Indonesiana 1971 May–Jun; 11(3):116–34. No prevalence data
1971. Suharjono, Sunoto, Budiarso A, et al. Lactose malabsorption in "healthy" Indonesian pre‐school children. Paediatr Indones 1971 Nov–Dec; 11(6):251–4. Not relevant to key questions
1972. Sullivan PB. Food allergy and food intolerance in childhood. Indian Journal of Pediatrics 1999; 66(1 Suppl):S37–45. No prevalence data
1973. Sun HM, Qiao YD, Chen F, et al. The lactase gene -13910T allele can not predict the lactase-persistence phenotype in north China. Asia Pac J Clin Nutr 2007; 16(4):598–601. Not relevant to key questions
1974. Sun QQ, Xu SS, Pan JL, et al. Huperzine-A capsules enhance memory and learning performance in 34 pairs of matched adolescent students. Zhongguo yao li xue bao = Acta pharmacologica Sinica Vol 20; 1999: 601–3. Not lactose intolerance study
1975. Sung YF, Kutner MH, Cerine FC, et al. Comparison of the effects of acupuncture and codeine on postoperative dental pain. Anesthesia and analgesia Vol 56; 1977: 473–8. Not lactose intolerance study
1976. Sungkapalee T, Puntukosit P, Eunsuwan O, et al. Incidence and clinical manifestations of rotavirus infection among children with acute diarrhea admitted at Buri Ram Hospital, Thailand. Southeast Asian J Trop Med Public Health 2006 Nov; 37(6):1125–31. Not relevant to key questions
1977. Sunoto, Suharjono, Lembong CM, et al. Lactose loading test on protein calorie malnutrition. Paediatr Indones 1973 Feb; 13(2):43–8. Not relevant to key questions
1978. Sunoto, Suharjono, Mangiwa J, et al. Lactose intolerance in chronic diarrhea among Indonesian children. Paediatr Indones 1971 Sep–Oct; 11(5):1–6. Not relevant to key questions
1979. Sunoto S, Sutedjo. Two years study on sugar intolerance in Indonesian children. Paediatr Indones 1973 Sep–Oct; 13(9):241–9. Not relevant to key questions
1980. Sureda A, Batle JM, Tauler P, et al. Vitamin C supplementation influences the antioxidant response and nitric oxide handling of erythrocytes and lymphocytes to diving apnea. European journal of clinical nutrition Vol 60; 2006: 838–46. Not lactose intolerance study
1981. Surjone A, Sebodo T, Sunarto J, et al. Lactose intolerance among healthy adults. Paediatr Indones 1973 Feb; 13(2):49–54. Not relevant to key questions
1982. Surjono A, Surjantoro, Sadjimin T, et al. Lactose tolerance test on Indonesian newborn infants. Paediatr Indones 1973 Jan; 13(1):11–6. Not relevant to key questions
1983. Sussman S, Grossman M, Magoffin R, et al. Dexamethasone (16 alpha methyl, 9 alpha fluoroprednisolone) in obstructive respiratory tract infections in children. Pediatrics Vol 34; 1964: 851–5. Not lactose intolerance study
1984. Sutanto AH, Sa'at R, Siregar H. Steatorrhoea in acute enteritis. Paediatr Indones 1982 Nov–Dec; 22(11–12):217–21. Not relevant to key questions
1985. Sutedjo. Cow's milk (lactose) intolerance among Indonesian doctors of the Dr. Tjipto Mangunkusumo General Hospital and Medical School, University of Indonesia. Paediatr Indones 1971 Mar–Apr; 11(2):43–6. Not relevant to key questions
1986. Suter CB. Letter: Lactose malabsorption. Am J Clin Nutr 1975 Apr; 28(4):308–9. Not relevant to key questions
1987. Suthutvoravut U, Tontisirin K, Varavithya W, et al. Wheat extract and milk mixture as a milk substitute for children with milk intolerance. J Diarrhoeal Dis Res 1984 Sep; 2(3):168‐72. Not relevant to key questions
1988. Sutnick MR. Vegetarian diets. Prim Care 1975 Jun; 2(2):309–15. Not relevant to key questions
1989. Sutton RE, Hamilton JR. Tolerance of young children with severe gastroenteritis to dietary lactose: a controlled study. Can Med Assoc J 1968 Nov 23; 99(20):980–2. Not relevant to key questions
1990. Suzuki K, Tanaka H, Yamanaka T, et al. The specificity of beta-galactosidase in the degradation of gangliosides. Adv Exp Med Biol 1980; 125:307–18. Not relevant to key questions
1991. Suzuki Y, Fukuoka K. Neuraminidase in mucolipidoses: normal activity in frozen autopsy tissues from three patients with I-cell disease and adult beta-galactosidase deficiency. Clin Chim Acta 1979 Dec 3; 99(2):107–12. Not relevant to key questions
1992. Suzuki Y, Fukuoka K, Sakuraba H, et al. Galatosialidosis (beta-galactosidase‐neuraminidase deficiency): clinical and biochemical studies on 13 patients. Adv Exp Med Biol 1982; 152:241–51. Not relevant to key questions
1993. Suzuki Y, Sakuraba H, Hayashi K, et al. Beta-galactosidase-neuraminidase deficiency: restoration of beta-galactosidase activity by protease inhibitors. J Biochem 1981 Jul; 90(1):271–3. Not relevant to key questions
1994. Svennerholm L. Diagnosis of the sphingolipidoses with labelled natural substrates. Adv Exp Med Biol 1978; 101:689–706. Not relevant to key questions
1995. Svenonius E, Arborelius M, Wiberg R, et al. Prevention of exercise-induced asthma by drugs inhaled from metered aerosols. Allergy Vol 43; 1988: 252–7. Not lactose intolerance study
1996. Swagerty DL, Jr., Walling AD, Klein RM. Lactose intolerance. Am Fam Physician 2002 May 1; 65(9):1845–50. Not relevant to key questions
1997. Szajewska H, Kantecki M, Albrecht P, et al. Carbohydrate intolerance after acute gastroenteritis--a disappearing problem in Polish children. Acta Paediatrica 1997 Apr; 86(4):347–50. Not original research
1998. Szilagyi A. Review article: lactose--a potential prebiotic. Aliment Pharmacol Ther 2002 Sep; 16(9):1591–602. Not relevant to key questions
1999. Szilagyi A. Redefining lactose as a conditional prebiotic. Canadian Journal of Gastroenterology 2004 Mar; 18(3):163–7. Review
2000. Szilagyi A, Cohen A, Vinokuroff C, et al. Deadaption and readaptation with lactose, but no cross-adaptation to lactulose: a case of occult colonic bacterial adaptation. Can J Gastroenterol 2004 Nov; 18(11):677–80. Not relevant to key questions
2001. Szilagyi A, Lerman S, Barr RG, et al. Reversible lactose malabsorption and intolerance in Graves' disease. Clin Invest Med 1991 Jun; 14(3):188–97. Not relevant to key questions
2002. Szilagyi A, Malolepszy P, Hamard E, et al. Comparison of a real-time polymerase chain reaction assay for lactase genetic polymorphism with standard indirect tests for lactose maldigestion. Clin Gastroenterol Hepatol 2007 Feb; 5(2):192–6. Not relevant to key questions
2003. Szilagyi A, Malolepszy P, Yesovitch S, et al. Inverse dose effect of pretest dietary lactose intake on breath hydrogen results and symptoms in lactase nonpersistent subjects. Dig Dis Sci 2005 Nov; 50(11):2178–82. Not relevant to key questions
2004. Szilagyi A, Nathwani U, Vinokuroff C, et al. Evaluation of relationships among national colorectal cancer mortality rates, genetic lactase non-persistence status, and per capita yearly milk and milk product consumption. Nutr Cancer 2006; 55(2):151–6. Not eligible outcomes
2005. Szilagyi A, Nathwani U, Vinokuroff C, et al. The effect of lactose maldigestion on the relationship between dairy food intake and colorectal cancer: a systematic review. Nutr Cancer 2006; 55(2):141–50. Not eligible outcomes
2006. Szilagyi A, Rivard J, Fokeeff K. Improved parameters of lactose maldigestion using lactulose. Dig Dis Sci 2001 Jul; 46(7):1509–19. Not relevant to key questions
2007. Szilagyi A, Salomon R, Martin M, et al. Lactose handling by women with lactose malabsorption is improved during pregnancy. Clin Invest Med 1996 Dec; 19(6):416–26. Not relevant to key questions
2008. Szilagyi A, Salomon R, Seidman E. Influence of loperamide on lactose handling and oral-caecal transit time. Aliment Pharmacol Ther 1996 Oct; 10(5):765–70. Not relevant to key questions
2009. Szilagyi A, Torchinsky A, Calacone A. Possible therapeutic use of loperamide for symptoms of lactose intolerance. Can J Gastroenterol 2000 Jul–Aug; 14(7):581–7. Not relevant to key questions
2010. Szustkiewicz C, Demetriou J. Detection of some clinically important carbohydrates in plasma and urine by means of thin-layer chromatography. Clin Chim Acta 1971 May; 32(3):355–9. Not relevant to key questions
2011. Tadesse K, Leung DT, Yuen RC. The status of lactose absorption in Hong Kong Chinese children. Acta Paediatrica 1992 Aug; 81(8):598–600. Not original research
2012. Tadesse K, Smith D, Eastwood MA. Breath hydrogen (H2) and methane (CH4) excretion patterns in normal man and in clinical practice. Quarterly Journal of Experimental Physiology Vol 65; 1980: 85–97. Not relevant to key questions
2013. Tag CG, Oberkanins C, Kriegshauser G, et al. Evaluation of a novel reverse-hybridization StripAssay for typing DNA variants useful in diagnosis of adult-type hypolactasia. Clin Chim Acta 2008 Jun; 392(1–2):58–62. Not relevant to key questions
2014. Taif B. Myths about milk. J Pract Nurs 1975 Nov; 25(11):16–7. Not relevant to key questions
2015. Tamir I, Levtow O, Dolizki F, et al. Changes in plasma free fatty acid concentration following oral lactose tolerance tests as a test for lactose absorption in infants and children. Am J Dig Dis 1974 Aug; 19(8):745–50. Not relevant to key questions
2016. Tamm A. Management of lactose intolerance. Scand J Gastroenterol Suppl 1994; 202:55‐63. Not relevant to key questions
2017. Tamura A, Shiomi T, Hachiya S, et al. Low activities of intestinal lactase suppress the early phase absorption of soy isoflavones in Japanese adults. Clin Nutr 2008 Apr; 27(2):248‐53. Not relevant to key questions
2018. Tandon R, Mandell H, Spiro HM, et al. Lactose intolerance in Jewish patients with ulcerative colitis. Am J Dig Dis 1971 Sep; 16(9):845–8. Not relevant to key questions
2019. Tandon RK, Goel U, Mukherjee SN, et al. Lactose intolerance during pregnancy in different Indian communities. Indian J Med Res 1977 Jul; 66(1):33–8. Not relevant to key questions
2020. Tandon RK, Joshi YK, Singh DS, et al. Lactose intolerance in North and South Indians. Am J Clin Nutr 1981 May; 34(5):943–6. Not relevant to key questions
2021. Tangpricha V, Koutkia P, Rieke SM, et al. Fortification of orange juice with vitamin D: a novel approach for enhancing vitamin D nutritional health. The American journal of clinical nutrition Vol 77; 2003: 1478–83. Not lactose intolerance study
2022. Tari MG, Mancino M, Monti G. Immunotherapy by inhalation of allergen in powder in house dust allergic asthma--a double-blind study. Journal of investigational allergology & clinical immunology : official organ of the International Association of Asthmology (INTERASMA) and Sociedad Latinoamericana de Alergia e Inmunología Vol 2; 1992: 59‐67. Not lactose intolerance study
2023. Tarlo SM, Broder I. Tartrazine and benzoate challenge and dietary avoidance in chronic asthma. Clinical Allergy Vol 12; 1982: 303–12. Not lactose intolerance study
2024. Tarshish P, Bernstein J, Tobin JN, et al. Treatment of mesangiocapillary glomerulonephritis with alternate-day prednisone--a report of the International Study of Kidney Disease in Children. Pediatric nephrology (Berlin, Germany) Vol 6; 1992: 123–30. Not lactose intolerance study
2025. Tasman-Jones C. Medium chain triglycerides in the therapy of small bowel Crohn's disease. N Z Med J 1971 Apr; 73(467):214–5. Not relevant to key questions
2026. Taylan B, Capan Y, Guven O, et al. Design and evaluation of sustained-release and buccal adhesive propranolol hydrochloride tablets. Journal of Controlled Release. Vol 38; 1996: 11‐20. Not lactose intolerance study
2027. Taylor C. Lactose intolerance in infants. Nursing Times 2006 Apr 25–May 1; 102(17):43–4. Not original research
2028. Taylor C, Hodgson K, Sharpstone D, et al. The prevalence and severity of intestinal disaccharidase deficiency in human immunodeficiency virus-infected subjects. Scandinavian journal of gastroenterology Vol 35; 2000: 599–606. Not lactose intolerance study
2029. Taylor D, O'Toole K, Auble T, et al. The psychometric and cardiac effects of pseudoephedrine and antihistamines in the hyperbaric environment. South Pacific Underwater Medicine Society Journal Vol 31; 2001: 50–7. Not lactose intolerance study
2030. Taylor HA, Stevenson RE, Parks SE. Beta-galactosidase deficiency: studies of two patients with prolonged survival. American Journal of Medical Genetics 1980; 5(3):235–45. Ineligible number of subjects
2031. Teegarden D, Lyle RM, Proulx WR, et al. Previous milk consumption is associated with greater bone density in young women. Am J Clin Nutr 1999 May; 69(5):1014–7. not eligible outcomes
2032. Teesalu S, Vihalemm T, Vaasa IO. Nutrition in prevention of osteoporosis. Scandinavian Journal of Rheumatology - Supplement 1996 discussion 83; 103:81–2. Not relevant to key questions
2033. Tepper BJ, Trail AC, Shaffer SE. Diet and physical activity in restrained eaters. Appetite 1996 Aug; 27(1):51–64. Not relevant to key questions
2034. Terezhalmy GT, Bottomley WK, Pelleu GB. The use of water-soluble bioflavonoid-ascorbic acid complex in the treatment of recurrent herpes labialis. Oral surgery, oral medicine, and oral pathology Vol 45; 1978: 56–62. Not lactose intolerance study
2035. Terrio K, Auld GW. Osteoporosis knowledge, calcium intake, and weight-bearing physical activity in three age groups of women. J Community Health 2002 Oct; 27(5):307–20. Not eligible target population
2036. Tesar R, Notelovitz M, Shim E, et al. Axial and peripheral bone density and nutrient intakes of postmenopausal vegetarian and omnivorous women. Am J Clin Nutr 1992 Oct; 56(4):699–704. Not eligible exposure
2037. Teuri U, Vapaatalo H, Korpela R. Fructooligosaccharides and lactulose cause more symptoms in lactose maldigesters and subjects with pseudohypolactasia than in control lactose digesters. Am J Clin Nutr 1999 May; 69(5):973–9. Not relevant to key questions
2038. Theofilopoulos N, Szabadi E, Bradshaw CM. Comparison of the effects of ranitidine, cimetidine and thioridazine on psychomotor functions in healthy volunteers. Br J Clin Pharmacol Vol 18; 1984: 135–44. Not lactose intolerance study
2039. Tholstrup T, Høy CE, Andersen LN, et al. Does fat in milk, butter and cheese affect blood lipids and cholesterol differently? Journal of the American College of Nutrition Vol 23; 2004: 169–76. Not lactose intolerance study
2040. Thomas E, von Unruh GE, Hesse A. Influence of a low- and a high-oxalate vegetarian diet on intestinal oxalate absorption and urinary excretion. Eur J Clin Nutr 2008 Sep; 62(9):1090‐ 7. Not eligible outcomes
2041. Thomas FB, Caldwell JH, Greenberger NJ. Steatorrhea in thyrotoxicosis. Relation to hypermotility and excessive dietary fat. Ann Intern Med 1973 May; 78(5):669–75. Not eligible target population
2042. Thomas S, Walker-Smith JA, Senewiratne B, et al. Age dependency of the lactase persistence and lactase restriction phenotypes among children in Sri Lanka and Britain. Journal of Tropical Pediatrics 1990 Apr; 36(2):80–5. Not population based study
2043. Thompson D, Bailey DM, Hill J, et al. Prolonged vitamin C supplementation and recovery from eccentric exercise. European journal of applied physiology Vol 92; 2004: 133–8. Not lactose intolerance study
2044. Thompson D, Williams C, McGregor SJ, et al. Prolonged vitamin C supplementation and recovery from demanding exercise. International journal of sport nutrition and exercise metabolism Vol 11; 2001: 466–81. Not lactose intolerance study
2045. Thompson JR, Sanders I. Lactose-barium small bowel study. Efficacy as a screening method. Am J Roentgenol Radium Ther Nucl Med 1971 Oct; 113(2):255–7. Not relevant to key questions
2046. Thompson JR, Sanders I. Lactose-barium small bowel study. Efficacy as a screening method. Am J Roentgenol Radium Ther Nucl Med 1972 Oct; 116(2):276–8. Not relevant to key questions
2047. Thompson M, Anderson M. Studies of gastrointestinal blood loss during ibuprofen therapy. Rheumatology and physical medicine Vol 10; 1970: Suppl 10:104–7. Not lactose intolerance study
2048. Thompson SJ, Leigh L, Christensen R, et al. Immediate neurocognitive effects of methylphenidate on learning-impaired survivors of childhood cancer. Journal of clinical oncology : official journal of the American Society of Clinical Oncology Vol 19; 2001: 1802‐ 8. Not lactose intolerance study
2049. Thong-Ngam D, Suwangool P, Prempracha J, et al. Lactose intolerance and intestinal villi morphology in Thai people. Journal of the Medical Association of Thailand 2001 Aug; 84(8):1090–6. Ineligible number of subjects
2050. Thoren P, Wallin A, Whitehead PJ, et al. The effect of different concentrations of lactose powder on the airway function of adult asthmatics. Respiratory medicine Vol 95; 2001: 870‐ 5. Not lactose intolerance study
2051. Thorne MG, Bradbeer WH. Disodium chromoglycate in the treatment of perennial allergic rhinitis. Acta allergologica Vol 27; 1972: 307–20. Not lactose intolerance study
2052. Tillotson JL, Grandits GA, Bartsch GE, et al. Chapter 10. Relation of dietary carbohydrates to blood lipids in the special intervention and usual care groups in the Multiple Risk Factor Intervention Trial. American Journal of Clinical Nutrition Vol 65; 1997: 314s–26s. Not lactose intolerance study
2053. Ting CW, Wu TC, Hwang B. Hydrogen breath test with physiological dose of lactose in children and adolescents. J Singapore Paediatr Soc 1987; 29 Suppl 1:170–1. Not relevant to key questions
2054. Tinmouth J, Kandel G, Tomlinson G, et al. The effect of dairy product ingestion on human immunodeficiency virus-related diarrhea in a sample of predominantly gay men: a randomized, controlled, double-blind, crossover trial. Archives of internal medicine Vol 166; 2006: 1178–83. Not relevant to key questions
2055. Tishkoff SA, Reed FA, Ranciaro A, et al. Convergent adaptation of human lactase persistence in Africa and Europe. Nat Genet 2007 Jan; 39(1):31–40. Not relevant to key questions
2056. Toaff R, Ashkenazi H, Schwartz A, et al. Effects of oestrogen and progestagen on the composition of human milk. Journal of reproduction and fertility Vol 19; 1969: 475–82. Not lactose intolerance study
2057. Tolboom JJ, Kabir H, Molatseli P, et al. Lactose malabsorption and giardiasis in Basotho school children. Acta Paediatrica Scandinavica 1987 Jan; 76(1):60–5. Ineligible number of subjects
2058. Tolboom JJ, Moteete M, Kabir H, et al. Incomplete lactose absorption from breast milk during acute gastroenteritis. Acta Paediatr Scand 1986 Jan; 75(1):151–5. Not relevant to key questions
2059. Tolboom JJ, Ralitapole-Maruping AP, Mothebe M, et al. Carbohydrate malabsorption in children with severe protein energy malnutrition. Trop Geogr Med 1984 Dec; 36(4):355–65. Not relevant to key questions
2060. Tolliver BA, Jackson MS, Jackson KL, et al. Does lactose maldigestion really play a role in the irritable bowel? J Clin Gastroenterol 1996 Jul; 23(1):15–7. Not relevant to key questions
2061. Tontisirin K, Tejavej A, Siripoonya P, et al. Effect of phototherapy on nutrients utilization in newborn infants with jaundice. Journal of the Medical Association of Thailand = Chotmaihet thangphaet Vol 72; 1989: 177–82. Not lactose intolerance study
2062. Tootla R, Kotru G, Connolly MA, et al. Asthma inhalers and subsurface enamel demineralisation: an in situ pilot study. European journal of paediatric dentistry : official journal of European Academy of Paediatric Dentistry Vol 6; 2005: 139–43. Not lactose intolerance study
2063. Tootla R, Toumba KJ, Duggal MS. An evaluation of the acidogenic potential of asthma inhalers. Archives of oral biology Vol 49; 2004: 275–83. Not lactose intolerance study
2064. Tormo R, Bertaccini A, Conde M, et al. Methane and hydrogen exhalation in normal children and in lactose malabsorption. Early Hum Dev 2001 Nov; 65 Suppl:S165–72. Not relevant to key questions
2065. Torun B, Solomons NW, Caballero B, et al. The effect of dietary lactose on the early recovery from protein-energy malnutrition. II. Indices of nutrient absorption. Am J Clin Nutr 1984 Sep; 40(3):601–10. Not eligible target population
2066. Torun B, Solomons NW, Viteri FE. Lactose malabsorption and lactose intolerance: implications for general milk consumption. Arch Latinoam Nutr 1979 Dec; 29(4):445–94. Not relevant to key questions
2067. Toseland PA. Specific determination of plasma and urinary lactose. J Clin Pathol 1968 Jan; 21(1):112–3. Not relevant to key questions
2068. Touhami M, Boudraa G, Mary JY, et al. [Clinical consequences of replacing milk with yogurt in persistent infantile diarrhea]. Annales de pédiatrie Vol 39; 1992: 79–86. Not relevant to key questions
2069. Treem WR, Ahsan N, Sullivan B, et al. Evaluation of liquid yeast-derived sucrase enzyme replacement in patients with sucrase-isomaltase deficiency. Gastroenterology Vol 105; 1993: 1061–8. Not lactose intolerance study
2070. Tremaine WJ, Newcomer AD, Riggs BL, et al. Calcium absorption from milk in lactase-deficient and lactase-sufficient adults. Dig Dis Sci 1986 Apr; 31(4):376–8. Not eligible outcomes
2071. Trinchieri A, Nespoli R, Ostini F, et al. A study of dietary calcium and other nutrients in idiopathic renal calcium stone formers with low bone mineral content. Journal of Urology 1998 Mar; 159(3):654–7. Not eligible target population
2072. Tripp-Reimer T, Pollack RB. Lactase deficiency. Nursing 1977 Nov; 7(11):82, 5. Not relevant to key questions
2073. Troelsen JT, Olsen J, Moller J, et al. An upstream polymorphism associated with lactase persistence has increased enhancer activity. Gastroenterology 2003 Dec; 125(6):1686–94. Not relevant to key questions
2074. Troncon LE, de Oliveira RB, Collares EF, et al. Gastric emptying of lactose and glucose-galactose in patients with low intestinal lactase activity. Arq Gastroenterol 1983 Jan–Mar; 20(1):8–12. Not relevant to key questions
2075. Troncone R, Caputo N, Florio G, et al. Increased intestinal sugar permeability after challenge in children with cow's milk allergy or intolerance. Allergy 1994 Mar; 49(3):142–6. Not relevant to key questions
2076. Truelove SC. Medical management of ulcerative colitis. Br Med J 1968 Jun 8; 2(5605):605–7. Not relevant to key questions
2077. Truesdell DD, Acosta PB. Feeding the vegan infant and child. J Am Diet Assoc 1985 Jul; 85(7):837–40. Review
2078. Truesdell DD, Whitney EN, Acosta PB. Nutrients in vegetarian foods. J Am Diet Assoc 1984 Jan; 84(1):28–35. Review
2079. Tsega E, Endeshaw Y, Mengesha B, et al. The role of milk and lactose intolerance in Ethiopian patients with non-ulcer dyspepsia: a case control study. Ethiop Med J 1989 Jul; 27(3):135–45. Not relevant to key questions
2080. Tsuchiya J, Barreto R, Okura R, et al. Single-blind follow-up study on the effectiveness of a symbiotic preparation in irritable bowel syndrome. Chinese journal of digestive diseases Vol 5; 2004: 169–74. Not lactose intolerance study
2081. Tsuji S, Yamada T, Ariga T, et al. Carrier detection of sialidosis with partial beta-galactosidase deficiency by the assay of lysosomal sialidase in lymphocytes. Ann Neurol 1984 Feb; 15(2):181–3. Not relevant to key questions
2082. Tuncbilek E, Turun R, Say B. Lactose intolerance in Turkey. Lancet 1973 Jul 21; 2(7821):151. Not relevant to key questions
2083. Tuohy KM, Ziemer CJ, Klinder A, et al. A human volunteer study to determine the prebiotic effects of lactulose powder on human colonic microbiota. Microbial Ecology in Health & Disease Vol 14; 2002: 165–73. Not lactose intolerance study
2084. Turner SJ, Daly T, Hourigan JA, et al. Utilization of a low-lactose milk. Am J Clin Nutr 1976 Jul; 29(7):739–44. Not relevant to key questions
2085. Turner-McGrievy GM, Barnard ND, Cohen J, et al. Changes in nutrient intake and dietary quality among participants with type 2 diabetes following a low-fat vegan diet or a conventional diabetes diet for 22 weeks. J Am Diet Assoc 2008 Oct; 108(10):1636–45. Not relevant to key questions
2086. Turner-McGrievy GM, Barnard ND, Scialli AR, et al. Effects of a low-fat vegan diet and a Step II diet on macro- and micronutrient intakes in overweight postmenopausal women. Nutrition 2004 Sep; 20(9):738–46. Not relevant to key questions
2087. Tursi A, Brandimarte G, Giorgetti G. High prevalence of small intestinal bacterial overgrowth in celiac patients with persistence of gastrointestinal symptoms after gluten withdrawal.[see comment]. American Journal of Gastroenterology 2003 Apr; 98(4):839–43. Ineligible number of subjects
2088. Tursi A, Brandimarte G, Giorgetti GM, et al. Transient lactose malabsorption in patients affected by symptomatic uncomplicated diverticular disease of the colon. Digestive Diseases & Sciences 2006 Mar; 51(3):461–5. Ineligible number of subjects
2089. Tylavsky FA, Anderson JJ. Dietary factors in bone health of elderly lactoovovegetarian and omnivorous women. Am J Clin Nutr 1988 Sep; 48(3 Suppl):842–9. Not target population
2090. Ulrich CM, Georgiou CC, Snow-Harter CM, et al. Bone mineral density in mother-daughter pairs: relations to lifetime exercise, lifetime milk consumption, and calcium supplements. Am J Clin Nutr 1996 Jan; 63(1):72–9. not eligible outcomes
2091. Urbach KF. Hypnotic properties of amitriptyline: comparison with secobarbital. Anesthesia and analgesia Vol 46; 1967: 835–42. Not lactose intolerance study
2092. Uribe M. Lactose to treat acute and chronic portal systemic encephalopathy. Hepatic encephalopathy in chronic liver failure: Plenum Press; 1984: 279–85. Not lactose intolerance study
2093. Uribe M, Berthier JM, Lewis H, et al. Lactose enemas plus placebo tablets vs. neomycin tablets plus starch enemas in acute portal systemic encephalopathy. A double-blind randomized controlled study. Gastroenterology Vol 81; 1981: 101–6. Not lactose intolerance study
2094. Uribe M, Campollo O, Vargas F, et al. Acidifying enemas (lactitol and lactose) vs. nonacidifying enemas (tap water) to treat acute portal-systemic encephalopathy: a double-blind, randomized clinical trial. Hepatology (Baltimore, Md.) Vol 7; 1987: 639–43. Not lactose intolerance study
2095. Uribe M, Lewis H, Moreno J, et al. Successful use of lactose enemas in acute portal systemic encephalopathy (PSE). A double blind controlled trial. Gastroenterology Vol 79; 1980: 1061. Not lactose intolerance study
2096. Uribe M, Marquez MA, Garcia-Ramos G, et al. Treatment of chronic portal-systemic encephalopathy with lactose in lactase-deficient patients. Digestive Diseases & Sciences 1980 Dec; 25(12):924–8. No prevalence data
2097. Uribe M, Morán S, Poo JL, et al. Beneficial effect of carbohydrate maldigestion induced by a disaccharidase inhibitor (AO-128) in the treatment of chronic portal-systemic encephalopathy. A double-blind, randomized, controlled trial. Scandinavian journal of gastroenterology Vol 33; 1998: 1099–106. Not lactose intolerance study
2098. Uribe M, Toledo H, Perez F, et al. Lactitol, a second-generation disaccharide for treatment of chronic portal-systemic encephalopathy. A double-blind, crossover, randomized clinical trial. Digestive diseases and sciences Vol 32; 1987: 1345–53. Not lactose intolerance study
2099. Uribe-Esquivel M, Moran S, Poo JL, et al. In vitro and in vivo lactose and lactulose effects on colonic fermentation and portal-systemic encephalopathy parameters. Scand J Gastroenterol Suppl 1997; 222:49–52. Not relevant to key questions
2100. Vakil DV, Ayiomamitis A, Nizami N, et al. A double-blind comparative study of pelletized cromolyn versus cromolyn blend in the treatment of asthma. The Journal of asthma : official journal of the Association for the Care of Asthma Vol 22; 1985: 279–84. Not lactose intolerance study
2101. Valman HB. Chronic diarrhoea. Br Med J (Clin Res Ed) 1981 Jun 27; 282(6282):2120–2. Not relevant to key questions
2102. Valsecchi R, Tribbia G, Rossi A, et al. Pseudo-cross-reactivity between aspirin and tartrazine. G Ital Dermatol Venereol Vol 123; 1988: 177–80. Not lactose intolerance study
2103. van Assendelft AH. Bronchospasm induced by vanillin and lactose. European journal of respiratory diseases Vol 65; 1984: 468–72. Not lactose intolerance study
2104. Van Beers EH, Einerhand AW, Taminiau JA, et al. Pediatric duodenal biopsies: mucosal morphology and glycohydrolase expression do not change along the duodenum. Journal of Pediatric Gastroenterology & Nutrition 1998 Feb; 26(2):186–93. No prevalence data
2105. Van Beers EH, Rings EH, Taminiau JA, et al. Regulation of lactase and sucrase-isomaltase gene expression in the duodenum during childhood. Journal of Pediatric Gastroenterology & Nutrition 1998 Jul; 27(1):37–46. No prevalence data
2106. Van Bever HP, Von Berg A, Schmidt P, et al. Safety and efficacy of fenoterol/ipratropium lactose based powder capsules compared to fenoterol/ipratropium MDI in pediatric patients with asthma [abstract]. European Respiratory Journal - Supplement Vol 12; 1998: 89s. Not lactose intolerance study
2107. Van Biervliet S, Eggermont E, Marien P, et al. Combined impact of mucosal damage and of cystic fibrosis on the small intestinal brush border enzyme activities. Acta Clinica Belgica 2003 Jul–Aug; 58(4):220–4. Ineligible number of subjects
2108. Van den Driessche M, Veereman-Wauters G. Functional foods in pediatrics. Acta Gastroenterol Belg 2002 Jan–Mar; 65(1):45–51. Not relevant to key questions
2109. van der Horst GT, Kleijer WJ, Hoogeveen AT, et al. Morquio B syndrome: a primary defect in beta-galactosidase. Am J Med Genet 1983 Oct; 16(2):261–75. Not relevant to key questions
2110. van der Klei-van Moorsel JM, Douwes AC, van Oeveren JP. New principle for estimation of hydrogen in expired air. Eur J Pediatr 1984 Feb; 141(4):221–4. Not relevant to key questions
2111. Van Diggelen OP, Schram AW, Sinnott ML, et al. Turnover of beta-galactosidase in fibroblasts from patients with genetically different types of beta-galactosidase deficiency. Biochem J 1981 Oct 15; 200(1):143–51. Not relevant to key questions
2112. van Faassen A, Hazen MJ, van den Brandt PA, et al. Bile acids and pH values in total feces and in fecal water from habitually omnivorous and vegetarian subjects. Am J Clin Nutr 1993 Dec; 58(6):917–22. Not eligible outcomes
2113. van Staveren WA, Dhuyvetter JH, Bons A, et al. Food consumption and height/weight status of Dutch preschool children on alternative diets. J Am Diet Assoc 1985 Dec; 85(12):1579–84. Not relevant to key questions
2114. VandenBergh MF, DeMan SA, Witteman JC, et al. Physical activity, calcium intake, and bone mineral content in children in The Netherlands. J Epidemiol Community Health 1995 Jun; 49(3):299–304. not eligible outcomes
2115. Varavithya W, Valyasevi A, Charuchinda S. Lactose malabsorption in Thai infants. Journal of Pediatrics 1971 Apr; 78(4):710–5. Subjects less than 4 years old
2116. Varavithya W, Valyasevi A, Manu P, et al. Lactose malabsorption in Thai infants and children: effect of prolonged milk feeding. Southeast Asian J Trop Med Public Health 1976 Dec; 7(4):591–5. Not relevant to key questions
2117. Varea V, de Carpi JM, Puig C, et al. Malabsorption of carbohydrates and depression in children and adolescents. Journal of Pediatric Gastroenterology & Nutrition 2005 May; 40(5):561–5. No prevalence data
2118. Varela-Moreiras G, Antoine JM, Ruiz-Roso B, et al. Effects of yogurt and fermented-then‐pasteurized milk on lactose absorption in an institutionalized elderly group. Journal of the American College of Nutrition 1992 Apr; 11(2):168–71. No prevalence data
2119. Vásquez-Garibay E, Stein K, Kratzsch J, et al. Effect of nucleotide intake and nutritional recovery on insulin-like growth factor I and other hormonal biomarkers in severely malnourished children. The British journal of nutrition Vol 96; 2006: 683–90. Not lactose intolerance study
2120. Vatn MH, Mogstad TE, Gjone E. A prospective study of patients with uncharacteristic abdominal disorders. Scand J Gastroenterol 1985 May; 20(4):407–14. Not eligible target population
2121. Vazquez B, Amador A. Radiological diagnosis of lactose intolerance in children with chronic diarrhoea. Acta Paediatr Acad Sci Hung 1973; 14(1):51–61. Not relevant to key questions
2122. Vega-Franco L, Meza C, Romero JL, et al. Breath hydrogen test in children with giardiasis. J Pediatr Gastroenterol Nutr 1987 May–Jun; 6(3):365–8. Not relevant to key questions
2123. Veligati LN, Treem WR, Sullivan B, et al. Delta 10 ppm versus delta 20 ppm: a reappraisal of diagnostic criteria for breath hydrogen testing in children. Am J Gastroenterol 1994 May; 89(5):758–61. Not relevant to key questions
2124. Venderley AM, Campbell WW. Vegetarian diets: nutritional considerations for athletes. Sports Med 2006; 36(4):293–305. Review
2125. Ventura A, Pineschi A, Tasso M. Cow's milk intolerance and abdominal surgery: a puzzling connection. Helvetica Paediatrica Acta 1986 Mar; 41(6):487–94. Ineligible number of subjects
2126. Verger P, Garnier-Sagne I, Leblanc JC. Identification of risk groups for intake of food chemicals. Regul Toxicol Pharmacol 1999 Oct; 30(2 Pt 2):S103–8. Not eligible outcomes
2127. Verkasalo M, Kuitunen P, Savilahti E, et al. Changing pattern of cow's milk intolerance. An analysis of the occurrence and clinical course in the 60s and mid-70s. Acta Paediatrica Scandinavica 1981; 70(3):289–95. Ineligible number of subjects
2128. Verma M, Saxena S. Lactose intolerance in children with protein-energy malnutrition. Indian J Pediatr 1980 Jul–Aug; 47(387):273–7. Not relevant to key questions
2129. Vernia P, Camillo MD, Marinaro V, et al. Effect of predominant methanogenic flora on the outcome of lactose breath test in irritable bowel syndrome patients. European Journal of Clinical Nutrition 2003 Sep; 57(9):1116–9. No prevalence data
2130. Vernia P, Frandina C, Bilotta T, et al. Sorbitol malabsorption and nonspecific abdominal symptoms in type II diabetes. Metabolism: Clinical & Experimental Vol 44; 1995: 796–9. Not lactose intolerance study
2131. Vernia P, Ricciardi MR, Frandina C, et al. Lactose malabsorption and irritable bowel syndrome. Effect of a long-term lactose-free diet. Italian Journal of Gastroenterology 1995 Apr; 27(3):117–21. No prevalence data
2132. Verwimp JJ, Bindels JG, Barents M, et al. Symptomatology and growth in infants with cow's milk protein intolerance using two different whey-protein hydrolysate based formulas in a Primary Health Care setting. European journal of clinical nutrition Vol 49; 1995: S39–48. Not relevant to key questions
2133. Vesa T, Marteau P, Briet F, et al. Role of the Viscosity of Therapeutic Milk on Digestibility and Tolerance of Lactose in Adults with Hypolactasia [abstract]. Gut Vol 39; 1996: A169. Not relevant to key questions
2134. Vesa TH, Marteau P, Korpela R. Lactose intolerance. Journal of the American College of Nutrition 2000 Apr; 19(2 Suppl):165S–75S. Not original research
2135. Vesa TH, Marteau P, Zidi S, et al. Digestion and Tolerance of Lactose from Yoghurt and Semi-Solid Fermented Diary Products - Is Bacterial Lactase Important? [abstract]. Gut Vol 39; 1996: A169. Not relevant to key questions
2136. Vesa TH, Marteau PR, Briet FB, et al. Raising milk energy content retards gastric emptying of lactose in lactose-intolerant humans with little effect on lactose digestion. J Nutr 1997 Dec; 127(12):2316–20. Not relevant to key questions
2137. Vesa TH, Marteau PR, Briet FB, et al. Effects of milk viscosity on gastric emptying and lactose intolerance in lactose maldigesters. Am J Clin Nutr 1997 Jul; 66(1):123–6. Not relevant to key questions
2138. Vesa TH, Seppo LM, Marteau PR, et al. Role of irritable bowel syndrome in subjective lactose intolerance. Am J Clin Nutr 1998 Apr; 67(4):710–5. Not relevant to key questions
2139. Vetvik K, Schrumpf E, Mowinckel P, et al. Effects of omeprazole and eradication of Helicobacter pylori on gastric and duodenal mucosal enzyme activities and DNA in duodenal ulcer patients. Scandinavian journal of gastroenterology Vol 29; 1994: 995–1000. Not lactose intolerance study
2140. Viall C, Porcelli K, Teran JC, et al. A double-blind clinical trial comparing the gastrointestinal side effects of two enteral feeding formulas. JPEN. Journal of parenteral and enteral nutrition Vol 14; 1990: 265–9. Not lactose intolerance study
2141. Vidgren M, Karkkainen A, Karjalainen P, et al. Effect of powder inhaler design on drug deposition in the respiratory tract. International Journal of Pharmaceutics Vol 42; 1988: 211‐ 6. Not lactose intolerance study
2142. Vidgren P, Vidgren M, Laurikainen K, et al. In vitro deposition and clinical efficacy of two sodium cromoglycate inhalation powders. International journal of clinical pharmacology, therapy, and toxicology Vol 29; 1991: 108–12. Not lactose intolerance study
2143. Vienna A, Biondi G. Culture and biology: surnames in evaluating genetic relationships among the ethnic minorities of Southern Italy and Sicily. Coll Antropol 2001 Jun; 25(1):189‐93. Not relevant to key questions
2144. Vigna GB, Costantini F, Aldini G, et al. Effect of a standardized grape seed extract on low-density lipoprotein susceptibility to oxidation in heavy smokers. Metabolism: clinical and experimental Vol 52; 2003: 1250–7. Not lactose intolerance study
2145. Villani RG, Gannon J, Self M, et al. L-Carnitine supplementation combined with aerobic training does not promote weight loss in moderately obese women. International journal of sport nutrition and exercise metabolism Vol 10; 2000: 199–207. Not lactose intolerance study
2146. Villar J, Kestler E, Castillo P, et al. Improved lactose digestion during pregnancy: a case of physiologic adaptation? Obstetrics & Gynecology 1988 May; 71(5):697–700. Secondary lactose intolerance
2147. Vince JD. Diarrhoea in children in Papua New Guinea. P N G Med J 1995 Dec; 38(4):262‐71. Not relevant to key questions
2148. Vissing J, Quistorff B, Haller RG. Effect of fuels on exercise capacity in muscle phosphoglycerate mutase deficiency. Archives of neurology Vol 62; 2005: 1440–3. Not lactose intolerance study
2149. Vitek V, Vitek K, Cowley RA. Increased urinary excretion of lactose in brain injury. Surg Forum 1973; 24:429–31. Not relevant to key questions
2150. Vivatvakin B, Jongpipatvanich S, Harikul S, et al. Control study of oral rehydration solution (ORS)/ORS + dioctahedral smectite in hospitalized Thai infants with acute secretory diarrhea. The Southeast Asian journal of tropical medicine and public health Vol 23; 1992: 414–9. Not lactose intolerance study
2151. Vivatvakin B, Kowitdamrong E. Randomized control trial of live Lactobacillus acidophilus plus Bifidobacterium infantis in treatment of infantile acute watery diarrhea. Journal of the Medical Association of Thailand = Chotmaihet thangphaet Vol 89; 2006: S126–33. Not lactose intolerance study
2152. Vlachos P, Liakakos D, Boviatsi E. Letter: Childhood lactose intolerance. N Engl J Med 1976 Jan 15; 294(3):163–4. Not relevant to key questions
2153. Vogelsang H, Ferenci P, Frotz S, et al. Acidic colonic microclimate--possible reason for false negative hydrogen breath tests. Gut 1988 Jan; 29(1):21–6. Not relevant to key questions
2154. Volpe R, Niittynen L, Korpela R, et al. Effects of yoghurt enriched with plant sterols on serum lipids in patients with moderate hypercholesterolaemia. The British journal of nutrition Vol 86; 2001: 233–9. Not lactose intolerance study
2155. von Scheele C. Levodopa in restless legs. Lancet Vol 2; 1986: 426–7. Not lactose intolerance study
2156. von Tirpitz C, Kohn C, Steinkamp M, et al. Lactose intolerance in active Crohn's disease: clinical value of duodenal lactase analysis. J Clin Gastroenterol 2002 Jan; 34(1):49–53. Not eligible target population
2157. von Wright A, Salminen S. Probiotics: established effects and open questions. Eur J Gastroenterol Hepatol 1999 Nov; 11(11):1195–8. Not relevant to key questions
2158. Vonk RJ, Lin Y, Koetse HA, et al. Lactose (mal)digestion evaluated by the 13C-lactose digestion test. European Journal of Clinical Investigation 2000 Feb; 30(2):140–6. No prevalence data
2159. Vonk RJ, Priebe MG, Koetse HA, et al. Lactose intolerance: analysis of underlying factors. Eur J Clin Invest 2003 Jan; 33(1):70–5. Not relevant to key questions
2160. Vonk RJ, Stellaard F, Hoekstra H, et al. 13C carbohydrate breath tests. Gut 1998 Nov; 43 Suppl 3:S20–2. Not relevant to key questions
2161. Vukovich MD, Sharp RL, Kesl LD, et al. Effects of a low-dose amino acid supplement on adaptations to cycling training in untrained individuals. International journal of sport nutrition Vol 7; 1997: 298–309. Not lactose intolerance study
2162. Vyhmeister IB, Register UD, Sonnenberg LM. Safe vegetarian diets for children. Pediatr Clin North Am 1977 Feb; 24(1):203–10. Review
2163. Wagh MG, Ghooi RB, Shetty RK. Lactose intolerance; physiological, clinical and therapeutic considerations. Indian J Pediatr 1984 Nov–Dec; 51(413):671–81. Not relevant to key questions
2164. Waickman FJ. Food hypersensitivity allergy or malabsorption. Laryngoscope 1977 May; 87(5 Pt 1):661–4. Not relevant to key questions
2165. Wald A, Chandra R, Fisher SE, et al. Lactose malabsorption in recurrent abdominal pain of childhood. Journal of Pediatrics 1982 Jan; 100(1):65–8. Ineligible number of subjects
2166. Waldmann A, Koschizke JW, Leitzmann C, et al. Dietary intakes and lifestyle factors of a vegan population in Germany: results from the German Vegan Study. Eur J Clin Nutr 2003 Aug; 57(8):947–55. Not relevant to key questions
2167. Walike BC, Walike JW. Lactose content of tube feeding diets as a cause of diarrhea. Laryngoscope 1973 Jul; 83(7):1109–15. Not relevant to key questions
2168. Walike BC, Walike JW. Relative lactose intolerance. A clinical study of tube-fed patients. JAMA 1977 Aug 29; 238(9):948–51. Not relevant to key questions
2169. Walker AC, Harry JG. A survey of diarrhoeal disease in malnourished aboriginal children. Med J Aust 1972 Apr 29; 1(18):904–11. Not relevant to key questions
2170. Walker-Smith J, Barnard J, Bhutta Z, et al. Chronic diarrhea and malabsorption (including short gut syndrome): Working Group Report of the First World Congress of Pediatric Gastroenterology, Hepatology, and Nutrition. J Pediatr Gastroenterol Nutr 2002; 35 Suppl 2:S98–105. Not relevant to key questions
2171. Walker-Smith JA. Cow's milk intolerance as a cause of postenteritis diarrhoea. J Pediatr Gastroenterol Nutr 1982; 1(2):163–73. Not relevant to key questions
2172. Walker-Smith JA, Bowdler JD. The role of radiology in the diagnosis of lactose intolerance in childhood. Gut 1969 Jan; 10(1):78–9. Not relevant to key questions
2173. Wall CR, Webster J, Quirk P, et al. The nutritional management of acute diarrhea in young infants: effect of carbohydrate ingested. Journal of Pediatric Gastroenterology & Nutrition 1994 Aug; 19(2):170–4. Not relevant to key questions
2174. Wallace D, Grieco MH. Double-blind, cross-over study of cromolyn sodium inhibition of exercise-induced bronchospasm in adults. Annals of Allergy Vol 37; 1976: 153–63. Not lactose intolerance study
2175. Wallin A, Sandstrom T. Bronchoconstriction due to inhaled lactose dry powder? [Abstract]. European Respiratory Journal. Supplement. Vol 8; 1995: 426s. Not lactose intolerance study
2176. Walsh NE, Ramamurthy S, Schoenfeld L, et al. Analgesic effectiveness of D-phenylalanine in chronic pain patients. Archives of physical medicine and rehabilitation Vol 67; 1986: 436‐ 9. Not lactose intolerance study
2177. Wanderer AA, St PJP, Ellis EF. Primary acquired cold urticaria. Double-blind comparative study of treatment with cyproheptadine, chlorpheniramine, and placebo. Archives of dermatology Vol 113; 1977: 1375–7. Not lactose intolerance study
2178. Wang Y, Harvey CB, Hollox EJ, et al. The genetically programmed down-regulation of lactase in children. Gastroenterology 1998 Jun; 114(6):1230–6. Ineligible number of subjects
2179. Wang Y, Harvey CB, Pratt WS, et al. The lactase persistence/non-persistence polymorphism is controlled by a cis-acting element. Hum Mol Genet 1995 Apr; 4(4):657–62. Not relevant to key questions
2180. Wang YF, Chiu JS, Chuang MH, et al. Bone mineral density of vegetarian and non-vegetarian adults in Taiwan. Asia Pac J Clin Nutr 2008; 17(1):101–6. Not eligible exposure
2181. Wapnick S. Milk and lactose intolerance following distal small bowel resection. Am J Clin Nutr 1972 Jul; 25(7):655–60. Not relevant to key questions
2182. Ward RJ, Abraham R, McFadyen IR, et al. Assessment of trace metal intake and status in a Gujerati pregnant Asian population and their influence on the outcome of pregnancy. Br J Obstet Gynaecol 1988 Jul; 95(7):676–82. Not eligible outcomes
2183. Warner J, Brooks SE, James WP, et al. Juvenile dermatitis herpetiformis in Jamaica: clinical and gastrointestinal features. Br J Dermatol 1972 Mar; 86(3):226–37. Not relevant to key questions
2184. Warren S, Taylor G, Smith J, et al. Gamma scintigraphic evaluation of a novel budesonide dry powder inhaler using a validated radiolabeling technique. Journal of aerosol medicine : the official journal of the International Society for Aerosols in Medicine Vol 15; 2002: 15–25. Not lactose intolerance study
2185. Waud JP, Matthews SB, Campbell AK. Measurement of breath hydrogen and methane, together with lactase genotype, defines the current best practice for investigation of lactose sensitivity. Ann Clin Biochem 2008 Jan; 45(Pt 1):50–8. Not relevant to key questions
2186. Weaver CM, McCabe LD, McCabe GP, et al. Bone mineral and predictors of bone mass in white, Hispanic, and Asian early pubertal girls. Calcif Tissue Int 2007 Nov; 81(5):352–63. Not eligible exposure/outcomes
2187. Weaver CM, Plawecki KL. Dietary calcium: adequacy of a vegetarian diet. Am J Clin Nutr 1994 May; 59(5 Suppl):1238S–41S. Review
2188. Weaver CM, Proulx WR, Heaney R. Choices for achieving adequate dietary calcium with a vegetarian diet. Am J Clin Nutr 1999 Sep; 70(3 Suppl):543S–8S. Not eligible outcomes
2189. Weber K, Barth C, Schuler D, et al. [Activation of CFTR-dependent chloride channels by tiotropium bromide]. Atemwegs- und Lungenkrankheiten Vol 30; 2004: 38–42. Not lactose intolerance study
2190. Weber W, Michaelis K, Luckow V, et al. Pharmacokinetics and bioavailability of pentaerithrityl tetranitrate and two of its metabolites. Arzneimittel-Forschung Vol 45; 1995: 781–4. Not lactose intolerance study
2191. Wedlake L, Thomas K, McGough C, et al. Small bowel bacterial overgrowth and lactose intolerance during radical pelvic radiotherapy: An observational study. European Journal of Cancer 2008 Oct; 44(15):2212–7. No prevalence data
2192. Wehrli SL, Berry GT, Palmieri M, et al. Urinary galactonate in patients with galactosemia: quantitation by nuclear magnetic resonance spectroscopy. Pediatric research 1997 Dec; 42(6):855–61. Not relevant to key questions
2193. Weinberg RB. Apolipoprotein A-IV-2 allele: association of its worldwide distribution with adult persistence of lactase and speculation on its function and origin. Genetic Epidemiology 1999 Nov; 17(4):285–97. No prevalence data
2194. Weiskirchen R, Tag CG, Mengsteab S, et al. Pitfalls in LightCycler diagnosis of the single-nucleotide polymorphism 13.9 kb upstream of the lactase gene that is associated with adult-type hypolactasia. Clin Chim Acta 2007 Sep; 384(1–2):93–8. Not relevant to key questions
2195. Weiss HJ, Aledort LM. Impaired platelet-connective-tissue reaction in man after aspirin ingestion. Lancet Vol 2; 1967: 495–7. Not lactose intolerance study
2196. Weiss KM. The unkindest cup. Lancet 2004 May 8; 363(9420):1489–90. Not relevant to key questions
2197. Weiss PA. Does milk cause cancer? Clin J Oncol Nurs 2008 Apr; 12(2):359–60. Not relevant to key questions
2198. Weiss RG, Stryker JA. 14C-lactose breath tests during pelvic radiotherapy: the effect of the amount of small bowel irradiated. Radiology 1982 Feb; 142(2):507–10. Not relevant to key questions
2199. Weizman Z. [Evaluation of a new Israel infant soy formula]. Harefuah Vol 120; 1991: 374‐ 6. Not relevant to key questions
2200. Welsh JD. On the lactose tolerance test. Gastroenterology 1966 Sep; 51(3):445–6. Not relevant to key questions
2201. Welsh JD. Commentary. Am J Dig Dis 1967 Apr; 12(4):424–5. Not relevant to key questions
2202. Welsh JD. Diet therapy in adult lactose malabsorption: present practices. American Journal of Clinical Nutrition 1978 Apr; 31(4):592–6. Not relevant to key questions
2203. Welsh JD, Cassidy D, Prigatano GP, et al. Chronic hepatic encephalopathy treated with oral lactose in a patient with lactose malabsorption. N Engl J Med 1974 Aug 1; 291(5):240–1. Not relevant to key questions
2204. Welsh JD, Griffiths WJ. Breath hydrogen test after oral lactose in postgastrectomy patients. Am J Clin Nutr 1980 Nov; 33(11):2324–7. Not relevant to key questions
2205. Welsh JD, Hall WH. Gastric emptying of lactose and milk in subjects with lactose malabsorption. Am J Dig Dis 1977 Dec; 22(12):1060–3. Not relevant to key questions
2206. Welsh JD, Langdon DE. Lactose to treat hepatic encephalopathy in patient with lactose malabsorption. N Engl J Med 1972 Feb 24; 286(8):436. Not relevant to key questions
2207. Welsh JD, Payne DL, Manion C, et al. Interval sampling of breath hydrogen (H2) as an index of lactose malabsorption in lactase-deficient subjects. Dig Dis Sci 1981 Aug; 26(8):681–5. Not relevant to key questions
2208. Welsh JD, Poley JR, Bhatia M, et al. Intestinal disaccharidase activities in relation to age, race, and mucosal damage. Gastroenterology 1978 Nov; 75(5):847–55. No prevalence data
2209. Welsh JD, Porter MG. Reversible secondary disaccharidase deficiency. Am J Dis Child 1967 Jun; 113(6):716–20. Not relevant to key questions
2210. Welsh JD, Rohrer GV, Drewry R, et al. Human intestinal disaccharidase activity. II. Diseases of the small intestine and deficiency states. Arch Intern Med 1966 Apr; 117(4):495‐503. Not relevant to key questions
2211. Welsh JD, Rohrer GV, Walker A. Human intestinal disaccharidase activity. I. Normal individuals. Arch Intern Med 1966 Apr; 117(4):488–94. Not relevant to key questions
2212. Welsh JD, Shaw RW, Walker A. Isolated lactase deficiency producing postgastrectomy milk intolerance. Ann Intern Med 1966 Jun; 64(6):1253–8. Not relevant to key questions
2213. Wemmer U. [Nutrition in infant enteritis]. Fortschritte der Medizin Vol 95; 1977: 94–8, 102. Not relevant to key questions
2214. Wen CP. Milk programs. Am J Public Health 1973 Aug; 63(8):669–71. Not relevant to key questions
2215. Wendland BE, Greenwood CE, Weinberg I, et al. Malnutrition in institutionalized seniors: the iatrogenic component. Journal of the American Geriatrics Society 2003 Jan; 51(1):85–90. Not relevant to key questions
2216. Werner I. Hospital food and possibilities of its improvement. Clinical aspects. Bibl Nutr Dieta 1973; (19):86–92. Not eligible target population
2217. Weser E, Rubin W, Ross L, et al. Lactase deficiency in patients with the "irritable-colon syndrome". N Engl J Med 1965 Nov 11; 273(20):1070–5. Not relevant to key questions
2218. Westman EC, Behm FM, Rose JE. Airway sensory replacement combined with nicotine replacement for smoking cessation. A randomized, placebo-controlled trial using a citric acid inhaler. Chest Vol 107; 1995: 1358–64. Not lactose intolerance study
2219. Wharton B, Howells G, Phillips I. Diarrhoea in kwashiorkor. Br Med J 1968 Dec 7; 4(5631):608–11. Not relevant to key questions
2220. Whitcomb JE, Findling JW, Raff H, et al. Randomized trial of oral hydrocortisone and its effect on emergency physicians during night duty. WMJ : official publication of the State Medical Society of Wisconsin Vol 99; 2000: 37–41, 6. Not lactose intolerance study
2221. Whitehead RG. Lowered energy intake and dietary macronutrient balance: potential consequences for micronutrient status. Nutr Rev 1995 Sep; 53(9 Pt 2):S2–8. Review
2222. Whitehead WE, Bosmajian L, Zonderman AB, et al. Symptoms of psychologic distress associated with irritable bowel syndrome. Comparison of community and medical clinic samples. Gastroenterology 1988 Sep; 95(3):709–14. Not relevant to key questions
2223. Whitehead WE, Holtkotter B, Enck P, et al. Tolerance for rectosigmoid distention in irritable bowel syndrome. Gastroenterology 1990 May; 98(5 Pt 1):1187–92. Not relevant to key questions
2224. Wiecha JM, Fink AK, Wiecha J, et al. Differences in dietary patterns of Vietnamese, white, African-American, and Hispanic adolescents in Worcester, Mass. J Am Diet Assoc 2001 Feb; 101(2):248–51. Not relevant to key questions
2225. Wigg AE, Prest C, Slobodian P, et al. A system for improving vitamin D nutrition in residential care. The Medical journal of Australia Vol 185; 2006: 195–8. Not lactose intolerance study
2226. Wilkin JK, Fortner G, Reinhardt LA, et al. Prostaglandins and nicotinate-provoked increase in cutaneous blood flow. Clinical pharmacology and therapeutics Vol 38; 1985: 273–7. Not lactose intolerance study
2227. Wilkinson AW. The starving newborn baby. Proc Nutr Soc 1969 Mar; 28(1):61–6. Not relevant to key questions
2228. Williams CA, Macdonald I. Serum galactose levels in lactose-intolerant persons receiving a galactose:glucose mixture. Hum Nutr Clin Nutr 1982; 36(2):149–53. Not relevant to key questions
2229. Williams CA, Phillips T, Macdonald I. The influence of glucose on serum galactose levels in man. Metabolism: Clinical & Experimental Vol 32; 1983: 250–6. Not lactose intolerance study
2230. Williams CN, Dickson RC. Cholestyramine and medium-chain triglyceride in prolonged management of patients subjected to ileal resection or bypass. Canadian Medical Association Journal 1972 Oct 7; 107(7):626–31. No prevalence data
2231. Williams EJ, Irvine WT. Functional and metabolic effects of total and selective vagotomy. Lancet 1966 May 14; 1(7446):1053–7. Not relevant to key questions
2232. Willumsen JF, Darling JC, Kitundu JA, et al. Dietary management of acute diarrhoea in children: effect of fermented and amylase-digested weaning foods on intestinal permeability. Journal of pediatric gastroenterology and nutrition Vol 24; 1997: 235–41. Not lactose intolerance study
2233. Wilmers MJ, Young WF, Valman HB. Acute infective gastroenteritis. Br Med J 1969 May 31; 2(5656):573. Not relevant to key questions
2234. Wilson J, Riedel G. Lactose intolerance. Can Nurse 1984 Nov; 80(10):27–9. Not relevant to key questions
2235. Wilson L, Taylor JD, Nash CW, et al. The combined effects of ethanol and amphetamine sulfate on performance of human subjects. Canadian Medical Association journal Vol 94; 1966: 478–84. Not lactose intolerance study
2236. Wirth FH, Numerof B, Pleban P, et al. Effect of lactose on mineral absorption in preterm infants. The Journal of pediatrics Vol 117; 1990: 283–7. Not eligible target population
2237. Wisuthsarewong W, Viravan S. Diagnostic criteria for atopic dermatitis in Thai children. Journal of the Medical Association of Thailand 2004 Dec; 87(12):1496–500. No prevalence data
2238. Wittenberg DF, Moosa A. Lactose maldigestion: increased age-related prevalence in institutionalized children. Journal of Pediatric Gastroenterology & Nutrition 1990 Nov; 11(4):489–95. Ineligible number of subjects
2239. Wittenberg DF, Moosa A. Lactose maldigestion--age-specific prevalence in black and Indian children. South African Medical Journal Suid-Afrikaanse Tydskrif Vir Geneeskunde 1990 Oct 20; 78(8):470–2. Ineligible number of subjects
2240. Wittenberg DF, Moosa A. The practical significance of lactose maldigestion in institutionalised black children. South African Medical Journal Suid-Afrikaanse Tydskrif Vir Geneeskunde 1991 Jan 19; 79(2):70–2. Ineligible number of subjects
2241. Wolever TMS, Wong GS, Kenshole A, et al. Lactose in the diabetic diet: A comparison with other carbohydrates. Nutrition Research Vol 5; 1985: 1335–45. Not relevant to key questions
2242. Wolfe BE, Metzger ED, Jimerson DC. Comparison of the effects of amino acid mixture and placebo on plasma tryptophan to large neutral amino acid ratio. Life sciences Vol 56; 1995: 1395–400. Not lactose intolerance study
2243. Wolfe BE, Metzger ED, Jimerson DC. Eating Behavior, Serotonin and Tryptophan Depletion. 149th Annual Meeting of the American Psychiatric Association. New York, New York, USA. 4–9th May, 1996.; 1996. Not lactose intolerance study
2244. Wong FH, Yeung CY, Fung KW, et al. Breath hydrogen (H2) analysis in southern Chinese children and infants by gas chromatography and a novel automatic sampling system. Singapore Med J 1996 Feb; 37(1):72–81. Not relevant to key questions
2245. Woo J, Kwok T, Ho SC, et al. Nutritional status of elderly Chinese vegetarians. Age Ageing 1998 Jul; 27(4):455–61. Not relevant to key questions
2246. Wood RJ, Hanssen DA. Effect of milk and lactose on zinc absorption in lactose-intolerant postmenopausal women. J Nutr 1988 Aug; 118(8):982–6. Not eligible outcomes
2247. Woodd-Walker RB, Hansen JD, Saunders SJ. The in vitro uptake of lysine and alanine by human jejunal mucosa in protein-calorie malnutrition, in gastroenteritis and after neomycin. Acta Paediatr Scand 1972 Mar; 61(2):140–4. Not relevant to key questions
2248. Woods RK, Weiner JM, Abramson M, et al. Do dairy products induce bronchoconstriction in adults with asthma? Journal of Allergy & Clinical Immunology 1998 Jan; 101(1 Pt 1):45‐50. Not relevant to key questions
2249. Woods RK, Weiner JM, Thien F, et al. The effects of monosodium glutamate in adults with asthma who perceive themselves to be monosodium glutamate-intolerant. The Journal of allergy and clinical immunology Vol 101; 1998: 762–71. Not lactose intolerance study
2250. Woods RK, Weiner JM, Thien F, et al. Respiratory pathophysiologic responses the effects of monosodium glutamate in adults with asthma who perceive themselves to be monosodium glutamate-intolerant. Journal of Allergy and Clinical Immunology Vol 101; 1998: 762–71. Not lactose intolerance study
2251. Woolf GM, Miller C, Kurian R, et al. Diet for patients with a short bowel: high fat or high carbohydrate? Gastroenterology Vol 84; 1983: 823–8. Not lactose intolerance study
2252. Woolf GM, Miller C, Kurian R, et al. Nutritional absorption in short bowel syndrome. Evaluation of fluid, calorie, and divalent cation requirements. Digestive Diseases & Sciences 1987 Jan; 32(1):8–15. Not relevant to key questions
2253. Wooten WJ, Price W. Consensus report of the National Medical Association. The role of dairy and dairy nutrients in the diet of African Americans. J Natl Med Assoc 2004 Dec; 96(12 Suppl):5S–31S. Concensus report
2254. Wu VT, Brochetti D, Duncan SE. Sensory characteristics and acceptability of lactose-reduced baked custards made with an egg substitute. J Am Diet Assoc 1998 Dec; 98(12):1467–9. Not relevant to key questions
2255. Wutzke KD, Heine WE, Plath C, et al. Evaluation of orocoecal transit time: A comparison of the lactose-[13C, 15N]ureide 13CO2- and the lactulose H2-breath test in humans. European Journal of Clinical Nutrition Vol 51; 1997: 11–9. Not relevant to key questions
2256. Wutzke KD, Schütt M. The duration of enzyme induction in orocaecal transit time measurements. European journal of clinical nutrition Vol 61; 2007: 1162–6. Not lactose intolerance
2257. Wynckel A, Jaisser F, Wong T, et al. Intestinal absorption of calcium from yogurt in lactase-deficient subjects. Reprod Nutr Dev 1991; 31(4):411–8. Not eligible outcomes
2258. Wytock DH, DiPalma JA. All yogurts are not created equal. Am J Clin Nutr 1988 Mar; 47(3):454–7. Not relevant to key questions
2259. Xiao SD, Zhang DZ, Lu H, et al. Multicenter, randomized, controlled trial of heat-killed Lactobacillus acidophilus LB in patients with chronic diarrhea. Advances in therapy Vol 20; 2003: 253–60. Not lactose intolerance study
2260. Xu SS, Cai ZY, Qu ZW, et al. Huperzine-A in capsules and tablets for treating patients with Alzheimer disease. Zhongguo yao li xue bao = Acta pharmacologica Sinica Vol 20; 1999: 486–90. Not lactose intolerance study
2261. Yabuuchi H, Okada S, Nishigaki M, et al. Studies on the pathogenesis of mucolipidosis. Monogr Hum Genet 1978; 10:27–31. Not relevant to key questions
2262. Yadrick MM, Halling JF, Beyer PL, et al. Comparison of the effects of diets high and low in simple sugars on bowel function in healthy, lactose-tolerant men. Journal of the American Dietetic Association Vol 92; 1992: 1121–3. Not lactose intolerance study
2263. Yahata H, Saito M, Sendo T, et al. Prophylactic effect of pemirolast, an antiallergic agent, against hypersensitivity reactions to paclitaxel in patients with ovarian cancer. International journal of cancer. Journal international du cancer Vol 118; 2006: 2636–8. Not lactose intolerance study
2264. Yale SH, Liu K. Echinacea purpurea therapy for the treatment of the common cold: a randomized, double-blind, placebo-controlled clinical trial. Archives of internal medicine Vol 164; 2004: 1237–41. Not lactose intolerance study
2265. Yamagata S, Ishikawa M, Wada T, et al. A Multicenter Double Blind Study of Carbenoxolone Sodium for Patients with Gastric Ulcer in Japan, Evaluated by Group Comparison with Nonparametric Analysis. Rinsho Hyoka (Clinical Evaluation) Vol 4; 1976: 247–69. Not lactose intolerance study
2266. Yamagata S, Ishimori A, Sat H, et al. Clinical course of peptic ulcer and the effect of pharmacotherapy:--multi-institutional double-blind controlled study. Gastroenterologia Japonica Vol 10; 1975: 323–41. Not lactose intolerance study
2267. Yanaka A, Zhang S, Sato D, et al. Geranylgeranylacetone protects the human gastric mucosa from diclofenac-induced injury via induction of heat shock protein 70. Digestion Vol 75; 2007: 148–55. Not lactose intolerance study
2268. Yáñez L, Jung H, Garza-Flores J, et al. Norethisterone-cholesterol eutectic mixture as an oral sustained-release hormonal preparation: bioequivalence study in humans. Contraception Vol 37; 1988: 349–57. Not lactose intolerance study
2269. Yang WH, Purchase EC, Rivington RN. Positive skin tests and Prausnitz-Küstner reactions in metabisulfite-sensitive subjects. The Journal of allergy and clinical immunology Vol 78; 1986: 443–9. Not lactose intolerance study
2270. Yano K, Heilbrun LK, Wasnich RD, et al. The relationship between diet and bone mineral content of multiple skeletal sites in elderly Japanese-American men and women living in Hawaii. Am J Clin Nutr 1985 Nov; 42(5):877–88. Correlation coefficient
2271. Yao XH, Kong BQ, Yan JX, et al. Lactose tolerance test by hydrogen breath method in Chinese. Chin Med J (Engl) 1987 Apr; 100(4):316–8. Not relevant to key questions
2272. Yap I, Berris B, Kang JY, et al. Lactase deficiency in Singapore-born and Canadian-born Chinese. Digestive Diseases & Sciences 1989 Jul; 34(7):1085–8. Ineligible number of subjects
2273. Yeh TF, Srinivasan G, Harris V, et al. Hydrocortisone therapy in meconium aspiration syndrome: a controlled study. The Journal of pediatrics Vol 90; 1977: 140–3. Not lactose intolerance study
2274. Yeoh E, Horowitz M, Russo A, et al. A retrospective study of the effects of pelvic irradiation for carcinoma of the cervix on gastrointestinal function. International Journal of Radiation Oncology, Biology, Physics 1993 May 20; 26(2):229–37. Ineligible number of subjects
2275. Yeoh E, Horowitz M, Russo A, et al. The effects of abdominal irradiation for seminoma of the testis on gastrointestinal function. J Gastroenterol Hepatol Vol 10; 1995: 125–30. Not lactose intolerance study
2276. Yeoh E, Horowitz M, Russo A, et al. Effect of pelvic irradiation on gastrointestinal function: a prospective longitudinal study. American Journal of Medicine 1993 Oct; 95(4):397–406. Ineligible number of subjects
2277. Yeoh EK, Horowitz M, Russo A, et al. Gastrointestinal function in chronic radiation enteritis--effects of loperamide-N-oxide. Gut Vol 34; 1993: 476–82. Not lactose intolerance study
2278. Yesovitch R, Cohen A, Szilagyi A. Failure to improve parameters of lactose maldigestion using the multiprobiotic product VSL3 in lactose maldigesters: a pilot study. Can J Gastroenterol 2004 Feb; 18(2):83–6. Not relevant to key questions
2279. Yeung CY, Ma YP, Wong FH, et al. Automatic end-expiratory air sampling device for breath hydrogen test in infants. Lancet 1991 Jan 12; 337(8733):90–3. Not relevant to key questions
2280. Yip I, Go VL, DeShields S, et al. Liquid meal replacements and glycemic control in obese type 2 diabetes patients. Obesity research Vol 9; 2001: 341s–7s. Not lactose intolerance study
2281. Yolken RH, Hart W, Oung I, et al. Gastrointestinal dysfunction and disaccharide intolerance in children infected with human immunodeficiency virus. Journal of Pediatrics 1991 Mar; 118(3):359–63. No prevalence data
2282. Yoshida Y, Sasaki G, Goto S, et al. Studies on the etiology of milk intolerance in Japanese adults. Gastroenterol Jpn 1975; 10(1):29–34. Not relevant to key questions
2283. Young DS. High pressure column chromatography of carbohydrates in the clinical laboratory. Am J Clin Pathol 1970 May; 53(5):803–10. Not relevant to key questions
2284. Young EA. Jonathan E. Rhoads Lecture. Medicine, nutrition, and patient care: a panoramic view. Jpen: Journal of Parenteral & Enteral Nutrition 1994 Sep–Oct; 18(5):387–95. Not original research
2285. Youngstedt SD, O'Connor PJ, Crabbe JB, et al. The influence of acute exercise on sleep following high caffeine intake. Physiology & behavior Vol 68; 2000: 563–70. Not lactose intolerance study
2286. Yudkoff M, Cohn RM, Segal S. Errors of carbohydrate metabolism in infants and children: a survey. Clin Pediatr (Phila) 1978 Nov; 17(11):820–8. Not relevant to key questions
2287. Zemel MB. Calcium utilization: effect of varying level and source of dietary protein. Am J Clin Nutr 1988 Sep; 48(3 Suppl):880–3. Comment
2288. Zhang Y, Ojima T, Murata C. Calcium intake pattern among Japanese women across five stages of health behavior change. J Epidemiol 2007 Mar; 17(2):45–53. Not eligible outcomes
2289. Zheng JJ, Gong ZL, Xue LS, et al. Lactose malabsorption and its ethnic differences in Hans and Uygurs. Chin Med J (Engl) 1988 Apr; 101(4):284–6. Not relevant to key questions
2290. Zhong Y, Priebe MG, Vonk RJ, et al. The role of colonic microbiota in lactose intolerance. Dig Dis Sci 2004 Jan; 49(1):78–83. Not relevant to key questions
2291. Zimmerman CL, O'Connell MB, Soria I. The effects of urine pH modification on the pharmacokinetics and pharmacodynamics of phenylpropanolamine. Pharmaceutical research Vol 7; 1990: 96–102. Not lactose intolerance study
2292. Zittermann A, Bock P, Drummer C, et al. Lactose does not enhance calcium bioavailability in lactose-tolerant, healthy adults. The American journal of clinical nutrition Vol 71; 2000: 931–6. Not eligible outcomes
2293. Zuccato E, Andreoletti M, Bozzani A, et al. Respiratory excretion of hydrogen and methane in Italian subjects after ingestion of lactose and milk. Eur J Clin Invest 1983 Jun; 13(3):261–6. Not relevant to key questions
2294. Zuin G, Fontana M, Monti S, et al. Malabsorption of different lactose loads in children with human immunodeficiency virus infection. Journal of Pediatric Gastroenterology & Nutrition 1992 Nov; 15(4):408–12. Ineligible number of subjects
2295. Zweig MH, Robertson EA. Why we need better test evaluations. Clinical Chemistry 1982 Jun; 28(6):1272–6. No prevalence data