# Search Strings

Q1

Database: Ovid MEDLINE(R)
Search Strategy:
1 | lactose intoleran*.mp. or exp Lactose Intolerance/(2726)
2 | milk intoleran*.mp. (286)
3 | lactose malabsor*.mp. (493)
4 | exp Lactase/or lactase deficien*.mp. (961)
5 | prevalen*.mp. or exp Prevalence/(325492)
6 | exp Population/or population.mp. (682952)
7 | exp Lactose Tolerance Test/(313)
8 | 4 or 1 or 3 or 7 or 2 (3490)
9 | 6 or 5 (914652)
10 | 8 and 9 (515)
11 | exp Cohort Studies/(694867)
12 | 11 or 5 (980226)
13 | 8 and 12 (424)
14 | limit 13 to (english language and humans) (365)
15 | remove duplicates from 14 (362)

Q2

Database: Ovid MEDLINE(R)
Search Strategy:
1 | exp Lactose Intolerance/dh [Diet Therapy] (185)
2 | limit 1 to english language (131)
3 | exp epidemiologic studies/(1121620)
4 | 3 and 2 (12)
5 | (lactose restricted or lactose free).mp. (242)
6 | dairy exclusion.mp. (0)
7 | dairy free.mp. (9)
8 | 7 or 5 (251)
9 | 8 and 3 (36)
10 | limit 9 to english language (28)
11 | 4 or 10 (35)

Database: Ovid MEDLINE(R)
Search Strategy:
1 | exp lactose/df (9)
2 | hypolactas$.mp. (181)
3 | (lactose adj2 free).mp. [mp=title, original title, abstract, name of substance word, subject heading word] (273)
4 | (dairy adj2 free).mp. [mp=title, original title, abstract, name of substance word, subject heading word] (42)
5 | (dairy adj2 exclu$).mp. (12)
6 | low lactose.mp. (123)
7 | limited lactose.mp. (2)
8 | (lactose adj2 restrict$).mp. (38)
9 | (dairy adj2 restrict$).mp. (19)
10 | exp Lactose Intolerance/(2478)
11 | 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 (2902)
12 | exp Diet/(144995)
13 | dh.fs. (29635)
14 | diet$.mp. (372626)
15 | 13 or 12 or 14 (405928)
16 | 11 and 15 (933)
17 | exp Bone Density/(28018)
18 | exp “Bone and Bones”/(382334)
19 | exp Osteoporosis/(33396)
20 | exp Fractures, Bone/(108442)
21 | exp Bone Diseases/(318865)
22 | 21 or 18 or 19 or 17 or 20 (653576)
23 | 22 and 16 (51)
24 | exp Treatment Outcome/(371740)
25 | “Outcome and Process Assessment (Health Care)”/(16843)
26 | outcome$.mp. (801020)
27 | 25 or 24 or 26 (813119)
28 | 27 and 16 (45)
29 | ep.fs. (828160)
30 | exp Epidemiologic Studies/(1087836)
31 | exp Epidemiologic Methods/(2978476)
32 | 30 or 31 or 29 (3265926)
33 | 32 and 16 (290)
34 | 33 or 28 or 23 (341)
35 | limit 34 to (english language and humans) (298)
36 | limit 35 to journal article (293)
37 | limit 35 to (case reports or comment or editorial or letter or “review”) (66)
38 | 36 not 37 (232)

MEDLINE® via Pubmed

Search “Diet, Vegetarian”[Mesh] AND calcium Limits: Humans, Journal Article, English | 158
Search “Diet, Vegetarian”[Mesh] AND relative risk AND dairy Limits: Humans, Journal Article, English, All Adult: 19+ years, Preschool Child: 2–5 years, Child: 6–12 years, Adolescent: 13–18 years | 20
Search “Diet, Vegetarian”[Mesh] AND relative risk Limits: Humans, Journal Article, English, All Adult: 19+ years, Preschool Child: 2–5 years, Child: 6–12 years, Adolescent: 13–18 years | 279
Search “Diet, Vegetarian”[Mesh] AND lactose Limits: Humans, Journal Article, English, All Adult: 19+ years, Preschool Child: 2–5 years, Child: 6–12 years, Adolescent: 13–18 years | 4
Search “Diet, Vegetarian”[Mesh] AND lactose free Limits: Humans, Journal Article, English, All Adult: 19+ years, Preschool Child: 2–5 years, Child: 6–12 years, Adolescent: 13–18 years | 0
Search “Diet, Vegetarian”[Mesh] AND cancer Limits: Humans, Journal Article, English, All Adult: 19+ years, Preschool Child: 2–5 years, Child: 6–12 years, Adolescent: 13–18 years | 156
Search “Diet, Vegetarian”[Mesh] AND bone Limits: Humans, Journal Article, English, All Adult: 19+ years, Preschool Child: 2–5 years, Child: 6–12 years, Adolescent: 13–18 years | 46
Search avoidance AND “Calcium, Dietary”[Mesh] AND “Dairy Products”[Mesh] Limits: Humans, Journal Article, English | 8
Search intolerance AND “Calcium, Dietary”[Mesh] AND “Dairy Products”[Mesh] Limits: Humans, Journal Article, English | 35
Search “Calcium, Dietary”[Mesh] AND “Dairy Products”[Mesh] Limits: Humans, Journal Article, English | 517
Search “Calcium, Dietary”[Mesh] AND relative risk AND lactose intolerance Limits: Humans, Journal Article, English | 22

Scirus

1–10 of 23 hits for “Lactose-free diet” (fracture)

Q3

Database: Ovid MEDLINE(R)
Search Strategy:
1 | exp epidemiologic studies/(1121620)
2 | exp lactose intolerance/(2583)
3 | exp Lactose Tolerance Test/(329)
4 | 3 and 2 (268)
5 | 1 and 4 (19)
6 | limit 5 to english language (18)
7 | exp lactose/ad (469)
8 | 7 and 2 (117)
9 | 8 and 1 (13)
10 | limit 9 to english language (13)
11 | 6 or 10 (27)
12 | lactose intake.mp. (63)
13 | 1 and 12 and 2 (8)
14 | limit 13 to english language (6)
15 | 11 or 14 (30)

Q4

Database: Ovid MEDLINE(R)
Search Strategy:
1 | exp epidemiologic studies/(1121620)
2 | exp Lactose Intolerance/dh, su, dt, th [Diet Therapy, Surgery, Drug Therapy, Therapy] (413)
3 | 1 and 2 (20)
4 | limit 3 to english language (16)
5 | exp lactose intolerance/(2583)
6 | limit 5 to “therapy (optimized)” (114)
7 | 1 and 6 (11)
8 | limit 7 to english language (11)
9 | 4 or 8 (24)

MEDLINE® via Pubmed

“Probiotics”[Mesh] AND “lactose intolerance” Limits: Humans, Journal Article, English probiotics | 45
Search lactose-free AND “lactose intolerance” Limits: Humans, Journal Article, English | 55

Q5

Database: Ovid MEDLINE(R)
Search Strategy:
1 | exp Lactose Intolerance/(2583)
2 | td.fs. (203594)
3 | 1 and 2 (4)
4 | from 3 keep 1 (1)
5 | future research.mp. (21817)
6 | research need$.mp. (2549)
7 | trend$.mp. (147898)
8 | 1 and 5 (2)
9 | 6 and 1 (0)
10 | 1 and 7 (14)
11 | 8 or 4 or 10 (17)
12 | from 11 keep 1–2,11–13 (5)
13 | further investigation.mp. (26459)
14 | 1 and 13 (6)
15 | from 14 keep 2,4–5 (3)
16 | 12 or 15 (7)
17 | understanding.mp. (243623)
18 | 1 and 17 (14)
19 | from 18 keep 1,3 (2)
20 | from 18 keep 1,3,6–11,13 (9)
21 | 19 or 16 or 20 (16)

The broader preliminary literature search in MEDLINE® via Pubmed can be summarized as follows:

Relevant MeSH terms | Number identified
“Lactose Intolerance”[Mesh] | 2461
“Lactose Intolerance”[Mesh] NOT review NOT comment Limits: Humans, Journal Article, English | 1355
“Lactose Intolerance”[Mesh] AND “Epidemiologic Studies”[Mesh] Limits: Humans, English | 122
“Lactose Intolerance”[Mesh] Limits: Humans, Randomized Controlled Trial, English | 84

Additionally, the Cochrane Central Register of Controlled Trials (CENTRAL) was searched using the terms “lactose OR lactase”, which yielded 792 references.