# Technical Expert Panel Members and Affiliation

TEP Member | Affiliation
Melvin Heyman, MD | School of Medicine University of California San Francisco, California
Jay Perman, MD | College of Medicine Chandler Medical Center Lexington, Kentucky
Frederick Suchy, MD | Pediatric Gastroenterology Mount Sinai Hospital New York, New York