# Appendixes

Appendix A Technical Expert Panel Members and Affiliation

Appendix B Search Strings

Appendix C List of Excluded Studies

Appendix D Evidence Tables