# Acknowledgments

We wish to thank the librarian, Judith Stanke, for her contributions to the literature search, Marilyn Eells for her outstanding work in the preparation and text editing of this report; Stephanie Chang, M.D., AHRQ Task Order Officer, for her patience and guidance; our Technical Expert Panel members for their helpful recommendations, and the reviewers for their comments and suggestions.