# List of Acronyms and Abbreviations

AHRQ: Agency for Healthcare Research and Quality
BMC: Bone mineral content
BMD: Bone mineral density
BMI: Body mass index
CaMos: Canadian Multicentre Osteoporosis Study
CH_4_: Methane
CI: Confidence interval
Co_2_: Carbon dioxide
DOES: Dubbo Osteoporosis Epidemiology Study
EPC: Evidence-based Practice Center
EPIC: European Prospective Investigation into Cancer and Nutrition
EPOS: European Prospective Osteoporosis Study
EVOS: European Vertebral Osteoporosis Study
g: Gram
GI: Gastrointestinal
GRADE: Grades of Recommendation Assessment, Development, and Evaluation
H_2_: Hydrogen gas
IBS: Irritable bowel syndrome
kg: Kilogram
L: Liter
LCT: Lactase gene
LI: Lactose intolerance
LM: Lactose malabsorption
mg: Milligram
ml: Milliliter
NHANES: National Health and Nutrition Examination Survey
NIH: National Institutes of Health
OMAR: Office of Medical Applications of Research
OR: Odds ratio
ppm: Parts per million
RCT: Randomized controlled trial
SNP: Single nucleotide polymorphism
TEP: Technical Expert Panel