# References

1 Agency for Healthcare Research and Quality. Healthcare Cost and Utilization Project (HCUP). http://hcupnet.ahrq.gov/. Accessed Dec 9, 2009.
2 Taffel SM, Placek PJ, Liss T. Trends in the United States cesarean section rate and reasons for the 1980–85 rise. Am J Public Health. 1987;77(8):955-959. [pmid: 3605474].
3 Cesarean Childbirth. NIH Consenus Statement Online. 1980;3(6):1-30.
4 Martin JA, Hamilton BE, Sutton PD, Ventura SJ, Menacker F, Kirmeyer S. Births: final data for 2004. Natl Vital Stat Rep. 2006;55(1):1-101.
5 Placek PJ, Taffel S, Moien M. Cesarean section delivery rates: United States, 1981. Am J Public Health. 1981;73(8):861-862. [pmid: 6869638].
6 Placek PJ, Taffel SM. The Frequency of Complications in Cesarean and Noncesarean Deliveries, 1970 and 1978. Public Health Rep. 1983;98(4):396-400. [pmid: 6611827].
7 Healthy People. 2010. http://www.healthypeople.gov/. Accessed Dec 4, 2009.
8 Hamilton B, Martin J, Ventura S. Births: Preliminary data for 2007. Natl Vital Stat Rep, Web Release. Hyattsville, MD. National Center for Vital Statistics. March. 18. 2009.
9 Martin JA, Hamilton BE, Sutton PD, et al. Births: Final Data for 2006. Natl Vital Stat Rep. 2009;57(7):1-102.
10 McMahon MJ, Luther ER, Bowes WA Jr, Olshan AF. Comparison of a trial of labor with an elective second cesarean section. N Engl J Med. 1996;335(10):689-695. [pmid: 8703167].
11 Lydon-Rochelle M, Holt VL, Easterling TR, Martin DP. Risk of uterine rupture during labor among women with a prior cesarean delivery. N Engl J Med. 2001;345(1):3-8. [pmid: 11439945].
12 Development OfECa. OECD health data 2007: statistics and indicators for 30 countries 2007. 6. 30. 2009. http://www.oecd.org/document/30/0,2340,en_2649_34631_12968734_1_1_1_1,00.html. Accessed Dec 16, 2009.
13 Eden KB, Hashima JN, Osterweil P, Nygren P, Guise J-M. Childbirth preferences after cesarean birth: a review of the evidence. Birth. 2004;31(1):49-60. [pmid: 15015993].
14 Fawcett J, Tulman L, Spedden J. Responses to vaginal birth after cesarean section. J Obstet Gynecol Neonatal Nurs. 1994;23(3):25-259.
15 Kirk EP, Doyle KA, Leigh J, Garrard ML. Vaginal birth after cesarean or repeat cesarean section: medical risks or social realities?. Am J Obstet Gynecol. 1990;162(6):1398-1403. discussion 1403–1395. [pmid: 2360572].
16 Lau TK, Wong SH, Li CY. A study of patients’ acceptance towards vaginal birth after caesarean section. Aust N Z J Obstet Gynaecol. 1996;36(2):155-158. [pmid: 8798303].
17 Murphy MC, Harvey SM. Choice of a childbirth method after cesarean. Women Health. 1989;15(2):67-85. [pmid: 2781811].
18 Moffat MA, Bell JS, Porter MA, et al. Decision making about mode of delivery among pregnant women who have previously had a caesarean section: A qualitative study. BJOG. 2007;114(1):86-93. [pmid: 17233863].
19 Farnworth A, Robson SC, Thomson RG, Watson DB, Murtagh MJ. Decision support for women choosing mode of delivery after a previous caesarean section: a developmental study. Patient Educ Couns. 2008;71(1):116-124. [pmid: 18255248].
20 McClain CS. The making of a medical tradition: vaginal birth after cesarean. Soc Sci Med. 1990;31(2):203-210. [pmid: 2389156].
21 Dilks FM, Beal JA. Role of self-efficacy in birth choice. J Perinat Neonatal Nurs. 1997;11(1):1-9. [pmid: 9214946].
22 Meddings F, Phipps FM, Haith-Cooper M, Haigh J. Vaginal birth after caesarean section (VBAC): exploring women’s perceptions. J Clin Nurs. 2007;16(1):160-167. [pmid: 17181678].
23 Cleary-Goldman J, Cornelisse K, Simpson LL, Robinson JN. Previous cesarean delivery: understanding and satisfaction with mode of delivery in a subsequent pregnancy in patients participating in a formal vaginal birth after cesarean counseling program. Am J Perinatol. 2005;22(4):217-221. [pmid: 15906216].
24 Lucas A. Information for women after CS: are they getting enough?. RCM Midwives. 2004;7(11):472-475. [pmid: 15612178].
25 Melnikow J, Romano P, Gilbert WM, Schembri M, Keyzer J, Kravitz RL. Vaginal birth after cesarean in California. Obstet Gynecol. 2001;98(3):421-426. [pmid: 11530123].
26 Norman P, Kostovcik S, Lanning A. Elective repeat cesarean sections: how many could be vaginal births?. CMAJ. 1993;149(4):431-435. [pmid: 8348425].
27 Selo-Ojeme D, Abulhassan N, Mandal R, Tirlapur S, Selo-Ojeme U. Preferred and actual delivery mode after a cesarean in London, UK. Int J Gynaecol Obstet. 2008;102(2):156-159. [pmid: 18436222].
28 Fraser W, Maunsell E, Hodnett E, Moutquin JM. Randomized controlled trial of a prenatal vaginal birth after cesarean section education and support program. Childbirth Alternatives Post-Cesarean Study Group. Am J Obstet Gynecol. 1997;176(2):419-425. [pmid: 9065192].
29 Renner RM, Eden KB, Osterweil P, Chan BK, Guise JM. Informational factors influencing patient’s childbirth preferences after prior cesarean. Am J Obstet Gynecol. 2007;196(5):e14-16. [pmid: 17466665].
30 Sur S, Mackenzie IZ. Does discussion of possible scar rupture influence preferred mode of delivery after a caesarean section?. J Obstet Gynaecol. 2005;25(4):338-341. [pmid: 16091312].
31 Eden KB, Dolan JG, Perrin NA, et al. Patients were more consistent in randomized trial at prioritizing childbirth preferences using graphic-numeric than verbal formats. J Clin Epidemiol. 2009;62(4):415-424. e413. [pmid: 19008073].
32 Montgomery AA, Emmett CL, Fahey T, et al. Two decision aids for mode of delivery among women with previous caesarean section: randomised controlled trial. BMJ. 2007;334(7607):1305. [pmid: 17540908].
33 Shorten A, Shorten B, Keogh J, West S, Morris J. Making choices for childbirth: a randomized controlled trial of a decision-aid for informed birth after cesarean. Birth. 2005;32(4):252-261. [pmid: 16336366].
34 Frost J, Shaw A, Montgomery A, Murphy DJ. Women’s views on the use of decision aids for decision making about the method of delivery following a previous caesarean section: qualitative interview study. BJOG. 2009;116(7):896-905. [pmid: 19385964].
35 Caron A, Neuhauser D. The effect of public accountability on hospital performance: trends in rates for cesarean sections and vaginal births after cesarean section in Cleveland, Ohio. Qual Manag Health Care. 1999;7(2):1-10. [pmid: 10346457].
36 Macones GA. Clinical outcomes in VBAC attempts: what to say to patients?. Am J Obstet Gynecol. 2008;199(1):1-2. [pmid: 18585519].
37 ACOG Releases 2009 Medical Liability Survey. Results Paint Dismal Reality for Ob-Gyns and Their Patients. http://www.acog.org/from_home/publications/press_releases/nr09-11-09.cfm. Accessed Dec 1, 2009.
38 Angelini DJ, Greenwald L. Closed claims analysis of 65 medical malpractice cases involving nurse-midwives. J Midwifery Womens Health. 2005;50(6):454-460. [pmid: 16260359].
39 Clark SL, Vines VL, Belfort MA. Fetal injury associated with routine vacuum use during cesarean delivery. Am J Obstet Gynecol. 2008;198(4):e4. [pmid: 18295178].
40 Stalnaker BL, Maher JE, Kleinman GE, Macksey JM, Fishman LA, Bernard JM. Characteristics of successful claims for payment by the Florida Neurologic Injury Compensation Association Fund. Am J Obstet Gynecol. 1997;177(2):268-271. discussion 271–263. [pmid: 9290439].
41 Localio AR, Lawthers AG, Bengston JM, et al. Relationship Between Malpractice Claims and Cesarean Delivery. JAMA. 1993;269(3):366-373. [pmid: 8418343].
42 Murthy K, Grobman WA, Lee TA, Holl JL. Association Between Rising Professional Liability Insurance Premiums and Primary Cesarean Delivery Rates. Obstet Gynecol. 2007;110(6):1264-1269. [pmid: 18055719].
43 Yang YT, Mello MM, Subramanian SV, Studdert DM. Relationship between malpractice litigation pressure and rates of cesarean section and vaginal birth after cesarean section. Med Care. 2009;47(2):234-242. [pmid: 19169125].
44 Brill Y, Kingdom J, Thomas J, et al. The management of VBAC at term: a survey of Canadian obstetricians. J Obstet Gynaecol Can. 2003;25(4):300-310. [pmid: 12679822].
45 Coleman VH, Erickson K, Schulkin J, Zinberg S, Sachs BP. Vaginal birth after cesarean delivery: practice patterns of obstetrician-gynecologists. J Reprod Med. 2005;50(4):261-266. [pmid: 15916210].
46 Dodd J, Crowther CA. Vaginal birth after Caesarean section: a survey of practice in Australia and New Zealand. Aust N Z J Obstet Gynaecol. 2003;43(3):226-231. [pmid: 14712990].
47 Kamal P, Dixon-Woods M, Kurinczuk JJ, Oppenheimer C, Squire P, Waugh J. Factors influencing repeat caesarean section: qualitative exploratory study of obstetricians’ and midwives’ accounts. BJOG. 2005;112(8):1054-1060. [pmid: 16045517].
48 Kenton K, Brincat C, Mutone M, Brubaker L. Repeat cesarean section and primary elective cesarean section: recently trained obstetrician- gynecologist practice patterns and opinions. Am J Obstet Gynecol. 2005;192(6):1872-1875. discussion 1875–1876. [pmid: 15970836].
49 Sur S, Murphy KW, Mackenzie IZ. Delivery after caesarean section: consultant obstetricians’ professional advice and personal preferences. J Obstet Gynaecol. 2009;29(3):212-216. [pmid: 19358027].
50 Guise J-M. Anticipating and responding to obstetric emergencies. Best Pract Res Clin Obstet Gynaecol. 2007;21(4):625-638. [pmid: 17467342].
51 Guise J-M, Segel S. Teamwork in obstetric critical care. Best Pract Res Clin Obstet Gynaecol. 2008;22(5):937-951. [pmid: 18701352].
52 Veltman L. Vaginal birth after cesarean checklist; an evidence-based approach to improving care during VBAC trials. J Healthc Risk Manag. 2009;29(1):22-27. [pmid: 19774969].
53 ACOG practice bulletin. Vaginal birth after previous cesarean delivery. Number 5, July 1999 (replaces practice bulletin number 2, October 1998). Clinical management guidelines for obstetrician-gynecologists. American College of Obstetricians and Gynecologists. Int J Gynaecol Obstet. 1999;66(2):197-204. [pmid: 10468354].
54 Pinette MG, Kahn J, Gross KL, Wax JR, Blackstone J, Cartin A. Vaginal birth after Cesarean rates are declining rapidly in the rural state of Maine. J Matern Fetal Neonatal Med. 2004;16(1):37-43. [pmid: 15370081].
55 Misra A. Impact of the HealthChoice program on cesarean section and vaginal birth after C-section deliveries: a retrospective analysis. Matern Child Health J. 2008;12(2):266-274. [pmid: 17549614].
56 Roberts RG, Deutchman M, King VJ, Fryer GE, Miyoshi TJ. Changing policies on vaginal birth after cesarean: impact on access. Birth. 2007;34(4):316-322. [pmid: 18021147].
57 Oleske DM, Linn ES, Nachman KL, Marder RJ, Thompson LD. Cesarean and VBAC delivery rates in Medicaid managed care, Medicaid fee- for-service, and private managed care. Birth. 1998;25(2):125-127. [pmid: 9668747].
58 Wagner CL, Metts AK. Rates of successful vaginal delivery after cesarean for patients with private versus public insurance. J Perinatol. 1999;19(1):14-18. [pmid: 10685196].
59 Grant D. Physician financial incentives and cesarean delivery: new conclusions from the healthcare cost and utilization project. J Health Econ. 2009;28(1):244-250. [pmid: 19027184].
60 Hammoud A, Hendler I, Gauthier RJ, Berman S, Sansregret A, Bujold E. The effect of gestational age on trial of labor after Cesarean section. J Matern Fetal Neonatal Med. 2004;15(3):202-206. [pmid: 15280148].
61 Quinones JN, Stamilio DM, Pare E, Peipert JF, Stevens E, Macones GA. The effect of prematurity on vaginal birth after cesarean delivery: success and maternal morbidity. Obstet Gynecol. 2005;105(3):519-524. [pmid: 15738018].
62 Guise JM, McDonagh MS, Hashima J, et al. Vaginal birth after cesarean (VBAC). Evid Rep Technol Assess (Summ). 2003;(71):1-8. [pmid: 12696509].
63 MacDorman MF, Kirmeyer S, MacDorman MF, Kirmeyer S. Fetal and perinatal mortality, United States, 2005. Natl Vital Stat Rep. 2009;57(8):1-19. [pmid: 19294965].
64 Slavin RE. Best Evidence Synthesis: An Intelligent Alternative to Meta-Analysis. J Clin Epidemiol. 1995;48(1):9-18. [pmid: 7853053].
65 Agency for Healthcare Research and Quality. Methods Reference Guide for Effectiveness and Comparative Effectiveness Reviews, Version 1.0. Rockville, MD. 2007.
66 Deeks JJ, Dinnes J, D’Amico R, et al. Evaluating non-randomised intervention studies. Health Tech Assess. 2003;7(27):iii-x. 1. 173.
67 Altman DG. Practical Statistics for Medical Research. London. Chapman & Hall. 1991.
68 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. 1986;7(3):177-188. [pmid: 3802833].
69 Higgins JP, Green S. Cochrane Handbook for Systematic Reviews of Interventions Version 5.0.2. The Cochrane Collaboration. 2009.
70 Tufts Medical Center. MetaAnalyst: Powerful meta-analysis software. http://tuftscaes.org/meta_analyst/. Accessed Dec 8, 2009.
71 Turner RM, Omar RZ, Yang M, Goldstein H, Thompson SG. A multilevel model framework for meta-analysis of clinical trials with binary outcomes. Stat Med. 2000;19:3417-3432. [pmid: 11122505].
72 Hamza TH, van Houwelingen HC, Stijnen T, Hamza TH, van Houwelingen HC, Stijnen T. The binomial distribution of meta-analysis was preferred to model within-study variability. J Clin Epidemiol. 2008;61(1):41-51. [pmid: 18083461].
73 Lewis S, Clarke M. Forest plots: trying to see the wood and the trees. BMJ. 2001;322(7300):1479-1480. [pmid: 11408310].
74 Sutton AJ, Abrams KR, Jones DR, Sheldon TA, Song F. Methods for Meta-Analysis in Medical Research. John Wiley & Sons, Inc. 2000.
75 Thompson SG, Sharp SJ. Explaining heterogeneity in meta-analysis: a comparison of methods. Stat Med. 1999;18(20):2693-2708. [pmid: 10521860].
76 Bais JM, van der Borden DM, Pel M, et al. Vaginal birth after caesarean section in a population with a low overall caesarean section rate. Eur J Obstet Gynecol Reprod Biol. 2001;96(2):158-162. [pmid: 11384799].
77 Flamm BL, Goings JR, Liu Y, Wolde-Tsadik G. Elective repeat cesarean delivery versus trial of labor: a prospective multicenter study. Obstet Gynecol. 1994;83(6):927-932. [pmid: 8190433].
78 Hibbard JU, Gilbert S, Landon MB, et al. Trial of labor or repeat cesarean delivery in women with morbid obesity and previous cesarean delivery. Obstet Gynecol. 2006;108(1):125-133. [pmid: 16816066].
79 Hook B, Kiwi R, Amini SB, Fanaroff A, Hack M. Neonatal morbidity after elective repeat cesarean section and trial of labor. Pediatrics. 1997;100(3 Pt 1):348-353. [pmid: 9282704].
80 Landon MB, Spong CY, Thom E, et al. Risk of uterine rupture with a trial of labor in women with multiple and single prior cesarean delivery. Obstet Gynecol. 2006;108(1):12-20. [pmid: 16816050].
81 Phelan JP, Clark SL, Diaz F, Paul RH. Vaginal birth after cesarean. Am J Obstet Gynecol. 1987;157(6):1510-1515. [pmid: 3425654].
82 Rozenberg P, Goffinet F, Philippe HJ, Nisand I. Thickness of the lower uterine segment: its influence in the management of patients with previous cesarean sections. Eur J Obstet Gynecol Reprod Biol. 1999;87(1):39-45. [pmid: 10579615].
83 Rozenberg P, Goffinet F, Phillippe HJ, Nisand I. Ultrasonographic measurement of lower uterine segment to assess risk of defects of scarred uterus. Lancet. 1996;347(8997):281-284. [pmid: 8569360].
84 Stovall TG, Shaver DC, Solomon SK, Anderson GD. Trial of labor in previous cesarean section patients, excluding classical cesarean sections. Obstet Gynecol. 1987;70(5):713-717. [pmid: 3658277].
85 Strong JM, McQuillan K. Factors affecting mode of delivery in labour following a single previous birth by cesarean. J Obstet Gynaecol. 1996;16(5).
86 Cameron CA, Roberts CL, Peat B. Predictors of labor and vaginal birth after cesarean section. Int J Gynaecol Obstet. 2004;85(3):267-269. [pmid: 15145263].
87 DeFranco EA, Rampersad R, Atkins KL, et al. Do vaginal birth after cesarean outcomes differ based on hospital setting?. Am J Obstet Gynecol. 2007;197(4):400.e401-406. [pmid: 17904977].
88 DiMaio H, Edwards RK, Euliano TY, Treloar RW, Cruz AC. Vaginal birth after cesarean delivery: an historic cohort cost analysis. Am J Obstet Gynecol. 2002;186(5):890-892. [pmid: 12015504].
89 Durnwald C, Mercer B. Vaginal birth after Cesarean delivery: predicting success, risks of failure. J Matern Fetal Neonatal Med. 2004;15(6):388-393. [pmid: 15280110].
90 Fisler RE, Cohen A, Ringer SA, Lieberman E. Neonatal outcome after trial of labor compared with elective repeat cesarean section. Birth. 2003;30(2):83-88. [pmid: 12752164].
91 Gonen R, Nisenblat V, Barak S, Tamir A, Ohel G. Results of a well-defined protocol for a trial of labor after prior cesarean delivery. Obstet Gynecol. 2006;107(2 Pt 1):240-245. [pmid: 16449107].
92 Gregory KD, Korst LM, Cane P, Platt LD, Kahn K. Vaginal birth after cesarean and uterine rupture rates in California. Obstet Gynecol. 1999;94(6):985-989. [pmid: 10576187].
93 Gregory KD, Korst LM, Fridman M, et al. Vaginal birth after cesarean: clinical risk factors associated with adverse outcome. Am J Obstet Gynecol. 2008;198(4):452.e451-410. discussion 452.e410–452. [pmid: 18395037].
94 Hueston WJ, Rudy M. Factors predicting elective repeat cesarean delivery. Obstet Gynecol. 1994;83(5 Pt 1):741-744. [pmid: 8164936].
95 Kugler E, Shoham-Vardi I, Burstien E, Mazor M, Hershkovitz R. The safety of a trial of labor after cesarean section in a grandmultiparous population. Arch Gynecol Obstet. 2008;277(4):339-344. [pmid: 17957377].
96 Locatelli A, Regalia AL, Ghidini A, Ciriello E, Biffi A, Pezzullo JC. Risks of induction of labour in women with a uterine scar from previous low transverse caesarean section. BJOG. 2004;111(12):1394-1399. [pmid: 15663125].
97 Loebel G, Zelop CM, Egan JFX, Wax J. Maternal and neonatal morbidity after elective repeat Cesarean delivery versus a trial of labor after previous Cesarean delivery in a community teaching hospital. J Matern Fetal Neonatal Med. 2004;15(4):243-246. [pmid: 15280132].
98 Macones GA, Peipert J, Nelson DB, et al. Maternal complications with vaginal birth after cesarean delivery: a multicenter study. Am J Obstet Gynecol. 2005;193(5):1656-1662. [pmid: 16260206].
99 McNally OM, Turner MJ. Induction of labour after 1 previous Caesarean section. Aust N Z J Obstet Gynaecol. 1999;39(4):425-429. [pmid: 10687757].
100 Obara H, Minakami H, Koike T, Takamizawa S, Matsubara S, Sato I. Vaginal birth after cesarean delivery: results in 310 pregnancies. J Obstet Gynaecol Res. 1998;24(2):129-134. [pmid: 9631601].
101 Pang MW, Law LW, Leung TY, Lai PY, La TK. Sociodemographic factors and pregnancy events associated with women who declined vaginal birth after cesarean section. Eur J Obstet Gynecol Reprod Biol. 2009;143(1):24-28. [pmid: 19136194].
102 Pickhardt MG, Martin JN Jr, Meydrech EF, et al. Vaginal birth after cesarean delivery: are there useful and valid predictors of success or failure?. Am J Obstet Gynecol. 1992;166(6 Pt 1):1811-1815. discussion 1815–1819. [pmid: 1615990].
103 Smith GCS, Pell JP, Cameron AD, Dobbie R. Risk of perinatal death associated with labor after previous cesarean delivery in uncomplicated term pregnancies. JAMA. 2002;287(20):2684-269. [pmid: 12020304].
104 Smith GCS, White IR, Pell JP, Dobbie R. Predicting cesarean section and uterine rupture among women attempting vaginal birth after prior cesarean section. PLoS Med. 2005;2(9):e252. [pmid: 16146414].
105 Socol ML, Peaceman AM. Vaginal birth after cesarean: an appraisal of fetal risk. Obstet Gynecol. 1999;93(5 Pt 1):674-679. [pmid: 10912965].
106 Spaans WA, Sluijs MB, van Roosmalen J, Bleker OP. Risk factors at caesarean section and failure of subsequent trial of labour. Eur J Obstet Gynecol Reprod Biol. 2002;100(2):163-166. [pmid: 11750957].
107 Troyer LR, Parisi VM. Obstetric parameters affecting success in a trial of labor: designation of a scoring system. Am J Obstet Gynecol. 1992;167(4 Pt 1):1099-1104. [pmid: 1415398].
108 Wen SW, Rusen ID, Walker M, et al. Comparison of maternal mortality and morbidity between trial of labor and elective cesarean section among women with previous cesarean delivery. Am J Obstet Gynecol. 2004;191(4):1263-1269. [pmid: 15507951].
109 Martin JA, Hamilton BE, Menacker F, Sutton PD, Mathews JT. Preliminary births for 2004: Infant and maternal health. Health E-stats. Hyattsville, MD. National Center for Health Statistics. 2005.
110 Durnwald CP, Ehrenberg HM, Mercer BM. The impact of maternal obesity and weight gain on vaginal birth after cesarean section success. Am J Obstet Gynecol. 2004;191(3):954-957. [pmid: 15467571].
111 Kabir AA, Pridjian G, Steinmann WC, Herrera EA, Khan MM. Racial differences in cesareans: an analysis of U.S. 2001 National Inpatient Sample Data.[see comment][erratum appears in Obstet Gynecol. 2005 Jun;105(6):1495]. Obstet Gynecol. 2005;105(4):710-718. [pmid: 15802395].
112 Bujold E. Uterine rupture during a trial of labor after a one- versus two-layer closure of low transverse cesarean. Am J Obstet Gynecol. 2001;184(suppl):S18.
113 Chang JJ, Stamilio DM, Macones GA. Effect of hospital volume on maternal outcomes in women with prior cesarean delivery undergoing trial of labor. Am J Epidemiol. 2008;167(6):711-718. [pmid: 18192674].
114 Harper LM, Cahill AG, Stamilio DM, Odibo AO, Peipert JF, Macones GA. Effect of gestational age at the prior cesarean delivery on maternal morbidity in subsequent VBAC attempt. Am J Obstet Gynecol. 2009;200(3):276.e271-276. [pmid: 19167694].
115 Hendler I, Bujold E. Effect of prior vaginal delivery or prior vaginal birth after cesarean delivery on obstetric outcomes in women undergoing trial of labor. Obstet Gynecol. 2004;104(2):273-277. [pmid: 15291999].
116 Jakobi P, Weissman A, Peretz BA, Hocherman I. Evaluation of prognostic factors for vaginal delivery after cesarean section. J Reprod Med. 1993;38(9):729-733. [pmid: 8254598].
117 Lieberman E, Ernst EK, Rooks JP, Stapleton S, Flamm B. Results of the national study of vaginal birth after cesarean in birth centers. Obstet Gynecol. 2004;104(5 Pt 1):933-942. [pmid: 15516382].
118 van Gelderen CJ, England MJ, Naylor GA, Katzeff TC. Labour in patients with a caesarean section scar. The place of oxytocin augmentation. S Afr Med J. 1986;70(9):529-532. [pmid: 3775598].
119 Caughey AB, Shipp TD, Repke JT, Zelop CM, Cohen A, Lieberman E. Rate of uterine rupture during a trial of labor in women with one or two prior cesarean deliveries. Am J Obstet Gynecol. 1999;181(4):872-876. [pmid: 10521745].
120 Costantine MM, Fox K, Byers BD, et al. Validation of the prediction model for success of vaginal birth after cesarean delivery. Obstet Gynecol. 2009;114(5):1029-1033. [pmid: 20168103].
121 Delaney T, Young DC. Spontaneous versus induced labor after a previous cesarean delivery. Obstet Gynecol. 2003;102(1):39-44. [pmid: 12850605].
122 Dinsmoor MJ, Brock EL. Predicting failed trial of labor after primary cesarean delivery. Obstet Gynecol. 2004;103(2):282-286. [pmid: 14754696].
123 Elkousy MA, Sammel M, Stevens E, Peipert JF, Macones G. The effect of birth weight on vaginal birth after cesarean delivery success rates. Am J Obstet Gynecol. 2003;188(3):824-830. [pmid: 12634665].
124 El-Sayed YY, Watkins MM, Fix M, Druzin ML, Pullen KM, Caughey AB. Perinatal outcomes after successful and failed trials of labor after cesarean delivery. Am J Obstet Gynecol. 2007;196(6):583.e581-585. discussion 583.e585. [pmid: 17547905].
125 Flamm BL, Goings JR, Fuelberth NJ, Fischermann E, Jones C, Hersh E. Oxytocin during labor after previous cesarean section: results of a multicenter study. Obstet Gynecol. 1987;70(5):709-712. [pmid: 3309751].
126 Goodall PT, Ahn JT, Chapa JB, Hibbard JU. Obesity as a risk factor for failed trial of labor in patients with previous cesarean delivery. Am J Obstet Gynecol. 2005;192(5):1423-1426. [pmid: 15902126].
127 Gyamfi C, Juhasz G, Gyamfi P, Stone JL. Increased success of trial of labor after previous vaginal birth after cesarean. Obstet Gynecol. 2004;104(4):715-719. [pmid: 15458891].
128 Hashima JN, Guise J-M. Vaginal birth after cesarean: a prenatal scoring tool. Am J Obstet Gynecol. 2007;196(5):e22-23. [pmid: 17466668].
129 Hollard AL, Wing DA, Chung JH, et al. Ethnic disparity in the success of vaginal birth after cesarean delivery. J Matern Fetal Neonatal Med. 2006;19(8):483-487. [pmid: 16966113].
130 Horenstein JM, Eglinton GS, Tahilramaney MP, Boucher M, Phelan JP. Oxytocin use during a trial of labor in patients with previous cesarean section. J Reprod Med. 1984;29(1):26-30. [pmid: 6708016].
131 Horenstein JM, Phelan JP. Previous cesarean section: the risks and benefits of oxytocin usage in a trial of labor. Am J Obstet Gynecol. 1985;151(5):564-569. [pmid: 3976755].
132 Hoskins IA, Gomez JL. Correlation between maximum cervical dilatation at cesarean delivery and subsequent vaginal birth after cesarean delivery. Obstet Gynecol. 1997;89(4):591-593. [pmid: 9083318].
133 Huang WH, Nakashima DK, Rumney PJ, Keegan KA Jr, Chan K. Interdelivery interval and the success of vaginal birth after cesarean delivery. Obstet Gynecol. 2002;99(1):41-44. [pmid: 11777508].
134 Johnson C, Oriol N, Flood K. Trial of labor: a study of 110 patients. J Clin Anesth. 1991;3(3):216-218. discussion 214–215. [pmid: 1878234].
135 Juhasz G, Gyamfi C, Gyamfi P, Tocce K, Stone JL. Effect of body mass index and excessive weight gain on success of vaginal birth after cesarean delivery. Obstet Gynecol. 2005;106(4):741-746. [pmid: 16199630].
136 Learman LA, Evertson LR, Shiboski S. Predictors of repeat cesarean delivery after trial of labor: do any exist?. J Am Coll Surg. 1996;182(3):257-262. [pmid: 8603247].
137 Nguyen TV, Dinh TV, Suresh MS, Kinch RA, Anderson GD. Vaginal birth after cesarean section at the University of Texas. J Reprod Med. 1992;37(10):880-882. [pmid: 1479573].
138 Ouzounian JG, Miller DA, Paul RH. Amnioinfusion in women with previous cesarean births: a preliminary report. Am J Obstet Gynecol. 1996;174(2):783-786. [pmid: 8623822].
139 Pathadey SD, Van Woerden HC, Jenkinson SD. Induction of labour after a previous caesarean section: a retrospective study in a district general hospital. J Obstet Gynaecol. 2005;25(7):662-665. [pmid: 16263539].
140 Raynor BD. The experience with vaginal birth after cesarean delivery in a small rural community practice. Am J Obstet Gynecol. 1993;168(1 Pt 1):60-62. [pmid: 8420350].
141 Sakala EP, Kaye S, Murray RD, Munson LJ. Oxytocin use after previous cesarean: why a higher rate of failed labor trial?. Obstet Gynecol. 1990;75(3 Pt 1):356-359. [pmid: 2304707].
142 Vinueza CA, Chauhan SP, Barker L, Hendrix NW, Scardo JA. Predicting the success of a trial of labor with a simple scoring system. J Reprod Med. 2000;45(4):332-336. [pmid: 10804491].
143 Weinstein D, Benshushan A, Tanos V, Zilberstein R, Rojansky N. Predictive score for vaginal birth after cesarean section. Am J Obstet Gynecol. 1996;174(1 Pt 1):192-198. [pmid: 8572005].
144 Yetman TJ, Nolan TE. Vaginal birth aftercesarean section: a reappraisal of risk. Am J Obstet Gynecol. 1989;161(5):1119-1123. [pmid: 2486193].
145 Yogev Y, Ben-Haroush A, Lahav E, Horowitz E, Hod M, Kaplan B. Induction of labor with prostaglandin E2 in women with previous cesarean section and unfavorable cervix. Eur J Obstet Gynecol Reprod Biol. 2004;116(2):173-176. [pmid: 15358459].
146 Zelop CM, Shipp TD, Cohen A, Repke JT, Lieberman E. Trial of labor after 40 weeks’gestation in women with prior cesarean. Obstet Gynecol. 2001;97(3):391-393. [pmid: 11239643].
147 Agnew G, Turner MJ. Vaginal prostaglandin gel to induce labour in women with one previous caesarean section. J Obstet Gynaecol. 2009;29(3):209-211. [pmid: 19358026].
148 Ben-Aroya Z, Hallak M, Segal D, Friger M, Katz M, Mazor M. Ripening of the uterine cervix in a post-cesarean parturient: prostaglandin E2 versus Foley catheter. J Matern Fetal Neonatal Med. 2002;12(1):42-45. [pmid: 12422908].
149 Blanco JD, Collins M, Willis D, Prien S. Prostaglandin E2 gel induction of patients with a prior low transverse cesarean section. Am J Perinatol. 1992;9(2):80-83. [pmid: 1590872].
150 Bujold E, Blackwell SC, Gauthier RJ. Cervical ripening with transcervical foley catheter and the risk of uterine rupture. Obstet Gynecol. 2004;103(1):18-23. [pmid: 14704239].
151 Chilaka VN, Cole MY, Habayeb OMH, Konje JC. Risk of uterine rupture following induction of labour in women with a previous caesarean section in a large UK teaching hospital. J Obstet Gynaecol. 2004;24(3):264-265. [pmid: 15203621].
152 Del Valle GO, Adair CD, Sanchez-Ramos L, Gaudier FL, McDyer DC, Delke I. Cervical ripening in women with previous cesarean deliveries. Int J Gynaecol Obstet. 1994;47(1):17-21. [pmid: 7813746].
153 Flamm BL, Anton D, Goings JR, Newman J. Prostaglandin E2 for cervical ripening: a multicenter study of patients with prior cesarean delivery. Am J Perinatol. 1997;14(3):157-160. [pmid: 9259919].
154 Gibson DH. Vaginal delivery after caesarean section in primigravidae. Ir J Med Sci. 1988;157(9):290-292. [pmid: 3235309].
155 Goldberger SB, Rosen DJ, Michaeli G, Markov S, Ben-Nun I, Fejgin MD. The use of PGE2 for induction of labor in parturients with a previous cesarean section scar. Acta Obstet Gynecol Scand. 1989;68(6):523-526. [pmid: 2520807].
156 Grobman WA, Gilbert S, Landon MB, et al. Outcomes of induction of labor after one prior cesarean. Obstet Gynecol. 2007;109(2 Pt 1):262-269. [pmid: 17267822].
157 Kayani SI, Alfirevic Z. Uterine rupture after induction of labour in women with previous caesarean section. BJOG. 2005;112(4):451-455. [pmid: 15777443].
158 Meehan FP, Burke G. Trial of labour following prior section; a 5 year prospective study (1982–1987). Eur J Obstet Gynecol Reprod Biol. 1989;31(2):109-117. [pmid: 2759320].
159 Norman M, Ekman G. Preinductive cervical ripening with prostaglandin E2 in women with one previous cesarean section. Acta Obstet Gynecol Scand. 1992;71(5):351-355. [pmid: 1326210].
160 Rageth JC, Juzi C, Grossenbacher H. Delivery after previous cesarean: a risk evaluation. Swiss Working Group of Obstetric and Gynecologic Institutions. Obstet Gynecol. 1999;93(3):332-337. [pmid: 10074973].
161 Rayburn WF, Gittens LN, Lucas MJ, Gall SA, Martin ME. Weekly administration of prostaglandin E2 gel compared with expectant management in women with previous cesareans. Prepidil Gel Study Group. Obstet Gynecol. 1999;94(2):250-254. [pmid: 10432137].
162 Silver RK, Gibbs RS. Predictors of vaginal delivery in patients with a previous cesarean section, who require oxytocin. Am J Obstet Gynecol. 1987;156(1):57-60. [pmid: 3799769].
163 Umeadi UP, Mehta R, Thomas S. Delivery outcome after induction of labour using prostaglandin in women with one previous caesarean section. J Obstet Gynaecol. 2007;27(8):810-811. [pmid: 18097900].
164 Zelop CM, Shipp TD, Repke JT, Cohen A, Caughey AB, Lieberman E. Uterine rupture during induced or augmented labor in gravid women with one prior cesarean delivery. Am J Obstet Gynecol. 1999;181(4):882-886. [pmid: 10521747].
165 Ardiet E, Subtil D, Puech F. Cervical ripening with dinoprostone gel and previous cesarean delivery. Int J Gynaecol Obstet. 2005;91(3):260-261. [pmid: 16229846].
166 Cnattingius R, Hoglund B, Kieler H. Emergency cesarean delivery in induction of labor: an evaluation of risk factors. Acta Obstet Gynecol Scand. 2005;84(5):456-462. [pmid: 15842210].
167 Flamm BL, Geiger AM. Vaginal birth after cesarean delivery: an admission scoring system. Obstet Gynecol. 1997;90(6):907-910. [pmid: 9397100].
168 Locatelli A, Ghidini A, Ciriello E, Incerti M, Bonardi C, Regalia AL. Induction of labor: comparison of a cohort with uterine scar from previous cesarean section vs. a cohort with intact uterus. J Matern Fetal Neonatal Med. 2006;19(8):471-475. [pmid: 16966111].
169 Ravasia DJ, Wood SL, Pollard JK. Uterine rupture during induced trial of labor among women with previous cesarean delivery. Am J Obstet Gynecol. 2000;183(5):1176-1179. [pmid: 11084562].
170 Taylor DR, Doughty AS, Kaufman H, Yang L, Iannucci TA. Uterine rupture with the use of PGE2 vaginal inserts for labor induction in women with previous cesarean sections. J Reprod Med. 2002;47(7):549-554. [pmid: 12170531].
171 Katz VL, Farmer RM, Dean CA, Carpenter ME. Use of misoprostol for cervical ripening. South Med J. 2000;93(9):881-884. [pmid: 11005347].
172 Choy-Hee L, Raynor BD. Misoprostol induction of labor among women with a history of cesarean delivery. Am J Obstet Gynecol. 2001;184(6):1115-1117. [pmid: 11349173].
173 Lelaidier C, Baton C, Benifla JL, Fernandez H, Bourget P, Frydman R. Mifepristone for labour induction after previous caesarean section. Br J Obstet Gynaecol. 1994;101(6):501-503. [pmid: 8018638].
174 Goetzl L, Shipp TD, Cohen A, Zelop CM, Repke JT, Lieberman E. Oxytocin dose and the risk of uterine rupture in trial of labor after cesarean. Obstet Gynecol. 2001;97(3):381-384. [pmid: 11239641].
175 Paul RH, Phelan JP, Yeh SY. Trial of labor in the patient with a prior cesarean birth. Am J Obstet Gynecol. 1985;151(3):297-304. [pmid: 3970097].
176 Taylor AVG, Sellers S, Ah-Moye M, MacKenzie IZ. A prospective random allocation trial to compare vaginal prostaglandin E2 with intravenous oxytocin for labour induction in women previously delivered by caesarean section. J Obstet Gynecol. 1993;13(5):333-336.
177 Hannah ME, Ohlsson A, Farine D, et al. Induction of labor compared with expectant management for prelabor rupture of the membranes at term. N Engl J Med. 1996;334(16):1005-1010. [pmid: 8598837].
178 Peleg D, Hannah ME, Hodnett ED, Foster GA, Willan AR, Farine D. Predictors of cesarean delivery after prelabor rupture of membranes at term. Obstet Gynecol. 1999;93(6):1031-1035. [pmid: 10362176].
179 Khotaba S, Volfson M, Tarazova L, et al. Induction of labor in women with previous cesarean section using the double balloon device. Acta Obstet Gynecol Scand. 2001;80(11):1041-1042. [pmid: 11703204].
180 Segal S, Gemer O, Zohav E, Siani M, Sassoon E. Evaluation of breast stimulation for induction of labor in women with a prior cesarean section and in grandmultiparas. Acta Obstet Gynecol Scand. 1995;74(1):40-41. [pmid: 7856430].
181 Grobman WA, Lai Y, Landon MB, et al. Development of a nomogram for prediction of vaginal birth after cesarean delivery. Obstet Gynecol. 2007;109(4):806-812. [pmid: 17400840].
182 Landon MB, Leindecker S, Spong CY, et al. The MFMU Cesarean Registry: factors affecting the success of trial of labor after previous cesarean delivery. Am J Obstet Gynecol. 2005;193(3 Pt 2):1016-1023. [pmid: 16157104].
183 Bujold E, Blackwell SC, Hendler I, Berman S, Sorokin Y, Gauthier RJ. Modified Bishop's score and induction of labor in patients with a previous cesarean delivery. Am J Obstet Gynecol. 2004;191(5):1644-1648. [pmid: 15547536].
184 Gonen R, Tamir A, Degani S, Ohel G. Variables associated with successful vaginal birth after one cesarean section: a proposed vaginal birth after cesarean section score. Am J Perinatol. 2004;21(8):447-453. [pmid: 15580540].
185 King DE, Lahiri K. Socioeconomic factors and the odds of vaginal birth after cesarean delivery. JAMA. 1994;272(7):524-529. [pmid: 8046806].
186 Shipp TD, Zelop CM, Repke JT, Cohen A, Caughey AB, Lieberman E. Labor after previous cesarean: influence of prior indication and parity. Obstet Gynecol. 2000;95(6 Pt 1):913-916. [pmid: 10831991].
187 Srinivas SK, Stamilio DM, Stevens EJ, Odibo AO, Peipert JF, Macones GA. Predicting failure of a vaginal birth attempt after cesarean delivery. Obstet Gynecol. 2007;109(4):800-805. [pmid: 17400839].
188 Zelop CM, Shipp TD, Repke JT, Cohen A, Lieberman E. Outcomes of trial of labor following previous cesarean delivery among women with fetuses weighing >4000 g. Am J Obstet Gynecol. 2001;185(4):903-905. [pmid: 11641675].
189 Macones GA, Hausman N, Edelstein R, Stamilio DM, Marder SJ. Predicting outcomes of trials of labor in women attempting vaginal birth after cesarean delivery: a comparison of multivariate methods with neural networks. Am J Obstet Gynecol. 2001;184(3):409-413. [pmid: 11228495].
190 Cahill AG, Stamilio DM, Odibo AO, Peipert J, Stevens E, Macones GA. Racial disparity in the success and complications of vaginal birth after cesarean delivery. Obstet Gynecol. 2008;111(3):654-658. [pmid: 18310368].
191 Caughey AB, Shipp TD, Repke JT, Zelop C, Cohen A, Lieherman E. Trial of labor after cesarean delivery: the effect of previous vaginal delivery. Am J Obstet Gynecol. 1998;179(4):938-941. [pmid: 9790374].
192 Mercer BM, Gilbert S, Landon MB, et al. Labor outcomes with increasing number of prior vaginal births after cesarean delivery. Obstet Gynecol. 2008;111(2 Pt 1):285-291. [pmid: 18238964].
193 Simon R, Altman D. Statistical aspects of prognostic factor studies in oncology. Br J Cancer. 1994;69:979-985. [pmid: 8198989].
194 Hashima JN, Eden KB, Osterweil P, Nygren P, Guise J-M. Predicting vaginal birth after cesarean delivery: a review of prognostic factors and screening tools. Am J Obstet Gynecol. 2004;190(2):547-555. [pmid: 14981405].
195 Altman D. Prognosis and prognostic research: validating prognostic model. BMJ. 2009;338:1430-1435.
196 Alamia VJ, Meyer BA, Selioutski O, Vohra N. Can a VBAC scoring system predict uterine rupture in patients attempting a trial of labor?. Paper presented at: ACOG 47th Annual Clinical Meeting. May 19, 1999.
197 Macones GA. The utility of clinical tests of eligibility for a trial of labour following a caesarean section: a decision analysis. Br J Obstet Gynaecol. 1999;106(7):642-646. [pmid: 10428518].
198 Hoyert DL, Hoyert DL. Maternal mortality and related concepts. Vital Health Stat [3]. 2007;(33):1-13.
199 Kung HC, Hoyert DL, Xu J, et al. Deaths: final data for 2005. Natl Vital Stat Rep. 2008;56(10):1-120. [pmid: 18512336].
200 Minino AM, Heron MP, Murphy SL, et al. Deaths: final data for 2004. Natl Vital Stat Rep. 2007;55(19):1-119. [pmid: 17867520].
201 Eglinton GS, Phelan JP, Yeh S, Diaz FP, Wallace TM, Paul RH. Outcome of a trial of labor after prior cesarean delivery. J Reprod Med. 1984;29(1):3-8. [pmid: 6708017].
202 Eriksen NL, Buttino L Jr. Vaginal birth after cesarean: a comparison of maternal and neonatal morbidity to elective repeat cesarean section. Am J Perinatol. 1989;6(4):375-379. [pmid: 2789534].
203 Martin JN Jr, Harris BA Jr, Huddleston JF, et al. Vaginal delivery following previous cesarean birth. Am J Obstet Gynecol. 1983;146(3):255-263. [pmid: 6859134].
204 Spong CY, Landon MB, Gilbert S, et al. Risk of uterine rupture and adverse perinatal outcome at term after cesarean delivery. Obstet Gynecol. 2007;110(4):801-807. [pmid: 17906012].
205 Cahill AG, Stamilio DM, Odibo AO, et al. Is vaginal birth after cesarean (VBAC) or elective repeat cesarean safer in women with a prior vaginal delivery?. Am J Obstet Gynecol. 2006;195(4):1143-1147. [pmid: 16846571].
206 Cowan RK, Kinch RA, Ellis B, Anderson R. Trial of labor following cesarean delivery. Obstet Gynecol. 1994;83(6):933-936. [pmid: 8190434].
207 Flamm BL, Lim OW, Jones C, Fallon D, Newman LA, Mantis JK. Vaginal birth after cesarean section: results of a multicenter study. Am J Obstet Gynecol. 1988;158(5):1079-1084. [pmid: 3369487].
208 Flamm BL, Newman LA, Thomas SJ, Fallon D, Yoshida MM. Vaginal birth after cesarean delivery: results of a 5-year multicenter collaborative study. Obstet Gynecol. 1990;76(5 Pt 1):750-754. [pmid: 2216218].
209 Caughey AB. Maternal mortality: more than just anecdotal evidence.[comment]. J Perinatol. 2007;27(10):595-596. [pmid: 17898791].
210 Weiss JB, Nannini A, Fogerty S. From the Centers for Disease Control and Prevention. Use of hospital discharge data to monitor uterine rupture--Massachusetts, 1990–1997. JAMA. 2000;283(16):2098-2100. [pmid: 10791492].
211 Blanchette HA, Nayak S, Erasmus S. Comparison of the safety and efficacy of intravaginal misoprostol (prostaglandin E1) with those of dinoprostone (prostaglandin E2) for cervical ripening and induction of labor in a community hospital. Am J Obstet Gynecol. 1999;180(6 Pt 1):1551-1559. [pmid: 10368503].
212 Strong TH Jr, Vega JS, O’Shaughnessy MJ, Feldman DB, Koemptgen JG. Amnioinfusion among women attempting vaginal birth after cesarean delivery. Obstet Gynecol. 1992;79(5 Pt 1):673-674. [pmid: 1565348].
213 Bujold E, Bujold C, Hamilton EF, Harel F, Gauthier RJ. The impact of a single-layer or double-layer closure on uterine rupture. Am J Obstet Gynecol. 2002;186(6):1326-1330. [pmid: 12066117].
214 Bujold E, Gauthier RJ. Neonatal morbidity associated with uterine rupture: what are the risk factors?. Am J Obstet Gynecol. 2002;186(2):311-314. [pmid: 11854656].
215 Grobman WA, Lai Y, Landon MB, et al. Prediction of uterine rupture associated with attempted vaginal birth after cesarean delivery. Am J Obstet Gynecol. 2008;199(1):30.e31-35. [pmid: 18439555].
216 Kieser KE, Baskett TF. A 10-year population-based study of uterine rupture. Obstet Gynecol. 2002;100(4):749-753. [pmid: 12383544].
217 Sciscione AC, Landon MB, Leveno KJ, et al. Previous preterm cesarean delivery and risk of subsequent uterine rupture. Obstet Gynecol. 2008;111(3):648-653. [pmid: 18310367].
218 Shipp TD, Zelop C, Cohen A, Repke JT, Lieberman E. Post-cesarean delivery fever and uterine rupture in a subsequent trial of labor. Obstet Gynecol. 2003;101(1):136-139. [pmid: 12517658].
219 Shipp TD, Zelop C, Lieberman E. Assessment of the rate of uterine rupture at the first prenatal visit: a preliminary evaluation. J Matern Fetal Neonatal Med. 2008;21(2):129-133. [pmid: 18240082].
220 Grobman WA, Gersnoviez R, Landon MB, et al. Pregnancy outcomes for women with placenta previa in relation to the number of prior cesarean deliveries. Obstet Gynecol. 2007;110(6):1249-1255. [pmid: 18055717].
221 Landon MB, Hauth JC, Leveno KJ, et al. Maternal and perinatal outcomes associated with a trial of labor after prior cesarean delivery. N Engl J Med. 2004;351(25):2581-2589. [pmid: 15598960].
222 Asakura H, Nakai A, Ishikawa G, Suzuki S, Araki T. Prediction of uterine dehiscence by measuring lower uterine segment thickness prior to the onset of labor: evaluation by transvaginal ultrasonography. J Nippon Med Sch. 2000;67(5):352-356. [pmid: 11031364].
223 Bujold E, Jastrow N, Simoneau J, Brunet S, Gauthier R. Prediction of complete uterine rupture by sonographic evaluation of the lower uterine segment. Am J Obstet Gynecol. 2009;201(3):320-322. [pmid: 19733288].
224 Cheung VYT. Sonographic measurement of the lower uterine segment thickness in women with previous caesarean section. J Obstet Gynaecol Can. 2005;27(7):674-681. [pmid: 16100622].
225 Gotoh H, Masuzaki H, Yoshida A, Yoshimura S, Miyamura T, Ishimaru T. Predicting incomplete uterine rupture with vaginal sonography during the late second trimester in women with prior cesarean. Obstet Gynecol. 2000;95(4):596-600. [pmid: 10725496].
226 Michaels WH, Thompson HO, Boutt A, Schreiber FR, Michaels SL, Karo J. Ultrasound diagnosis of defects in the scarred lower uterine segment during pregnancy. Obstet Gynecol. 1988;71(1):112-120. [pmid: 3275907].
227 Petrikovsky BM. Endoscopic assessment of the integrity of the postcesarean uterine wall before a trial of labor. Transcervical Endoscopy Registry. J Reprod Med. 1994;39(6):464-466. [pmid: 7932401].
228 Sibony O, Alran S, Oury J-F. Vaginal birth after cesarean section: X-ray pelvimetry at term is informative. J Perinat Med. 2006;34(3):212-215. [pmid: 16602841].
229 Tanik A, Ustun C, Cil E, Arslan A. Sonographic evaluation of the wall thickness of the lower uterine segment in patients with previous cesarean section. J Clin Ultrasound. 1996;24(7):355-357. [pmid: 8873858].
230 Macones GA, Cahill AG, Stamilio DM, Odibo A, Peipert J, Stevens EJ. Can uterine rupture in patients attempting vaginal birth after cesarean delivery be predicted?. Am J Obstet Gynecol. 2006;195(4):1148-1152. [pmid: 17000247].
231 Bujold E, Mehta SH, Bujold C, Gauthier RJ. Interdelivery interval and uterine rupture. Am J Obstet Gynecol. 2002;187(5):1199-1202. [pmid: 12439503].
232 Leung AS, Farmer RM, Leung EK, Medearis AL, Paul RH. Risk factors associated with uterine rupture during trial of labor after cesarean delivery: a case-control study. Am J Obstet Gynecol. 1993;168(5):1358-1363. [pmid: 8498412].
233 Leung AS, Leung EK, Paul RH. Uterine rupture after previous cesarean delivery: maternal and fetal consequences. Am J Obstet Gynecol. 1993;169(4):945-950. [pmid: 8238154].
234 Hibbard JU, Ismail MA, Wang Y, Te C, Karrison T. Failed vaginal birth after a cesarean section: how risky is it? I. Maternal morbidity. Am J Obstet Gynecol. 2001;184(7):1365-1371. discussion 1371–1363. [pmid: 11408854].
235 Juntunen K, Makarainen L, Kirkinen P. Outcome after a high number (4–10) of repeated caesarean sections. BJOG. 2004;111(6):561-563. [pmid: 15198783].
236 Silver RM, Landon MB, Rouse DJ, et al. Maternal morbidity associated with multiple repeat cesarean deliveries. Obstet Gynecol. 2006;107(6):1226-1232. [pmid: 16738145].
237 Stafford I, Dildy GA, Clark SL, Belfort MA. Visually estimated and calculated blood loss in vaginal and cesarean delivery. Am J Obstet Gynecol. 2008;199(5):e1-7.
238 Toledo P, McCarthy RJ, Hewlett BJ, Fitzgerald PC, Wong CA. The accuracy of blood loss estimation after simulated vaginal delivery. Anesth Analg. 2007;105(6):1736-1740. [pmid: 18042876].
239 Al-Zirqi I, Vangen S, Forsen L, Stray-Pedersen B. Effects of onset of labor and mode of delivery on severe postpartum hemorrhage. Am J Obstet Gynecol. 2009;201(3):273.e271-279. [pmid: 19733277].
240 Chauhan SP, Magann EF, Carroll CS, Barrilleaux PS, Scardo JA, Martin JN Jr. Mode of delivery for the morbidly obese with prior cesarean delivery: vaginal versus repeat cesarean section. Am J Obstet Gynecol. 2001;185(2):349-354. [pmid: 11518890].
241 Upadhyaya CD, Upadhyaya DM, Carlan SJ. Vaginal birth after cesarean delivery in a small rural community with a solo practice. Am J Perinatol. 2003;20(2):63-67. [pmid: 12660910].
242 Hansell RS, McMurray KB, Huey GR. Vaginal birth after two or more cesarean sections: a five-year experience. Birth. 1990;17(3):146-150. discussion 150–141. [pmid: 2222640].
243 Granovsky-Grisaru S, Shaya M, Diamant YZ. The management of labor in women with more than one uterine scar: is a repeat cesarean section really the only “safe” option?. J Perinat Med. 1994;22(1):13-17. [pmid: 8035290].
244 Phipps MG, Watabe B, Clemons JL, Weitzen S, Myers DL. Risk factors for bladder injury during cesarean delivery. Obstet Gynecol. 2005;105(1):156-160. [pmid: 15625157].
245 Makoha FW, Fathuddien MA, Felimban HM. Choice of abdominal incision and risk of trauma to the urinary bladder and bowel in multiple cesarean sections. Eur J Obstet Gynecol Reprod Biol. 2006;125(1):50-53. [pmid: 16029923].
246 Richter HE, Brumfield CG, Cliver SP, Burgio KL, Neely CL, Varner RE. Risk factors associated with anal sphincter tear: a comparison of primiparous patients, vaginal births after cesarean deliveries, and patients with previous vaginal delivery. Am J Obstet Gynecol. 2002;187(5):1194-1198. [pmid: 12439502].
247 Hemminki E, Shelley J, Gissler M. Mode of delivery and problems in subsequent births: a register-based study from Finland. Am J Obstet Gynecol. 2005;193(1):169-177. [pmid: 16021075].
248 Hershkowitz R, Fraser D, Mazor M, Leiberman JR. One or multiple previous cesarean sections are associated with similar increased frequency of placenta previa. Eur J Obstet Gynecol Reprod Biol. 1995;62(2):185-188. [pmid: 8582493].
249 Nisenblat V, Barak S, Griness OB, Degani S, Ohel G, Gonen R. Maternal complications associated with multiple cesarean deliveries. Obstet Gynecol. 2006;108(1):21-26. [pmid: 16816051].
250 Odibo AO, Cahill AG, Stamilio DM, Stevens EJ, Peipert JF, Macones GA. Predicting placental abruption and previa in women with a previous cesarean delivery. Am J Perinatol. 2007;24(5):299-305. [pmid: 17514600].
251 Rouse DJ, MacPherson C, Landon M, et al. Blood transfusion and cesarean delivery.[erratum appears in Obstet Gynecol. 2006 Dec;108(6):1556]. Obstet Gynecol. 2006;108(4):891-897. [pmid: 17012451].
252 Bodelon C, Bernabe-Ortiz A, Schiff MA, Reed SD. Factors associated with peripartum hysterectomy. Obstet Gynecol. 2009;114(1):115-123. [pmid: 19546767].
253 Gilliam M, Rosenberg D, Davis F. The likelihood of placenta previa with greater number of cesarean deliveries and higher parity. Obstet Gynecol. 2002;99(6):976-980. [pmid: 12052584].
254 Knight M, Kurinczuk JJ, Spark P, Brocklehurst P. United Kingdom Obstetric Surveillance System Steering C. Cesarean delivery and peripartum hysterectomy. Obstet Gynecol. 2008;111(1):97-105. [pmid: 18165397].
255 Laughon SK, Wolfe HM, Visco AG. Prior cesarean and the risk for placenta previa on second-trimester ultrasonography. Obstet Gynecol. 2005;105(5 Pt 1):962-965. [pmid: 15863531].
256 Wu S, Kocherginsky M, Hibbard JU. Abnormal placentation: twenty-year analysis. Am J Obstet Gynecol. 2005;192(5):1458-1461. [pmid: 15902137].
257 Lynch CM, Kearney R, Turner MJ. Maternal morbidity after elective repeat caesarean section after two or more previous procedures. Eur J Obstet Gynecol Reprod Biol. 2003;106(1):10-13. [pmid: 12475574].
258 Miller DA, Chollet JA, Goodwin TM. Clinical risk factors for placenta previa-placenta accreta. Am J Obstet Gynecol. 1997;177(1):210-214. [pmid: 9240608].
259 Olive EC, Roberts CL, Algert CS, Morris JM. Placenta praevia: maternal morbidity and place of birth. Aust N Z J Obstet Gynaecol. 2005;45(6):499-504. [pmid: 16401216].
260 Zelop CM, Harlow BL, Frigoletto FD Jr, Safon LE, Saltzman DH. Emergency peripartum hysterectomy. Am J Obstet Gynecol. 1993;168(5):1443-1448. [pmid: 8498425].
261 Taylor VM, Kramer MD, Vaughan TL, Peacock S. Placenta previa and prior cesarean delivery: how strong is the association?. Obstet Gynecol. 1994;84(1):55-57. [pmid: 8008323].
262 Clark SL, Koonings PP, Phelan JP. Placenta previa/accreta and prior cesarean section. Obstet Gynecol. 1985;66(1):89-92. [pmid: 4011075].
263 Macones GA, Cahill A, Pare E, et al. Obstetric outcomes in women with two prior cesarean deliveries: is vaginal birth after cesarean delivery a viable option?. Am J Obstet Gynecol. 2005;192(4):1223-1228. discussion 1228–1229. [pmid: 15846208].
264 Grubb DK, Kjos SL, Paul RH. Latent labor with an unknown uterine scar. Obstet Gynecol. 1996;88(3):351-355. [pmid: 8752238].
265 Lin C, Raynor BD. Risk of uterine rupture in labor induction of patients with prior cesarean section: an inner city hospital experience. Am J Obstet Gynecol. 2004;190(5):1476-1478. [pmid: 15167874].
266 Tahilramaney MP, Boucher M, Eglinton GS, Beall M, Phelan JP. Previous cesarean section and trial of labor. Factors related to uterine dehiscence. J Reprod Med. 1984;29(1):17-21. [pmid: 6708014].
267 Bujold E, Hammoud A, Schild C, Krapp M, Baumann P. The role of maternal body mass index in outcomes of vaginal births after cesarean. Am J Obstet Gynecol. 2005;193(4):1517-1521. [pmid: 16202749].
268 Carroll CS Sr., Magann EF, Chauhan SP, Klauser CK, Morrison JC. Vaginal birth after cesarean section versus elective repeat cesarean delivery: Weight-based outcomes. Am J Obstet Gynecol. 2003;188(6):1516-1520. discussion 1520–1512. [pmid: 12824987].
269 Edwards RK, Harnsberger DS, Johnson IM, Treloar RW, Cruz AC. Deciding on route of delivery for obese women with a prior cesarean delivery. Am J Obstet Gynecol. 2003;189(2):385-389. discussion 389–390. [pmid: 14520202].
270 Hamel KJ. Incidence of adhesions at repeat cesarean delivery. Am J Obstet Gynecol. 2007;196(5):e31-32. [pmid: 17466672].
271 Ogunyemi D, Hullett S, Leeper J, Risk A. Prepregnancy body mass index, weight gain during pregnancy, and perinatal outcome in a rural black population. J Matern Fetal Med. 1998;7(4):190-193. [pmid: 9730485].
272 Boukerrou M, Lambaudie E, Collinet P, Crepin G, Cosson M. A history of cesareans is a risk factor in vaginal hysterectomies. Acta Obstet Gynecol Scand. 2003;82(12):1135-1139. [pmid: 14616260].
273 David-Montefiore E, Rouzier R, Chapron C, Darai E. Collegiale d’Obstetrique et Gynecologie de Paris-Ile de F. Surgical routes and complications of hysterectomy for benign disorders: a prospective observational study in French university hospitals. Hum Reprod. 2007;22(1):260-265. [pmid: 16950826].
274 Myers SA, Bennett TL. Incidence of significant adhesions at repeat cesarean section and the relationship to method of prior peritoneal closure. J Reprod Med. 2005;50(9):659-662. [pmid: 16363753].
275 Tulandi T, Agdi M, Zarei A, Miner L, Sikirica V. Adhesion development and morbidity after repeat cesarean delivery. Am J Obstet Gynecol. 2009;201(1):56.e51-56. [pmid: 19576375].
276 Al-Took S. Adhesion-related small-bowel obstruction after gynecologic operations. Am J Obstet Gynecol. 1999;180(2):313-315. [pmid: 9988792].
277 Bahl R, Strachan B, Murphy DJ. Outcome of subsequent pregnancy three years after previous operative delivery in the second stage of labour: cohort study. BMJ. 2004;328(7435):311. [pmid: 14724128].
278 Murphy DJ, Stirrat GM, Heron J, Team AS. The relationship between Caesarean section and subfertility in a population-based sample of 14 541 pregnancies. Hum Reprod. 2002;17(7):1914-1917. [pmid: 12093860].
279 Cramer DW, Xu H, Harlow BL. Does “incessant“ ovulation increase risk for early menopause?. Am J Obstet Gynecol. 1995;172(2 Pt 1):568-573. [pmid: 7856687].
280 Bahtiyar MO, Julien S, Robinson JN, et al. Prior cesarean delivery is not associated with an increased risk of stillbirth in a subsequent pregnancy: analysis of U.S. perinatal mortality data, 1995–1997. Am J Obstet Gynecol. 2006;195(5):1373-1378. [pmid: 16677588].
281 Smith GCS, Pell JP, Dobbie R. Caesarean section and risk of unexplained stillbirth in subsequent pregnancy. Lancet. 2003;362(9398):1779-1784. [pmid: 14654315].
282 Bujold E, Francoeur D. Neonatal morbidity and decision-delivery interval in patients with uterine rupture.[comment]. J Obstet Gynaecol Can. 2005;27(7):671-673. author reply 673. [pmid: 16100621].
283 Paterson CM, Saunders NJ. Mode of delivery after one caesarean section: audit of current practice in a health region. BMJ. 1991;303(6806):818-821. [pmid: 1932972].
284 Richardson BS, Czikk MJ, daSilva O, Natale R. The impact of labor at term on measures of neonatal outcome. Am J Obstet Gynecol. 2005;192(1):219-226. [pmid: 15672028].
285 The World Factbook 2008. Washington, D. C. Central Intelligence Agency. 2008.
286 Kamath BD, Todd JK, Glazner JE, Lezotte D, Lynch AM. Neonatal outcomes after elective cesarean delivery. Obstet Gynecol. 2009;113(6):1231-1238. [pmid: 19461417].
287 Warren J, Anderson JM. Respiratory Distress in the Term Infant: A Review. [in press]. Pediatrics. 2009.
288 Hankin G, Speer M. Defining the pathogenesis and pathophysiology of neonatal encephalopathy and cerebral palsy. Obstet Gynecol. 2003;102(3):628-636. [pmid: 12962954].
289 Committee on Fetus and Newborn. Levels of Neonatal Care. Pediatrics. 2004;114(5):1341-1347. [pmid: 15520119].
290 Brown P. How to formulate research recommendations. BMJ. 2006;333(14):804-806. [pmid: 17038740].
291 Ecker JL. Once a pregnancy, always a cesarean? Rationale and feasibility of a randomized controlled trial. Am J Obstet Gynecol. 2004;190(2):314-318. [pmid: 14981367].