# Discussion

Each year 1.5 million childbearing women have cesarean deliveries, and this population continues to increase. While cesarean deliveries represent a third of all births, they account for almost half of the childbirth-related expenses of hospitalization at $7.8 billion annually.1 Therefore, the appropriate and safe use of cesarean and vaginal birth after cesarean (VBAC) is not only an individual patient- and provider-level concern but it is also a national health policy concern.

Prior cesarean delivery is the most common indication for cesarean, accounting for over a third (534,180,000) of cesarean deliveries, almost twice the rate of any other indication. Thus, an important contributor to the increase in cesareans is the rapid decline in VBACs witnessed over the last decade. In 2007, only 8.7 percent of childbirth-related hospitalizations among women with a previous cesarean delivery were VBACs, suggesting that over 90 percent of all women with a previous cesarean will deliver by planned or elective repeat cesarean delivery (ERCD).

One of the major findings of this report is that the best evidence suggests that VBAC is a reasonable and safe choice for the majority of women with prior cesarean. Moreover, the report raises concerns over the serious morbidity accruing from multiple cesareans, a result of the increased use of ERCD over VBAC. In addition to health outcomes, some relatively unexamined contextual factors relating to VBAC drive patient, provider, hospital, and policy decisionmaking. Regional-, hospital-, and individual-level liability have all been associated with increased cesarean delivery rates. Even a perception of increased risk for liability was reported to be associated with increased use of cesarean. Similarly, some data suggest that economic incentives appear to affect cesarean delivery rates. It is financially untenable for many rural hospitals to offer the 24-hour in-house availability that is suggested to allow VBAC as an option. Economic incentives may need to be changed to prioritize access to VBAC services. Patients and providers are influenced by the short- and long-term benefits and risks of route of delivery as well as family obligations, costs, societal norms, and regional availability of options. Although studies of VBAC are numerous, the numbers of studies providing high quality information on important clinical questions are limited.

The literature concerning trial of labor (TOL) and ERCD is flawed in several ways: imprecise measurement of outcomes (e.g., maternal infection, perinatal death), making it difficult to determine the portion of events directly attributable to route of delivery; lack of standards for terminology (e.g., no standard classification for severity of health consequences related to uterine rupture); and limited attention to comparability between groups (e.g., studies of ERCD in which it is unclear whether patients were eligible for TOL). Data on maternal and infant outcomes, of great interest to most patients, suffer from a lack of standardization of terminology and measurement. This is especially highlighted by the trends seen with studies reporting both hemorrhage and transfusion in TOL and ERCD. In studies where hemorrhage was reported as higher in one group, the transfusion rates were lower. Additionally, alternative interventions to transfusion, such as IV iron therapy, were not reported. Investigations into the neonatal effects of ERCD and VBAC suffer even greater problems of measurement, lack of standardization, and insufficient data. How, then, are these studies to be interpreted by the individual clinician, much less combined for guidance? Further complicating interpretation are both the unreported societal and monetary costs of intervention associated with these modes of delivery. This highlights a particular problem with the research in this area; the easiest outcomes to measure are not generally the outcomes most pertinent to the clinician or the patient.

Studies of VBAC versus ERCD have traditionally reported outcomes based upon actual route of delivery rather than intended route, leading to misclassification of patients who intend ERCD but go into labor prior to their cesarean or women who intend TOL but who are delivered by cesarean. A good demonstration of the complexity of this issue comes from the first National Institute of Child Health and Human Development Maternal-Fetal Medicine Units Network (MFMU) studies. The studies report on 45,988 women with singleton gestation and prior cesarean delivery at term. The original article by Landon published in 2004^221^ considered women who presented in labor at 4 cm or greater cervical dilation or anyone receiving oxytocin in the TOL group; and women who presented in early labor who subsequently underwent cesarean were excluded. Ultimately, 12,289 women (27 percent of population at term with prior cesarean delivery)--9,013 who had an indicated repeat cesarean delivery (IRCD) and 3,276 women who presented in early labor and subsequently delivered by cesarean delivery--were excluded from the analysis. Thus Landon’s analysis presented data for 33,699 women: 17,898 women classified as undergoing TOL and 15,801 undergoing an ERCD. Uterine rupture rates in these two groups were 124/17,898 (0.7 percent) in TOL versus 0/15,801 (0 percent) in ERCD. A subsequent analysis performed by Spong in 2007^204^ aimed to provide information that would be clinically useful to the clinician providing antepartum counseling for VBAC and classified patients quite differently. She broke the group into three main categories: TOL (15,323), ERCD (17,714, without medical indication), and IRCD (6,080). Ultimately, not only did she include 5,418 additional patients for a total of 39,117, but 2,575 women who were initially considered TOL in Landon’s study were now distributed to either IRCD or ERCD with labor. While this reclassification did not change the uterine rupture rate for the TOL group (0.74 percent in Spong204 versus 0.7 percent for Landon221), it substantially changed the uterine rupture rate among the ERCD group (without indication).

The design of most studies, including the largest and widely cited Spong study discussed above, render them unable to identify the ideal population - women who plan VBAC or plan RCD. The evidence from these studies is at best indirect and difficult to apply to a woman who plans for either option. These studies also lack data concerning important contextual factors such as whether and how hospital structure, setting, staffing, economics, and liability affect processes and outcomes. Each potential bias leaves clinicians and patients uncertain of the ramification for their decisionmaking and masks potential adverse effects of desiring one route of delivery but having another.

A longitudinal study design that begins after first cesarean and measures patient intent would allow measurement of outcomes, preferences, and adverse events throughout the entire spectrum of concepts presented in the analytic framework. Because issues of access and capacity to handle obstetric emergencies, such as uterine rupture, are likely to impact a woman’s ability to have the delivery she desires as well as the ultimate outcome of any emergency, a national study that could examine regional variation would be ideal.

Table 36 summarizes the strength of evidence and findings for all key questions reviewed in this report. Briefly, there is moderate evidence that women who have a TOL have a high probability of having a vaginal delivery (74 percent) which can be enhanced by maximizing favorable clinical conditions such as waiting for a favorable cervical examination if possible. Overall, maternal morbidity is reduced from TOL compared with ERCD. Of particular note is the significantly decreased risk of maternal mortality and the serious morbidity associated with multiple repeat cesareans. Overall--with the exception of perinatal, fetal, and neonatal mortality rates, which are significantly higher for TOL--the literature on neonatal outcomes are insufficient. Therefore, the inherent complexities of weighing maternal and infant risks remain a challenge for clinicians and patients.

Table 36 Summary of evidence for key questions

Key Question | Study Type* | GRADE of Evidence | Findings
Among women who attempt a trial of labor after prior cesarean, what is the vaginal delivery rate and the factors that influence it?
Individual Risk Factors | Cohorts | N/A | - In U.S. studies launched after 1996, less than half of women had a TOL.; - Most evidence of TOL and VBAC rates are from studies based in large tertiary care centers or teaching hospitals.; - While TOL rates reported in observational studies have dropped over time, VBAC rates have remained constant for the women who have a TOL.; - In studies based in the U.S., 74% of women who had a TOL delivered vaginally.
Predictive Tools | Cohorts | N/A | - All scored models provide reasonable ability to identify women who are good candidates for; - VBAC but none have discriminating ability to consistently identify women who are at risk for CD.
What are the short- and long-term benefits and harms to the mother of attempting trial of labor after prior cesarean versus elective repeat cesarean delivery, and what factors influence benefits and harms?
Maternal Death | Cohorts | High | - Overall, maternal death is a rare event with a rate of approximately 10/100,000 when all studies are combined; - Mortality appears to be increased with ERCD compared with TOL, however the difference is not statistically significant; - For both TOL and ERCD, a trend was seen of increased maternal mortality in studies including all gestational ages compared with term delivery limited studies
Uterine Rupture | Cohorts | Moderate (Low uterine segment thickness studies only) | - The rate of uterine rupture for all women with prior cesarean is very low 0.30% (3/1,000); - the risk of uterine rupture for women undergoing a TOL is 0.47% ten times higher than for women undergoing an ERCD 0.03%; - Overall, the risk of perinatal death in the event of a uterine rupture was 6.2%; - There were no uterine rupture associated maternal deaths among term studies; - The overall risk of rupture with any induction method at term was 1.5% and 1.0% when any gestational age is considered.; - Among women with gestational age > 40 weeks, the rate was highest at 3.2%.; - There was significant heterogeneity among studies; - Study design appeared to play a role in reported frequencies of uterine rupture
Predictors of uterine rupture | Cohorts, case series and case-controls | N/A | - Uterine rupture risk is decreased by prior vaginal delivery and prior VBAC; - Uterine rupture risk is increased by short inter-delivery intervals <18–24 months and gestational age; - There is insufficient or conflicting evidence regarding the role of single layer closure, preterm delivery, maternal age, post-term status, birth weight, oxytocin, prostaglandin and epidural use.; - ultrasound measurements of uterine thickness may play a promising role in predicting populations at risk for uterine rupture
Predictive Tool | Cohorts | N/A | - Accurate and reliable tool to predict an individual woman’s risk of uterine rupture has not been achieved.
Hysterectomy | Cohorts | Medium | - Hysterectomy is rare with either ERCD or TOL, occurring in less than 3% of deliveries; - Hysterectomy rate for ERCD ranged from 0% to 1.7%; - Hysterectomy rates for TOL ranged from 0.1%–0.5%; - The majority of studies report a non-significant increase in hysterectomy for ERCD; - High-risk populations (maternal complications) may be at increased risk for hysterectomy
Hemorrhage/Transfusion | Cohorts | Medium/Low | - Overall hemorrhage rates were higher in the ERCD group 0.3–29% versus 0.6–17% for any gestational age; - Transfusion rates in TOL were 0.8% versus 1.2% in ERCD for any gestational age, compared with 0.66% TOL and 0.46% ERCD for term delivery only studies; - Transfusion risk appears to be modified by gestational age at delivery; - Data on maternal hemorrhage is limited by inconsistent reporting and definition of the term hemorrhage among different studies
Infection | Cohorts | Low (All definitions of infection) | - TOL appears to be associated with increased risk of febrile morbidity for populations that include preterm patients but not studies limited to term.; - TOL is associated with a decreased risk of maternal fever compared with ERCD (RR= 0.63, 95% CI= 0.43 to 0.91) however significant discrepancies exist in the definition of fever
Surgical Injury | Cohorts | N/A | - There is insufficient data regarding risk of surgical injury for TOL and ERCD patients; - Prior vertical cesarean is associated with increased risk for bladder injury
Embolic events | Cohorts | N/A | - TOL is associated with lower rates of embolic events compared with ERCD (0.04% versus 0.1%); - The risk of embolic events for ERCD is similar regardless of number of prior cesareans at 0.1%; - Data is limited for this outcome
Length of stay | Cohorts | N/A | - TOL had a mean difference in LOS for all studies compared with ERCD; - Mean LOS difference for TOL was − 1.3 days (95% CI= − 1.6 to − 1.0); - Obesity was associated with increased hospital stay but data is limited
Effect of Hospital Setting | Cohorts | N/A | - Data are based on only one study which reported increased odds of short term complications in low volume maternity wards (particularly death and uterine rupture); - No studies directly describe the long-term outcomes of TOL, VBAC, and ERCD
Multiple cesareans and placenta | Cohorts | N/A | - >3 prior CD is associated with increased rates of previa (2.3–4.2%), accreta (4.7–6.7%), and hysterectomy (1.1–9.0%).; - Prior CD is a significant risk factor for maternal morbidity in women with previa. The risk increases with increasing number of prior CD.; - Women with ≥ 3 prior CD and previa had a statistically significant increased risk of accreta (3.3–4% vs. 50–67%), hysterectomy (0.7– 4% vs. 50–67%), and composite maternal morbidity (15% vs. 83%) compared with women with previa and no CD.
What are the short- and long-term benefits and harms to the baby of maternal attempt at trial of labor after prior cesarean versus elective repeat cesarean delivery, and what factors influence benefits and harms?
Apgar scores | Cohorts | N/A | - There is little to no significant difference between Apgar scores of infants delivered by VBAC and ERCD
Respiratory complications | Cohorts | TTN: Low Bag/Mask: Low Intubation: Moderate | - Few studies define terms for respiratory complications, there is little consensus between studies regarding safer delivery method (VBAC versus ERCD) in regards to this intermediate outcome.
Sepsis | Cohorts | Low | - Definition of infantile sepsis is unclear, few studies examine rates of this diagnosis and even fewer measure the confirmation of sepsis.
Asphyxia/HIE | Cohorts | Low | - There are no consistent definitions of HIE among term studies and few report it. Needed: neonates diagnosed with HIE should be followed to measure associated long-term health outcomes
NICU admissions | Cohorts | Low | - No consistent definition for NICU admission criteria, no difference between VBAC/ERCD. Currently: NICU admission is an imprecise measure of infant health, as reason for admission could differ greatly between cases. Study findings are often confounded by classification bias
Stillbirth/Infant death | Cohorts | Perinatal: Moderate Fetal: Low Neonatal: Moderate | - Conflicting evidence of whether a previous CD increases the risk for stillbirth in subsequent pregnancies.; - Perinatal and infant deaths are rare, but occur significantly less often in ERCD
Neurological Development | Cohorts | Insufficient | - No studies measure neurologic development; studies that go beyond the immediate postpartum period are necessary to capture neurological development
Macrosomia | Cohorts | N/A | - Heavier women have heavier babies, macrosomic infants are less likely to be delivered by VBAC, especially in infants > 4,500 grams
Fetal presentation | Cohorts | N/A | - No data on fetal presentation
Gestational age | Cohorts | N/A | - Analysis for Key Question 3 was limited to term infants, no studies broke down term data by week in a VBAC versus ERCD format
Breastfeeding | Cohorts | Insufficient | - No studies to determine breastfeeding indicators
What are the critical gaps in the evidence for decision-making, and what are the priority investigations needed to address these gaps?
| None | N/A | - Because studies largely report actual route of delivery they are subject to misclassification bias which weakens ability to measure magnitude and direction of risk for TOL versus ERCD; - Ideal cohort study would construct cohort by intended route of delivery; - Infant outcomes are poorly defined and addressed; - Important associations and outcomes for uterine rupture were not addressed; - Rate and predictors for uterine- rupture associated infant and maternal mortality and morbidity; - Reliability for signs and symptoms of rupture; - How hospital staffing, structure, etc impact outcomes for uterine rupture

Abbreviations: CD=cesarean delivery; CI=confidence interval; ERCD=elective repeat cesarean delivery; g=grams; HIE=hypoxic ischemic encephalopathy; LOS=length of stay; N/A=not applicable; NICU=neonatal intensive care unit; RR=relative risk; TOL=trial of labor; TTN=transient tachypnea of the newborn; U.S.=United States; VBAC=vaginal birth after cesarean section; VD=vaginal delivery

A systematic review strives to be patient-centered and to provide both patients and clinicians with meaningful numbers or estimates so they can make informed decisions. Often, however, the data do not allow a direct estimate to calculate the numbers that people desire such as the number of cesareans needed to avoid one uterine rupture related death. The assumptions that are required to make such estimates from the available data introduce additional uncertainty that cannot be quantified. If we make a simplistic assumption that 6 percent of all uterine ruptures result in perinatal death (as found from the summary estimate), the range of estimated numbers of cesareans needed to be performed to prevent one uterine rupture related perinatal death would be 2,400 from the largest study,204 and 3,900–6,100 from the other three studies of uterine rupture for TOL and ERCD.10, 97, 205 Taken in aggregate, the evidence suggests that the approximate risks and benefits that would be expected for a hypothetical group of 100,000 women at term gestational age (GA) who plan VBAC rather than ERCD include: 10 fewer maternal deaths, 650 additional uterine ruptures, and 50 additional neonatal deaths. Additionally, it is important to consider the morbidity in future pregnancies that would be averted from multiple cesareans particularly in association with placental abnormalities.

One persistent trend emerging from analysis of the evidence in this report is the influence of GA on vaginal delivery rates and outcomes. There appears to be increased risk of uterine rupture and transfusion among term pregnancies undergoing TOL. Further, limited information from induction studies suggests that risks of induction are particularly increased as GA exceeds 40 weeks. These data together pose a particular challenge for the management of the post-date pregnancy. Mode of delivery for subsequent pregnancies poses a difficult question for women with prior cesarean and their providers. Some women have already made their decision prior to leaving the hospital after their cesarean due to factors surrounding that birth. Others will decide early in pregnancy, and still others will remain undecided until presenting in labor. Some women will not have a choice due to provider, hospital, insurance, or medical-legal factors that mandate RCD. This report suggests that, although there are statistically significant differences between ERCD and TOL, there are few clinically significant differences.

## What are the critical gaps in the evidence for decisionmaking, and what are the priority investigations needed to address these gaps?

Future research sections of evidence reports have been criticized for not providing sufficient detail to provide researchers the information they need to improve their study designs.290 Further, evidence reports have been dismissed for cataloging all possible research efforts rather than prioritizing future research. To take advantage of the peer review process—which distributes the draft report to federal agencies, including the FDA, CDC, and NIH; maternity and pediatric clinicians; advocacy groups; payers; policymakers; content experts; and researchers—our peer reviewers were asked to provide feedback on both investigator ideas on important gaps in the literature and to provide their own perspectives and priorities for future research. Specifically, experts were asked if stated topic areas were of low, medium, or high priority for future research, and to also provide additional clarification on their positions. Those areas that were rated as highest priority are discussed here (highest priority means that 50 percent of the experts rated the domain as high).

The decision on route of delivery for women with prior cesarean delivery is particularly challenging and complex for patients, providers, and decisionmakers. Patients and providers are influenced by the short- and long-term benefits and risks of route of delivery as well as family obligations, costs, societal norms, and regional availability of options. Although the numbers of studies on VBAC are numerous, the numbers of studies providing high quality information on important clinical questions are limited. An analysis of the areas with the most uncertainty, gaps in the evidence, is presented in Table 37. While many believe the ideal study design for an intervention such as TOL versus ERCD would be a randomized controlled trial, none has been done, and several papers indicate that such a trial is unlikely in the U.S.291 The evidence for this systematic review is based almost entirely on observational studies, which are more susceptible to bias. Misclassification of patients and outcomes is a challenge to this literature. Steps to improve these areas in research are necessary to provide clinicians and families with accurate and timely information on route of delivery. In particular, studies of VBAC versus ERCD have traditionally reported outcomes based upon actual route of delivery rather than intended route. This can lead to misclassification of patients who intend ERCD but go into labor prior to their cesarean or women who intended TOL but who are delivered by cesarean delivery. Each leads to misclassification of outcomes for a particular group, and leaves clinicians and patients still uncertain of the ramification for their decisionmaking. It also masks the potential adverse effects of desiring one route of delivery but having another either due to medical complications or other reasons.

Table 37 Future research

Research Question | Domains Pertaining to Overall Strength of Evidence
Research Question | Results of Literature Review | Types of Studies Needed to Answer Question
Create standard for referencing predictors | Each study uses different reference in their analysis of predictor making pooling difficult. | Evidence review to propose stand way to compare predictors. E.g., prior CD indication (breech) could always be compared to “not breech” rather than to FTP or fetal indication.
Predicting TOL | Only 2 studies examined this. No evidence on race or ethnicity to determine if there is health disparity | Multi-center prospective cohort study of eligible women for TOL. Measure rates of TOL and rates of ERCD along with predictors including race, ethnicity.
What are the predictors of a cesarean after a TOL? | Current prediction ability is low. | Multi-center prospective cohort study of women eligible for TOL. Record TOL, ERCD and VBAC rates, Emergency CD rates. Measure effect of intervention predictors.
How often do uterine ruptures that occur in hospitals result in serious harms for mother or infant? How does this vary by setting? How does this compare to non- hospital births? | 6/6 cohort studies reported on neonatal death 4of 6 cohort studies reported on maternal death | - - Multi-centered cohort; - - National registry of Uterine ruptures
What are the long-term maternal outcomes of VBAC versus ERCD? | Limited data. | Long-term follow-up study, beginning to follow women from their 1^st^ CD, surveying them regarding future fertility, and follow for 30 to 40 years.
What are the rates and differences of infections of VBAC versus ERCD? | Limited data with un- combinable studies | Large multicenter cohort utilizing standardized definition of endometritis as fever > x 24 hours post delivery requiring IV antibiotics. Other infectious morbidity should also be evaluated, but well defined, specifically x-ray confirmed pneumonia; wound infection defined as fever >100.5, with IV or PO antibiotics required; fever of unknown origin >48 hours.
What is the rate of specific surgical injuries with ERCD and TOL? | None | Large multicenter study, which defines injury specifically by type/organ of injury: bladder; bowel; uterus (includes uterine artery laceration); cervix; 3^rd^ or 4^th^ degree perineal laceration. Included in this should be length of surgery time as a marker for complexity of the case.
What are appropriate definitions for maternal outcomes (such as, infection, hemorrhage, surgical injury, etc)? | Definitions are not consistent across studies, making it impossible to combine results & difficult to interpret data. | Consensus conference to determine appropriate definitions.
Effect of study design on outcomes | This report found that studies differed substantially though not statistically significantly in their rates of uterine rupture based on study design (30/10,000 versus 52/10,000 risk). This has large implications for what studies are sufficient to based clinical practice and policy. | Conduct 2 cohort studies simultaneously keeping results blinded from other study - One that would define trial of labor and study only trial of labor patients and one that would consider the entire cohort of women with prior cesarean who have TOL versus ERCD
How does TOL versus ERCD effect breastfeeding initiation and continuation? | No evidence | Large cohort study
What is the chance of VBAC when induction is required? | Proportion with VBAC is 54 percent to 69 percent, depending on type of induction, but influence of confounding factors such as dose, prior VD, number of CDs not clear. | RCT with power calculations to insure adequate numbers of subjects and planned univariate and multivariate regression analyses to examine impact of individual and combined potential confounding factors. Comparison group: expectant management
What is the chance of uterine rupture when induction is required? | Rate of rupture is estimated to be 1.2 percent for all induction methods combined, however this is limited by the accuracy of the definition and ascertainment of rupture. | RCT with power calculations to insure adequate numbers of subjects and planned univariate and multivariate regression analyses to examine impact of individual and combined potential confounding factors. Comparison group: expectant management. Uterine rupture must be defined and ascertainment methods should include chart review.
How does the cumulative dose and regimen of induction agent (PGE_2_, oxytocin, etc.) affect maternal and infant harms? | Insufficient | - - RCT of women who are candidates for induction of TOL with 2 groups: induction or expectant management.
How does the cumulative dose and rate of infusion of oxytocin used for augmentation of labor affect infant and maternal harms? | Insufficient | - - RCT of women who are candidates for induction of TOL with 2 groups: induction or expectant management..
What are appropriate definitions for infant outcomes (death, respiratory, neurological)? | Definitions are not consistent across studies, making it impossible to combine results & difficult to interpret data. | Consensus conference to determine appropriate definitions.

Abbreviations: CD=cesarean delivery; ERCD=elective repeat cesarean delivery; FTP=failure to progress; IV=intravenous; PGE=prostaglandin E_2_; PO=orally administered; RCT=randomized controlled trial; TOL=trial of labor; VBAC=vaginal birth after cesarean; VD=vaginal delivery

### National Childbirth Study

Investigators and reviewers agree that the existing evidence is insufficient to adequately answer several questions (Table 37). Additionally, it was agreed that the most effective way to address these gaps in the literature is the undertaking of a large, prospective longitudinal national childbirth randomized trial or cohort study. Participants would need to be enrolled early in their pregnancy, and grouped by their intended route of delivery. Whether randomized or a cohort, this landmark study would use clearly defined outcomes, preferences, and risk factors. Such a study would be designed to follow women and their fetuses/infants from early pregnancy to long-term followup. This type of study would allow researchers and clinicians to establish a cohort at risk. Investigators and experts also agreed on the importance of establishing the appropriate definitions for maternal outcomes (such as, infection, hemorrhage, and surgical injury) and for infant outcomes (such as death or respiratory or neurological issues). A prospective approach is paramount, given the problems with variation in patient classification, outcome definition, and method of measurement found in retrospective studies. Outcome definition was noted as being critical to interpretation of the literature by peer reviewers, and as a main problem in synthesizing existing evidence by reviewers. Composite outcomes are particularly problematic, although even individual outcomes were often poorly defined or defined with wide variation in the existing literature. A consensus conference on health outcome definitions with key leaders in the field should be held prior to conducting such a study. It is recognized that enormous challenges may exist in developing such a large scale effort. These include but are not limited to establishing consensus on definitions; acquiring funding; delineating external influences (litigation; popular press; and societal, patient, and provider assumptions); and obstacles to randomization, IRB approval, and long-term followup.

In addition to, or in support of, such a study, there are specific questions for which an RCT is possible and the best methodological approach. Administrative or other types of databases may be useful in assessing some outcomes, particularly long-term harms. However, methods for using such databases in studying VBAC need to be developed.

Specific areas identified that require additional research included prediction tools, maternal health outcomes, infant health outcomes, and cost.

### Prediction Tools

Of priority to the experts surveyed in this domain include the ability to predict uterine rupture, VBAC, or emergency cesarean delivery (failed TOL). This report identifies gaps in the ability of existing prediction tools at selecting women for a successful TOL. Studies need to be large and prospective in nature and should use standard health outcome definitions. Such tools should address non-medical factors associated with a successful or failed TOL; the impact of induction; and whether there are differences among racial, ethnic, or socioeconomic groups. Where differences exist, future research should be designed to identify the reasons for such differences.

### Maternal Health Outcomes

Better understanding of the short- and long-term outcomes comparing VBAC with ERCD is needed, particularly in order to inform women’s choices, especially among those who will have future pregnancies. This is especially important looking at the proportion of women who have three or more children and the extent of unplanned pregnancies. Future studies must include a full range of reproductive outcomes, including quality of life. Current evidence is lacking in standardization of definitions of short-term outcomes as well as methods of ascertainment and reporting. Examples of short-term outcomes that require better research are infection and surgical injury. Outcomes that affect both mother and infant, such as those related to breastfeeding and parental attachment, have not been studied in relation to VBAC. Comparison of long-term outcomes between VBAC and ERCD are also in need of better examination, with better evaluation of the impact of the age of the mother being taken into account along with multiple other factors.

Uterine rupture. Interpretation of the uterine rupture research is difficult for the many reasons previously described. A potentially promising area of inquiry might be using imaging to predict UR or outcomes; however, the current evidence in this area is insufficient for using ultrasound imaging of the uterine scar or lower uterine segment to predict the risk of uterine rupture with TOL. A large multi-centered RCT could take one of two approaches: randomize patients to ultrasound or no ultrasound, or perform ultrasound on all patients but randomize which providers receive the results prior to delivery.

The impact of setting on the short- and long-term outcomes for mothers and infants has not been well studied. A prospective study of uterine rupture could be created to answer several questions. The study would need to use a standard definition and method of ascertainment to compare events at various types of hospital and non-hospital settings, with variation in staffing and the ability to provide “immediate access to cesarean delivery.” Implementation of a national registry of ruptures and using linked data systems may be a way to approach these questions.

Evidence on the risk of uterine rupture when induction or augmentation is needed is lacking appropriate comparison groups and long- or short-term evidence on infant and maternal harms. Women who are candidates for induction should be compared with similar women who undergo expectant management. Additionally, the role of uterine wall thickness has not been studied in relation to induction for TOL. The best study to answer these questions is an RCT of induction or expectant management. The effect of uterine wall thickness could be examined within such a study or as a separate study.

### Infant Health Outcomes

Experts and reviewers agreed that two pressing issues in VBAC continue to be identifying and then studying the most meaningful infant outcomes and agreeing on clear and precise definitions and methods of ascertainment. Although similar issues are seen with maternal outcomes and definitions, those reported as specific to infants include evaluation of variation in gestational age associated with the different delivery methods (ERCD and TOL with and without induction).

### Cost

Costs were not examined explicitly in this report, but experts expressed the need to correlate beneficial or harmful outcomes to health-system costs. Economic analyses could be designed to coincide with studies described here. Additional studies to identify the best reimbursement model to provide financial incentives for critical elements of VBAC—which may include increased access in rural areas, 24 hour in-house surgical coverage, etc.—are needed. Again, clear definitions of outcomes are essential.

Appendixes and evidence tables cited in this report are available at http://www.ahrq.gov/downloads/pub/evidence/pdf/vbacup/vbacup.pdf.