# Appendixes

Appendix A Technical Expert Panel Members

Appendix B Expert Reviewers

Appendix C Search Strategies

Appendix D List of Developed Countries

Appendix E Inclusion and Exclusion Criteria

Appendix F Excluded Studies List

Appendix G List of Citations From the Maternal-Fetal Medicine Units Network Cohort

Appendix H Quality Rating Criteria

Appendix I Individual Quality Rating Tables

Appendix J Strength of Evidence Table

Appendix K Detailed Evaluation of Predictors of Trial of Labor and Vaginal Birth After Cesarean

Appendix L Detailed Evaluation of Vaginal Birth After Cesarean Rates

Appendix M Induction of Labor Additional Figures

Appendix N Detailed Evaluation of Screening Tools for Predicting Vaginal Birth After Cesarean

Appendix O Detailed Maternal Mortality Table

Appendix P Predictive Tools of Uterine Rupture Table

Appendix Q Detailed Transfusion/Hemorrhage Table

Appendix R Detailed Infection Table

Appendix S Detailed Hospital Stay Table