# Individual Quality Rating Tables

Quality Ratings of Randomized Controlled Trials

Study, Year | Random assignment | Allocation concealed | Groups comparable at baseline & maintained | Eligibility criteria specified | Blinded: Outcome Assessors/Care Provider/Patient | Report of attrition Differential loss to follow-up | Analysis considerations | Quality Score
Grubb, 1996^1^ | Yes | No | Yes | Yes | No/No/No | 8/188 lost to follow-up, <20% | Yes | Fair
Peleg, 1999^2^ | Yes | Yes | NR | Yes | No/No/No | Unclear | Unclear | Fair
Thubisi, 1993^3^ | No. “Allocated alternately by admitting clerks” | No | Yes | Yes | No/No/No | No data given | No | Poor*
Wing, 1998^4^ | NR | NR | NR/NR | Yes | No/No/No | No data given | No | Poor*

Quality Ratings of Cohort Studies

Study, Year | Assembly of Groups | Maintenance of comparable groups | Outcome measures reliable & valid | Outcome assessor blind to exposure status | Missing data | Follow-up long enough for outcomes to occur | Consider/adjust for potential confounders (obstetric conditions) | Quality Score
Amir, 1987^5^ | Yes | Yes | Unclear | Unclear | None | Yes | Yes/No | Fair
Asakura, 1995^6^ | Unclear | Unclear | Unclear | No | Unclear | Yes | No/No | Poor*
Bahtiyar, 2006^7^ | Yes | Yes | No | No | Unclear | Yes | Yes/Yes | Fair
Bais, 2001^8^ | Yes | Unclear | Yes | Yes | No | Yes | Yes/No | Fair
Bashiri, 2008^9^ | Yes | No | Yes | Yes | No | Yes | Yes/Yes | Good
Blanchette, 1999^10^ | Yes | Unclear | Unclear | Not reported | Not reported | Yes | No/No | Poor*
Blanchette, 2001^11^ | Unclear | No | No | Unclear | Unclear | Yes | Yes/Yes for uterine rupture, no for all others | Poor*
Bujold, 2002^12^ | Yes | No | Unclear | Unclear | Unclear | Yes | Yes/Yes | Fair
Bujold, 2002^13^ | Yes | Yes | Yes | No | No | Yes | Yes/Yes | Good
Bujold, 2004^14^ | Yes | Yes | Unclear | No | No | Yes | Yes/Yes | Fair
Bujold, 2004^15^ | Yes | Yes | Unclear | No | No | Yes | Yes/Yes | Fair
Bujold, 2005^16^ | Yes | Yes | Yes | Not reported | No | Yes | Yes/Yes | Good
Cahill, 2006^17^ | Yes | No | Yes | Yes | No | Yes | Yes/Yes | Fair
Carroll, 2003^18^ | Yes | Unclear | Unclear | Unclear | Unclear | Yes | Yes/Yes | Fair
Caughey, 1999^19^ | Yes | Yes | Unclear | Unclear | <20% | Yes | Yes/Yes | Fair
Chang, 2008^20^ | Yes | Yes | Yes | No | None | Yes | Yes/Yes | Good
Chapman, 1997^21^ | Yes | No | Unclear | Unclear | Unclear | Yes | No/No | Poor*
Chauhan, 2001^22^ | Yes | No | Yes | Unclear | No | Yes | Yes/Some | Fair
Chauhan, 2002^23^ | Yes | Unclear | Unclear | No | Low, 1/156 | Yes | Yes/Yes | Fair
Chestnut, 1985^24^ | Unclear | Yes | Unclear | No | Maternal morbidity for post-op: 25%; Other outcomes: 0% for other outcomes | Yes | Some/No | Poor*
Coughlan, 2002^25^ | Yes | No | Yes | Unclear | Unclear | Yes | No/No | Poor*
DeFranco, 2007^26^ | Yes | Yes | Yes | No | None | Yes | Yes/Yes | Good
Delaney, 2003^27^ | Yes | Yes | Yes | Unclear | None | Yes | Yes/No | Fair
Dhall, 1987^28^ | Yes | Unclear | Unclear | Unclear | Not reported | Yes | Yes/Yes | Poor*
DiMaio, 2002^29^ | Yes | No | Yes | Unclear | Not applicable | Yes | No | Fair
Dinsmoor, 2004^30^ | Yes | No | Yes | Yes | Low, 12% | Yes | Yes/Yes | Fair
Duff, 1988^31^ | Yes | Unclear | Yes | Unclear | Unclear | Yes | No/No | Poor*
Durnwald, 2004^32^ | Unclear | Unclear | Yes | Unclear | Unclear | Yes | Yes/Yes | Fair
Durnwald, 2004^33^ | Yes | Yes | No | No | No | Yes | No/No | Fair
Edwards, 2003^34^ | Yes | Unclear | No | No | No | Yes | Yes/No | Poor*
Eglinton, 1984^35^ | Yes | Unclear | Yes | Unclear | Low, 5% | Yes | Yes/Yes | Fair
Elkousy, 2003^36^ | Unclear | Unclear | No | Unclear | Unclear | Yes | Yes/Yes | Fair
El-Sayed, 2007^37^ | Unclear | Not applicable | Unclear | No | <20% | Yes | Yes/Yes | Fair
Eriksen, 1989^38^ | Unclear | Yes | Unclear | Unclear | No | Yes | Some/No | Fair
Fisler, 2003^39^ | Yes | Yes | Yes | No | No | Yes | Yes/Yes | Fair
Flamm, 1987^40^ | Yes | Not applicable | Yes | No | Not applicable | Yes | Yes/Yes | Fair
Flamm, 1989^41^ | Yes | Unclear | Unclear | No | No | Unclear | No/No | Poor*
Flamm, 1994^42^ | Yes | Not applicable | Yes | No | Not applicable | Yes | Yes/Yes | Good
Flamm, 1997^43^ | Yes | Yes | Yes | No | Not applicable | Yes | Yes/Yes | Good
Gemer, 1992^44^ | Yes | Unclear | Yes | Unclear | No | Yes | Yes/No | Poor*
Getahun, 2006^45^ | Unclear | Unclear | Unclear | Unclear | Unclear | Yes | Yes/Yes | Poor*
Gibson, 1988^46^ | Unclear | Unclear | Unclear | No | None | Yes | No/No | Fair
Gonen, 2006^47^ | Unclear | No | Yes | No | Unclear | Yes | Yes/Yes | Fair
Gonen, 2007^48^ | Yes | No | Unclear | Unclear | Unclear | Yes | No/No | Poor*
Goodall, 2005^49^ | Yes | Unclear | Yes | Unclear | No | Yes | Yes/Yes | Fair
Granovsky- Grisaru, 1994^50^ | Yes | Unclear | Unclear | Unclear | Not applicable | Yes | Yes/Yes | Fair
Gregory, 1999^51^ | Yes | Not applicable | Yes | Not applicable | Not applicable | Not applicable | Yes/Yes | Good
Gregory, 2008^52^ | Yes | No | No | No | Unclear | Unclear | Yes/Yes | Fair
Grobman, 2007^53^ | Yes | Unclear | Yes | Yes | No | Yes | Yes/Yes | Good
Grobman, 2008^54^ | Yes | Unclear | Yes | No | Missing 30% of body mass indexes, and 25% of prior birth weights | Yes | Yes/Yes | Good
Grossetti, 2007^55^ | Unclear | Yes | Unclear | No | No | Yes | Unclear | Fair
Hammoud, 2004^56^ | Yes | No | Unclear | Unclear | Unclear | Yes | Yes/Yes | Fair
Hansell, 1990^57^ | Yes | Yes | Yes | Yes | No | Yes | Yes/No | Fair
Hashima, 2007^58^ | Yes | No | Yes | Yes | Unclear | Yes | Yes/Yes | Fair
Hemminki, 2005^59^ | Yes | Unclear | Unclear | Unclear | 1.20% | Yes | Yes/Yes | Fair
Hershkowitz, 1995^60^ | Yes | Unclear | Unclear | Unclear | Unclear | Yes | Yes/Yes | Fair
Hibbard, 2001^61^ | Unclear | No | Yes | Unclear | ERCD: 2.4%; VBAC: 6.9% | Yes | Yes/Yes | Fair
Hibbard, 2006^62^ | Yes | Yes | Yes | No | No | Yes | Yes/Yes | Good
Hollard, 2006^63^ | Yes | No | Yes | Yes | No | Yes | Yes/Yes | Good
Hook, 1997^64^ | Yes | Yes | Yes | Not reported | No | Yes | Yes/Yes | Good
Horenstein, 1984^65^ | Unclear | Yes | Unclear | No | No | Yes | Very little/No | Fair
Horenstein, 1985^66^ | Unclear | Yes | Unclear | No | No | Yes | Very little/No | Fair
Hoskins, 1997^67^ | Yes | Not applicable | Yes | Unclear | Not applicable | Yes | No | Fair
Johnson, 1991^68^ | Yes | Unclear | Yes | No | Unclear | Yes | No/No | Fair
Juhasz, 2005^69^ | Yes | Unclear | Yes | Unclear | No | Yes | Yes/Yes | Fair
Kamath, 2009^70^ | Yes | No | Yes | No | No | Yes | Yes/Yes | Fair
Kayani, 2005^71^ | Yes | Yes | Unclear | No | No | Yes | Very little/No | Fair
Kugler, 2008^72^ | Unclear | Not applicable | No | No | No | Yes | No/No | Fair
Kwee, 2007^73^ | Yes | Unclear | Yes | No | No | Yes | No/No | Fair
Landon, 2004^74^ | Yes | No | Yes | No | < 20% | Yes | Yes/Yes | Fair
Landon, 2006^75^ | Yes | No | Yes | Unclear | <20% - 7% (unknown intent to trial of labor) | Yes | Yes/Yes | Fair
Lieberman, 2004^76^ | Yes | Yes | Unclear | No | Unclear | Yes | Yes/No | Fair
Lin, 2004^77^ | Yes | Yes | Yes | No | No | Yes | Unclear | Fair
Loebel, 2004^78^ | Unclear | Yes | Unclear | No | No | Yes | No/No | Fair
Lydon-Rochelle, 2001^79^ | Yes | No | Unclear | Unclear | No data given | Yes | Yes/Yes | Fair
Lyndon-Rochelle, 2001^80^ | Yes | Not applicable | No | No | Not applicable | Yes | Yes/Yes | Poor*
Macones, 2005^81^ | Yes | Not applicable | Yes | No | Not applicable | Yes | Yes/No | Fair
Martin, 1983^82^ | Yes | Not applicable | Yes. No for fever | No | Not applicable | Yes | No/No | Fair
McMahon, 1996^83^ | Yes | Not applicable | Yes | No | Not applicable | Yes | Yes/Yes | Good
Melnikow, 2001^84^ | Yes | Unclear | Yes | Yes | Low, 73/1662 | Not applicable | Not reported | Fair
Miller, 1992^85^ | Yes | Not applicable | Yes | Yes | Not applicable | Not applicable | No/No | Poor*
Naef, 1995^86^ | Yes | No | Yes | No | Unclear | Yes | No/No | Poor*
Nisenblat, 2006^87^ | Yes | No | Yes | No | Unclear | Yes | Yes/Yes | Fair
Obara, 1998^88^ | Yes | No | Unclear | Unclear | Unclear | Yes | Yes/No | Fair
Odibo, 2007^89^ | Yes | Unclear | unclear | Unclear | Unclear | Yes | Yes/Yes | Fair
Ogunyemi, 1998^90^ | Yes | No | Unclear | Not applicable | No | Yes | No/No | Poor*
Ouzounian, 1996^91^ | Unclear | Yes | Yes | No | No | Yes | No/No | Fair
Paterson, 1991^92^ | Yes | Yes | Unclear | Unclear | Not applicable | Yes | Unclear | Fair
Pathadey, 2005^93^ | Yes | Yes | Unclear | No | No | Yes | Yes/No | Fair
Paul, 1985^94^ | Yes | Not applicable | Yes | No | Not applicable | Yes | Yes/No | Fair
Peaceman, 2006^95^ | Yes | No | Yes | Unclear | Unclear | Yes | Yes/Yes | Fair
Phelan, 1987^96^ | Yes | Not applicable | Yes | No | Not applicable | Yes | Yes/No | Fair
Phelan, 1989^97^ | Yes | Unclear | Yes for uterine rupture. No for fever | Yes | No | Yes | Yes/No | Poor*
Pruett, 1988^98^ | Yes | Unclear | Yes | No | Unclear | Yes | No/No | Poor*
Quinones, 2005^99^ | Unclear | Unclear | Yes | No | low | Yes | Yes/Yes | Fair
Rageth, 1999^100^ | No | Not applicable | No | No | Not applicable | Yes | No/No | Poor*
Ravasia, 2000^101^ | Unclear | No | No | No | No | Yes | No/No | Poor*
Raynor, 1993^102^ | Yes | Not applicable | Yes | Unclear | Not applicable | Yes | No | Fair
Richardson, 2005^103^ | Yes | Unclear | Yes | No | No | Yes | Yes/Yes | Fair
Richter, 2002^104^ | Yes | No | Yes | No | No | Yes | Some/No | Fair
Rozenberg, 1996^105^ | Yes | Yes | Yes | Yes | No | Yes | Yes/Yes | Good
Rozenberg, 1999^106^ | No | Yes | Yes | No | No | Yes | Yes/Unclear | Fair
Rudick, 1984^107^ | Yes | Yes | Unclear | No | No | Yes | Yes/No | Fair
Russillo, 2008^108^ | Yes | Unclear | Unclear | Yes | No | Yes | Yes/No | Poor*
Sakala, 1990^109^ | Yes | Yes | Unclear | No | No | Yes | Yes/No | Fair
Sakala, 1990^110^ | Unclear | Unclear | Unclear | No | No | Yes | No/No | Poor*
Schneider, 1988^111^ | Inclusion criteria are described, but methods to ascertain group are not discussed. Elective repeat cesarean group includes medical and obstetric reasons as well as maternal decisions, and methods for ascertaining the reason are not described | Unclear | Unclear | Unclear | No | Yes | Yes/No | Poor*
Sciscione, 2008^112^ | Yes | No | Yes | Yes | No | Yes | Yes/Yes | Good
Shipp, 2008^113^ | Yes | No | Yes | Yes | No | Yes | Yes/Yes | Fair
Smith, 2002^114^ | Yes | Yes | Yes | No | No | Yes | Yes/Some | Good
Socol, 1999^115^ | Yes | Unclear | Yes | Unclear | No | Yes | No/No | Fair
Spaans, 2003^116^ | Yes | Unclear | Unclear | Unclear | Unclear | Yes | No/No | Poor*
Spong, 2007^117^ | Yes. However, the number (39,177) for term singleton gestation with prior cesarean is different from prior publication (Landon, 2006) | Yes | Yes | No | Yes | Yes | Yes/Yes | Fair
Stone, 2000^118^ | Unclear | Not applicable | Unclear | No | Not applicable | Yes | No/No | Poor*
Strong, 1992^119^ | Unclear | Yes | No | No | No | Yes | No/No | Poor*
Stovall, 1987^120^ | Yes | Not applicable | Yes/Yes | Unclear | Not applicable | Yes | No | Fair
Tahilramaney, 1984^121^ | Yes | Yes | Unclear | No | No | Yes | Yes/Yes | Fair
Tucker, 1993^122^ | Yes | Unclear | No | No | No | Yes | No/No | Poor*
Upadhyaya, 2003^123^ | Unclear | Unclear | Yes | Unclear | Not applicable | Yes | Yes/Yes | Fair
Van der Walt, 1994^124^ | Unclear | Unclear | Yes | Unclear | Yes | Yes | Yes/Yes | Fair
Van Gelderen, 1986^125^ | Unclear | Yes | Unclear | No | No | Yes | No/No | Fair
Videla, 1995^126^ | Yes | Unclear | No | No | Yes | Yes | No/No | Poor*
Weinstein, 1996^127^ | Yes | Yes | For some, not for others | No | Not applicable | Yes | Yes/Yes | Fair
Wen, 2004^128^ | Unclear | Yes | Unclear | No | No | Yes | Some/Some | Fair
Yetman, 1989^129^ | Yes | Unclear | No | Yes | Low, 5% | Yes | No/No | Fair
Yogev, 2004^130^ | Unclear | Yes | Yes | No | No | Yes | Yes/Yes | Fair
Zelop, 1999^131^ | Yes | Yes | Yes | No | No | Yes | No/No | Fair
Zelop, 2000^132^ | Yes | Unclear | No | No | Yes | Yes | No/No | Poor*
Zelop, 2001^133^ | Yes | Yes | Yes | No | Not applicable | Yes | Yes/Yes | Fair

Quality Ratings of Case-Control Studies

Study, Year | Explicit definition of cases | Disease state of the cases similar & reliably assessed | Case ascertainment reliable, valid & applied appropriately | Nonbiased selection of controls | Cases/controls:comparable confounding factors | Study procedures applied equally | Appropriate attention to confounders (consider & adjust) | Appropriate statistical analysis used (matched, unmatched, overmatching) | Quality Score
Adair, 1995^134^ | Yes | Unclear | Unclear | No | No | Unclear | Yes/No | Unmatched | Poor*
Bashiri, 2008^9^ | Yes | Unclear | No | Yes | No | No | Unclear | Overmatched | Poor*
Bodelon, 2009^135^ | Yes | Yes | Unclear | Yes | No | Unclear | Yes/Yes | Unclear | Fair
Buhimschi, 2005^136^ | Yes | Yes | Yes | Yes | Yes | Yes | No/No | Yes | Good
Gilliam, 2002^137^ | Yes | Yes | No | Yes | No | Yes | Yes/Yes | Yes | Fair
Guihard, 2001^138^ | Yes | Yes | Yes | Unclear | Unclear | Yes | Yes/Yes | Yes | Fair
Hadley, 1986^139^ | Somewhat | Yes | Yes | Yes | No | Yes | NA | No | Poor*
Juntunen, 2004^140^ | Yes | Unclear | Yes | Unclear | Unclear | Yes | No/No | Unclear | Fair
Kacmar, 2003^141^ | Yes | Yes | Unclear | Yes | No | Yes | Yes/Yes | Unclear | Fair
Laughon, 2005^142^ | Yes | Yes | Yes | Yes | No | Yes | Yes/Yes | Unclear | Fair
Leung, 1993^143^ | Yes | Yes | Unclear | Yes | Unclear | Unclear | No/No | Yes | Fair
Macones, 2001^144^ | Yes | Yes/No | Yes | No | Yes | Yes/No | Yes/Yes | Yes | Fair
Macones, 2005^81^ | Yes | Yes | No | Unclear | Unclear | Yes | Yes/Unclear | Some. 4:1 matching | Fair
Macones, 2006^145^ | Yes | Yes | Yes | Yes | No | Yes | Yes/Yes | Yes. No matching | Good
McMahon, 1997^146^ | Yes | Unclear. Used birth certificate data for previa | Unclear | Yes | No | Unclear | No/No | Unclear | Poor*
Miles, 2000^147^ | Yes | Yes | Unclear | No | Unclear | Unclear | Some/No | Yes | Poor*
Pickhardt, 1992^148^ | Yes | Yes/No | Yes/No | No | Yes | Yes/No | Yes | Yes | Fair
Rochelson, 2005^149^ | Yes | Yes | Yes | Unclear | Matched on # prior cesarean otherwise non-matched | Yes | No/No | Yes | Poor*
Rouse, 2006^150^ | Yes | Yes | Unclear | Unclear | No | Unclear | Yes/Yes | Unclear | Fair
Seidman, 1994^151^ | Yes | Yes | Unclear | Unclear | No | Unclear | Yes/Yes | Unclear | Poor*
Shimonovitz, 2000^152^ | No | Unclear | No | Yes | Yes | Unclear | Unclear | Unclear | Fair
Shipp, 2003^153^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes/Yes | Yes | Good
Tikkanen, 2006^154^ | Yes | Unclear | No | No | No | Unclear | Yes/Yes | Unclear | Poor*
Uygur, 2005^155^ | Yes | Yes | Yes | No | No | Yes | No/No | Unclear | Poor*
Uygur, 2005^156^ | Yes | Unclear | | No | No | Yes | No/No | Unclear | Poor*
Wu, 2005^157^ | Yes | Yes | No | Yes | No | Unclear | Yes/Yes | Unclear | Fair

Quality Ratings of Case Series Studies

Study, Year | Representative sample selected from a relevant population | Explicit definition of cases | Sufficient description of distribution of prognostic factors | Follow-up long enough for important events to occur | Outcomes assessed using objective criteria/blinding used | Quality Score
Armstrong, 2004^158^ | Yes | Yes | Yes | Yes | Unclear | Fair
Asakura, 2000^159^ | Unclear | Yes | Yes | Yes | Some/No | Fair
Blanco, 1992^160^ | Yes | Yes | No | Yes | No | Fair
Bujold, 2002^161^ | Yes | Yes | Yes | Yes | No | Fair
Chilaka, 2004^162^ | Yes | Yes | Unclear | Yes | No | Fair
Gotoh, 2000^163^ | No | No | Yes | Yes | Yes | Fair
Grobman, 2007^164^ | Yes | Yes | Yes | Yes | Unclear | Good
Kieser, 2002^165^ | Yes | Yes | Yes | Yes | Yes/No | Good
Landon, 2005^166^ | Yes | Yes | Yes | Yes | Unclear | Good
Leung, 1993^167^ | Yes | Yes | Yes | Yes | Unclear | Fair
Lynch, 2002^168^ | Yes | Yes | Yes | Yes | Unclear | Good
Meehan, 1989^169^ | NR | NR | Somewhat | Yes | No | Fair
Mercer, 2008^170^ | Yes | Yes | Yes | Yes | Unclear | Good
Raynor, 1993^102^ | Yes | Yes | NA | NA | Yes | Fair
Scott, 2001^171^ | Yes | Yes | Yes | Yes | Unclear | Poor*
Sheiner, 2004^172^ | Yes | Yes | Unclear | Yes | Unclear | Poor*
Shellhaas, 2009 | Yes | Yes | Yes | Yes | Unclear | Good
Shipp, 2002^173^ | Yes | Yes | Somewhat | Yes | Unclear | Fair
Silver, 2006^174^ | Yes | Yes | Yes | Yes | Unclear | Good
Stovall, 1987^120^ | Yes | Yes | No | Yes | Unclear | Poor*
Yucel, 2006^175^] | Yes | Yes | No | Yes | Unclear | Poor*
Zelop, 1993^176^ | Yes | Yes | Yes | Yes | Unclear | Fair

Quality Ratings of Cohort Prediction Studies

Study, Year | Comparable Groups Clear inclusion and exclusion criteria for VBAC | Maintenance of comparable groups | Clear definition of prognostic factors | Measures reliable, valid | Unbiased assessment of data and analysis of results | Loss/Drop-out rate | Follow-up long enough for outcomes to occur | Adjust for potential confounders (obstetric conditions) | Quality Score
Bujold, 2001^177^ | No | NA | Yes | Yes/Yes | Unclear | NA | Yes | No | Fair
Bujold, 2004^14^ | Yes | NA | Yes | Yes/Yes | Yes | NA | Yes | Yes | Good
Cameron, 2004^178^ | Yes | NA | Yes | Yes/Yes | No | NA | Yes | Yes | Good
Chang, 2008^20^ | Yes | NA | Yes | Yes/Yes | Yes | NA | Yes | Yes | Good
Costantine, 2009^179^ | Yes. Unclear for twins | NA | Yes | Yes/Yes | No | NA | Yes | Yes | Good
Dinsmoor, 2004^30^ | Yes | NA | Yes | Yes/Yes | Unclear | NA | Yes | No | Fair
Flamm, 1997^43^ | Yes | NA | Yes | Yes/Yes | Yes | NA | Yes | Yes | Good
Gonen, 2004^180^ | Yes | NA | Yes | Yes/Yes | Unclear | NA | Yes | Yes | Good
Grobman, 2007^164^ | Yes | NA | Yes | Yes/Yes | Yes | NA | Yes | Yes | Good
Gyamfi, 2004^181^ | Yes | Yes | Yes | Yes/Yes | Unclear | NA | Yes | Yes | Good
Harper, 2009^182^ (Macones 2005^81^) | Yes | NA | Yes | Yes/Yes | Yes | NA | Yes | Yes | Good
Hashima, 2007^58^ | No. Exclusion not defined | NA | Yes | Yes/Yes | Unclear | NA | Yes | Yes | Fair
Hendler, 2004^183^ | No. Exclusion not defined | Yes | Yes | Yes/Yes | Unclear | NA | Yes | Yes | Good
Huang, 2002^184^ | No. Exclusion not defined | NA | Yes | Yes/Yes | Unclear | NA | Yes | Yes | Fair
Hueston, 1994^185^ | No. Exclusion not defined. Unclear for twins | NA | No | Yes/Yes | Unclear | NA | Yes | Yes | Fair
Grobman, 2007^164^ | Yes | NA | Yes | Yes/Yes | Yes | NA | Yes | Yes | Good
Jakobi, 1993^186^ | Yes | Yes | Yes | Yes/Yes | No | NA | Yes | Yes | Good
Kabir, 2005^187^ | Yes | NA | Yes | Yes/Yes | NA | NA | Yes | Yes | Good
King, 1994^188^ | Yes | NA | Yes | Yes/Yes | Unclear | NA | NA | Yes | Good
Landon, 2005^166^ | Yes | NA | Yes | Yes/Yes | No | NA | Yes | Yes | Good
Learman, 1996^189^ | Yes | NA | Yes | Yes/Yes | No | NA | Yes | Yes | Good
Macones, 2001^144^ | Unclear how controls were selected. | NA | Yes | Yes/Yes | Unclear | NA | Yes | Yes | Fair
Macones, 2005^81^ | Yes | NA | Yes | Yes/Yes | Yes | NA | Yes | Yes | Good
McMahon, 1996^83^ | Yes | Yes | Yes | Yes/Yes | Yes | NA | Yes | Yes | Good
Mercer, 2008^170^ | Yes | NA | Yes | Yes/Yes | NA | NA | Yes | No | Fair
Pang, 2009^190^ | Yes | Yes | Yes | Yes/Yes | Unclear | NA | Yes | Yes | Good
Pickhardt, 1992^148^ | No. Exclusion not defined | NA | No | Yes/Yes | Unclear | NA | Yes | Yes | Fair
Quinones, 2005^99^ | Yes | NA | Yes | Yes/Yes | No | NA | Yes | Yes | Good
Selo-Ojeme, 2008^191^ | No. Exclusion not defined | NA | Yes | Yes/Yes | No | NA | Yes | Yes | Fair
Shipp, 2000^192^ | Unclear comparison between repeat CD and primary CD | NA | Yes | Yes/Yes | Yes | NA | Yes | Yes | Fair
Smith, 2005^193^ | Yes | Yes | Yes | Yes/Yes | No | NA | Yes | Yes | Good
Spaans, 2002^194^ | Yes | NA | Yes | Yes/Yes | No | NA | Yes | No | Fair
Srinivas, 2007^195^ | Yes | Yes | Yes | Yes/Yes | Yes | NA | Yes | Yes | Good
Strong, 1996^196^ | No. Exclusion not defined | Yes | Yes | Yes/Yes | No | NA | Yes | Yes | Fair
Troyer, 1992^197^ | Yes | NA | Yes | Yes/No | Unclear | NA | Yes | No | Fair
Vinueza, 2000^198^ | Yes | NA | Yes | Yes/No | No | NA | Yes | Unclear for prediction | Fair
Weinstein, 1996^127^ | Yes | NA | Yes | Yes/Yes | Unclear | NA | Yes | Yes | Good

* Poor quality studies are not included in the narrative or synthesis of the final report, unless no studies of better quality were available for a given topic and/or key question.

Abbreviations: CD=cesarean delivery; ERCD=elective repeat cesarean delivery; VBAC=vaginal birth after cesarean

## References

1 Grubb DK, Kjos SL, Paul RH. Latent labor with an unknown uterine scar. Obstet Gynecol. 1996;88(3):351-355. [pmid: 8752238].
2 Peleg D, Hannah ME, Hodnett ED, Foster GA, Willan AR, Farine D. Predictors of cesarean delivery after prelabor rupture of membranes at term. Obstet Gynecol. 1999;93(6):1031-1035. [pmid: 10362176].
3 Thubisi M, Ebrahim A, Moodley J, Shweni PM. Vaginal delivery after previous caesarean section: is X-ray pelvimetry necessary?. Br J Obstet Gynaecol. 1993;100(5):421-424. [pmid: 8518240].
4 Wing DA, Lovett K, Paul RH. Disruption of prior uterine incision following misoprostol for labor induction in women with previous cesarean delivery. Obstet Gynecol. 1998;91(5 Pt 2):828-830. [pmid: 9572178].
5 Amir W, Peter J, Etan Z. Trial of labor without oxytocin in patients with a previous cesarean section. Am J Perinatol. 1987;4(2):140-143. [pmid: 3566882].
6 Asakura H, Myers SA. More than one previous cesarean delivery: a 5-year experience with 435 patients. Obstet Gynecol. 1995;85(6):924-929. [pmid: 7770261].
7 Bahtiyar MO, Julien S, Robinson JN, et al. Prior cesarean delivery is not associated with an increased risk of stillbirth in a subsequent pregnancy: analysis of U.S. perinatal mortality data, 1995–1997. Am J Obstet Gynecol. 2006;195(5):1373-1378. [pmid: 16677588].
8 Bais JM, van der Borden DM, Pel M, et al. Vaginal birth after caesarean section in a population with a low overall caesarean section rate. Eur J Obstet Gynecol Reprod Biol. 2001;96(2):158-162. [pmid: 11384799].
9 Bashiri A, Burstein E, Rosen S, Smolin A, Sheiner E, Mazor M. Clinical significance of uterine scar dehiscence in women with previous cesarean delivery: prevalence and independent risk factors. J Reprod Med. 2008;53(1):8-14. [pmid: 18251354].
10 Blanchette HA, Nayak S, Erasmus S. Comparison of the safety and efficacy of intravaginal misoprostol (prostaglandin E1) with those of dinoprostone (prostaglandin E2) for cervical ripening and induction of labor in a community hospital. Am J Obstet Gynecol. 1999;180(6 Pt 1):1551-1559. [pmid: 10368503].
11 Blanchette H, Blanchette M, McCabe J, Vincent S. Is vaginal birth after cesarean safe? Experience at a community hospital. Am J Obstet Gynecol. 2001;184(7):1478-1484. discussion 1484–1477. [pmid: 11408871].
12 Bujold E, Mehta SH, Bujold C, Gauthier RJ. Interdelivery interval and uterine rupture. Am J Obstet Gynecol. 2002;187(5):1199-1202. [pmid: 12439503].
13 Bujold E, Bujold C, Hamilton EF, Harel F, Gauthier RJ. The impact of a single-layer or double-layer closure on uterine rupture. Am J Obstet Gynecol. 2002;186(6):1326-1330. [pmid: 12066117].
14 Bujold E, Blackwell SC, Hendler I, Berman S, Sorokin Y, Gauthier RJ. Modified Bishop's score and induction of labor in patients with a previous cesarean delivery. Am J Obstet Gynecol. 2004;191(5):1644-1648. [pmid: 15547536].
15 Bujold E, Hammoud AO, Hendler I, et al. Trial of labor in patients with a previous cesarean section: does maternal age influence the outcome?. Am J Obstet Gynecol. 2004;190(4):1113-1118. [pmid: 15118651].
16 Bujold E, Hammoud A, Schild C, Krapp M, Baumann P. The role of maternal body mass index in outcomes of vaginal births after cesarean. Am J Obstet Gynecol. 2005;193(4):1517-1521. [pmid: 16202749].
17 Cahill AG, Stamilio DM, Odibo AO, et al. Is vaginal birth after cesarean (VBAC) or elective repeat cesarean safer in women with a prior vaginal delivery?. Am J Obstet Gynecol. 2006;195(4):1143-1147. [pmid: 16846571].
18 Carroll CS Sr., Magann EF, Chauhan SP, Klauser CK, Morrison JC. Vaginal birth after cesarean section versus elective repeat cesarean delivery: Weight-based outcomes. Am J Obstet Gynecol. 2003;188(6):1516-1520. discussion 1520–1512. [pmid: 12824987].
19 Caughey AB, Shipp TD, Repke JT, Zelop CM, Cohen A, Lieberman E. Rate of uterine rupture during a trial of labor in women with one or two prior cesarean deliveries. Am J Obstet Gynecol. 1999;181(4):872-876. [pmid: 10521745].
20 Chang JJ, Stamilio DM, Macones GA. Effect of hospital volume on maternal outcomes in women with prior cesarean delivery undergoing trial of labor. Am J Epidemiol. 2008;167(6):711-718. [pmid: 18192674].
21 Chapman SJ, Owen J, Hauth JC. One-versus two-layer closure of a low transverse cesarean: the next pregnancy. Obstet Gynecol. 1997;89(1):16-18. [pmid: 8990429].
22 Chauhan SP, Magann EF, Carroll CS, Barrilleaux PS, Scardo JA, Martin JN Jr. Mode of delivery for the morbidly obese with prior cesarean delivery: vaginal versus repeat cesarean section. Am J Obstet Gynecol. 2001;185(2):349-354. [pmid: 11518890].
23 Chauhan SP, Magann EF, Wiggs CD, Barrilleaux PS, Martin JN Jr. Pregnancy after classic cesarean delivery. Obstet Gynecol. 2002;100(5 Pt 1):946-950. [pmid: 12423858].
24 Chestnut DH. Effect of anesthesia for repeat cesarean section on postoperative infectious morbidity. Obstet Gynecol. 1985;66(2):199-202. [pmid: 4022483].
25 Coughlan C, Kearney R, Turner MJ. What are the implications for the next delivery in primigravidae who have an elective caesarean section for breech presentation?. BJOG: An International Journal of Obstetrics & Gynaecology. 2002;109(6):624-626. [pmid: 12118638].
26 DeFranco EA, Rampersad R, Atkins KL, et al. Do vaginal birth after cesarean outcomes differ based on hospital setting?. Am J Obstet Gynecol. 2007;197(4):400.e401-406. [pmid: 17904977].
27 Delaney T, Young DC. Spontaneous versus induced labor after a previous cesarean delivery. Obstet Gynecol. 2003;102(1):39-44. [pmid: 12850605].
28 Dhall K, Mittal SC, Grover V, Dhall GI. Childbirth following primary cesarean section--evaluation of a scoring system. Int J Gynaecol Obstet. 1987;25(3):199-205. [pmid: 2886378].
29 DiMaio H, Edwards RK, Euliano TY, Treloar RW, Cruz AC. Vaginal birth after cesarean delivery: an historic cohort cost analysis. Am J Obstet Gynecol. 2002;186(5):890-892. [pmid: 12015504].
30 Dinsmoor MJ, Brock EL. Predicting failed trial of labor after primary cesarean delivery. Obstet Gynecol. 2004;103(2):282-286. [pmid: 14754696].
31 Duff P, Southmayd K, Read JA. Outcome of trial of labor in patients with a single previous low transverse cesarean section for dystocia. Obstet Gynecol. 1988;71(3 Pt 1):380-384. [pmid: 3347423].
32 Durnwald CP, Ehrenberg HM, Mercer BM. The impact of maternal obesity and weight gain on vaginal birth after cesarean section success. Am J Obstet Gynecol. 2004;191(3):954-957. [pmid: 15467571].
33 Durnwald C, Mercer B. Vaginal birth after Cesarean delivery: predicting success, risks of failure. J Matern Fetal Neonatal Med. 2004;15(6):388-393. [pmid: 15280110].
34 Edwards RK, Harnsberger DS, Johnson IM, Treloar RW, Cruz AC. Deciding on route of delivery for obese women with a prior cesarean delivery. Am J Obstet Gynecol. 2003;189(2):385-389. discussion 389–390. [pmid: 14520202].
35 Eglinton GS, Phelan JP, Yeh S, Diaz FP, Wallace TM, Paul RH. Outcome of a trial of labor after prior cesarean delivery. J Reprod Med. 1984;29(1):3-8. [pmid: 6708017].
36 Elkousy MA, Sammel M, Stevens E, Peipert JF, Macones G. The effect of birth weight on vaginal birth after cesarean delivery success rates. Am J Obstet Gynecol. 2003;188(3):824-830. [pmid: 12634665].
37 El-Sayed YY, Watkins MM, Fix M, Druzin ML, Pullen KM, Caughey AB. Perinatal outcomes after successful and failed trials of labor after cesarean delivery. Am J Obstet Gynecol. 2007;196(6):583. e581-585. discussion 583. e585. [pmid: 17547905].
38 Eriksen NL, Buttino L Jr. Vaginal birth after cesarean: a comparison of maternal and neonatal morbidity to elective repeat cesarean section. Am J Perinatol. 1989;6(4):375-379. [pmid: 2789534].
39 Fisler RE, Cohen A, Ringer SA, Lieberman E. Neonatal outcome after trial of labor compared with elective repeat cesarean section. Birth. 2003;30(2):83-88. [pmid: 12752164].
40 Flamm BL, Goings JR, Fuelberth NJ, Fischermann E, Jones C, Hersh E. Oxytocin during labor after previous cesarean section: results of a multicenter study. Obstet Gynecol. 1987;70(5):709-712. [pmid: 3309751].
41 Flamm BL, Goings JR. Vaginal birth after cesarean section: is suspected fetal macrosomia a contraindication?. Obstet Gynecol. 1989;74(5):694-697. [pmid: 2638575].
42 Flamm BL, Goings JR, Liu Y, Wolde-Tsadik G. Elective repeat cesarean delivery versus trial of labor: a prospective multicenter study. Obstet Gynecol. 1994;83(6):927-932. [pmid: 8190433].
43 Flamm BL, Geiger AM. Vaginal birth after cesarean delivery: an admission scoring system. Obstet Gynecol. 1997;90(6):907-910. [pmid: 9397100].
44 Gemer O, Segal S, Sassoon E. Detection of scar dehiscence at delivery in women with prior cesarean section. Acta Obstet Gynecol Scand. 1992;71(7):540-542. [pmid: 1332375].
45 Getahun D, Oyelese Y, Salihu HM, Ananth CV. Previous cesarean delivery and risks of placenta previa and placental abruption. Obstet Gynecol. 2006;107(4):771-778. [pmid: 16582111].
46 Gibson DH. Vaginal delivery after caesarean section in primigravidae. Ir J Med Sci. 1988;157(9):290-292. [pmid: 3235309].
47 Gonen R, Nisenblat V, Barak S, Tamir A, Ohel G. Results of a well-defined protocol for a trial of labor after prior cesarean delivery. Obstet Gynecol. 2006;107(2 Pt 1):240-245. [pmid: 16449107].
48 Gonen R, Barak S, Nissenblat V, Ohel G. The outcome and cumulative morbidity associated with the second and third postcesarean delivery. Am J Perinatol. 2007;24(8):483-486. [pmid: 17853343].
49 Goodall PT, Ahn JT, Chapa JB, Hibbard JU. Obesity as a risk factor for failed trial of labor in patients with previous cesarean delivery. Am J Obstet Gynecol. 2005;192(5):1423-1426. [pmid: 15902126].
50 Granovsky-Grisaru S, Shaya M, Diamant YZ. The management of labor in women with more than one uterine scar: is a repeat cesarean section really the only "safe" option?. J Perinat Med. 1994;22(1):13-17. [pmid: 8035290].
51 Gregory KD, Korst LM, Cane P, Platt LD, Kahn K. Vaginal birth after cesarean and uterine rupture rates in California. Obstet Gynecol. 1999;94(6):985-989. [pmid: 10576187].
52 Gregory KD, Korst LM, Fridman M, et al. Vaginal birth after cesarean: clinical risk factors associated with adverse outcome. Am J Obstet Gynecol. 2008;198(4):452.e451-410. discussion 452.e410–452. [pmid: 18395037].
53 Grobman WA, Gilbert S, Landon MB, et al. Outcomes of induction of labor after one prior cesarean. Obstet Gynecol. 2007;109(2 Pt 1):262-269. [pmid: 17267822].
54 Grobman WA, Lai Y, Landon MB, et al. Prediction of uterine rupture associated with attempted vaginal birth after cesarean delivery. Am J Obstet Gynecol. 2008;199(1):30.e31-35. [pmid: 18439555].
55 Grossetti E, Vardon D, Creveuil C, Herlicoviez M, Dreyfus M. Rupture of the scarred uterus. Acta Obstet Gynecol Scand. 2007;86(5):572-578. [pmid: 17464586].
56 Hammoud A, Hendler I, Gauthier RJ, Berman S, Sansregret A, Bujold E. The effect of gestational age on trial of labor after Cesarean section. J Matern Fetal Neonatal Med. 2004;15(3):202-206. [pmid: 15280148].
57 Hansell RS, McMurray KB, Huey GR. Vaginal birth after two or more cesarean sections: a five-year experience. Birth. 1990;17(3):146-150. discussion 150–141. [pmid: 2222640].
58 Hashima JN, Guise J-M. Vaginal birth after cesarean: a prenatal scoring tool. Am J Obstet Gynecol. 2007;196(5):e22-23. [pmid: 17466668].
59 Hemminki E, Shelley J, Gissler M. Mode of delivery and problems in subsequent births: a register-based study from Finland. Am J Obstet Gynecol. 2005;193(1):169-177. [pmid: 16021075].
60 Hershkowitz R, Fraser D, Mazor M, Leiberman JR. One or multiple previous cesarean sections are associated with similar increased frequency of placenta previa. Eur J Obstet Gynecol Reprod Biol. 1995;62(2):185-188. [pmid: 8582493].
61 Hibbard JU, Ismail MA, Wang Y, Te C, Karrison T. Failed vaginal birth after a cesarean section: how risky is it? I. Maternal morbidity. Am J Obstet Gynecol. 2001;184(7):1365-1371. discussion 1371–1363. [pmid: 11408854].
62 Hibbard JU, Gilbert S, Landon MB, et al. Trial of labor or repeat cesarean delivery in women with morbid obesity and previous cesarean delivery. Obstet Gynecol. 2006;108(1):125-133. [pmid: 16816066].
63 Hollard AL, Wing DA, Chung JH, et al. Ethnic disparity in the success of vaginal birth after cesarean delivery. J Matern Fetal Neonatal Med. 2006;19(8):483-487. [pmid: 16966113].
64 Hook B, Kiwi R, Amini SB, Fanaroff A, Hack M. Neonatal morbidity after elective repeat cesarean section and trial of labor. Pediatrics. 1997;100(3 Pt 1):348-353. [pmid: 9282704].
65 Horenstein JM, Eglinton GS, Tahilramaney MP, Boucher M, Phelan JP. Oxytocin use during a trial of labor in patients with previous cesarean section. J Reprod Med. 1984;29(1):26-30. [pmid: 6708016].
66 Horenstein JM, Phelan JP. Previous cesarean section: the risks and benefits of oxytocin usage in a trial of labor. Am J Obstet Gynecol. 1985;151(5):564-569. [pmid: 3976755].
67 Hoskins IA, Gomez JL. Correlation between maximum cervical dilatation at cesarean delivery and subsequent vaginal birth after cesarean delivery. Obstet Gynecol. 1997;89(4):591-593. [pmid: 9083318].
68 Johnson C, Oriol N, Flood K. Trial of labor: a study of 110 patients. J Clin Anesth. 1991;3(3):216-218. discussion 214–215. [pmid: 1878234].
69 Juhasz G, Gyamfi C, Gyamfi P, Tocce K, Stone JL. Effect of body mass index and excessive weight gain on success of vaginal birth after cesarean delivery. Obstet Gynecol. 2005;106(4):741-746. [pmid: 16199630].
70 Kamath BD, Todd JK, Glazner JE, Lezotte D, Lynch AM. Neonatal outcomes after elective cesarean delivery. Obstet Gynecol. 2009;113(6):1231-1238. [pmid: 19461417].
71 Kayani SI, Alfirevic Z. Uterine rupture after induction of labour in women with previous caesarean section. BJOG: An International Journal of Obstetrics & Gynaecology. 2005;112(4):451-455. [pmid: 15777443].
72 Kugler E, Shoham-Vardi I, Burstien E, Mazor M, Hershkovitz R. The safety of a trial of labor after cesarean section in a grandmultiparous population. Arch Gynecol Obstet. 2008;277(4):339-344. [pmid: 17957377].
73 Kwee A, Bots ML, Visser GHA, Bruinse HW. Obstetric management and outcome of pregnancy in women with a history of caesarean section in the Netherlands. Eur J Obstet Gynecol Reprod Biol. 2007;132(2):171-176. [pmid: 16904813].
74 Landon MB, Hauth JC, Leveno KJ, et al. Maternal and perinatal outcomes associated with a trial of labor after prior cesarean delivery. N Engl J Med. 2004;351(25):2581-2589. [pmid: 15598960].
75 Landon MB, Spong CY, Thom E, et al. Risk of uterine rupture with a trial of labor in women with multiple and single prior cesarean delivery. Obstet Gynecol. 2006;108(1):12-20. [pmid: 16816050].
76 Lieberman E, Ernst EK, Rooks JP, Stapleton S, Flamm B. Results of the national study of vaginal birth after cesarean in birth centers. Obstet Gynecol. 2004;104(5 Pt 1):933-942. [pmid: 15516382].
77 Lin C, Raynor BD. Risk of uterine rupture in labor induction of patients with prior cesarean section: an inner city hospital experience. Am J Obstet Gynecol. 2004;190(5):1476-1478. [pmid: 15167874].
78 Loebel G, Zelop CM, Egan JFX, Wax J. Maternal and neonatal morbidity after elective repeat Cesarean delivery versus a trial of labor after previous Cesarean delivery in a community teaching hospital. J Matern Fetal Neonatal Med. 2004;15(4):243-246. [pmid: 15280132].
79 Lydon-Rochelle M, Holt VL, Easterling TR, Martin DP. First-birth cesarean and placental abruption or previa at second birth(1). Obstet Gynecol. 2001;97(5 Pt 1):765-769. [pmid: 11339931].
80 Lydon-Rochelle M, Holt VL, Easterling TR, Martin DP. Risk of uterine rupture during labor among women with a prior cesarean delivery. N Engl J Med. 2001;345(1):3-8. [pmid: 11439945].
81 Macones GA, Peipert J, Nelson DB, et al. Maternal complications with vaginal birth after cesarean delivery: a multicenter study. Am J Obstet Gynecol. 2005;193(5):1656-1662. [pmid: 16260206].
82 Martin JN Jr, Harris BA Jr, Huddleston JF, et al. Vaginal delivery following previous cesarean birth. Am J Obstet Gynecol. 1983;146(3):255-263. [pmid: 6859134].
83 McMahon MJ, Luther ER, Bowes WA Jr, Olshan AF. Comparison of a trial of labor with an elective second cesarean section. N Engl J Med. 1996;335(10):689-695. [pmid: 8703167].
84 Melnikow J, Romano P, Gilbert WM, Schembri M, Keyzer J, Kravitz RL. Vaginal birth after cesarean in California. Obstet Gynecol. 2001;98(3):421-426. [pmid: 11530123].
85 Miller M, Leader LR. Vaginal delivery after caesarean section. Aust N Z J Obstet Gynaecol. 1992;32(3):213-216. [pmid: 1445129].
86 Naef RW 3rd, Ray MA, Chauhan SP, Roach H, Blake PG, Martin JN Jr. Trial of labor after cesarean delivery with a lower-segment, vertical uterine incision: is it safe?. Am J Obstet Gynecol. 1995;172(6):1666-1673. discussion 1673–1664. [pmid: 7778619].
87 Nisenblat V, Barak S, Griness OB, Degani S, Ohel G, Gonen R. Maternal complications associated with multiple cesarean deliveries. Obstet Gynecol. 2006;108(1):21-26. [pmid: 16816051].
88 Obara H, Minakami H, Koike T, Takamizawa S, Matsubara S, Sato I. Vaginal birth after cesarean delivery: results in 310 pregnancies. J Obstet Gynaecol Res. 1998;24(2):129-134. [pmid: 9631601].
89 Odibo AO, Cahill AG, Stamilio DM, Stevens EJ, Peipert JF, Macones GA. Predicting placental abruption and previa in women with a previous cesarean delivery. Am J Perinatol. 2007;24(5):299-305. [pmid: 17514600].
90 Ogunyemi D, Hullett S, Leeper J, Risk A. Prepregnancy body mass index, weight gain during pregnancy, and perinatal outcome in a rural black population. J Matern Fetal Med. 1998;7(4):190-193. [pmid: 9730485].
91 Ouzounian JG, Miller DA, Paul RH. Amnioinfusion in women with previous cesarean births: a preliminary report. Am J Obstet Gynecol. 1996;174(2):783-786. [pmid: 8623822].
92 Paterson CM, Saunders NJ. Mode of delivery after one caesarean section: audit of current practice in a health region. BMJ. 1991;303(6806):818-821. [pmid: 1932972].
93 Pathadey SD, Van Woerden HC, Jenkinson SD. Induction of labour after a previous caesarean section: a retrospective study in a district general hospital. J Obstet Gynaecol. 2005;25(7):662-665. [pmid: 16263539].
94 Paul RH, Phelan JP, Yeh SY. Trial of labor in the patient with a prior cesarean birth. Am J Obstet Gynecol. 1985;151(3):297-304. [pmid: 3970097].
95 Peaceman AM, Gersnoviez R, Landon MB, et al. The MFMU Cesarean Registry: impact of fetal size on trial of labor success for patients with previous cesarean for dystocia. Am J Obstet Gynecol. 2006;195(4):1127-1131. [pmid: 17000245].
96 Phelan JP, Clark SL, Diaz F, Paul RH. Vaginal birth after cesarean. Am J Obstet Gynecol. 1987;157(6):1510-1515. [pmid: 3425654].
97 Phelan JP, Ahn MO, Diaz F, Brar HS, Rodriguez MH. Twice a cesarean, always a cesarean?. Obstet Gynecol. 1989;73(2):161-165. [pmid: 2911420].
98 Pruett KM, Kirshon B, Cotton DB, Poindexter AN 3rd. Is vaginal birth after two or more cesarean sections safe?. Obstet Gynecol. 1988;72(2):163-165. [pmid: 3393359].
99 Quinones JN, Stamilio DM, Pare E, Peipert JF, Stevens E, Macones GA. The effect of prematurity on vaginal birth after cesarean delivery: success and maternal morbidity. Obstet Gynecol. 2005;105(3):519-524. [pmid: 15738018].
100 Rageth JC, Juzi C, Grossenbacher H. Delivery after previous cesarean: a risk evaluation. Swiss Working Group of Obstetric and Gynecologic Institutions. Obstet Gynecol. 1999;93(3):332-337. [pmid: 10074973].
101 Ravasia DJ, Wood SL, Pollard JK. Uterine rupture during induced trial of labor among women with previous cesarean delivery. Am J Obstet Gynecol. 2000;183(5):1176-1179. [pmid: 11084562].
102 Raynor BD. The experience with vaginal birth after cesarean delivery in a small rural community practice. Am J Obstet Gynecol. 1993;168(1 Pt 1):60-62. [pmid: 8420350].
103 Richardson BS, Czikk MJ, daSilva O, Natale R. The impact of labor at term on measures of neonatal outcome. Am J Obstet Gynecol. 2005;192(1):219-226. [pmid: 15672028].
104 Richter HE, Brumfield CG, Cliver SP, Burgio KL, Neely CL, Varner RE. Risk factors associated with anal sphincter tear: a comparison of primiparous patients, vaginal births after cesarean deliveries, and patients with previous vaginal delivery. Am J Obstet Gynecol. 2002;187(5):1194-1198. [pmid: 12439502].
105 Rozenberg P, Goffinet F, Phillippe HJ, Nisand I. Ultrasonographic measurement of lower uterine segment to assess risk of defects of scarred uterus. Lancet. 1996;347(8997):281-284. [pmid: 8569360].
106 Rozenberg P, Goffinet F, Philippe HJ, Nisand I. Thickness of the lower uterine segment: its influence in the management of patients with previous cesarean sections. Eur J Obstet Gynecol Reprod Biol. 1999;87(1):39-45. [pmid: 10579615].
107 Rudick V, Niv D, Hetman-Peri M, Geller E, Avni A, Golan A. Epidural analgesia for planned vaginal delivery following previous cesarean section. Obstet Gynecol. 1984;64(5):621-623. [pmid: 6493654].
108 Russillo B, Sewitch MJ, Cardinal L, Brassard N. Comparing rates of trial of labour attempts, VBAC success, and fetal and maternal complications among family physicians and obstetricians. J Obstet Gynaecol Can. 2008;30(2):123-128. [pmid: 18254993].
109 Sakala EP, Kaye S, Murray RD, Munson LJ. Oxytocin use after previous cesarean: why a higher rate of failed labor trial?. Obstet Gynecol. 1990;75(3 Pt 1):356-359. [pmid: 2304707].
110 Sakala EP, Kaye S, Murray RD, Munson LJ. Epidural analgesia. Effect on the likelihood of a successful trial of labor after cesarean section. J Reprod Med. 1990;35(9):886-890. [pmid: 2231564].
111 Schneider J, Gallego D, Benito R. Trial of labor after an earlier cesarean section. A conservative approach. J Reprod Med. 1988;33(5):453-456. [pmid: 3385700].
112 Sciscione AC, Landon MB, Leveno KJ, et al. Previous preterm cesarean delivery and risk of subsequent uterine rupture. Obstet Gynecol. 2008;111(3):648-653. [pmid: 18310367].
113 Shipp TD, Zelop C, Lieberman E. Assessment of the rate of uterine rupture at the first prenatal visit: a preliminary evaluation. J Matern Fetal Neonatal Med. 2008;21(2):129-133. [pmid: 18240082].
114 Smith GCS, Pell JP, Cameron AD, Dobbie R. Risk of perinatal death associated with labor after previous cesarean delivery in uncomplicated term pregnancies. JAMA. 2002;287(20):2684-2690. [pmid: 12020304].
115 Socol ML, Peaceman AM. Vaginal birth after cesarean: an appraisal of fetal risk. Obstet Gynecol. 1999;93(5 Pt 1):674-679. [pmid: 10912965].
116 Spaans WA, van der Vliet LME, Roell-Schorer EAM, Bleker OP, van Roosmalen J. Trial of labour after two or three previous caesarean sections. Eur J Obstet Gynecol Reprod Biol. 2003;110(1):16-19. [pmid: 12932864].
117 Spong CY, Landon MB, Gilbert S, et al. Risk of uterine rupture and adverse perinatal outcome at term after cesarean delivery. Obstet Gynecol. 2007;110(4):801-807. [pmid: 17906012].
118 Stone C, Halliday J, Lumley J, Brennecke S. Vaginal births after Caesarean (VBAC): a population study. Paediatr Perinat Epidemiol. 2000;14(4):340-348. [pmid: 11101021].
119 Strong TH Jr, Vega JS, O'Shaughnessy MJ, Feldman DB, Koemptgen JG. Amnioinfusion among women attempting vaginal birth after cesarean delivery. Obstet Gynecol. 1992;79(5 Pt 1):673-674. [pmid: 1565348].
120 Stovall TG, Shaver DC, Solomon SK, Anderson GD. Trial of labor in previous cesarean section patients, excluding classical cesarean sections. Obstet Gynecol. 1987;70(5):713-717. [pmid: 3658277].
121 Tahilramaney MP, Boucher M, Eglinton GS, Beall M, Phelan JP. Previous cesarean section and trial of labor. Factors related to uterine dehiscence. J Reprod Med. 1984;29(1):17-21. [pmid: 6708014].
122 Tucker JM, Hauth JC, Hodgkins P, Owen J, Winkler CL. Trial of labor after a one-or two-layer closure of a low transverse uterine incision. Am J Obstet Gynecol. 1993;168(2):545-546. [pmid: 8438925].
123 Upadhyaya CD, Upadhyaya DM, Carlan SJ. Vaginal birth after cesarean delivery in a small rural community with a solo practice. Am J Perinatol. 2003;20(2):63-67. [pmid: 12660910].
124 van der Walt WA, Cronje HS, Bam RH. Vaginal delivery after one cesarean section. Int J Gynaecol Obstet. 1994;46(3):271-277. [pmid: 7805995].
125 van Gelderen CJ, England MJ, Naylor GA, Katzeff TC. Labour in patients with a caesarean section scar. The place of oxytocin augmentation. Samj, S. 1986;70(9):529-532.
126 Videla FL, Satin AJ, Barth WH Jr, Hankins GD. Trial of labor: a disciplined approach to labor management resulting in a high rate of vaginal delivery. Am J Perinatol. 1995;12(3):181-184. [pmid: 7612091].
127 Weinstein D, Benshushan A, Tanos V, Zilberstein R, Rojansky N. Predictive score for vaginal birth after cesarean section. Am J Obstet Gynecol. 1996;174(1 Pt 1):192-198. [pmid: 8572005].
128 Wen SW, Rusen ID, Walker M, et al. Comparison of maternal mortality and morbidity between trial of labor and elective cesarean section among women with previous cesarean delivery. Am J Obstet Gynecol. 2004;191(4):1263-1269. [pmid: 15507951].
129 Yetman TJ, Nolan TE. Vaginal birth after cesarean section: a reappraisal of risk. Am J Obstet Gynecol. 1989;161(5):1119-1123. [pmid: 2486193].
130 Yogev Y, Ben-Haroush A, Lahav E, Horowitz E, Hod M, Kaplan B. Induction of labor with prostaglandin E2 in women with previous cesarean section and unfavorable cervix. Eur J Obstet Gynecol Reprod Biol. 2004;116(2):173-176. [pmid: 15358459].
131 Zelop CM, Shipp TD, Repke JT, Cohen A, Caughey AB, Lieberman E. Uterine rupture during induced or augmented labor in gravid women with one prior cesarean delivery. Am J Obstet Gynecol. 1999;181(4):882-886. [pmid: 10521747].
132 Zelop CM, Shipp TD, Repke JT, Cohen A, Lieberman E. Effect of previous vaginal delivery on the risk of uterine rupture during a subsequent trial of labor. Am J Obstet Gynecol. 2000;183(5):1184-1186. [pmid: 11084564].
133 Zelop CM, Shipp TD, Cohen A, Repke JT, Lieberman E. Trial of labor after 40 weeks' gestation in women with prior cesarean. Obstet Gynecol. 2001;97(3):391-393. [pmid: 11239643].
134 Adair CD, Sanchez-Ramos L, Gaudier FL, Kaunitz AM, McDyer DC, Briones D. Labor induction in patients with previous cesarean section. Am J Perinatol. 1995;12(6):450-454. [pmid: 8579661].
135 Bodelon C, Bernabe-Ortiz A, Schiff MA, Reed SD. Factors associated with peripartum hysterectomy. Obstet Gynecol. 2009;114(1):115-123. [pmid: 19546767].
136 Buhimschi CS, Buhimschi IA, Patel S, Malinow AM, Weiner CP. Rupture of the uterine scar during term labour: contractility or biochemistry?. BJOG: An International Journal of Obstetrics & Gynaecology. 2005;112(1):38-42. [pmid: 15663395].
137 Gilliam M, Rosenberg D, Davis F. The likelihood of placenta previa with greater number of cesarean deliveries and higher parity. Obstet Gynecol. 2002;99(6):976-980. [pmid: 12052584].
138 Guihard P, Blondel B. Trends in risk factors for caesarean sections in France between 1981 and 1995: lessons for reducing the rates in the future. BJOG: An International Journal of Obstetrics & Gynaecology. 2001;108(1):48-55. [pmid: 11213004].
139 Hadley CB, Mennuti MT, Gabbe SG. An evaluation of the relative risks of a trial of labor versus elective repeat cesarean section. Am J Perinatol. 1986;3(2):107-114. [pmid: 3964379].
140 Juntunen K, Makarainen L, Kirkinen P. Outcome after a high number (4–10) of repeated caesarean sections. BJOG: An International Journal of Obstetrics & Gynaecology. 2004;111(6):561-563. [pmid: 15198783].
141 Kacmar J, Bhimani L, Boyd M, Shah-Hosseini R, Peipert J. Route of delivery as a risk factor for emergent peripartum hysterectomy: a case-control study. Obstet Gynecol. 2003;102(1):141-145. [pmid: 12850620].
142 Laughon SK, Wolfe HM, Visco AG. Prior cesarean and the risk for placenta previa on second-trimester ultrasonography. Obstet Gynecol. 2005;105(5 Pt 1):962-965. [pmid: 15863531].
143 Leung AS, Farmer RM, Leung EK, Medearis AL, Paul RH. Risk factors associated with uterine rupture during trial of labor after cesarean delivery: a case-control study. Am J Obstet Gynecol. 1993;168(5):1358-1363. [pmid: 8498412].
144 Macones GA, Hausman N, Edelstein R, Stamilio DM, Marder SJ. Predicting outcomes of trials of labor in women attempting vaginal birth after cesarean delivery: a comparison of multivariate methods with neural networks. Am J Obstet Gynecol. 2001;184(3):409-413. [pmid: 11228495].
145 Macones GA, Cahill AG, Stamilio DM, Odibo A, Peipert J, Stevens EJ. Can uterine rupture in patients attempting vaginal birth after cesarean delivery be predicted?. Am J Obstet Gynecol. 2006;195(4):1148-1152. [pmid: 17000247].
146 McMahon MJ, Li R, Schenck AP, Olshan AF, Royce RA. Previous cesarean birth. A risk factor for placenta previa?. J Reprod Med. 1997;42(7):409-412. [pmid: 9252931].
147 Miles AL, Monga M, Waller DK, Dande D, Pschirrer ER. Risk factors for symptomatic uterine rupture during a trial of labor: the 1990s. Am J Perinatol. 2000;17(7):385-389. [pmid: 12141526].
148 Pickhardt MG, Martin JN Jr, Meydrech EF, et al. Vaginal birth after cesarean delivery: are there useful and valid predictors of success or failure?. Am J Obstet Gynecol. 1992;166(6 Pt 1):1811-1815. discussion 1815–1819. [pmid: 1615990].
149 Rochelson B, Pagano M, Conetta L, et al. Previous preterm cesarean delivery: identification of a new risk factor for uterine rupture in VBAC candidates. J Matern Fetal Neonatal Med. 2005;18(5):339-342. [pmid: 16390795].
150 Rouse DJ, Owen J, Hauth JC. Active-phase labor arrest: oxytocin augmentation for at least 4 hours. Obstet Gynecol. 1999;93(3):323-328. [pmid: 10074971].
151 Seidman DS, Paz I, Nadu A, et al. Are multiple cesarean sections safe?. Eur J Obstet Gynecol Reprod Biol. 1994;57(1):7-12. [pmid: 7821507].
152 Shimonovitz S, Botosneano A, Hochner-Celnikier D. Successful first vaginal birth after cesarean section: a predictor of reduced risk for uterine rupture in subsequent deliveries. Isr Med Assoc J. 2000;2(7):526-528. [pmid: 10979328].
153 Shipp TD, Zelop C, Cohen A, Repke JT, Lieberman E. Postcesarean delivery fever and uterine rupture in a subsequent trial of labor. Obstet Gynecol. 2003;101(1):136-139. [pmid: 12517658].
154 Tikkanen M, Nuutila M, Hiilesmaa V, Paavonen J, Ylikorkala O. Prepregnancy risk factors for placental abruption. Acta Obstet Gynecol Scand. 2006;85(1):40-44. [pmid: 16521678].
155 Uygur D, Gun O, Kelekci S, Ozturk A, Ugur M, Mungan T. Multiple repeat caesarean section: is it safe?. Eur J Obstet Gynecol Reprod Biol. 2005;119(2):171-175. [pmid: 15808374].
156 Uygur D, Tapisiz OL, Mungan T. Multiple repeat cesarean sections: maternal and neonatal outcomes. Int J Gynaecol Obstet. 2005;89(3):284-285. [pmid: 15919400].
157 Wu S, Kocherginsky M, Hibbard JU. Abnormal placentation: twenty-year analysis. Am J Obstet Gynecol. 2005;192(5):1458-1461. [pmid: 15902137].
158 Armstrong CA, Harding S, Matthews T, Dickinson JE. Is placenta accreta catching up with us?. Aust N Z J Obstet Gynaecol. 2004;44(3):210-213. [pmid: 15191444].
159 Asakura H, Nakai A, Ishikawa G, Suzuki S, Araki T. Prediction of uterine dehiscence by measuring lower uterine segment thickness prior to the onset of labor: evaluation by transvaginal ultrasonography. J Nippon Med Sch. 2000;67(5):352-356. [pmid: 11031364].
160 Blanco JD, Collins M, Willis D, Prien S. Prostaglandin E2 gel induction of patients with a prior low transverse cesarean section. Am J Perinatol. 1992;9(2):80-83. [pmid: 1590872].
161 Bujold E, Gauthier RJ. Neonatal morbidity associated with uterine rupture: what are the risk factors?. Am J Obstet Gynecol. 2002;186(2):311-314. [pmid: 11854656].
162 Chilaka VN, Cole MY, Habayeb OMH, Konje JC. Risk of uterine rupture following induction of labour in women with a previous caesarean section in a large UK teaching hospital. J Obstet Gynaecol. 2004;24(3):264-265. [pmid: 15203621].
163 Gotoh H, Masuzaki H, Yoshida A, Yoshimura S, Miyamura T, Ishimaru T. Predicting incomplete uterine rupture with vaginal sonography during the late second trimester in women with prior cesarean. Obstet Gynecol. 2000;95(4):596-600. [pmid: 10725496].
164 Grobman WA, Lai Y, Landon MB, et al. Development of a nomogram for prediction of vaginal birth after cesarean delivery. Obstet Gynecol. 2007;109(4):806-812. [pmid: 17400840].
165 Kieser KE, Baskett TF. A 10-year population-based study of uterine rupture. Obstet Gynecol. 2002;100(4):749-753. [pmid: 12383544].
166 Landon MB, Leindecker S, Spong CY, et al. The MFMU Cesarean Registry: factors affecting the success of trial of labor after previous cesarean delivery. Am J Obstet Gynecol. 2005;193(3 Pt 2):1016-1023. [pmid: 16157104].
167 Leung AS, Leung EK, Paul RH. Uterine rupture after previous cesarean delivery: maternal and fetal consequences. Am J Obstet Gynecol. 1993;169(4):945-950. [pmid: 8238154].
168 Lynch JC, Pardy JP. Uterine rupture and scar dehiscence. A five-year survey. Anaesth Intensive Care. 1996;24(6):699-704. [pmid: 8971320].
169 Meehan FP, Burke G. Trial of labour following prior section; a 5 year prospective study (1982–1987). Eur J Obstet Gynecol Reprod Biol. 1989;31(2):109-117. [pmid: 2759320].
170 Mercer BM, Gilbert S, Landon MB, et al. Labor outcomes with increasing number of prior vaginal births after cesarean delivery. Obstet Gynecol. 2008;111(2 Pt 1):285-291. [pmid: 18238964].
171 Scott JR. Mandatory trial of labor after cesarean delivery: an alternative viewpoint. Obstet Gynecol. 1991;77(6):811-814. [pmid: 2030847].
172 Sheiner E, Levy A, Menes TS, Silverberg D, Katz M, Mazor M. Maternal obesity as an independent risk factor for caesarean delivery. Paediatr Perinat Epidemiol. 2004;18(3):196-201. [pmid: 15130159].
173 Shipp TD, Zelop C, Repke JT, Cohen A, Caughey AB, Lieberman E. The association of maternal age and symptomatic uterine rupture during a trial of labor after prior cesarean delivery. Obstet Gynecol. 2002;99(4):585-588. [pmid: 12039116].
174 Silver RM, Landon MB, Rouse DJ, et al. Maternal morbidity associated with multiple repeat cesarean deliveries. Obstet Gynecol. 2006;107(6):1226-1232. [pmid: 16738145].
175 Yucel O, Ozdemir I, Yucel N, Somunkiran A. Emergency peripartum hysterectomy: a 9-year review. Arch Gynecol Obstet. 2006;274(2):84-87. [pmid: 16463166].
176 Zelop CM, Harlow BL, Frigoletto FD Jr, Safon LE, Saltzman DH. Emergency peripartum hysterectomy. Am J Obstet Gynecol. 1993;168(5):1443-1448. [pmid: 8498425].
177 Bujold E. Uterine rupture during a trial of labor after a one-versus two-layer closure of low transverse cesarean. Am J Obstet Gynecol. 2001;184(suppl S18).
178 Cameron CA, Roberts CL, Peat B. Predictors of labor and vaginal birth after cesarean section. Int J Gynaecol Obstet. 2004;85(3):267-269. [pmid: 15145263].
179 Costantine MM, Fox K, Byers BD, et al. Validation of the prediction model for success of vaginal birth after cesarean delivery. Obstet Gynecol. 2009;114(5):1029-1033. [pmid: 20168103].
180 Gonen R, Tamir A, Degani S, Ohel G. Variables associated with successful vaginal birth after one cesarean section: a proposed vaginal birth after cesarean section score. Am J Perinatol. 2004;21(8):447-453. [pmid: 15580540].
181 Gyamfi C, Juhasz G, Gyamfi P, Stone JL. Increased success of trial of labor after previous vaginal birth after cesarean. Obstet Gynecol. 2004;104(4):715-719. [pmid: 15458891].
182 Harper LM, Cahill AG, Stamilio DM, Odibo AO, Peipert JF, Macones GA. Effect of gestational age at the prior cesarean delivery on maternal morbidity in subsequent VBAC attempt. Am J Obstet Gynecol. 2009;200(3):276. e271-276. [pmid: 19167694].
183 Hendler I, Bujold E. Effect of prior vaginal delivery or prior vaginal birth after cesarean delivery on obstetric outcomes in women undergoing trial of labor. Obstet Gynecol. 2004;104(2):273-277. [pmid: 15291999].
184 Huang WH, Nakashima DK, Rumney PJ, Keegan KA Jr, Chan K. Interdelivery interval and the success of vaginal birth after cesarean delivery. Obstet Gynecol. 2002;99(1):41-44. [pmid: 11777508].
185 Hueston WJ, Rudy M. Factors predicting elective repeat cesarean delivery. Obstet Gynecol. 1994;83(5 Pt 1):741-744. [pmid: 8164936].
186 Jakobi P, Weissman A, Peretz BA, Hocherman I. Evaluation of prognostic factors for vaginal delivery after cesarean section. J Reprod Med. 1993;38(9):729-733. [pmid: 8254598].
187 Kabir AA, Pridjian G, Steinmann WC, Herrera EA, Khan MM. Racial differences in cesareans: an analysis of U.S. 2001 National Inpatient Sample Data. Obstet Gynecol. 2005;105(4):710-718. [pmid: 15802395].
188 Fawcett J, Tulman L, Spedden J. Responses to vaginal birth after cesarean section. J Obstet Gynecol Neonatal Nurs. 1994;23(3):253-259.
189 Learman LA, Evertson LR, Shiboski S. Predictors of repeat cesarean delivery after trial of labor: do any exist?. J Am Coll Surg. 1996;182(3):257-262. [pmid: 8603247].
190 Pang MW, Law LW, Leung TY, Lai PY, La TK. Sociodemographic factors and pregnancy events associated with women who declined vaginal birth after cesarean section. Eur J Obstet Gynecol Reprod Biol. 2009;143(1):24-28. [pmid: 19136194].
191 Selo-Ojeme D, Abulhassan N, Mandal R, Tirlapur S, Selo-Ojeme U. Preferred and actual delivery mode after a cesarean in London, UK. Int J Gynaecol Obstet. 2008;102(2):156-159. [pmid: 18436222].
192 Shipp TD, Zelop CM, Repke JT, Cohen A, Caughey AB, Lieberman E. Labor after previous cesarean: influence of prior indication and parity. Obstet Gynecol. 2000;95(6 Pt 1):913-916. [pmid: 10831991].
193 Smith GCS, White IR, Pell JP, Dobbie R. Predicting cesarean section and uterine rupture among women attempting vaginal birth after prior cesarean section. PLoS Med. 2005;2(9):e252. [pmid: 16146414].
194 Spaans WA, Sluijs MB, van Roosmalen J, Bleker OP. Risk factors at caesarean section and failure of subsequent trial of labour. Eur J Obstet Gynecol Reprod Biol. 2002;100(2):163-166. [pmid: 11750957].
195 Srinivas SK, Stamilio DM, Stevens EJ, Odibo AO, Peipert JF, Macones GA. Predicting failure of a vaginal birth attempt after cesarean delivery. Obstet Gynecol. 2007;109(4):800-805. [pmid: 17400839].
196 Strong JM, McQuillan K. Factors affecting mode of delivery in labour following a single previous birth by cesarean. Journal of Obs & Gyn. 1996;16(5).
197 Troyer LR, Parisi VM. Obstetric parameters affecting success in a trial of labor: designation of a scoring system. Am J Obstet Gynecol. 1992;167(4 Pt 1):1099-1104. [pmid: 1415398].
198 Vinueza CA, Chauhan SP, Barker L, Hendrix NW, Scardo JA. Predicting the success of a trial of labor with a simple scoring system. J Reprod Med. 2000;45(4):332-336. [pmid: 10804491].