# List of Citations From the Maternal-Fetal Medicine Units Network Cohort

Overview: This appendix contains the full-text papers used from the National Institute of Child Health and Human Development Maternal-Fetal Medicine Units Network (MFMU) in this report by key question.

Description of overall cohort: The MFMU cohort drew subjects from 19 academic medical centers and report on 45,988 women with singleton gestation and prior cesarean delivery. The Network, established in 1986, was designed to focus on clinical questions in maternal-fetal medicine and obstetrics, particularly with respect to the continuing problem of preterm birth.

## Key Question 1

- Grobman, 2007^1^
- Landon, 2004^2^
- Mercer, 2008^3^
- Peaceman, 2006^4^

## Key Question 2

- Grobman, 2007^5^
- Grobman, 2008^6^
- Hibbard, 2006^7^
- Landon, 2004^2^
- Landon, 2006^8^
- Mercer, 2008^3^
- Rouse, 2006^9^
- Silver, 2006^10^
- Spong, 2007^11^

## Key Question 3

- Grobman, 2007^5^
- Hibbard, 2006^7^
- Landon, 2006^8^
- Spong, 2007^11^

## References

1 Grobman WA, Lai Y, Landon MB, et al. Development of a nomogram for prediction of vaginal birth after cesarean delivery. Obstet Gynecol. 2007;109(4):806-812. [pmid: 17400840].
2 Landon MB, Hauth JC, Leveno KJ, et al. Maternal and perinatal outcomes associated with a trial of labor after prior cesarean delivery. N Engl J Med. 2004;351(25):2581-2589. [pmid: 15598960].
3 Mercer BM, Gilbert S, Landon MB, et al. Labor outcomes with increasing number of prior vaginal births after cesarean delivery. Obstet Gynecol. 2008;111(2 Pt 1):285-291. [pmid: 18238964].
4 Peaceman AM, Gersnoviez R, Landon MB, et al. The MFMU Cesarean Registry: impact of fetal size on trial of labor success for patients with previous cesarean for dystocia. American Journal of Obstetrics & Gynecology. 2006;195(4):1127-1131. [pmid: 17000245].
5 Grobman WA, Gilbert S, Landon MB, et al. Outcomes of induction of labor after one prior cesarean. Obstet Gynecol. 2007;109(2 Pt 1):262-269. [pmid: 17267822].
6 Grobman WA, Lai Y, Landon MB, et al. Prediction of uterine rupture associated with attempted vaginal birth after cesarean delivery. American Journal of Obstetrics & Gynecology. 2008;199(1):30.e31-35. [pmid: 18439555].
7 Hibbard JU, Gilbert S, Landon MB, et al. Trial of labor or repeat cesarean delivery in women with morbid obesity and previous cesarean delivery. Obstet Gynecol. 2006;108(1):125-133. [pmid: 16816066].
8 Landon MB, Spong CY, Thom E, et al. Risk of uterine rupture with a trial of labor in women with multiple and single prior cesarean delivery. Obstet Gynecol. 2006;108(1):12-20. [pmid: 16816050].
9 Rouse DJ, MacPherson C, Landon M, et al. Blood transfusion and cesarean delivery.[erratum appears in Obstet Gynecol. 2006 Dec;108(6):1556]. Obstet Gynecol. 2006;108(4):891-897. [pmid: 17012451].
10 Silver RM, Landon MB, Rouse DJ, et al. Maternal morbidity associated with multiple repeat cesarean deliveries. Obstet Gynecol. 2006;107(6):1226-1232. [pmid: 16738145].
11 Spong CY, Landon MB, Gilbert S, et al. Risk of uterine rupture and adverse perinatal outcome at term after cesarean delivery. Obstet Gynecol. 2007;110(4):801-807. [pmid: 17906012].