# Inclusion and Exclusion Criteria

## Abstract Review Coding

### Inclusions

- IN for a specific key question or topic area
- Background for general, question 1 or question 2

### Exclusions

- No data
- Wrong Population (animal study, abortion, multiple gestations, etc)
- Opinion or Letter with No Data
- No previous cesarean
- Developing country

## Full-Text Paper Review Coding

### Inclusions

- IN for a specific key question or topic area
- In, but no comparator
- Background for general, question 1 or question 2

### Exclusions

- No data for topic
- Wrong Population (specify reason: no previous cesarean, animal study, abortion, multiple gestations, pre-existing medical condition, pre-term (<37 weeks), cadavers, etc)
- No full-text paper or Opinion or Letter with No Data
- Cannot isolate our population of interest (specify reason)
- Developing country/Not in English
- < 10 subjects
- Study began or published before 1980
- Insufficient to determine population