# List of Developed Countries

## Excerpt from CIA World Factbook 2008^1^

### Developed Countries

The top group in the hierarchy of developed countries (DCs), former USSR/Eastern Europe (former USSR/EE), and less developed countries (LDCs); includes the market-oriented economies of the mainly democratic nations in the Organization for Economic Cooperation and Development (OECD), Bermuda, Israel, South Africa, and the European ministates; also known as the First World, high-income countries, the North, industrial countries; generally have a per capita GDP in excess of $10,000 although four OECD countries and South Africa have figures well under $10,000 and two of the excluded OPEC countries have figures of more than $10,000.

### The 34 DCs are

Andorra

Australia

Austria

Belgium

Bermuda

Canada

Denmark

Faroe Islands

Finland

France

Germany

Greece

Holy See

Iceland

Ireland

Israel

Italy

Japan

Liechtenstein

Luxembourg

Malta

Monaco

Netherlands

NZ

Norway

Portugal

San Marino

South Africa

Spain, Sweden

Switzerland

Turkey

UK

US

1 The World Factbook 2008. Washington, D. C. Central Intelligence Agency. 2008.