# Search Strategies

## Core Search

Database: Ovid MEDLINE(R) <1950 to August Week 4 2009>

1. exp Vaginal Birth after Cesarean/(856)
2. vbac.mp. (264)
3. (vagina$ adj3 (birth$ or born or deliver$) adj7 ((after$ or follow$ or previous$ or prior or history) adj3 (cesarean$ or caesarean$))).mp. [mp=title, original title, abstract, name of substance word, subject heading word] (1448)
4. 1 or 3 or 2 (1470)
5. exp "Trial of Labor"/(682)
6. (trial of labor or trial of labour).mp. [mp=title, original title, abstract, name of substance word, subject heading word] (937)
7. tol.mp. (949)
8. 6 or 7 (1833)
9. exp pregnancy/or exp pregnancy complications/(654827)
10. exp Infant, Newborn/(429340)
11. exp Obstetrics/(13288)
12. exp Obstetric Surgical Procedures/(89545)
13. 11 or 10 or 9 or 12 (981159)
14. 8 and 13 (947)
15. 14 or 5 (947)
16. exp Cesarean Section, Repeat/(395)
17. ((repeat$ or multip$ or another or prior or previous$) adj3 (cesarean$ or caesarean$)).mp. [mp=title, original title, abstract, name of substance word, subject heading word] (2585)
18. ((second or third) adj cesarean).mp. [mp=title, original title, abstract, name of substance word, subject heading word] (30)
19. 16 or 17 or 18 (2601)
20. 4 or 19 or 15 (3607)
21. limit 20 to (english language and humans) (2888)

Database: EBM Reviews - Cochrane Central Register of Controlled Trials <3rd Quarter 2009>

1. vbac.mp. (6)
2. (vagina$ adj3 (birth$ or born or deliver$) adj7 ((after$ or follow$ or previous$ or prior or history) adj3 (cesarean$ or caesarean$))).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] (14)
3. 1 or 2 (17)
4. (trial of labor or trial of labour).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] (38)
5. tol.mp. (16)
6. 4 or 5 (53)
7. ((repeat$ or multip$ or another or prior or previous$) adj3 (cesarean$ or caesarean$)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] (113)
8. ((second or third) adj cesarean).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] (1)
9. 7 or 8 (113)
10. 6 or 3 or 9 (160)

Database: EBM Reviews - Cochrane Database of Systematic Reviews <1st Quarter 2009>

1. vbac.mp. (4)
2. (vagina$ adj3 (birth$ or born or deliver$) adj7 ((after$ or follow$ or previous$ or prior or history) adj3 (cesarean$ or caesarean$))).mp. [mp=title, abstract, full text, keywords, caption text] (15)
3. 1 or 2 (16)
4. (trial of labor or trial of labour).mp. [mp=title, abstract, full text, keywords, caption text] (13)
5. tol.mp. (2)
6. 4 or 5 (15)
7. ((repeat$ or multip$ or another or prior or previous$) adj3 (cesarean$ or caesarean$)).mp. [mp=title, abstract, full text, keywords, caption text] (65)
8. ((second or third) adj cesarean).mp. [mp=title, abstract, full text, keywords, caption text] (0)
9. 7 or 8 (65)
10. 6 or 3 or 9 (72)

Database: EBM Reviews - Database of Abstracts of Reviews of Effects <3rd Quarter 2009>

1. vbac.mp. (2)
2. (vagina$ adj3 (birth$ or born or deliver$) adj7 ((after$ or follow$ or previous$ or prior or history) adj3 (cesarean$ or caesarean$))).mp. [mp=title, full text, keywords] (1)
3. 1 or 2 (3)
4. (trial of labor or trial of labour).mp. [mp=title, full text, keywords] (8)
5. tol.mp. (3)
6. 4 or 5 (9)
7. ((repeat$ or multip$ or another or prior or previous$) adj3 (cesarean$ or caesarean$)).mp. [mp=title, full text, keywords] (17)
8. ((second or third) adj cesarean).mp. [mp=title, full text, keywords] (0)
9. 7 or 8 (17)

## Uterine Rupture Specific Search

Database: Ovid MEDLINE(R) <1950 to August Week 4 2009>

1. exp Vaginal Birth after Cesarean/(858)
2. vbac.mp. (266)
3. (vagina$ adj3 (birth$ or born or deliver$) adj7 ((after$ or follow$ or previous$ or prior or history) adj3 (cesarean$ or caesarean$))).mp. [mp=title, original title, abstract, name of substance word, subject heading word] (1450)
4. 1 or 3 or 2 (1473)
5. exp "Trial of Labor"/(682)
6. (trial of labor or trial of labour).mp. [mp=title, original title, abstract, name of substance word, subject heading word] (937)
7. tol.mp. (949)
8. 6 or 7 (1833)
9. exp pregnancy/or exp pregnancy complications/(655357)
10. exp Infant, Newborn/(429611)
11. exp Obstetrics/(13301)
12. exp Obstetric Surgical Procedures/(89607)
13. 11 or 10 or 9 or 12 (981885)
14. 8 and 13 (947)
15. 14 or 5 (947)
16. exp Cesarean Section, Repeat/(396)
17. ((repeat$ or multip$ or another or prior or previous$) adj3 (cesarean$ or caesarean$)).mp. [mp=title, original title, abstract, name of substance word, subject heading word] (2587)
18. ((second or third) adj cesarean).mp. [mp=title, original title, abstract, name of substance word, subject heading word] (30)
19. 16 or 17 or 18 (2603)
20. 4 or 19 or 15 (3610)
21. limit 20 to (english language and humans) (2891)
22. ((uterine or uterus) adj5 (ruptur$ or tear$ or torn or perforat$ or lacerat$ or trauma$ or damag$ or injur$)).mp. (5413)
23. 22 and 21 (611)

## Obesity Specific Search

Database: Ovid MEDLINE(R) <1950 to August Week 4 2009>

1. exp Vaginal Birth after Cesarean/(858)
2. vbac.mp. (266)
3. (vagina$ adj3 (birth$ or born or deliver$) adj7 ((after$ or follow$ or previous$ or prior or history) adj3 (cesarean$ or caesarean$))).mp. [mp=title, original title, abstract, name of substance word, subject heading word] (1450)
4. 1 or 3 or 2 (1473)
5. exp "Trial of Labor"/(682)
6. (trial of labor or trial of labour).mp. [mp=title, original title, abstract, name of substance word, subject heading word] (937)
7. tol.mp. (949)
8. 6 or 7 (1833)
9. exp pregnancy/or exp pregnancy complications/(655357)
10. exp Infant, Newborn/(429611)
11. exp Obstetrics/(13301)
12. exp Obstetric Surgical Procedures/(89607)
13. 11 or 10 or 9 or 12 (981885)
14. 8 and 13 (947)
15. 14 or 5 (947)
16. exp Cesarean Section, Repeat/(396)
17. ((repeat$ or multip$ or another or prior or previous$) adj3 (cesarean$ or caesarean$)).mp. [mp=title, original title, abstract, name of substance word, subject heading word] (2587)
18. ((second or third) adj cesarean).mp. [mp=title, original title, abstract, name of substance word, subject heading word] (30)
19. 16 or 17 or 18 (2603)
20. 4 or 19 or 15 (3610)
21. limit 20 to (english language and humans) (2891) 22 exp Obesity/(91434)
22. body weight/or exp body weight changes/or exp overweight/or thinness/(239228)
23. exp "Body Weights and Measures"/(322374)
24. 22 or 24 or 23 (342869)
25. 21 and 25 (207)

## Multiple Cesarean Specific Search

Database: Ovid MEDLINE(R) <1950 to October Week 4 2009>

1. exp Cesarean Section, Repeat/(429)
2. ((repeat$ or multip$ or another) adj3 cesarean).mp. (1041)
3. ((second or third) adj cesarean).mp. (32)
4. 3 or 1 or 2 (1061)
5. limit 4 to (english language and humans) (855)
6. limit 5 to yr="1980 -Current" (833)
7. 4 not 1 (632)
8. limit 1 to (english language and humans and yr="1980 -Current") (364)
9. exp "Outcome and Process Assessment (Health Care)"/(471672)
10. exp Postoperative Complications/(344232)
11. (ae or co).fs. (2302892)
12. 11 or 10 or 9 (2833102)
13. ((repeat$ or multip$ or another or subsequent$ or previous$ or prior) adj3 cesarean).mp. (2237)
14. 3 or 13 (2254)
15. 12 and 14 (910)
16. limit 15 to (english language and humans and yr="1980 -Current") (716)
17. 16 not 8 (535)
18. 9 and 14 (107)
19. limit 18 to (english language and humans and yr="1980 -Current") (96)
20. 19 not 8 (75)
21. 17 not 20 (460)
22. from 21 keep 1–460 (460)

## Background Questions Specific Search

Database: Ovid MEDLINE(R) <1950 to October Week 1 2009>

1. exp Vaginal Birth after Cesarean/(888)
2. vbac.mp. (275)
3. (vagina$ adj3 (birth$ or born or deliver$) adj7 ((after$ or follow$ or previous$ or prior or history) adj3 cesarean)).mp. (1347)
4. 1 or 2 or 3 (1374)
5. exp "Trial of Labor"/(691)
6. (trial adj2 labor).mp. (927)
7. tol.mp. (984)
8. 6 or 7 (1856)
9. exp pregnancy/or exp pregnancy complications/(655043)
10. exp Infant, Newborn/(431654)
11. exp Obstetrics/(13439)
12. exp Obstetric Surgical Procedures/(89191)
13. 9 or 10 or 11 or 12 (985177)
14. 8 and 13 (938)
15. 5 or 14 (938)
16. exp Cesarean Section, Repeat/(428)
17. ((repeat$ or multip$ or another) adj3 cesarean).mp. (1039)
18. ((second or third) adj cesarean).mp. (32)
19. 18 or 16 or 17 (1059)
20. 4 or 19 or 15 (2507)
21. exp LEGISLATION as topic/(55190)
22. exp JURISPRUDENCE/(137951)
23. lj.fs. (171704)
24. 22 or 21 or 23 (295921)
25. 24 and 20 (68)
26. exp bioethical issues/(3229)
27. exp bioethics/(8140)
28. (ethic$ or bioethic$).mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier] (106986)
29. 27 or 28 or 26 (106986)
30. 29 and 20 (22)
31. exp human rights/(97424)
32. 31 and 20 (36)
33. 25 or 32 or 30 (95)
34. Physician's Practice Patterns/(29292)
35. 20 and 34 (55)
36. exp Attitude to Health/(216292)
37. 20 and 36 (138)
38. exp Economics/(415371)
39. ec.fs. (262834)
40. 38 or 39 (490853)
41. 20 and 40 (112)
42. exp Decision Making/(86984)
43. 20 and 42 (93)
44. exp Counseling/(26819)
45. 20 and 44 (14)
46. "attitude of health personnel"/or refusal to treat/(75034)
47. 20 and 46 (32)
48. exp Health Services Accessibility/(64701)
49. 20 and 48 (6)
50. exp "Health Services Needs and Demand"/(36937)
51. 20 and 50 (5)
52. exp Social Control Policies/(94601)
53. 20 and 52 (16)
54. exp Hospital Administration/(183749)
55. 20 and 54 (35)
56. 35 or 33 or 53 or 51 or 41 or 47 or 49 or 37 or 45 or 43 or 55 (424)
57. from 56 keep 1–424 (424)