# Expert Reviewers

## Individuals

Eugene Declercq, Ph.D. Assistant Dean, Doctoral Education Professor, Department of Community Health Sciences at Boston University
William Grobman, M.D., M.B.A. Assistant Professor of Obstetrics and Gynecology, Section of Maternal-Fetal Medicine, Department of Obstetrics and Gynecology, Assistant Professor of Preventative Medicine, Department of Preventative Medicine, Northwestern University Medical School
Stanley Ip, M.D. Investigator, TUFTS University Evidence-based Practice Center at New England Medical Center
Diana Petitti, M.D., M.P.H. Professor of Biomedical Informatics at Arizona State University
Amelia Psmythe Executive Director, Nursing Mothers Counsel of Oregon
Carol Sakala, Ph.D., M.S.P.H. Director of Programs with Childbirth Connections.
James Scott, M.D. Professor of Obstetrics and Gynecology in the School of Medicine at the University of Utah and Editor of the Green Journal

## Professional Organization Representation

American Academy of Family Physicians Represented by: Eric Wall, M.D., FAAFP; Senior Medical Director of Qualis Health
American College of Nurse-Midwives Represented by: Nancy Lowe, C.N.M., Ph.D.; Professor of Nurse-Midwifery in the college of Nursing at the University of Colorado Denver
American College of Obstetricians and Gynecologists Represented by: Carolyn Zelop, M.D.; St. Francis Care, Department of Maternal Fetal Medicine

## Federal Reviewers

Suzanne Haynes, Ph.D. Senior Science Advisor, Office on Women’s Health, US Department of Health and Human Services
Mark Klebanoff, M.D., M.P.H. Senior Investigator, National Institute of Child Health and Human Development, Epidemiology (EPI) Branch
Miriam Kuppermann, Ph.D., M.P.H. Professor in the Department of Obstetrics, Gynecology & Reproductive Sciences at the University of California, San Francisco
Susan Meikle, M.D., M.S.P.H. Contraception & Reproductive Health (CRH) Branch, National Institute of Child Health and Human Development, Contraception & Reproductive Health (CRH) Branch
Jun Zhang, M.D., Ph.D. Senior Investigator, National Institute of Child Health and Human Development, Epidemiology (EPI) Branch