# Detailed Hospital Stay Table

Table S-1 Length of stay: all studies from the United States

Author, year | Study description | N | Length of stay (days)
Term gestational age
Gregory, 2008^1^ | Retrospective cohort; - -Low risk: absence of maternal complications; - -High Risk: any maternal condition ICD-9 codes | 41,450 | Low-risk-TOL: 2.25 High-risk TOL: 2.86 | Low-risk ERCD: 3.02 High-risk ERCD: 3.26
Loebel, 2004^2^ | Retrospective cohort community teaching hospital | 1,408 | TOL: 2.02 | ERCD: 3.14
Hook, 1997^3^ | Prospective cohort level 1, 2, & 3 hospitals included | 989 | TOL only: 3.6(±1) VBAC: 3.1; (±2) TOL-CD: 4.8; (±2)^*^ | ERCD: 4.5(±1)^†^
Any gestational age
Eglinton, 1984^4^ | Retrospective cohort university hospital | 871 | VBAC 2.4(1.0) TOL-CD 5(1.4) | ERCD-VD :2.3 (0.7) ERCD no labor:4.9 (1.6) ERCD labor:4.9 (1.5)
Eriksen, 1989^5^ | Retrospective cohort military base | 139 | TOL: 3.1 ± 1.6 | ERCD: 5.4 days ± 2.0^‡^
Flamm, 1994^6^ | Prospective cohort 10 Kaiser hospitals in California | 7,229 | TOL: 57.2 hours ± 31.1 | ERCD: 84.9 hours ±26.3^§^
Hibbard, 2001^7^ | Prospective cohort university hospital | 2,450 | TOL: 3.26 ± 2.61 VBAC: 2.34 ± 1.85 TOL-CD: 5.31 ± 2.88 | ERCD: 5.04 ± 3.09
Phelan, 1987^8^ | Prospective cohort university hospital >2 prior CD only | 2,643 | VBAC: 2.2 TOL-CD: 4.2 | ERCD: 4.2

* p <0.01

† p =0.002

‡ p=0.001

§ p<0.001

Abbreviations: CD=cesarean delivery; ERCD=elective repeat cesarean delivery; TOL=trial of labor; TOL- CD=trial of labor followed by a cesarean delivery; VBAC=vaginal birth after a cesarean

## References

1 Gregory KD, Korst LM, Fridman M, et al. Vaginal birth after cesarean: clinical risk factors associated with adverse outcome. Am J Obstet Gynecol. 2008;198(4):452.e451-410. discussion 452.e410–452. [pmid: 18395037].
2 Loebel G, Zelop CM, Egan JFX, Wax J. Maternal and neonatal morbidity after elective repeat Cesarean delivery versus a trial of labor after previous Cesarean delivery in a community teaching hospital. J Matern Fetal Neonatal Med. 2004;15(4):243-246. [pmid: 15280132].
3 Hook B, Kiwi R, Amini SB, Fanaroff A, Hack M. Neonatal morbidity after elective repeat cesarean section and trial of labor. Pediatrics. 1997;100(3 Pt 1):348-353. [pmid: 9282704].
4 Eglinton GS, Phelan JP, Yeh S, Diaz FP, Wallace TM, Paul RH. Outcome of a trial of labor after prior cesarean delivery. J Reprod Med. 1984;29(1):3-8. [pmid: 6708017].
5 Eriksen NL, Buttino L Jr. Vaginal birth after cesarean: a comparison of maternal and neonatal morbidity to elective repeat cesarean section. Am J Perinatol. 1989;6(4):375-379. [pmid: 2789534].
6 Flamm BL, Goings JR, Liu Y, Wolde-Tsadik G. Elective repeat cesarean delivery versus trial of labor: a prospective multicenter study. Obstet Gynecol. 1994;83(6):927-932. [pmid: 8190433].
7 Hibbard JU, Ismail MA, Wang Y, Te C, Karrison T. Failed vaginal birth after a cesarean section: how risky is it? I. Maternal morbidity. Am J Obstet Gynecol. 2001;184(7):1365-1371. discussion 1371–1363. [pmid: 11408854].
8 Phelan JP, Clark SL, Diaz F, Paul RH. Vaginal birth after cesarean. Am J Obstet Gynecol. 1987;157(6):1510-1515. [pmid: 3425654].