# Detailed Infection Table

Table R-1 Infection rates for trial of labor versus elective repeat cesarean delivery

Author, year | Study description | N | Fever | Fever per 10,000 | Endometritis Chorio-amnionitis | Endometritis or Chorio-amnionitis per 10,000 | Wound/Other | Wound/Other per 10,000
Term gestational age
Eriksen, 1989^1^ | Retrospective cohort military base | 139 | TOL: 4/71 (5.6%) ERCD: 7/68 (10.2%) (p:NS) | TOL: 560 ERCD: 1020 (p:NS) | TOL: 2/71 (2.8%) ERCD: 1/68 (1.5%) (p:NS) | TOL: 280 ERCD: 150 | Not reported
Hook, 1997^2^ | Prospective cohort level 1, 2, & 3 hospital included | 989 | Maternal fever TOL: 38/492 (8%) ERCD: 0/497 (0%) (p=<0.0002) | Maternal fever TOL: 80 ERCD: 0 (p=<0.0002) | Not reported | Not reported | Not reported | Not reported
Loebel,2004^3^ | Retrospective cohort community teaching hospital | 1,408 | Not reported | Not reported | Not reported | Not reported | “Infection” ERCD: 11/481 (1.9%) VBAC 14/749 (2.3%) TOL-CD 9/178 (5.1%) (p:NS) | Infection” ERCD: 190 VBAC 230 TOL-CD 510 (p:NS)
Spong, 2007^4^ | MFMU network cohort 19 university hospitals | 39,117 | Not reported | Not reported | TOL: 442/15,323 (2.9%) ERCD no labor: 260/14,993(1.7 %) ERCD + labor: 101/2721 (3.7%) IRCD no labor 137/5002 (2.7%) IRCD + labor: 54/1078 (5.0%) | TOL: 290 ERCD no labor: 170 ERCD + labor: 370 IRCD no labor 270 IRCD + labor: 500 | Not reported | Not reported
Wen, 2004^5^ | Retrospective cohort Canadian registry ICD-9 codes | 308,755 | Not reported | Not reported | Not reported | Not reported | “Postpartum Infection” TOL: 487/128,960 (0.38%) ERCD: 837/179,795 (0.47%); Adjusted odds ratio: 0.86 (0.77–0.97) | “Postpartum Infection” TOL: 380 ERCD: 470 Adjusted odds ratio: 0.86 (0.77–0.97)
All gestational ages
Bais, 2001^6^ | Prospective cohort Netherlands regional hospital | 252 | TOL: 16/184 (9%) ERCD: 7/68 (10%) | TOL: 900 ERCD: 1000 | Not reported | Not reported | Not reported | Not reported
Cahill, 2006^7^ | Retrospective cohort 16 university & community hospitals | 6,619 | TOL: 329/5041 (6.52%) ERCD: 294/1578(18.63 %) | TOL: 652 ERCD: 1863 | Not reported | Not reported | Not reported | Not reported
Durnwald, 2004^8^ | Retrospective cohort university hospital | 768 | TOL: 27/522(5.2%) VBAC: 7/344(2.0%) TOL-CD: 20/178 (11.2%) ERCD: 6/246 (2.4%) | TOL: 520 VBAC: 200 TOL-CD: 1120 ERCD: 240 | Chorio- amnionitis TOL: 31/522(5.9%) VBAC: 18/344(5.2%) TOL-CD: 13/178(7.3%) ERCD: 0/246(0%) Endometritis TOL: 24/522 (4.6%) VBAC: 7/344(2%) TOL-CD: 17/178(9.6%) ERCD: 5/246(2%) | Chorio- amnionitis TOL: 590 VBAC: 520 TOL-CD: 730 ERCD: 0 Endometritis TOL: 460 VBAC: 200 TOL-CD: 960 ERCD: 200 | Not reported | Not reported
Flamm, 1994^9^ | Prospective cohort 10 Kaiser hospital in California | 7,229 | TOL: 638/5022 (12.7%) ERCD: 362/2208 (16.4%) | TOL: 1270 ERCD: 1640 | Not reported | Not reported | Not reported | Not reported
McMahon, 1996^10^ | Retrospective cohort population based longitudinal study Canada | 6,138 | TOL: 171/3424 (5.3%) ERCD: 185/2889 (6.4%) | TOL: 530 ERCD: 640 | Not reported | Not reported | Wound TOL 43/3424 (1.3%) ERCD 63/2889 (2.2%) | Wound TOL 130 ERCD 220
Phelan, 1987^11^ | Prospective Cohort University hospital ≥ 2 prior CD only | 2,643 | Planned TOL 159/1,796 (8.9%)^*^ VBAC: 53/1465 (3.6%) TOL-CD: 106/331 (32%) No Planned TOL 163/847 (19.2%) VBAC: 4/69 (5.8%) ERCD: 56/314 (18%) IRCD: 103/464 (22%) | Planned TOL 890^*^ VBAC: 360 TOL-CD: 320 No Planned TOL 1920 VBAC: 580 ERCD: 1800 IRCD: 2200 | Not reported | Not reported | Not reported | Not reported
Kugler, 2008^12^ | Retrospective cohort Israel University grand multiparous | 1,102 | IRCD^†^ 10/328 (3%), TOL: 9/619(1.5%), VBAC: 1/155(0.6%) | IRCD^†^ 300 TOL: 150 VBAC: 60 | Amnionitis IRCD^a^ 4/328(1.2%) TOL: 5/619 (0.8%), VBAC: 14/155 (9.0%) | Amnionitis IRCD^a^ 120 TOL: 80 VBAC: 900 | Not reported | Not reported
Eglinton, 1984^13^ | Retrospective cohort university hospital | 871 | VBAC: 6/240(2.5%) TOL-CD: 27/136 (19.8%) ERCD: 176/495 (35.5%) | VBAC: 250 TOL-CD: 1980 ERCD: 3550 | Not reported | Not reported | Not reported | Not reported
Chauhan, 2001^14^ | | 69 | Not reported | Not reported | TOL: 9/30 (30%) ERCD: 7/39 (18%) | TOL: 300 ERCD: 1800 | Wound TOL: 8/30(27%) ERCD: 3/39(8%) | Wound TOL: 2700 ERCD: 800
Hibbard, 2001^15^ | Prospective cohort university hospital | 2,450 | Not reported | Not reported | Endometritis ERCD: 38/431 (8.8%) TOL: 108/1,324 (8.2%) VBAC: 31/908 (3.4%) TOL-CD: 77/416 (18.5%) Chorio- amnionitis ERCD: 18/431 (4.2%) TOL: 169/1,324 (12.8%) VBAC: 102/908 (11.2%) TOL-CD: 67/416 (16%) | Endometritis ERCD: 880 TOL: 820 VBAC: 340 TOL-CD: 1850 Chorio- amnionitis ERCD: 420 TOL: 1280 VBAC: 1120 TOL-CD: 1600 | Not reported | Not reported
Martin, 1983^16^ | Prospective cohort 2 university centers | 709 | Not reported | Not reported | Endometritis VBAC: 1/101(1%) TOL-CD: 7/61 (11.5%) ERCD: 42/547 (7.7%) TOL: 8/162 = 4.9% | Endometritis VBAC: 100 TOL-CD: 1150 ERCD: 770 TOL: 490 | Wound VBAC: 0/101 TOL-CD: 3/61 (4.9%) ERCD: 12/547 (2.2%) Any TOL: 3/162 (1.9%) Pulmonary: VBAC: 5/101 (5%) TOL-CD: 1/61 (1.6%) ERCD: 31/547 (5.7%) Other: VBAC: 3/101 (3%) TOL-CD: 2/61 (3.2%) ERCD:36/547(6.6%) | Wound VBAC: 0 TOL-CD: 490 ERCD: 220 Any TOL: 190 Pulmonary VBAC: 500 TOL-CD: 160 ERCD: 570 Other: VBAC: 300 TOL-CD: 320 ERCD: 660

* p < .05;

† includes both ERCD as well as emergency CD

Abbreviations: ERCD=elective repeat cesarean delivery; IRCD=indicated repeat cesarean delivery; NS=not significant; TOL=trial of labor; TOL-CD=trial of labor followed by a cesarean delivery; UTI=urinary tract infection; VBAC=vaginal birth after cesarean

## References

1 Eriksen NL, Buttino L Jr. Vaginal birth after cesarean: a comparison of maternal and neonatal morbidity to elective repeat cesarean section. Am J Perinatol. 1989;6(4):375-379. [pmid: 2789534].
2 Hook B, Kiwi R, Amini SB, Fanaroff A, Hack M. Neonatal morbidity after elective repeat cesarean section and trial of labor. Pediatrics. 1997;100(3 Pt 1):348-353. [pmid: 9282704].
3 Loebel G, Zelop CM, Egan JFX, Wax J. Maternal and neonatal morbidity after elective repeat Cesarean delivery versus a trial of labor after previous Cesarean delivery in a community teaching hospital. J Matern Fetal Neonatal Med. 2004;15(4):243-246. [pmid: 15280132].
4 Spong CY, Landon MB, Gilbert S, et al. Risk of uterine rupture and adverse perinatal outcome at term after cesarean delivery. Obstet Gynecol. 2007;110(4):801-807. [pmid: 17906012].
5 Wen SW, Rusen ID, Walker M, et al. Comparison of maternal mortality and morbidity between trial of labor and elective cesarean section among women with previous cesarean delivery. Am J Obstet Gynecol. 2004;191(4):1263-1269. [pmid: 15507951].
6 Bais JM, van der Borden DM, Pel M, et al. Vaginal birth after caesarean section in a population with a low overall caesarean section rate. Eur J Obstet Gynecol Reprod Biol. 2001;96(2):158-162. [pmid: 11384799].
7 Cahill AG, Stamilio DM, Odibo AO, et al. Is vaginal birth after cesarean (VBAC) or elective repeat cesarean safer in women with a prior vaginal delivery?. Am J Obstet Gynecol. 2006;195(4):1143-1147. [pmid: 16846571].
8 Durnwald C, Mercer B. Vaginal birth after Cesarean delivery: predicting success, risks of failure. J Matern Fetal Neonatal Med. 2004;15(6):388-393. [pmid: 15280110].
9 Flamm BL, Goings JR, Liu Y, Wolde-Tsadik G. Elective repeat cesarean delivery versus trial of labor: a prospective multicenter study. Obstet Gynecol. 1994;83(6):927-932. [pmid: 8190433].
10 McMahon MJ, Luther ER, Bowes WA Jr, Olshan AF. Comparison of a trial of labor with an elective second cesarean section.[see comment]. N Engl J Med. 1996;335(10):689-695. [pmid: 8703167].
11 Phelan JP, Clark SL, Diaz F, Paul RH. Vaginal birth after cesarean. Am J Obstet Gynecol. 1987;157(6):1510-1515. [pmid: 3425654].
12 Kugler E, Shoham-Vardi I, Burstien E, Mazor M, Hershkovitz R. The safety of a trial of labor after cesarean section in a grandmultiparous population. Arch Gynecol Obstet. 2008;277(4):339-344. [pmid: 17957377].
13 Eglinton GS, Phelan JP, Yeh S, Diaz FP, Wallace TM, Paul RH. Outcome of a trial of labor after prior cesarean delivery. J Reprod Med. 1984;29(1):3-8. [pmid: 6708017].
14 Chauhan SP, Magann EF, Carroll CS, Barrilleaux PS, Scardo JA, Martin JN Jr. Mode of delivery for the morbidly obese with prior cesarean delivery: vaginal versus repeat cesarean section. Am J Obstet Gynecol. 2001;185(2):349-354. [pmid: 11518890].
15 Hibbard JU, Ismail MA, Wang Y, Te C, Karrison T. Failed vaginal birth after a cesarean section: how risky is it? I. Maternal morbidity. Am J Obstet Gynecol. 2001;184(7):1365-1371. discussion 1371–1363. [pmid: 11408854].
16 Martin JN Jr, Harris BA Jr, Huddleston JF, et al. Vaginal delivery following previous cesarean birth. Am J Obstet Gynecol. 1983;146(3):255-263. [pmid: 6859134].