# Predictive Tools of Uterine Rupture Table

Table P-2 Predictive tools of uterine rupture

Author, year, country | Study years/Population | # UR/population | Score development | Predictors included(point values if provided) | Factors, OR, and score | Score and UR
Shipp, 2008^1^ US | Retrospective Cohort 1984–1996 TOL among prior cesarean(4% among women with>1 CD) | 40/4,383 TOLs | Score development only | Maternal age (<30, 30–39; >40) interdelivery interval >18 months having > 1 prior cesarean number of prior VDs | [underlined: Factor OR (95%CI) Score] Age>40 5.8 (1.6–20.3) 2 Age 30–39 2.6 (1.1–6.0) 1 ≥ 2 prior CD 5.3 (2.1–12.9) 2 Interdelivery 2.4 (1.0–5.6) interval 1 Prior VD 0.3 (0.1–0.9) −1 | [underlined: Score% w/Score% UR (n)] −1 8.9% 0.26% (1) 0 36.8% 0.25 (4) 1 43.2% 1.11% (21) 2 8.4% 2.43% (9) 3 2.5% 3.70% (4) 4 0.2% 14.29% (1) Overall UR rate: 0.91%
Macones, 2006^2^ USA | Secondary Analysis of Nested Case- Control (nested in retrospective cohort) identified by ICD9 code 1996–2000 | 134 cases UR (670 controls)/25,000 TOLs Cases: UR TOL Controls: no UR TOL | At least 17 factors examined and analyzed using Chi square, unpaired-tests and the Mann- Whitney U test. Those significant at p<0.1 were included in two regression models using backwards stepwise elimination: antepartum and early intrapartum factors Final model selected by ROC characteristics | “No individual factors are sufficient” | [underlined: Factor OR (95%CI) Beta Coefficient] Mat Age 1.11 (1.05–1.17) 0.05 GA at deliv 1.12 (0.97–1.20) 0.11 Ethnicity .84 (.74–1.0) −0.43 Prior VD .40 (.20–.80) −0.83 Cerv dil >3cm .66 (.41–1.11) −0.39 IOL 1.94 (1.32–2.81) 0.59 | Antepartum model AUC 0.67 Intrapartum + Antepartum model AUC 0.70 optimal cut point yield sensititvity of 75% and FP rate of 40% Overall UR rate: 0.98%
Smith, 2005^3^ Scotland | Retrospective Cohort1985–2001 National Dataset hosp discharge and perinatal deaths Designed to look at unplanned CD (UR secondary) 40–43wks GA | 101 UR/23,386 1 prior CD | Score Development and Validation Groups | | [underlined: Factor for Emergent CD OR (95%CI)] Mat Age (5yr inc) 1.22 (1.16–1.28) Mat Ht (5cm inc) 0.75 (0.73–0.78) Male infant 1.18 (1.08–1.29) Prior VD 0.19 (0.17– 0.22) -1/5.08 (4.52–5.72) GA .66 | Predicted risk of UR associated with risk of Emergent CD Overall UR rate: 0.4–0.5%
Grobman, 2008^4^ | Cohort MFMU Cesarean registry 1999–2002 1 prior LTCD ≥37 weeks looked for factors known prenatally or at admission | 83 UR/11,855 LTCD TOL | Logistic Regression of factors associated with UR (20 factors) Divided population into development and testing populations ROC generated from regression and c statistic was determined Partitioned UR into 10 groups 0–0.5% 0.5–1.0% … 4.5–5.0% | Maternal age, ethnicity, BMI, Medical HX: recurrent indication for CD, time since last CD, N prior VD, VD before CD, prior PTD, prior birth wt, GDM, asthma, CHTN, connective tissue disorder Intrapartum: IOL, IOL indication, cervical exam, EGA, PIH | “Predictive nomogram was not developed because it would have little clinical value” [underlined: Factor OR (95%CI)] Any prior VD 0.44 (0.27–0.71) IOL 1.71 (1.11–2.69) Best Model to predict UR exp(w)/[1+exp(w)], where w=−4.81–0.82(previous VD) + 0.55(IOL) | ROC - 0.627 (0.568–0.686) ”predicted probabilities do not reflect empiric probabilities that the pt experienced” Overall UR rate: 0.7%

Abbreviations: CD=cesarean delivery; CHTN=chronic hypertension; CI=confidence interval; cm=centimeter; EGA= estimated gestational age; GA=gestational age; GDM=gestational diabetes mellitus; IOL=induction of labor; LTCD=low transverse cesarean delivery; MFMU=Maternal-Fetal Medicine Units Network; Ob HX= obstetric history; OR=odds ratio; PIH=pregnancy induced hypertension; PTD=permanently and totally disabled; ROC= receiver operating characteristic; TOL=trial of labor; UR= uterine rupture; VD=vaginal delivery; wks=weeks; wt=weight; y=year(s)

## References

1 Shipp TD, Zelop C, Lieberman E. Assessment of the rate of uterine rupture at the first prenatal visit: a preliminary evaluation. J Matern Fetal Neonatal Med. 2008;21(2):129-133. [pmid: 18240082].
2 Macones GA, Cahill AG, Stamilio DM, Odibo A, Peipert J, Stevens EJ. Can uterine rupture in patients attempting vaginal birth after cesarean delivery be predicted?[see comment]. Am J Obstet Gynecol. 2006;195(4):1148-1152. [pmid: 17000247].
3 Smith GCS, White IR, Pell JP, Dobbie R. Predicting cesarean section and uterine rupture among women attempting vaginal birth after prior cesarean section.[see comment]. PLoS Med. 2005;2(9):e252. [pmid: 16146414].
4 Grobman WA, Lai Y, Landon MB, et al. Prediction of uterine rupture associated with attempted vaginal birth after cesarean delivery. Am J Obstet Gynecol. 2008;199(1):30.e31-35. [pmid: 18439555].