# Detailed Maternal Mortality Table

Table O-1 Maternal mortality rates for trial of labor versus elective repeat cesarean delivery among any gestational age studies

Author, year | Study description | N | Overall maternal death (followed by death per 100,000) | Maternal death by delivery type (followed by death per 100,000)
Term gestational age
Gregory, 2008^1^ | Retrospective cohort Low risk = absence of maternal complications High Risk = any maternal condition ICD9 codes | 41,450 | 2/41,450 (0.005%) Overall: 5/100,000 Low-risk 1/29,126 (0.003%) 3/100,000 High-risk 1/12,324 (0.008%) 8/100,000 | Low-risk TOL: 0/8,292 (0%) RCD: 1/20,834 (0.005%) 4.7/100,000 High-risk TOL: 0/3,188 (0%) ERCD: 1/9,136 (0.011%) 10.9/100,000
Loebel 2004^2^ | Retrospective Cohort Community Teaching Hospital | 1,408 | 0/1,408 (0%) | TOL: 0/927 ERCD: 0/481
Spong,2007^3^ | MFMU Network cohort 19 University hospitals | 39,117 | 6/39,117 (0.015%) 15/100,000 | TOL: 1/15,323 (0.007%) 6.5/100,000 ERCD: (no indication/no labor): 5/14,993 (0.033%) 33.3/100,000 All other groups: 0
Wen, 2004^4^ | Retrospective cohort Canadian Registry ICD9 codes | 308,755 | 12/308,755 (0.004%) 4/100,000 | TOL: 2/128,960 (0.002%) 15/100,000 ERCD: 10/179,795 (0.006%) 5.6/100,000
Any gestational age
Bais, 2001^5^ | Prospective Cohort Netherlands Regional hospital | 252 | 0/252 (0%) | TOL: 0/184 ERCD: 0/68 O–1
Eglinton 1984^6^ | Retrospective cohort University Hospital | 871 | 1/871 (0.115%) 115/100,000 | TOL:0/308 ERCD: 1/563 117.6/100,000
Eriksen, 1989^7^ | Retrospective Cohort Military Base | 139 | 0/139 (0%) | TOL: 0/71 ERCD: 0/68
Flamm, 1994^8^ | Prospective cohort 10 Kaiser Hospital in CA | 7,229 | 1/7229 (0.014%) 14/100,000 | TOL 1/5022 (0.020%) 20/100,000 ERCD: 0/2208 (0%)
Martin, 1983^9^ | Prospective Cohort 2 University Centers | 709 | 0/709 (0%) | TOL: 0/162 ERCD: 0/547
Obara, 1998^10^ | Prospective Cohort University Hospital, Japan | 310 | 0/310 (0%) | TOL: 0/214 ERCD:0/96
Phelan,1987^11^ | Prospective Cohort University hospital ≤2 prior CD only | 2,643 | 2/2643 (0.076%) 76/100,000 | TOL: 1/1796 (0.056%) 55.7/100,000 RCD: 1/847 (0.118%)
Zelop, 1999^12^ | Retrospective Cohort University Hospital | 2,774 | 0/2774 (0%) | Not reported

Abbreviations: CA=California; CD=cesarean delivery; ERCD=elective repeat cesarean delivery; ICD-9= International Classification of Diseases, 9th Edition/Revision; MFMU=Maternal Fetal Medicine Units; RCD=repeat cesarean delivery; TOL=trial of labor

## References

1 Gregory KD, Korst LM, Fridman M, et al. Vaginal birth after cesarean: clinical risk factors associated with adverse outcome. Am J Obstet Gynecol. 2008;198(4):452.e451-410. discussion 452.e410–452. [pmid: 18395037].
2 Loebel G, Zelop CM, Egan JFX, Wax J. Maternal and neonatal morbidity after elective repeat Cesarean delivery versus a trial of labor after previous Cesarean delivery in a community teaching hospital. J Matern Fetal Neonatal Med. 2004;15(4):243-246. [pmid: 15280132].
3 Spong CY, Landon MB, Gilbert S, et al. Risk of uterine rupture and adverse perinatal outcome at term after cesarean delivery. Obstet Gynecol. 2007;110(4):801-807. [pmid: 17906012].
4 Wen SW, Rusen ID, Walker M, et al. Comparison of maternal mortality and morbidity between trial of labor and elective cesarean section among women with previous cesarean delivery. Am J Obstet Gynecol. 2004;191(4):1263-1269. [pmid: 15507951].
5 Bais JM, van der Borden DM, Pel M, et al. Vaginal birth after caesarean section in a population with a low overall caesarean section rate. Eur J Obstet Gynecol Reprod Biol. 2001;96(2):158-162. [pmid: 11384799].
6 Eglinton GS, Phelan JP, Yeh S, Diaz FP, Wallace TM, Paul RH. Outcome of a trial of labor after prior cesarean delivery. J Reprod Med. 1984;29(1):3-8. [pmid: 6708017].
7 Eriksen NL, Buttino L Jr. Vaginal birth after cesarean: a comparison of maternal and neonatal morbidity to elective repeat cesarean section. Am J Perinatol. 1989;6(4):375-379. [pmid: 2789534].
8 Flamm BL, Goings JR, Liu Y, Wolde-Tsadik G. Elective repeat cesarean delivery versus trial of labor: a prospective multicenter study. Obstet Gynecol. 1994;83(6):927-932. [pmid: 8190433].
9 Martin JN Jr, Harris BA Jr, Huddleston JF, et al. Vaginal delivery following previous cesarean birth. Am J Obstet Gynecol. 1983;146(3):255-263. [pmid: 6859134].
10 Obara H, Minakami H, Koike T, Takamizawa S, Matsubara S, Sato I. Vaginal birth after cesarean delivery: results in 310 pregnancies. J Obstet Gynaecol Res. 1998;24(2):129-134. [pmid: 9631601].
11 Phelan JP, Clark SL, Diaz F, Paul RH. Vaginal birth after cesarean. Am J Obstet Gynecol. 1987;157(6):1510-1515. [pmid: 3425654].
12 Zelop CM, Shipp TD, Repke JT, Cohen A, Caughey AB, Lieberman E. Uterine rupture during induced or augmented labor in gravid women with one prior cesarean delivery. Am J Obstet Gynecol. 1999;181(4):882-886. [pmid: 10521747].