# Induction of Labor Additional Figures

Figure M-1 Proportion with vaginal birth after cesarean and any method of induction of labor

Abbreviations: NaN=Not a number; VBAC=vaginal birth after cesarean

Figure M-2 Proportion with vaginal birth after cesarean after induction of labor with prostaglandin E_2_

Abbreviations: NaN=Not a number; VBAC=vaginal birth after cesarean

Figure M-3 Vaginal birth after cesarean rates with oxytocin augmentation