# Detailed Evaluation of Vaginal Birth After Cesarean Rates

## Introduction

A brief description on the vaginal birth after cesarean (VBAC) rate is included in the text of the evidence report. Detailed descriptions of the studies and analyses conducted on this topic are included in this appendix.

### Vaginal Birth After Cesarean

Sixty-seven studies, 14 fair quality prospective cohort studies1–14 and 53 retrospective cohort studies15–67 provided an overall summary estimate for VBAC of 74 percent (95 percent CI: 72 to 75 percent). The heterogeneity of this meta-analysis of 67 observational studies that included 368,304 women was high, I^2^ greater than 98 percent. To examine this heterogeneity, these studies were stratified and analyzed by study design (prospective versus retrospective; true cohort that included trial of labor (TOL) and elective repeat cesarean delivery (ERCD) versus studies of TOL only), country (United States [U.S.] versus non-U.S.), gestational age ([GA] term only versus all GAs) and by years when the data were collected (completed before 1996, during 1996, and started after 1996). None of these factors were found to result in statistically significant differences analysis of study design yielded a statistically significant association (p<0.05). The summary estimate for VBAC for 14 prospective studies was 73 percent (95 percent CI: 71 to 74 percent) compared with 77 percent (95 percent CI: 75 to 79 percent) for the 53 retrospective studies. The VBAC rate did not differ between studies that included both TOL and ERCD groups and those that focused exclusively on TOL (73 percent; 95 percent CI: 71 to 75 percent versus 74 percent; 95 percent CI 71 to 77 percent).Similarly when studies were stratified by country (U.S. versus Non-U.S.) and by GA at enrollment (term versus non-term studies), no clear associations emerged (Figures L-1 and L-2). The summary estimates for rates of VBAC were similar: for the 43 studies conducted in the U.S., 74 percent (95 percent CI: 72 to 76 percent) versus 73 percent (95 percent CI: 71 to 74 percent) for the 24 studies conducted outside the U.S.. In examining the GA for enrolled patients, the summary estimates for rates of VBAC were again similar: for the 18 studies of term deliveries, 73 percent (95 percent CI: 71 to 75 percent) versus 74 percent (95 percent CI: 72 to 76 percent) for the 49 studies that included preterm and term deliveries.

Figure L-1 Vaginal birth after cesarean rates in United States studies

Figure L-2 Vaginal birth after cesarean rates in studies conducted outside the United States

Finally, when the studies were stratified by years of data collection, the summary estimates of VBAC again remained similar: 73 percent (95 percent CI: 70 to 77 percent) for the 31 studies completed before 1996;^1, 2, 5, 8–14, 16, 26, 27, 30, 36–38, 43, 47–50, 53–55, 59, 61, 63, 65, 67, 68^ ; 74 percent (95 percent CI: 72 to 76 percent) for the 19 studies that included data collection during 1996^3, 19, 22–25, 32–34, 42, 44–46, 52, 57, 58, 60, 62, 64^ and 73 percent (95 percent CI: 70 to 75 percent) for the 17 studies started after 1996.^4, 6, 7, 15, 17, 18, 20, 21, 28, 29, 31, 35, 39, 41, 51, 56, 66^

#### Summary of vaginal Birth After Cesarean Rate

The rates of VBAC are highly variable in these studies. Most evidence of VBAC rates are from studies based in large tertiary care centers. While TOL rates have dropped over time, VBAC rates reported in observational studies have remained constant for the women who have a TOL. In studies based in the U.S., 74 percent of women who had a TOL delivered vaginally.

## References

1 Bais JM, van der Borden DM, Pel M, et al. Vaginal birth after caesarean section in a population with a low overall caesarean section rate. Eur J Obstet Gynecol Reprod Biol. 2001;96(2):158-162. [pmid: 11384799].
2 Flamm BL, Goings JR, Liu Y, Wolde-Tsadik G. Elective repeat cesarean delivery versus trial of labor: a prospective multicenter study. Obstet Gynecol. 1994;83(6):927-932. [pmid: 8190433].
3 Hendler I, Bujold E. Effect of prior vaginal delivery or prior vaginal birth after cesarean delivery on obstetric outcomes in women undergoing trial of labor. Obstet Gynecol. 2004;104(2):273-277. [pmid: 15291999].
4 Hibbard JU, Gilbert S, Landon MB, et al. Trial of labor or repeat cesarean delivery in women with morbid obesity and previous cesarean delivery. Obstet Gynecol. 2006;108(1):125-133. [pmid: 16816066].
5 Hook B, Kiwi R, Amini SB, Fanaroff A, Hack M. Neonatal morbidity after elective repeat cesarean section and trial of labor. Pediatrics. 1997;100(3 Pt 1):348-353. [pmid: 9282704].
6 Jakobi P, Weissman A, Peretz BA, Hocherman I. Evaluation of prognostic factors for vaginal delivery after cesarean section. J Reprod Med. 1993;38(9):729-733. [pmid: 8254598].
7 Landon MB, Spong CY, Thom E, et al. Risk of uterine rupture with a trial of labor in women with multiple and single prior cesarean delivery. Obstet Gynecol. 2006;108(1):12-20. [pmid: 16816050].
8 Lieberman E, Ernst EK, Rooks JP, Stapleton S, Flamm B. Results of the national study of vaginal birth after cesarean in birth centers. Obstet Gynecol. 2004;104(5 Pt 1):933-942. [pmid: 15516382].
9 Phelan JP, Clark SL, Diaz F, Paul RH. Vaginal birth after cesarean. Am J Obstet Gynecol. 1987;157(6):1510-1515. [pmid: 3425654].
10 Rozenberg P, Goffinet F, Philippe HJ, Nisand I. Thickness of the lower uterine segment: its influence in the management of patients with previous cesarean sections. Eur J Obstet Gynecol Reprod Biol. 1999;87(1):39-45. [pmid: 10579615].
11 Rozenberg P, Goffinet F, Phillippe HJ, Nisand I. Ultrasonographic measurement of lower uterine segment to assess risk of defects of scarred uterus. Lancet. 1996;347(8997):281-284. [pmid: 8569360].
12 Stovall TG, Shaver DC, Solomon SK, Anderson GD. Trial of labor in previous cesarean section patients, excluding classical cesarean sections. Obstet Gynecol. 1987;70(5):713-717. [pmid: 3658277].
13 Strong JM, McQuillan K. Factors affecting mode of delivery in labour following a single previous birth by cesarean. Journal of Obs & Gyn. 1996;16(5).
14 van Gelderen CJ, England MJ, Naylor GA, Katzeff TC. Labour in patients with a caesarean section scar. The place of oxytocin augmentation. Samj, S. 1986;70(9):529-532.
15 Cameron CA, Roberts CL, Peat B. Predictors of labor and vaginal birth after cesarean section. Int J Gynaecol Obstet. 2004;85(3):267-269. [pmid: 15145263].
16 Caughey AB, Shipp TD, Repke JT, Zelop CM, Cohen A, Lieberman E. Rate of uterine rupture during a trial of labor in women with one or two prior cesarean deliveries. Am J Obstet Gynecol. 1999;181(4):872-876. [pmid: 10521745].
17 Costantine MM, Fox K, Byers BD, et al. Validation of the prediction model for success of vaginal birth after cesarean delivery. Obstet Gynecol. 2009;114(5):1029-1033. [pmid: 20168103].
18 DeFranco EA, Rampersad R, Atkins KL, et al. Do vaginal birth after cesarean outcomes differ based on hospital setting?. Am J Obstet Gynecol. 2007;197(4):400.e401-406. [pmid: 17904977].
19 Delaney T, Young DC. Spontaneous versus induced labor after a previous cesarean delivery. Obstet Gynecol. 2003;102(1):39-44. [pmid: 12850605].
20 DiMaio H, Edwards RK, Euliano TY, Treloar RW, Cruz AC. Vaginal birth after cesarean delivery: an historic cohort cost analysis. Am J Obstet Gynecol. 2002;186(5):890-892. [pmid: 12015504].
21 Dinsmoor MJ, Brock EL. Predicting failed trial of labor after primary cesarean delivery. Obstet Gynecol. 2004;103(2):282-286. [pmid: 14754696].
22 Durnwald C, Mercer B. Vaginal birth after Cesarean delivery: predicting success, risks of failure. J Matern Fetal Neonatal Med. 2004;15(6):388-393. [pmid: 15280110].
23 Durnwald CP, Ehrenberg HM, Mercer BM. The impact of maternal obesity and weight gain on vaginal birth after cesarean section success. Am J Obstet Gynecol. 2004;191(3):954-957. [pmid: 15467571].
24 Elkousy MA, Sammel M, Stevens E, Peipert JF, Macones G. The effect of birth weight on vaginal birth after cesarean delivery success rates. Am J Obstet Gynecol. 2003;188(3):824-830. [pmid: 12634665].
25 El-Sayed YY, Watkins MM, Fix M, Druzin ML, Pullen KM, Caughey AB. Perinatal outcomes after successful and failed trials of labor after cesarean delivery. Am J Obstet Gynecol. 2007;196(6):583.e581-585. discussion 583.e585. [pmid: 17547905].
26 Fisler RE, Cohen A, Ringer SA, Lieberman E. Neonatal outcome after trial of labor compared with elective repeat cesarean section. Birth. 2003;30(2):83-88. [pmid: 12752164].
27 Flamm BL, Goings JR, Fuelberth NJ, Fischermann E, Jones C, Hersh E. Oxytocin during labor after previous cesarean section: results of a multicenter study. Obstet Gynecol. 1987;70(5):709-712. [pmid: 3309751].
28 Gonen R, Nisenblat V, Barak S, Tamir A, Ohel G. Results of a well-defined protocol for a trial of labor after prior cesarean delivery. Obstet Gynecol. 2006;107(2 Pt 1):240-245. [pmid: 16449107].
29 Goodall PT, Ahn JT, Chapa JB, Hibbard JU. Obesity as a risk factor for failed trial of labor in patients with previous cesarean delivery. Am J Obstet Gynecol. 2005;192(5):1423-1426. [pmid: 15902126].
30 Gregory KD, Korst LM, Cane P, Platt LD, Kahn K. Vaginal birth after cesarean and uterine rupture rates in California. Obstet Gynecol. 1999;94(6):985-989. [pmid: 10576187].
31 Gregory KD, Korst LM, Fridman M, et al. Vaginal birth after cesarean: clinical risk factors associated with adverse outcome. Am J Obstet Gynecol. 2008;198(4):452.e451-410. discussion 452.e410–1452. [pmid: 18395037].
32 Gyamfi C, Juhasz G, Gyamfi P, Stone JL. Increased success of trial of labor after previous vaginal birth after cesarean. Obstet Gynecol. 2004;104(4):715-719. [pmid: 15458891].
33 Hammoud A, Hendler I, Gauthier RJ, Berman S, Sansregret A, Bujold E. The effect of gestational age on trial of labor after Cesarean section. J Matern Fetal Neonatal Med. 2004;15(3):202-206. [pmid: 15280148].
34 Hashima JN, Guise J-M. Vaginal birth after cesarean: a prenatal scoring tool. Am J Obstet Gynecol. 2007;196(5):e22-23. [pmid: 17466668].
35 Hollard AL, Wing DA, Chung JH, et al. Ethnic disparity in the success of vaginal birth after cesarean delivery. J Matern Fetal Neonatal Med. 2006;19(8):483-487. [pmid: 16966113].
36 Horenstein JM, Eglinton GS, Tahilramaney MP, Boucher M, Phelan JP. Oxytocin use during a trial of labor in patients with previous cesarean section. J Reprod Med. 1984;29(1):26-30. [pmid: 6708016].
37 Horenstein JM, Phelan JP. Previous cesarean section: the risks and benefits of oxytocin usage in a trial of labor. Am J Obstet Gynecol. 1985;151(5):564-569. [pmid: 3976755].
38 Hoskins IA, Gomez JL. Correlation between maximum cervical dilatation at cesarean delivery and subsequent vaginal birth after cesarean delivery. Obstet Gynecol. 1997;89(4):591-593. [pmid: 9083318].
39 Huang WH, Nakashima DK, Rumney PJ, Keegan KA Jr, Chan K. Interdelivery interval and the success of vaginal birth after cesarean delivery. Obstet Gynecol. 2002;99(1):41-44. [pmid: 11777508].
40 Johnson C, Oriol N, Flood K. Trial of labor: a study of 110 patients. J Clin Anesth. 1991;3(3):216-218. discussion 214–1215. [pmid: 1878234].
41 Juhasz G, Gyamfi C, Gyamfi P, Tocce K, Stone JL. Effect of body mass index and excessive weight gain on success of vaginal birth after cesarean delivery. Obstet Gynecol. 2005;106(4):741-746. [pmid: 16199630].
42 Kugler E, Shoham-Vardi I, Burstien E, Mazor M, Hershkovitz R. The safety of a trial of labor after cesarean section in a grandmultiparous population. Arch Gynecol Obstet. 2008;277(4):339-344. [pmid: 17957377].
43 Learman LA, Evertson LR, Shiboski S. Predictors of repeat cesarean delivery after trial of labor: do any exist?. J Am Coll Surg. 1996;182(3):257-262. [pmid: 8603247].
44 Locatelli A, Regalia AL, Ghidini A, Ciriello E, Biffi A, Pezzullo JC. Risks of induction of labour in women with a uterine scar from previous low transverse caesarean section. BJOG. 2004;111(12):1394-1399. [pmid: 15663125].
45 Loebel G, Zelop CM, Egan JFX, Wax J. Maternal and neonatal morbidity after elective repeat Cesarean delivery versus a trial of labor after previous Cesarean delivery in a community teaching hospital. J Matern Fetal Neonatal Med. 2004;15(4):243-246. [pmid: 15280132].
46 Macones GA, Peipert J, Nelson DB, et al. Maternal complications with vaginal birth after cesarean delivery: a multicenter study. Am J Obstet Gynecol. 2005;193(5):1656-1662. [pmid: 16260206].
47 McMahon MJ, Luther ER, Bowes WA Jr, Olshan AF. Comparison of a trial of labor with an elective second cesarean section. N Engl J Med. 1996;335(10):689-695. [pmid: 8703167].
48 Nguyen TV, Dinh TV, Suresh MS, Kinch RA, Anderson GD. Vaginal birth after cesarean section at the University of Texas. J Reprod Med. 1992;37(10):880-882. [pmid: 1479573].
49 Obara H, Minakami H, Koike T, Takamizawa S, Matsubara S, Sato I. Vaginal birth after cesarean delivery: results in 310 pregnancies. J Obstet Gynaecol Res. 1998;24(2):129-134. [pmid: 9631601].
50 Ouzounian JG, Miller DA, Paul RH. Amnioinfusion in women with previous cesarean births: a preliminary report. Am J Obstet Gynecol. 1996;174(2):783-786. [pmid: 8623822].
51 Pang MW, Law LW, Leung TY, Lai PY, La TK. Sociodemographic factors and pregnancy events associated with women who declined vaginal birth after cesarean section. Eur J Obstet Gynecol Reprod Biol. 2009;143(1):24-28. [pmid: 19136194].
52 Pathadey SD, Van Woerden HC, Jenkinson SD. Induction of labour after a previous caesarean section: a retrospective study in a district general hospital. J Obstet Gynaecol. 2005;25(7):662-665. [pmid: 16263539].
53 Pickhardt MG, Martin JN Jr, Meydrech EF, et al. Vaginal birth after cesarean delivery: are there useful and valid predictors of success or failure?. Am J Obstet Gynecol. 1992;166(6 Pt 1):1811-1815. discussion 1815–11819. [pmid: 1615990].
54 Raynor BD. The experience with vaginal birth after cesarean delivery in a small rural community practice. Am J Obstet Gynecol. 1993;168(1 Pt 1):60-62. [pmid: 8420350].
55 Sakala EP, Kaye S, Murray RD, Munson LJ. Oxytocin use after previous cesarean: why a higher rate of failed labor trial?. Obstet Gynecol. 1990;75(3 Pt 1):356-359. [pmid: 2304707].
56 Selo-Ojeme D, Abulhassan N, Mandal R, Tirlapur S, Selo-Ojeme U. Preferred and actual delivery mode after a cesarean in London, UK. Int J Gynaecol Obstet. 2008;102(2):156-159. [pmid: 18436222].
57 Smith GCS, Pell JP, Cameron AD, Dobbie R. Risk of perinatal death associated with labor after previous cesarean delivery in uncomplicated term pregnancies. JAMA. 2002;287(20):2684-2690. [pmid: 12020304].
58 Smith GCS, White IR, Pell JP, Dobbie R. Predicting cesarean section and uterine rupture among women attempting vaginal birth after prior cesarean section. PLoS Med. 2005;2(9):e252. [pmid: 16146414].
59 Socol ML, Peaceman AM. Vaginal birth after cesarean: an appraisal of fetal risk. Obstet Gynecol. 1999;93(5 Pt 1):674-679. [pmid: 10912965].
60 Spaans WA, Sluijs MB, van Roosmalen J, Bleker OP. Risk factors at caesarean section and failure of subsequent trial of labour. Eur J Obstet Gynecol Reprod Biol. 2002;100(2):163-166. [pmid: 11750957].
61 Troyer LR, Parisi VM. Obstetric parameters affecting success in a trial of labor: designation of a scoring system. Am J Obstet Gynecol. 1992;167(4 Pt 1):1099-1104. [pmid: 1415398].
62 Vinueza CA, Chauhan SP, Barker L, Hendrix NW, Scardo JA. Predicting the success of a trial of labor with a simple scoring system. J Reprod Med. 2000;45(4):332-336. [pmid: 10804491].
63 Weinstein D, Benshushan A, Tanos V, Zilberstein R, Rojansky N. Predictive score for vaginal birth after cesarean section. Am J Obstet Gynecol. 1996;174(1 Pt 1):192-198. [pmid: 8572005].
64 Wen SW, Rusen ID, Walker M, et al. Comparison of maternal mortality and morbidity between trial of labor and elective cesarean section among women with previous cesarean delivery. Am J Obstet Gynecol. 2004;191(4):1263-1269. [pmid: 15507951].
65 Yetman TJ, Nolan TE. Vaginal birth after cesarean section: a reappraisal of risk. Am J Obstet Gynecol. 1989;161(5):1119-1123. [pmid: 2486193].
66 Yogev Y, Ben-Haroush A, Lahav E, Horowitz E, Hod M, Kaplan B. Induction of labor with prostaglandin E2 in women with previous cesarean section and unfavorable cervix. Eur J Obstet Gynecol Reprod Biol. 2004;116(2):173-176. [pmid: 15358459].
67 Zelop CM, Shipp TD, Cohen A, Repke JT, Lieberman E. Trial of labor after 40 weeks' gestation in women with prior cesarean. Obstet Gynecol. 2001;97(3):391-393. [pmid: 11239643].
68 Johnson KC, Gaskin IM. Vaginal delivery after caesarean section. Safety of single-layer suturing in caesarean sections must be proved. BMJ. 2001;323(7324):1307-1308. [pmid: 11764760].