# Detailed Evaluation of Predictors of Trial of Labor and Vaginal Birth After Cesarean

## Introduction

A brief description on the predictors of trial of labor (TOL) and vaginal birth after cesarean (VBAC) is included in the text of the evidence report. Detailed descriptions of the studies and analyses conducted on these topics are included in this appendix.

### Predictors of Trial of Labor

Three good quality retrospective cohort studies,1–3 five fair quality retrospective cohort studies4–8 and one fair quality retrospective cross sectional study9 looked for factors known in the prenatal setting that may predict TOL. Predictors have been categorized into three categories as they relate to the likelihood of TOL: 1) nonclinical which includes the site of care and type of insurance 2) demographic which include maternal age, race and economic status and 3) past obstetric factors which include a history of a vaginal birth and the gestational age of the prior cesarean delivery. Unless otherwise noted, all results are presented in odds ratios. If studies reported relative risks (RR), these are noted in the tables.

#### Nonclinical Factors

Among the studies that reported factors related to TOL rates, location of delivery (volume), hospital level, and access to private insurance were considered nonclinical factors.

Three retrospective studies found that the location of delivery was associated with TOL1, 2 or related to unnecessary RCDs.9 In a secondary analysis of the Agency for Healthcare Research and Quality’s (AHRQ) 2001 Healthcare Cost and Utilization Project (HCUP) National Inpatient Sample database, investigators reported that women had a reduced likelihood of TOL if they were delivered in rural or nonteaching urban hospitals (Table K-1).9 These investigators identified all women who had unnecessary (had no discharge indication, ICD-9 code, for a repeat cesarean delivery [RCD]) RCDs as a way to quantify the number of women who may not have been offered a TOL; the database includes data from 33 states. In this study, a prior cesarean alone was not considered as sufficient justification for a RCD. With this definition, 65 percent of RCDs were considered unnecessary and overall bed size of the hospital was not related to unnecessary RCDs.

Table K-1 Nonclinical factors as predictors of trial of labor

Author, Year | Characteristic | Adjusted odds ratio for TOL | 95% CI
Site of Care (volume of deliveries)
Hueston, 1994^7^ | 252 women with prior CD/2y | 1.00 | Referent
Hueston, 1994^7^ | 135 women with prior CD/2 y | 0.46 | 0.29–0.74
Hueston, 1994^7^ | 179 women with prior CD/2 y | 0.57 | 0.38–0.85
Hueston, 1994^7^ | 193 women with prior CD/2y | 0.38 | 0.25–0.56
Hospital Level
Cameron, 2004^1^ | Level 6 (Perinatal center) | 1.00 | Referent
Cameron, 2004^1^ | Level 5 (High-risk care) | 1.22 | 1.09–1.37
Cameron, 2004^1^ | Level 4 (moderate-risk care) | 0.90 | 0.81–0.99
Cameron, 2004^1^ | Level 1–3 (Rural)^*^ | 0.66 | 0.58–0.74
Cameron, 2004^1^ | Private | 0.45 | 0.41–0.50
McMahon, 1996^2^ | Tertiary Care | 1.00 | Referent
McMahon, 1996^2^ | Regional Hospital | 0.50 | 0.50–0.60
McMahon, 1996^2^ | Community Hospital | 0.40 | 0.30–0.50
Private Insurance
Hueston, 1994^7^ | Yes | 0.52 | 0.35–70

* 96 percent rural hospitals

Abbreviations: CD=cesarean delivery; CI=confidence interval; TOL=trial of labor; y=year(s)

In a study of Australian deliveries during 1998 to 2001,^1^ predictors of TOL were evaluated for 14,350 charts of women eligible for TOL by the American College of Obstetricians and Gynecologists (ACOG) standards. Women had an increased likelihood of TOL if they delivered at a Level 5 or 6 hospital (metro district hospital for high-risk mothers/babies or perinatal center) and a decreased likelihood at a Level 4 or below (metro district for moderate-risk mothers/babies, rural, and private hospitals).1 A study conducted in Nova Scotia, Canada, between 1986 and 1992, similarly found that women in community and regional hospitals were half as likely to have a TOL as women delivering in tertiary care centers.2 Further examination of rural community hospitals suggest that women delivering at rural teaching hospitals with lower volumes of deliveries and women with private insurance had a decreased likelihood of TOL even when adjusting for race, employment and marital status.7 Interestingly, the only study to date that considered the volume of VBAC deliveries found no relationship between annual VBAC volume and rate of TOL (not shown as no odds ratio or RR were provided).5 In this secondary analysis5 of a large, retrospective cohort study,10 55, 51, and 57 percent of women had TOL in hospitals that had less than 70; 70 to 100, or more than 100 VBAC deliveries per year, respectively.

#### Demographic and Pre-Existing Factors

Studies reported only maternal age, race and economic status as current demographic factors affecting rates of TOL.

Two studies provided evidence that advancing maternal age may change the likelihood of TOL (Table K-2).1, 2 In the older of the two studies, conducted between 1986 and 1992, younger women (age 19 and younger) and older women (age 30 and older) were more likely to have a TOL compared with 25 to 29 year old women.2 In the second study conducted between 1998 and 2001, older women were less likely to have a TOL.1 In contrast to this more recent finding, women age 35 and older in a US study conducted in 2001 had a reduced likelihood of an unnecessary RCD (or increased likelihood of TOL).9 In this retrospective cross-sectional study 67 percent of women under age 35 had unnecessary RCDs compared with 60 percent of women age 35 and older, p<0.001.

Table K-2 Demographic factors as predictors of trial of labor

Author, Year Study Design | Characteristic | Adjusted odds ratio for TOL | 95% CI
Maternal Age
Cameron, 2004^1^ Retrospective Cohort | <30 y | 1.00 | Referent
Cameron, 2004^1^ Retrospective Cohort | 30–39 y | 0.86 | 0.80–0.92
Cameron, 2004^1^ Retrospective Cohort | 40 y and older | 0.40 | 0.33–0.48
McMahon, 1996^2^ Retrospective Cohort | ≤19 y | 1.40 | 1.00–2.10
McMahon, 1996^2^ Retrospective Cohort | 20–24 y | 1.00 | 0.80–1.10
McMahon, 1996^2^ Retrospective Cohort | 25–29 y | 1.00 | Referent
McMahon, 1996^2^ Retrospective Cohort | 30–34 y | 1.10 | 1.00–1.20
McMahon, 1996^2^ Retrospective Cohort | ≥35 y | 1.20 | 1.00–1.40
Race
Selo-Ojeme, 2008^8^ Retrospective Cohort | White | 1.00 | Referent
Selo-Ojeme, 2008^8^ Retrospective Cohort | Non-white (Afro-Caribbean, Asian) | 3.5 | 1.90–6.10

Abbreviations: CI=confidence interval; TOL=trial of labor; y=year(s)

Two studies found that non-white women had an increased likelihood of a TOL compared with white women. In a study based in the United Kingdom (UK) that recorded the rate of TOL in 2007, 77 percent of Afro-Caribbean women, 68 percent of Asian women and 41 percent of white women chose a TOL.8 In a US study, 66 percent of white women had unnecessary RCDs compared with 62 percent of African American women, suggesting that white women had less opportunity for a TOL (p<0.001).9 Race in this study was an independent predictor of TOL even when type of insurance was included in a regressive model.

One retrospective study of women in Hong Kong conducted between 2002 and 2006 reported social economic factors influenced the decision. When the family monthly income was $3,850 or less US dollars, the woman was less likely to choose a TOL (adjusted odds ratio 0.64; 95% CI: 0.43 to 0.97).3

#### Past obstetric factors

The number of previous vaginal deliveries and gestational age (GA) at prior caesarean delivery are the past-obstetric factors that have been assessed for their influence on TOL rates

Careful attention is given to prior obstetric history in estimating likelihood of VBAC, which, in turn may influence the initial decision to have a TOL. Three retrospective cohort studies,1–3 described above, and a secondary analysis6 of a large retrospective study10 examined whether obstetric factors such as number of prior vaginal deliveries or GA at the prior cesarean predicted TOL (Table K-3). The likelihood of TOL increased for women with prior vaginal deliveries1–3 while it decreased for women who had a prior cesarean before 34 weeks GA.6

Table K-3 Past obstetric factors as predictors of trial of labor

Author, Year Study Design | Characteristic | Adjusted odds ratio or relative risk for VBAC | 95% CI
Number of previous vaginal deliveries
Cameron, 2004^1^ Retrospective Cohort | 1 Prior VD | 1.51 | 1.35–1.68
Cameron, 2004^1^ Retrospective Cohort | 2 Prior VDs | 2.35 | 1.92–2.86
Cameron, 2004^1^ Retrospective Cohort | ≥ 3 Prior VDs | 2.94 | 2.23–3.88
McMahon, 1996^2^ Retrospective Cohort | 1 Prior VD | 3.20 | Not reported
McMahon, 1996^2^ Retrospective Cohort | 2 Prior VDs | 4.00 | Not reported
Pang, 2009 Retrospective Cohort | History of VD | 6.67 | 2.70–16.67
Gestational age of prior cesarean delivery
Harper, 2009^6^ Retrospective Cohort | GA ≥ 34 wk | 1 | Referent
Harper, 2009^6^ Retrospective Cohort | GA < 34 wk | 1.2 RR | 1.1–1.2

Abbreviations: CI=confidence interval; GA=gestational age; RR=Relative Risk; VBAC=vaginal birth after cesarean; VD=vaginal delivery; wk=week(s)

#### Summary of Predictors of Trial of Labor

Trial of labor is more likely in hospitals with higher delivery volumes, tertiary care centers, and teaching hospitals. Women with a prior vaginal delivery or non-white women were more likely to have a TOL (odds ratio 1.51 to 6.67).

### Predictors of Vaginal Birth After Cesarean

The impact of individual factors on VBAC discussed in the evidence report can overlap and interact with each other such that a factor found to have statistically significant influence on VBAC rate may no longer be significant when other key factors are taken into account. Studies that evaluate these factors in concert, using regression analyses for example, can provide a higher level of evidence on the residual influence of individual factors. Four prospective cohort studies,11–14 18 retrospective cohort studies,1, 5, 8, 15–29 and one case-control study30 addressed predictive factors for VBAC. The key factors considered by these studies were demographic factors that included maternal age, ethnicity, race, and marital status; nonclinical factors that included insurance status, site of delivery, and volume of VBACs; past obstetric factors that included prior vaginal delivery and prior indications for cesarean; pre-existing and current factors that included maternal height, body mass index (BMI), substance abuse, and pre-existing maternal disease; and current obstetric factors related to the infant gender, age and size. Finally, the section folds in factors related to the labor experience (dilation, effacement, station, Bishop score, cervix position, type of labor and epidural use).

#### Demographic Factors

Maternal age, ethnicity, race and marital status have been examined for their ability to predict VBAC in women who attempt a TOL (Table K-4). Eight cohort studies provided inconsistent evidence on the effect of advancing age on the VBAC rate.1, 11–13, 19, 21, 24, 27 In five of the eight studies, younger women were more likely to have a VBAC, particularly women under age 40.^1, 11, 12, 19, 24^ In the other studies, there was no statistically significant relationship between maternal age and likelihood of VBAC.13, 21, 27 Taken as a group, the overall trend appears to be that younger women have a higher likelihood of a VBAC.

Table K-4 Demographic factors as predictors of vaginal birth after cesarean

Author, Year Study Design | Characteristic | Adjusted OR for VBAC | 95% CI
Maternal age
Flamm, 1997^11^ Prospective Cohort | >40y | 0.39 | 0.23–0.65
McNally, 1999^21^ Retrospective Cohort | Per y | 1.18 | 0.98–1.40
Weinstein, 1996^27^ Retrospective Cohort | >37 y | 0.9 | 0.5–1.7
Smith, 2005^24^ Retrospective Cohort | Per 5 y increase | 0.82 | 0.78–0.86
King, 1994^19^ Retrospective Cohort | Per 5 y increase | 0.85 | 0.81–0.90
Cameron, 2004^1^ Retrospective Cohort | <30 y | 1.0 | referent
Cameron, 2004^1^ Retrospective Cohort | 30–39 y | 0.86 | 0.77–0.95
Cameron, 2004^1^ Retrospective Cohort | >40 y | 0.59 | 0.43–0.82
Grobman, 2007^12^ Prospective Cohort | Per yr | 0.96 | 0.95–0.97
Landon, 2005^13^ Prospective Cohort | <17 y | 0.84^*^ | 0.57–1.25
Landon, 2005^13^ Prospective Cohort | 18–34 y | 1.0 | referent
Landon, 2005^13^ Prospective Cohort | >35 y | 1.0^*^ | 0.91–1.10
Ethnicity, race and marital status
Hispanic
Grobman, 2007^12^ Prospective Cohort | Referent: Non-Hispanic | 0.51 | 0.44–0.59
Landon, 2005^13^ Prospective Cohort | Referent: Non-Hispanic | 0.65^*^ | 0.59–0.72
Srinivas, 2007^26^ Retrospective Cohort | Referent: White | 0.69 | 0.56–0.84
King, 1994^19^ Retrospective Cohort | Referent: White | 0.61 | 0.51–0.73
African American
Grobman, 2007^12^ Prospective Cohort | Referent: White | 0.51 | 0.44–0.59
Landon, 2005^13^ Prospective Cohort | Referent: White | 0.69^*^ | 0.63–0.75
Srinivas, 2007^26^ Retrospective Cohort | Referent: White | 0.58 | 0.52–0.67
King, 1994^19^ Retrospective Cohort | Referent: White | 0.80 | 0.70–0.93
Afro-Caribbean
Selo-Ojeme, 2008^8^ Retrospective Cohort | Referent: White | 3.22 | 1.5–7.14
Asian
Srinivas, 2007^26^ Retrospective Cohort | Referent: White | 0.80 | 0.61–1.05
Other
Landon, 2005^13^ Prospective Cohort | Referent: White | 0.71^*^ | 0.60–0.84
Unmarried
Landon, 2005^13^ Prospective Cohort | Referent: Married | 0.88 | 0.82–0.95
Education
King, 1994^19^ Retrospective Cohort | <12 y | 1.0 | Referent
King, 1994^19^ Retrospective Cohort | 12 y | 1.15 | 0.99–1.34
King, 1994^19^ Retrospective Cohort | 13–15 y | 1.36 | 1.16–1.60
King, 1994^19^ Retrospective Cohort | 16 y | 1.59 | 1.32–1.93
King, 1994^19^ Retrospective Cohort | 17 y | 2.00 | 1.64–2.45

* Only provided univariate odds ratio

Abbreviations: CI=confidence interval; OR=odds ratio; VBAC=vaginal birth after cesarean; y=year(s)

In all four cohort studies reporting on ethnicity and race, Hispanic and African American women had a reduced likelihood to have a VBAC compared with non-Hispanic and white women, respectively.12, 13, 19, 26 Two large prospective cohort studies reported reduced likelihood of VBAC for Hispanic and for African American women (Table K-4).12, 13 In both studies data were analyzed from the National Institute of Child Health and Human Development Maternal-Fetal Medicine Units Network (MFMU, Appendix G). While different subsets of data were analyzed based on GA, both studies reached the same conclusions about the effects of race or ethnicity on likelihood of VBAC. In one study,13 the VBAC rate was evaluated for women with GAs of at least 20 weeks. In this study, Hispanic women were 35 percent less likely to have a VBAC and African American women were 31 percent less likely to have a VBAC compared with non-Hispanic and white women respectively.

It is interesting to note that non-white women were more likely to have a TOL but less likely to have a VBAC.8 This suggests that other factors related to patient preferences may be driving this result. In a prior systematic review,31 underlying cultural ideologies were found to influence the desire to go through the painful labor process. Non-white women in 100 structured interviews reported that labor was a painful process that did not relate to motherhood.32 By contrast, white women in the same cohort study viewed vaginal birth as an experience “not to be missed” in motherhood.32

Additionally, unmarried women had a reduced likelihood of a VBAC.13. Finally, in a retrospective study of births in New York in 1989, women with more than 12 years of education had an increased likelihood of a VBAC.19

#### Nonclinical Factors

Nonclinical factors such as insurance and site of delivery play an important role in deciding what kind of birthing options are pursued. Women with non-private insurance or who were uninsured had a decreased likelihood for VBAC (Table K-5).13 However, women in Health Maintenance Organizations (HMO) had an increased likelihood of VBAC.19 The level of the hospital at which the birth takes place is also a major factor in the likelihood of VBAC. Women at rural and private hospitals that provide obstetric care for lower risk deliveries had a decreased likelihood of VBAC.1 This finding is consistent with another finding by the same investigators1 that women at rural and private hospitals were less likely to attempt a TOL. Private hospitals in this study had an average VBAC rate of 57 percent compared with a VBAC rate of 66 percent for level 6 hospitals.1 Finally, in a secondary analysis5 of a retrospective cohort study,10 the annual VBAC volume at the hospital did not change the likelihood of VBAC.

Table K-5 Nonclinical factors as predictors of vaginal birth after cesarean

Author, Year Study Design | Characteristic | Adjusted OR for VBAC | 95% CI
Insurance Status
Landon, 2005^13^ Prospective Cohort | Private | 1.00 | Referent
Landon, 2005^13^ Prospective Cohort | Non-private | 0.88^*^ | 0.81–0.95
Landon, 2005^13^ Prospective Cohort | Uninsured | 0.74^*^ | 0.66–0.83
King, 1994^19^ Retrospective Cohort | Private | 1.00 | Referent
King, 1994^19^ Retrospective Cohort | HMO | 1.15 | 1.02–1.30
King, 1994^19^ Retrospective Cohort | Self-pay | 1.19 | 0.96–1.47
King, 1994^19^ Retrospective Cohort | Medicaid | 1.01 | 0.89–1.15
Hospital Level of Birth
Cameron, 2004^1^ Retrospective Cohort | Level 6 (Perinatal center) | 1.0 | Referent
Cameron, 2004^1^ Retrospective Cohort | Level 5 (High-risk care) | 0.96 | 0.82–1.12
Cameron, 2004^1^ Retrospective Cohort | Level 4 (Moderate-risk care) | 1.02 | 0.89–1.19
Cameron, 2004^1^ Retrospective Cohort | Level 1–3 (Rural^†^) | 0.79 | 0.65–0.95
Cameron, 2004^1^ Retrospective Cohort | Private | 0.72 | 0.62–0.84
Volume of VBACs
Chang, 2008^5^ Retrospective Cohort | <70 per year | 1.11 | 0.79–1.56
Chang, 2008^5^ Retrospective Cohort | 70–100 per year | 1.16 | 0.93–1.45
Chang, 2008^5^ Retrospective Cohort | >100 per year | 1.00 | Referent

* Only provided univariate odds ratio

† 96 percent rural hospitals

Abbreviations: CI=confidence interval; HMO=health management organization; OR=odds ratio; VBAC=vaginal birth after cesarean

#### Past obstetric Factors

There is particular interest in whether demographic factors, nonclinical and past obstetric factors may predict VBAC since these factors are known prenatally and would allow clinicians to provide information on prognosis early in pregnancy. Investigators from studies have explored prior vaginal delivery, years since prior cesarean delivery, prior labor experience and prior baby weight as potential factors for predicting VBAC. A prior history of vaginal delivery was consistently reported to increase likelihood of VBAC in all 13 cohort studies (Table K-6).1, 11–13, 15, 17, 18, 20, 21, 24, 26, 27, 33 in one case-control study30 Women with a vaginal delivery after their prior cesarean (prior VBAC) were three to seven times more likely to have a VBAC for their current delivery11–13, 15, 17, 18, 30, 33 compared with women with no prior VDs. Women who had a vaginal delivery before their cesarean deliveries also had an increased likelihood to have a VBAC.11, 27

Table K-6 Past obstetric factor as predictors of vaginal birth after cesarean: prior deliveries

Author, Year Study Design | Characteristic | Adjusted OR^*^ or RR for VBAC | 95% CI
Multipara/vaginal delivery
Learman, 1996^20^ Retrospective Cohort | Yes | 03.45 RR | 1.0–12.50 RR
Prior vaginal delivery
McNally, 1999^21^ Retrospective Cohort | Yes | 27.78 | 3.85–200
Grobman, 2007^12^ Prospective Cohort | Yes | 2.43 | 2.04–2.89
Landon, 2005^13^ Prospective Cohort | Yes | 3.90 | 3.60–4.30
Smith, 2005^24^ Retrospective Cohort | Yes | 5.08 | 4.82–5.72
Cameron, 2004^1^ Retrospective Cohort | 1 prior | 2.95 | 2.47–3.53
Cameron, 2004^1^ Retrospective Cohort | 2 prior | 5.58 | 3.92–7.96
Cameron, 2004^1^ Retrospective Cohort | 3 prior | 3.57 | 2.43–5.26
Bujold, 2004^15^ Retrospective Cohort | Yes | 2.69 | 1.41–5.13
Srinivas, 2007^26^ Retrospective Cohort | Yes | 4.76 | 4.17–5.26
Gyamfi, 2004^18^ Retrospective Cohort | Spontaneous vaginal delivery | 1.83 | 1.29–2.60
Vaginal delivery before prior cesarean
Flamm, 1997^11^ Prospective Cohort | Yes | 1.53 | 1.12–2.10
Weinstein, 1996^27^ Retrospective Cohort | Yes | 1.8 | 1.1–3.1
Vaginal delivery after prior cesarean
Flamm, 1997^11^ Prospective Cohort | Yes | 3.39 | 2.25–5.11
Macones, 2001^30^ Case Control | Yes | 7.69 | 3.23–20
Gonen, 2004^17^ Retrospective Cohort | Yes | 7.20 | 2.10–24.80
Grobman, 2007^12^ Prospective Cohort | Yes | 2.73 | 2.21–3.36
Landon, 2005^13^ Prospective Cohort | No | 1.0 | referent
Landon, 2005^13^ Prospective Cohort | Yes | 4.76^*^ | 4.35–5.26
Bujold, 2004^15^ Retrospective Cohort | Yes | 3.32 | 1.35–8.13
Gyamfi, 2004^18^ Retrospective Cohort | Yes | 7.40 | 4.51–12.16
Vaginal delivery after prior cesarean versus vaginal delivery before prior cesarean
Caughey, 1998^33^ Retrospective Cohort | Yes | 3.48 | 1.9–6.1
Vaginal delivery before and vaginal delivery after prior cesarean
Flamm, 1997^11^ Prospective Cohort | Yes | 9.11 | 2.2–38.0

* Only provided univariate odds ratio

Abbreviations: CI=confidence interval; OR=odds ratio; RR=relative risk when odds ratio not reported; VBAC=vaginal birth after cesarean

One secondary analysis of a retrospective cohort study10 of 16 community and university hospitals that is not included in Table K-6 because it did not provide odds ratios34 specifically examined the effect of prior vaginal delivery before a cesarean and of a prior VBAC on the current TOL. The VBAC rate for women with no history of vaginal delivery was 65 percent, 83 percent for women with a prior vaginal delivery before a cesarean, and 94 percent for women with a prior VBAC.34 Finally, a secondary analysis of the MFMU cohort data reported that the likelihood of a VBAC increased with each prior VBAC.35 Women with zero, one, two, three, and four or more prior VBACs had likelihoods of VBAC of 63.3, 87.6, 90.9, 90.6, and 91.6 percent (p<0.001), respectively.

In examining the indication for the prior cesarean delivery, the evidence suggested an association between a prior indication of breech and a VBAC (Table K-7). One retrospective study17 showed that a prior cesarean delivery due to malpresentation (breech) significantly increased likelihood of VBAC (adjusted odds ratio 7.4; 95% CI: 2.8 to 19.2, compared with an indication for failure to progress [FTP]) and a second retrospective study27 suggested a relationship that was not statistically significant (adjusted odds ratio 1.0; 95% CI: 1.0 to 3.6 compared to a non-breech indication). Consistent with these findings, a third retrospective study23 reported that women with a prior breech indication had the same risk of a RCD as a nulliparous woman’s risk of a primary cesarean (risk of RCD odds ratio 0.95; 95% CI: 0.70 to 1.30).

Table K-7 Past obstetric factor as predictors of vaginal birth after cesarean: prior indications

Author, Year Study Design | Characteristic | Adjusted OR^*^ or RR for VBAC | 95% CI
Recurring versus nonrecurring
Weinstein, 1996^27^ Retrospective Cohort | Referent: Nonrecurring | 0.80 | 0.3–2.0
Grobman, 2007^12^ Prospective Cohort | Referent: Nonrecurring indication for arrest in dilation or descent | 0.53 | 0.48–0.60
Gyamfi, 2004^18^ Retrospective Cohort | Referent: Nonrecurring | 0.42 | 0.31–0.57
Mal-presentation (breech)
Weinstein, 1996^27^ Retrospective Cohort | Yes | 1.9 | 1.0–3.6
Gonen, 2004^17^ Retrospective Cohort | Referent: FTP | 7.40 | 2.8–19.2
Dystocia
Landon, 2005^13^ Retrospective Cohort | Referent: Breech | 0.59 | 0.56–0.67
Bujold, 2004^15^ Retrospective Cohort | 1st stage of labor Referent: fetal indication | 0.5 | 0.34–0.74
Bujold, 2004^15^ Retrospective Cohort | 2nd stage of labor Referent: fetal indication | 0.97 | 0.50–1.88
Cephalopelvic disproportion
Srinivas, 2007^26^ Retrospective Cohort | Any CPD | 0.69 | 0.63–0.77
Failure to progress
Weinstein, 1996^27^ Retrospective Cohort | FTP | 0.81 | 0.3–2.0
Learman, 1996^20^ Retrospective Cohort | FTP | 0.83 (RR) | 0.36–1.67
Flamm, 1997^11^ Prospective Cohort | FTP | 0.52 | 0.43–0.63
Spaans, 2002 Retrospective Study | FTE or suspected cephalic pelvic distortion | 0.34 | 0.15–0.77
Cervical ripening with foley catheter
Bujold, 2004^15^ Retrospective Cohort | Referent: fetal indication | 0.60 | 0.40–0.89
Fetal wellbeing
Landon, 2005^13^ Prospective Cohort | Non-reassuring fetal well-being Referent: Breech | 0.51^*^ | 0.45–0.5
Weinstein, 1996^27^ Retrospective Cohort | Fetal Distress | 1.05 | 0.4–2.6

* Only univariate odds ratio provided

Abbreviations: CI=confidence interval; CPD=cephalopelvic disproportion; FTP=failure to progress; OR=odds ratio; RR=Relative Risk; VBAC=vaginal birth after cesarean

This same study reported that women with a prior indication of FTP were four times (odds ratio 4.50; 95% CI: 3.60 to 5.50) as likely to have a RCD when compared with the risk of a nulliparous woman to have a primary cesarean.23 This finding supports the trend shown in Table K-7 that a prior indication of FTP reduces the likelihood of a VBAC.11, 20, 27

The evidence on prior indications for dystocia, FTP or for fetal concern was inconsistent in predicting VBAC.13, 15, 20, 25, 27 Cervical ripening with a Foley catheter was also reported in one study15 to reduce likelihood of VBAC (adjusted odds ratio 0.6; 95% CI: 0.40 to 0.89) compared with a fetal indication.

In considering other factors about the prior cesarean delivery, two studies found no relationship in the spacing of deliveries: less than 19 months36 or less than 2 years13 compared to larger inter-delivery spacing. Compared with women who had an unknown scar, women with a LTCS had a reduced likelihood of VBAC (univariate odds ratio 0.71; 95% CI: 0.64 to 0.79).13 Finally, Women who delivered prior babies greater than 4,000 grams, were less likely to have a VBAC (adjusted odds ratio 0.52; 95% CI: 0.32 to 0.85).15

#### Pre-Existing and Current Obstetric Factors

Many pre-existing factors (maternal height, BMI, smoking and substance use, and maternal disease) greatly impact the likelihood of VBAC (Table K-8). In examining pre-existing factors, women with greater maternal height (for each 5 cm increase) had an increased likelihood of VBAC.24 Increased BMI at the first prenatal visit (per BMI unit)12 or an increased BMI at delivery (greater than 30) resulted in decreased likelihood of VBAC.13 Women who smoked or reported any substance abuse had an increased likelihood of VBAC but neither study adjusted for socioeconomic status.13, 30 However, in three of four cohort studies in Table K-8, women with a maternal disease (hypertension, diabetes, asthma, seizures, renal disease, thyroid disease, or collagen vascular disease) had a decreased likelihood of VBAC.13, 18, 26 By contrast, in a large prospective study by Grobman et al,12 the presence of diabetes, asthma, chronic hypertension, renal disease or heart disease, was not significant in the study’s multivariable logistic model.

Table K-8 Pre-existing maternal factors predicting vaginal birth after cesarean

Author, Year Study Design | Characteristic | Adjusted OR for VBAC | 95% CI
Maternal height
Smith, 2005^24^ Retrospective Cohort | Per 5 cm increase | 1.33 | 1.28–1.37
BMI at first prenatal visit
Grobman, 2007^12^ Prospective Cohort | Per BMI unit | 0.94 | 0.93–0.95
BMI at delivery
Landon, 2005^13^ Prospective Cohort | >30 | 0.55^*^ | 0.51–0.60
Smoking
Landon, 2005^13^ Prospective Cohort | Smoker | 1.15^*^ | 1.04–1.28
Substance Abuse
Macones, 2001^30^ Case Control | Yes | 3.70 | 1.25–11.11
Maternal disease
Srinivas, 2007^26^ Retrospective Cohort | Chronic hypertension | 0.70 | 0.56–0.86
Srinivas, 2007^26^ Retrospective Cohort | Gestational diabetes | 0.68 | 0.58–0.81
Grobman, 2007^12^ Prospective Cohort | Diabetes | Not significant | Not significant
Gymafi, 2004^18^ Retrospective Cohort | Diabetes or gestational diabetes | 0.42 | 0.28–0.62
Landon, 2005^13^ Prospective Cohort | Hypertension, diabetes, asthma, seizures, renal disease, thyroid disease, or collagen vascular disease. | 0.83 | 0.71–0.71
Grobman, 2007^12^ | Hypertension, cardiac disease, asthma, renal disease, or connective tissue disorder | Not reported | Not reported

* Only univariate odds ratio provided

Abbreviations: BMI=body mass index; CI=confidence interval; cm=centimeters; OR=odds ratio; VBAC=vaginal birth after cesarean

Many current obstetric factors related to the infant (GA, birth weight and infant gender) predicted VBAC or TOL followed by a cesarean delivery (Table K-9). Of these, the most consistent finding is that as infant weight increases the likelihood of VBAC decreases. Four of five studies reported that infants weighing more than 4 kilograms (kg) were less likely to be delivered vaginally.1, 13, 18, 27, 28 The oldest of these studies27 found no relationship between a birth weight over 4,000 grams and likelihood of VBAC.

Table K-9 Current obstetric factors: infant gender, gestational age, and weight

Author, Year Study Design | Characteristic | Adjusted OR^*^ or RR for VBAC | 95% CI
Gestational age
Srinivas, 2007^26^ Retrospective Cohort | 37–41 wk | 1.00 | Referent
Srinivas, 2007^26^ Retrospective Cohort | <32 wk | 2.32 | 1.67–3.33
Srinivas, 2007^26^ Retrospective Cohort | 32–37 wk | 1.37 | 1.14–1.67
Srinivas, 2007^26^ Retrospective Cohort | >41 wk | 1.25 | 1.10–1.41
Cameron, 2004^1^ Retrospective Cohort | 40 wk | 1.00 | Referent
Cameron, 2004^1^ Retrospective Cohort | 37 wk | 0.43 | 0.34–0.54
Cameron, 2004^1^ Retrospective Cohort | 38 wk | 0.51 | 0.44–0.60
Cameron, 2004^1^ Retrospective Cohort | 39 wk | 0.74 | 0.65–0.85
Cameron, 2004^1^ Retrospective Cohort | 41 wk | 0.89 | 0.77–1.04
Landon, 2005^13^ Prospective Cohort | 37 0/7–40 6/7 wk/d | 1.00 | Referent
Landon, 2005^13^ Prospective Cohort | >41 wk | 0.61^*^ | 0.55–0.68
Smith, 2005^24^ Retrospective Cohort | 40 wk | 1.00 | Referent
Smith, 2005^24^ Retrospective Cohort | 41 wk | 0.77 | 0.7–0.85
Smith, 2005^24^ Retrospective Cohort | 42 wk | 0.72 | 0.62–0.85
Gonen, 2004^17^ | ≥41 wk | 0.36 | 0.14–0.91
Learman, 1996^20^ Retrospective Cohort | >41 wk | 1.25 (*RR) | 0.53–3.33
Quiñones, 2005^22^ Retrospective Cohort | 33.9 wk | 1.54 | 1.27–1.86
Quiñones, 2005^22^ Retrospective Cohort | 39.2 wk | 1.0 | Referent
Gestational age and labor
Zelop, 2001^28^ Retrospective Cohort | >40wks spontaneous | 0.67 | 0.56–0.83
Zelop, 2001^28^ Retrospective Cohort | >40wks induced | 0.67 | 0.45–0.91
Birth weight
Weinstein, 1996^27^ Retrospective Cohort | >4000g | 1.05 | 0.20–5.88
Zelop, 2001^28^ Retrospective Cohort | >4000g | 0.59 | 0.45–0.77
Gyamfi, 2004^18^ Retrospective Cohort | >4000g | 0.49 | 0.30–0.78
Cameron, 2004^1^ Retrospective Cohort | 3000–3499g | 1.0 | Referent
Cameron, 2004^1^ Retrospective Cohort | <2500g | 0.66 | 0.45–0.97
Cameron, 2004^1^ Retrospective Cohort | 2500–2999g | 0.93 | 0.78–1.10
Cameron, 2004^1^ Retrospective Cohort | 3500–3999g | 0.75 | 0.66–0.85
Cameron, 2004^1^ Retrospective Cohort | >4000g | 0.54 | 0.46–0.64
Landon, 2005^13^ Prospective Cohort | >4000g | 0.50 | 0.43–0.56
Mean estimated fetal weight
Gonen, 2004^17^ Prospective Cohort | 3360g ± 395 | 0.9 | 0.8–0.9
Learman, 1996^20^ Retrospective Cohort | >3800g | 0.53 (*RR) | 0.24–1.11
Sex of Infant
Smith, 2005^24^ Retrospective Cohort | Female | 1.18 | 1.08–1.28

* Only univariate odds ratio provided

Abbreviations: CI=confidence interval; d=day(s); g=gram(s); kg=kilogram(s); OR=odds ratio; RR=relative risk; VBAC=vaginal birth after cesarean; wk= week(s);

Obstetric factors related to the labor itself (dilation, effacement, station, Bishop score, cervix position) consistently predicted VBAC (Table K-10). Three prospective cohort studies,11, 13, 17 one retrospective study20 and one case-control study30 provided consistent evidence that women who were more dilated at admission or at rupture of membranes (ROM) were more likely to deliver vaginally. All three studies that examined effacement reported increased likelihood as effacement reached 75 to 100 percent.11, 17, 21 Similarly, all three studies that examined head position reported that as the baby’s position was vertex, engaged or at a lower station, the likelihood of VBAC increased.14, 19, 20 Both studies that examined Bishop’s score showed that as the score increased the likelihood of VBAC increased two15 to six times.27

Table K-10 Current obstetric factors: cervical dilation, etc

Author, Year Study Design | Characteristic | Adjusted OR^*^ or RR for VBAC | 95% CI
Cervical dilation at admission
Flamm, 1997^11^ Prospective Cohort | >4cm | 2.16 | 1.66–2.82
Landon, 2005^13^ Prospective Cohort | >4cm | 2.56^*^ | 2.38–2.78
Macones, 2001^30^ Case Control | Per cm increase | 1.89 | 1.13–3.22
Gonen, 2004^17^ Prospective Cohort | >2cm | 3.00 | 1.70–5.30
Learman, 1996^20^ Retrospective Cohort | >2cm | 1.69 (*RR) | 0.80–3.45 RR
Effacement
Flamm, 1997^11^ Prospective Cohort | >75% Referent: <25% | 2.72 | 2.00–3.71
Flamm, 1997^11^ Prospective Cohort | 25–75% Referent: <25% | 1.79 | 1.31–2.44
McNally, 1999^21^ Retrospective Cohort | 100% | 5.0 | 1.28–19.2
Head position and station
King, 1994^19^ Retrospective Cohort | Head in vertex position | 7.69 | 5.26–12.5
Strong, 1996^14^ Prospective Cohort | Head engaged on admission | 12.3 | 4.6–33.3
Learman, 1996^20^ Retrospective Cohort | Lower than −3 cm | 2.10 (*RR) | 1.10–4.20 RR
Bishop score
Weinstein, 1996^27^ Retrospective Cohort | >4 | 6.00 | 3.5–10.4
Bujold, 2004^15^ Retrospective Cohort | >6: modified | 2.07 | 1.28–3.35

* Only univariate odds ratio provided

Abbreviations: CI=confidence interval; cm=centimeters; OR=odds ratio; RR: relative risk; VBAC=vaginal birth after cesarean

Other obstetric factors related to interventions (augmentation, induction, or epidural use) were examined in predicting VBAC (Table K-11). Three studies consistently showed reduced likelihood of VBAC with augmentation.13, 17, 30 Two studies13, 20 showed that induction reduced the likelihood of VBAC and three more studies showed the same trend.17, 24, 25 One of these studies showed no effect when a non-prostaglandin was used but showed a reduced likelihood of VBAC if a prostaglandin was used.24

Table K-11 Current obstetric factors: type of labor

Author, Year Study Design | Characteristic | Adjusted OR^*^ or RR for VBAC | 95% CI or P value
Augmentation
Macones, 2001^30^ Case Control | Yes | 0.47 | 0.25–0.88
Landon, 2005^13^ Prospective Cohort | Referent: Spontaneous | 0.68^*^ | 0.62–0.75
Gonen, 2004^17^ Prospective Cohort | Augmentation with oxytocin | 0.29 | 0.16–0.53
Spaans, 2002^25^ Retrospective Cohort | Yes | 0.83 | 0.30–2.50
Induction
Gonen, 2004^17^ Prospective Cohort | On admit Referent: in labor and ROM | 0.6 | 0.3–1.5
Gonen, 2004^17^ Prospective Cohort | During labor | 0.5 | 0.23–1.11
Landon, 2005^13^ Prospective Cohort | Referent: Spontaneous | 0.5^*^ | 0.45–0.55
Learman, 1996^20^ Retrospective Cohort | Yes | 0.34 (*RR) | 0.19–0.67 RR
Spaans, 2002^25^ Retrospective Cohort | Yes | 0.67 | 0.16–3.33
Smith, 2005^24^ Retrospective Cohort | IOL: Non-prostaglandin Referent: Spontaneous | 1.00 | 0.87–1.14
Smith, 2005^24^ Retrospective Cohort | IOL: With prostaglandin Referent: Spontaneous | 0.70 | 0.63–0.79
Epidural use
McNally, 1999^21^ Retrospective Cohort | Yes | 0.26 | 0.06–1.12
Landon, 2005^13^ Prospective cohort | Yes | 2.70^*^ | 2.44–3.03
Gonen, 2004^17^ Prospective Cohort | Yes | 0.17 | 0.09–0.35

* Only univariate odds ratio provided

Abbreviations: CI=confidence interval; IOL=induction of labor; OR=odds ratio; ROM=rupture of membranes; RR=relative risk; VBAC=vaginal birth after cesarean

The overall evidence suggests that epidurals reduced the likelihood of VBAC17, 21 but is not completely consistent with one study showing an increased likelihood of VBAC.13

#### Summary of Predictors of Vaginal Birth After Cesarean

With the exception of three studies,11, 12, 24 these prognostic studies of VBAC could be described as exploratory.37 According to Simon and Altman, studies that report association and identify patients at risk but that have not yet had results confirmed in followup studies with pre-stated hypotheses, do not yet provide sufficient evidence to change clinical practice.37 The three studies11, 12, 24 that provided this cross-validation evidence also proposed screening tools for VBAC and are discussed in detail in the section on Screening Tools for VBAC and in Appendix N.

### Summary of Predictors

Hispanic and African American women were more likely to have a TOL but less likely to have a VBAC compared with non-Hispanic and white women, respectively. Women at rural and private hospitals had a decreased likelihood of TOL and a decreased likelihood of VBAC. A prior history of vaginal delivery was consistently reported to increase likelihood of VBAC. Women delivering infants over 4 kg have a reduced likelihood of VBAC. Greater progress of labor--measured as greater dilation, lower station and higher Bishop score--predicts a higher likelihood of VBAC. The effect of epidural use on the likelihood of VBAC is uncertain.

## References

1 Cameron CA, Roberts CL, Peat B. Predictors of labor and vaginal birth after cesarean section. Int J Gynaecol Obstet. 2004;85(3):267-269. [pmid: 15145263].
2 McMahon MJ, Luther ER, Bowes WA Jr, Olshan AF. Comparison of a trial of labor with an elective second cesarean section. N Engl J Med. 1996;335(10):689-695. [pmid: 8703167].
3 Pang MW, Law LW, Leung TY, Lai PY, La TK. Sociodemographic factors and pregnancy events associated with women who declined vaginal birth after cesarean section. Eur J Obstet Gynecol Reprod Biol. 2009;143(1):24-28. [pmid: 19136194].
4 Bujold E. Uterine rupture during a trial of labor after a one- versus two-layer closure of low transverse cesarean. Am J Obstet Gynecol. 2001;184(suppl S18).
5 Chang JJ, Stamilio DM, Macones GA. Effect of hospital volume on maternal outcomes in women with prior cesarean delivery undergoing trial of labor. Am J Epidemiol. 2008;167(6):711-718. [pmid: 18192674].
6 Harper LM, Cahill AG, Stamilio DM, Odibo AO, Peipert JF, Macones GA. Effect of gestational age at the prior cesarean delivery on maternal morbidity in subsequent VBAC attempt. Am J Obstet Gynecol. 2009;200(3):276.e271-276. [pmid: 19167694].
7 Hueston WJ, Rudy M. Factors predicting elective repeat cesarean delivery. Obstet Gynecol. 1994;83(5 Pt 1):741-744. [pmid: 8164936].
8 Selo-Ojeme D, Abulhassan N, Mandal R, Tirlapur S, Selo-Ojeme U. Preferred and actual delivery mode after a cesarean in London, UK. Int J Gynaecol Obstet. 2008;102(2):156-159. [pmid: 18436222].
9 Kabir AA, Pridjian G, Steinmann WC, Herrera EA, Khan MM. Racial differences in cesareans: an analysis of U.S. 2001 National Inpatient Sample Data. Obstet Gynecol. 2005;105(4):710-718. [pmid: 15802395].
10 Macones GA, Peipert J, Nelson DB, et al. Maternal complications with vaginal birth after cesarean delivery: a multicenter study. Am J Obstet Gynecol. 2005;193(5):1656-1662. [pmid: 16260206].
11 Flamm BL, Geiger AM. Vaginal birth after cesarean delivery: an admission scoring system. Obstet Gynecol. 1997;90(6):907-910. [pmid: 9397100].
12 Grobman WA, Lai Y, Landon MB, et al. Development of a nomogram for prediction of vaginal birth after cesarean delivery. Obstet Gynecol. 2007;109(4):806-812. [pmid: 17400840].
13 Landon MB, Leindecker S, Spong CY, et al. The MFMU Cesarean Registry: factors affecting the success of trial of labor after previous cesarean delivery. Am J Obstet Gynecol. 2005;193(3 Pt 2):1016-1023. [pmid: 16157104].
14 Strong JM, McQuillan K. Factors affecting mode of delivery in labour following a single previous birth by cesarean. Journal of Obs & Gyn. 1996;16(5).
15 Bujold E, Blackwell SC, Hendler I, Berman S, Sorokin Y, Gauthier RJ. Modified Bishop's score and induction of labor in patients with a previous cesarean delivery. Am J Obstet Gynecol. 2004;191(5):1644-1648. [pmid: 15547536].
16 Caughey AB, Shipp TD, Repke JT, Zelop CM, Cohen A, Lieberman E. Rate of uterine rupture during a trial of labor in women with one or two prior cesarean deliveries. Am J Obstet Gynecol. 1999;181(4):872-876. [pmid: 10521745].
17 Gonen R, Tamir A, Degani S, Ohel G. Variables associated with successful vaginal birth after one cesarean section: a proposed vaginal birth after cesarean section score. Am J Perinatol. 2004;21(8):447-453. [pmid: 15580540].
18 Gyamfi C, Juhasz G, Gyamfi P, Stone JL. Increased success of trial of labor after previous vaginal birth after cesarean. Obstet Gynecol. 2004;104(4):715-719. [pmid: 15458891].
19 King DE, Lahiri K. Socioeconomic factors and the odds of vaginal birth after cesarean delivery. JAMA. 1994;272(7):524-529. [pmid: 8046806].
20 Learman LA, Evertson LR, Shiboski S. Predictors of repeat cesarean delivery after trial of labor: do any exist?. J Am Coll Surg. 1996;182(3):257-262. [pmid: 8603247].
21 McNally OM, Turner MJ. Induction of labour after 1 previous Caesarean section. Aust N Z J Obstet Gynaecol. 1999;39(4):425-429. [pmid: 10687757].
22 Quinones JN, Stamilio DM, Pare E, Peipert JF, Stevens E, Macones GA. The effect of prematurity on vaginal birth after cesarean delivery: success and maternal morbidity. Obstet Gynecol. 2005;105(3):519-524. [pmid: 15738018].
23 Shipp TD, Zelop CM, Repke JT, Cohen A, Caughey AB, Lieberman E. Labor after previous cesarean: influence of prior indication and parity. Obstet Gynecol. 2000;95(6 Pt 1):913-916. [pmid: 10831991].
24 Smith GCS, White IR, Pell JP, Dobbie R. Predicting cesarean section and uterine rupture among women attempting vaginal birth after prior cesarean section. PLoS Med. 2005;2(9):e252. [pmid: 16146414].
25 Spaans WA, Sluijs MB, van Roosmalen J, Bleker OP. Risk factors at caesarean section and failure of subsequent trial of labour. Eur J Obstet Gynecol Reprod Biol. 2002;100(2):163-166. [pmid: 11750957].
26 Srinivas SK, Stamilio DM, Stevens EJ, Odibo AO, Peipert JF, Macones GA. Predicting failure of a vaginal birth attempt after cesarean delivery. Obstet Gynecol. 2007;109(4):800-805. [pmid: 17400839].
27 Weinstein D, Benshushan A, Tanos V, Zilberstein R, Rojansky N. Predictive score for vaginal birth after cesarean section. Am J Obstet Gynecol. 1996;174(1 Pt 1):192-198. [pmid: 8572005].
28 Zelop CM, Shipp TD, Cohen A, Repke JT, Lieberman E. Trial of labor after 40 weeks' gestation in women with prior cesarean. Obstet Gynecol. 2001;97(3):391-393. [pmid: 11239643].
29 Zelop CM, Shipp TD, Repke JT, Cohen A, Lieberman E. Outcomes of trial of labor following previous cesarean delivery among women with fetuses weighing >4000 g. Am J Obstet Gynecol. 2001;185(4):903-905. [pmid: 11641675].
30 Macones GA, Hausman N, Edelstein R, Stamilio DM, Marder SJ. Predicting outcomes of trials of labor in women attempting vaginal birth after cesarean delivery: a comparison of multivariate methods with neural networks. Am J Obstet Gynecol. 2001;184(3):409-413. [pmid: 11228495].
31 Eden KB, Hashima JN, Osterweil P, Nygren P, Guise J-M. Childbirth preferences after cesarean birth: a review of the evidence. Birth. 2004;31(1):49-60. [pmid: 15015993].
32 McClain CS. The making of a medical tradition: vaginal birth after cesarean. Soc Sci Med. 1990;31(2):203-210. [pmid: 2389156].
33 Caughey AB, Shipp TD, Repke JT, Zelop C, Cohen A, Lieherman E. Trial of labor after cesarean delivery: the effect of previous vaginal delivery. Am J Obstet Gynecol. 1998;179(4):938-941. [pmid: 9790374].
34 Elkousy MA, Sammel M, Stevens E, Peipert JF, Macones G. The effect of birth weight on vaginal birth after cesarean delivery success rates. Am J Obstet Gynecol. 2003;188(3):824-830. [pmid: 12634665].
35 Mercer BM, Gilbert S, Landon MB, et al. Labor outcomes with increasing number of prior vaginal births after cesarean delivery. Obstet Gynecol. 2008;111(2 Pt 1):285-291. [pmid: 18238964].
36 Huang WH, Nakashima DK, Rumney PJ, Keegan KA Jr, Chan K. Interdelivery interval and the success of vaginal birth after cesarean delivery. Obstet Gynecol. 2002;99(1):41-44. [pmid: 11777508].
37 Simon R, Altman D. Statistical aspects of prognostic factor studies in oncology. Br J Cancer. 1994;69:979-985. [pmid: 8198989].