# Strength of Evidence Table

| Domains pertaining to strength of evidence | | | | Magnitude of effect | Strength of Evidence
# of Studies; # of Subjects | Risk of Bias (Design/Quality) | Consistency | Directness | Precision | Vaginal Birth After Cesarean Rate | Low, Moderate, High
Vaginal Birth After Cesarean Rate
67 368,304 | Medium 16 cohort (Good Quality); 51 cohort (Fair Quality) | Inconsistent | Direct for delivery outcome | Precise | 74% (95% CI: 72% to 75%) | Moderate
# of Studies; # of Subjects | Risk of Bias (Design/Quality) | Consistency | Directness | Precision | Proportion of Induced Trials of Labor | Low, Moderate, High
Any Induction Method in Trial of Labor: Proportion with Vaginal Birth After Cesarean
28 11,938 | Medium 1 RCT, 19 cohort, 9 case series (Fair Quality) | Consistent | Direct | Precise | 63% (95% CI: 59% to 67%) | Moderate
Prostaglandin E_2_ Induction in Trial of Labor: Proportion with Vaginal Birth After Cesarean
5 1671 | Medium 11 case series, 4 cohort (Fair Quality) | Inconsistent | Direct | Precise | 63% (95% CI: 58% to 69%) | Moderate
Misoprostol Induction in TOL: Proportion with Vaginal Birth After Cesarean
2 96 | Medium Cohort, (Fair Quality) | Inconsistent | Direct | Imprecise | 61% (95% CI: 27% to 90%) | Low
Oxytocin Induction in Trial of Labor: Proportion with Vaginal Birth After Cesarean
5 308 | Low 2 cohort, 3 case series (Fair Quality) | Inconsistent | Direct | Imprecise | 62% (95% CI: 53% to 70%) | Low
Oxytocin Augmentation in Trial of Labor: Proportion with Vaginal Birth After Cesarean
7 660^*^ | Medium 5 cohort, 2 case series (Fair Quality) | Inconsistent | Direct | Imprecise | 68% (95% CI: 64% to 72%) | Low
Oxytocin verses Prostaglandin E_2_ Induction in Trial of Labor: Proportion with Vaginal Birth After Cesarean
2 3301 | 1 RCT (Poor Quality) 1 cohort (Fair Quality) | Inconsistent | Indirect | Imprecise | Not applicable | Low
Mechanical Induction in Trial of Labor: Proportion with Vaginal Birth After Cesarean
Foley Catheter
2 416 | 2 cohort (Fair Quality) | Consistent | Direct | Imprecise | 54% (95% CI: 49% to 59%) | Moderate
# of Studies; # of Subjects | Risk of Bias (Design/Quality) | Consistency | Directness | Precision | Trial of Labor versus Elective Repeat Cesarean Delivery | Low, Moderate, High
Maternal Mortality
14 405,827 | Medium 13 cohort (2 Good, 11 Fair Quality); 1 case control (Fair Quality) | Consistent | Direct | Precise | TOL: 3.8/100,000 (95% CI: 0.9/100,000 to 15.5/100,000) ERCD: 13.4/100,000 (95% CI: 4.3/100,000 to 41.6/100,000) | High
Maternal Outcomes: Uterine Rupture Rate
8 63,499 | Medium 4 prospective cohort; 4 retrospective cohort (4 include both TOL and ERCD) | Consistent | Direct | Precise | Overall: 3% (95% CI: 0.2% to 0.4%) TOL: 0.47% (95% CI: 0.28% to 0.68%) ERCD: 0.04% (95% CI: 0.018% to 0.11%) | Moderate
# of Studies; # of Subjects | Risk of Bias (Design/Quality) | Consistency | Directness | Precision | Proportion of Induced Trials of Labor | Low, Moderate, High
Any Induction Method in Trial of Labor: Uterine Rupture
7 5296 | Medium 5 cohort, 2 case series (Fair Quality) | Inconsistent | Direct | Imprecise | 1.2% (95% CI: 0.7% to 1.9%) | Low
Prostaglandin E_2_ Induction in Trial of Labor: Uterine Rupture
12 | 6 cohort (5 Fair, 1 Good Quality) 6 case series (Fair Quality) | Inconsistent | Direct | Imprecise | 2% (95% CI: 1.1% to 3.5%) | Low
Misoprostol Induction in Trial of Labor: Uterine Rupture
1 226 | Cohort (Fair Quality) | NA | Direct | Imprecise | 13% | Low
Oxytocin Induction in Trial of Labor: Uterine Rupture
9 5713 | Medium 1 case control, 5 cohort, 3 case series (Fair Quality) | Inconsistent | Direct | Precise | 1.1% (95% CI: 0.9% to 1.5%) | Moderate
Oxytocin Augmentation in Trial of Labor: Uterine Rupture
Insufficient data to assess
Oxytocin verses Prostaglandin E_2_ Induction in Trial of Labor: Uterine Rupture
1 3035 | Medium 1 cohort (Fair Quality) | NA | Direct | Imprecise | Increased risk found in oxytocin groups | Low
Mechanical Induction in Trial of Labor: Uterine Rupture
Insufficient data to assess
Any Induction method in Trial of Labor: Other Harms
Insufficient data to assess
Prostaglandin E_2_ Induction in Trial of Labor: Other Harms
Insufficient data to assess
Misoprostol Induction in Trial of Labor: Other Harms
Insufficient data to assess
Oxytocin Induction in Trial of Labor: Other Harms
Insufficient data to assess
Oxytocin Augmentation in Trial of Labor: Other Harms
Insufficient data to assess
Oxytocin verses Prostaglandin E_2_ Induction in Trial of Labor: Other Harms
Insufficient data to assess
Mechanical Induction in Trial of Labor: Other Harms
Insufficient data to assess
# of Studies; # of Subjects | Risk of Bias (Design/Quality) | Consistency | Directness | Precision | Trial of Labor versus Elective Repeat Cesarean Delivery | Low, Moderate, High
Maternal Outcomes: Hysterectomy
16 402,059 | Medium 14 cohort (4 Good, 10 Fair Quality); 1 case control (Good Quality) | Inconsistent | Direct | Precise | Overall: 0.537/1,000 (95% CI: −1.49/1,000 to 0.419/1,000) TOL: 1.73/1,000 (95% CI: 0.115/1,000 to 2.42/1,000) ERCD: 3.1/1,000 (95% CI: 0.172/1,000 to 4.88/1,000) | Moderate
Maternal Outcomes: Transfusion
10 409,382 | Medium 10 cohort (4 Good, 6 Fair Quality) | Consistent | Direct | Precise | Overall: −0.818/1,000 (95% CI: −0.339/1,000 to 1.76/1,000) TOL: 8.81/1,000 (95% CI: 4.2/1,000 to 15.1/1,000) ERCD:11.6/1,000 (95% CI: 6.39/1,000 to 18.3/1,000) | Moderate
Maternal Outcomes: Blood Loss/Hemorrhage
7 47,754 | High 7 cohort (1 Good, 6 Fair Quality) | Inconsistent | Indirect | Imprecise | General trend toward increased blood loss with ERCD and RCD after a TOL when reported | Low
Maternal Outcomes: Effect of Induction on Hemorrhage
Insufficient data to assess
Maternal Outcomes: Infection, All Definitions
22 354,060 | High 20 cohort (5 Good, 15 Fair Quality); 2 case control (Fair Quality) | Inconsistent | Indirect | Imprecise | Overall: 0.93% (95% CI: 0.068% to 1.8%) TOL: 6.3% (95% CI: 3.4% to 10.1%) ERCD: 3.9% (95% CI: 2.3% to 5.8%) | Low
Maternal Outcomes: Fever
12;26,679 | High 1 cohort (1 Good, 11 Fair Quality) | Inconsistent | Direct | Imprecise | Overall: −5.4% (95% CI: −9.9% to −0.80%) TOL: 6.6% (95% CI: 4.4% to 9.3%) ERCD: 10.2% (95% CI: 4.9% to 17.1%) | Low
Long Term Maternal Outcomes: Adhesions
Insufficient data to assess
Long Term Maternal Outcomes: Pelvic Pain
Insufficient data to assess
Long Term Maternal Outcomes: Reproductive Health
Insufficient data to assess
Infant Outcomes: Perinatal Mortality (infant death occurring ≥20 weeks-28 days life)
5 76,899 | Medium 4 cohort (3 Good, 1 Fair Quality) | Consistent | Indirect | Imprecise | TOL: 0.00133 (95% CI: 0.00059 to 0.00034) ERCD: 0.00050 (95% CI: 0.00007 to 0.00382) | Moderate
Infant Outcomes: Fetal Mortality (infant death occurring ≥20 weeks gestation, but prior to birth)
2 63,646 | Medium 2 cohort (Good Quality, 1with AP/IP deaths; 1 IP only) | Consistent | Indirect | Imprecise | TOL (overall): 39/30,834 (1.3/1000) ERCD (overall): 23/32,806 (0.7/1000) | Low (2 cohort studies)
Infant Outcomes: Neonatal Mortality (infant death occurring after birth but ≤ 28 days of life)
6 108,328 | Medium 6 cohorts (3 Fair, 3 Good Quality) | Consistent | Indirect | Imprecise | TOL: 0.00114 (95% CI: 0.00063 to 0.00204) ERCD: 0.00055 (95% CI: 0.00020 to 0.00150) | Moderate
Term Infant Outcomes: Transient Tachypnea of the Newborn
3 4,927 | Medium 3 cohort (Fair Quality) | Inconsistent | Direct | Imprecise | TOL: 36.1/1,000 ERCD: 42/1,000 | Low
Term Infant Outcomes: Neonatal Respiratory Morbidity with Bag & Mask Ventilation
3 2,110 | Medium 3 cohort (Fair Quality) | Inconsistent | Direct | Imprecise | TOL: 53.7/1000 ERCD: 25/1000 | Low
Term Infant Outcomes: Neonatal Respiratory Morbidity with Intubation for Meconium
2 1438 | Medium 2 cohort (Fair Quality) | Consistent | Direct | Precise | TOL: 11.5% ERCD: 1.5% | Moderate
Term Infant Outcomes: Hypoxic Ischemic Encephalopathy and Asphyxia
3 62,829 | High (definition issues) 3 cohort (Fair Quality) | Inconsistent | Low | Imprecise | Cannot calculate summary estimate | Low
Term Infant Outcomes: Neonatal Intensive Care Unit Admissions
*8 65,121 | Medium 8 cohort (2 Good, 6 Fair Quality) | Inconsistent | Indirect | Imprecise | Cannot calculate summary estimate | Low
Term Infant Outcomes: Short and Long Term Neurologic Outcomes
Insufficient data to assess
Term Infant Outcomes: Confirmed Sepsis
Insufficient data to assess | High (definition issues) 3 cohort (Fair Quality) | Inconsistent | Indirect | Imprecise | Cannot calculate summary estimate | Low
Term Infant Outcomes: Trauma
2 41,899 | High (definition issues) 2 cohort (Fair Quality) | Inconsistent | Indirect | Imprecise | Cannot calculate summary estimate | Insufficient
Term Infant Outcomes: Breastfeeding
Insufficient data to assess

* 1 case series included 628 women with induced labor, number with augmentation not reported

Abbreviations: AP=antepartum; CI=confidence interval; ERCD=elective repeat cesarean delivery; IP=intrapartum; RCD=repeat cesarean delivery; TOL=trial of labor