# Technical Expert Panel Members

## Technical Expert Panel Members

Eugene Declercq, Ph.D. Assistant Dean, Doctoral Education Professor, Department of Community Health Sciences at Boston University
Stanley Ip, M.D. Investigator, TUFTS University Evidence-based Practice Center at New England Medical Center
Amelia Psmythe Executive Director, Nursing Mothers Counsel of Oregon
Carol Sakala, Ph.D., M.S.P.H. Director of Programs with Childbirth Connections.
John M. Thorp, Jr., M.D. Division Director, Professor Adjunct Professor in the Department of Obstetrics and Gynecology at the University of North Carolina
Linda J. Van Marter, M.D., M.P.H. Associate Professor of Pediatrics at Harvard Medical School, Children's Hospital

## Professional Organization Representation

American Academy of Family Physicians Represented by: Lesley Atwood, M.D.
American Academy of Pediatrics Represented by: Allen Merritt, M.D., M.P.A:HA
American College of Nurse-Midwives Represented by: Mary Barger, C.N.M., M.P.H.
American College of Obstetricians and Gynecologists Represented by: Carolyn Zelop, M.D.