# Acknowledgments

This systematic evidence review was developed for the National Institutes of Health Consensus Development Conference on Vaginal Birth After Cesarean: New Insights. It was supported by the Office of Medical Applications of Research (OMAR) at the National Institutes of Health and the Agency for Healthcare Research and Quality (AHRQ) and the investigators acknowledge the contributions of Shilpa Amin, M.D., M.B.sc, FAAFP, Task Order Officer, AHRQ; Lata Nerurkar, Ph.D., OMAR, Jennifer Croswell, M.D., M.P.H, OMAR; and Gary Cunningham, M.D., Chair of the Consensus Development Conference Panel. Investigators thank the Technical Expert Panel members for providing guidance for the project, the peer reviewers for providing feedback on the draft report, Andrew Hamilton, M.L.S., M.S., for conducting the literature searches; and Benjamin Chan, M.S., for providing statistical assistance; Abby Parsons, M.D., for providing abstract and paper review assistance; JoDee Anderson, M.D. for assistance on neonatal outcomes; and Alia Broman for data abstraction assistance.