# Abbreviations and Acronyms

ACOG: [underlined: A]merican [underlined: C]ollege of [underlined: O]bstetricians and [underlined: G]ynecologists
AUROC: Area Under the Receiver Operating Characteristic curve
AHRQ: Agency for Healthcare Research and Quality
AAP: American Academy of Pediatrics
BMI: Body mass index
CDC: Centers for Disease Control and Prevention
CI: Confidence interval
DARE: Database of Abstracts of Reviews of Effectiveness
EPC: Evidence-based Practice Center
ERCD: Elective repeat cesarean delivery
FDA: Food and Drug Administration
FHR: Fetal heart rate
FMR: Fetal mortality rate
FTP: Failure to progress
GA: Gestational age
HCUP: Healthcare Cost and Utilization Project
HIE: Hypoxic-ischemic encephalopathy
HMO: Health Maintenance Organizations
I/A: Induction/augmentation
ICD-9: International Classification of Diseases, 9th Edition/Revision
ICU: Intensive care unit
IOL: Induction of labor
IRB: Institutional review board
IRCD: Indicated repeat cesarean delivery
IUFD: Intrapartum fetal demise
kg: Kilograms
LTCD: Low transverse cesarean delivery
  National Institute of Child Health and Human Development Maternal-Fetal Medicine
MFMU: Units
mL: Milliliters
mm: Millimeters
NICU: Neonatal intensive care unit
NIH: National Institutes of Health
NMR: Neonatal mortality rate
NNH: Number needed to harm
NS: Not significant
OMAR: National Institutes of Health Office of Medical Applications of Research
OECD: Organization for Economic Cooperation and Development
OR: Odds ratio
PGE_2_: prostaglandin E_2_
PMR: Perinatal mortality rate
RCD: Repeat cesarean delivery
RCT: Randomized controlled trial
RD: Risk difference
RDS: Respiratory distress syndrome
ROC: Receiver operating characteristic
ROM: Rupture of the membranes
RR: Relative risk
TEP: Technical expert panel
TTN: Transient tachypnea of the newborn
UK: United Kingdom
US: United States of America
USPSTF: US Preventive Services Task Force
VBAC: Vaginal birth after cesarean section
wk: Week(s)