# References

1 Jerant AF, Fenton JJ, Franks P. Determinants of racial/ethnic colorectal cancer screening disparities. Arch Intern Med. Jun. 23. 2008;168(12):1317-24. [pmid: 18574089].
2 Wong ST, Gildengorin G, Nguyen T, et al. Disparities in colorectal cancer screening rates among Asian Americans and non-Latino whites. Cancer. Dec. 15. 2005;104(12 Suppl):2940-7. [pmid: 16276538].
3 Screening for colorectal cancer: U. S. Preventive Services Task Force recommendation statement. Ann Intern Med. Nov. 4. 2008;149(9):627-37. [pmid: 18838716].
4 Levin B, Lieberman DA, McFarland B, et al. Screening and surveillance for the early detection of colorectal cancer and adenomatous polyps, 2008: a joint guideline from the American Cancer Society, the US Multi-Society Task Force on Colorectal Cancer, and the American College of Radiology. Gastroenterology. May. 2008;134(5):1570-95. [pmid: 18384785].
5 Chassin MR, Galvin RW. The urgent need to improve health care quality. Institute of Medicine National Roundtable on Health Care Quality. J Am Med Assoc. Sep. 16. 1998;280(11):1000-5.
6 Winawer SJ, Stewart ET, Zauber AG, et al. A comparison of colonoscopy and double-contrast barium enema for surveillance after polypectomy. National Polyp Study Work Group. N Engl J Med. Jun. 15. 2000;342(24):1766-72. [pmid: 10852998].
7 Mandel JS, Bond JH, Church TR, et al. Reducing mortality from colorectal cancer by screening for fecal occult blood. Minnesota Colon Cancer Control Study. N Engl J Med. May. 13. 1993;328(19):1365-71. [pmid: 8474513].
8 Hardcastle JD, Chamberlain JO, Robinson MH, et al. Randomised controlled trial of faecal-occult-blood screening for colorectal cancer. Lancet. Nov. 30. 1996;348(9040):1472-7. [pmid: 8942775].
9 Kronborg O, Fenger C, Olsen J, et al. Randomised study of screening for colorectal cancer with faecal‐occult-blood test. Lancet. Nov. 30. 1996;348(9040):1467-71. [pmid: 8942774].
10 Lindholm E, Brevinge H, Haglind E. Survival benefit in a randomized clinical trial of faecal occult blood screening for colorectal cancer. Br J Surg. Aug. 2008;95(8):1029-36. [pmid: 18563785].
11 US Preventive Services Task Force. Guide to clinical preventive services. Baltimore. Williams & Wilkins. 1989.
12 US Preventive Services Task Force. Guide to clinical preventive services. 2nd ed. Baltimore. Williams and Wilkins. 1996.
13 Screening for colorectal cancer: recommendation and rationale. Ann Intern Med. Jul. 16. 2002;137(2):129-31. [pmid: 12118971].
14 Pignone M, Rich M, Teutsch SM, et al. Screening for colorectal cancer in adults at average risk: a summary of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. Jul. 16. 2002;137(2):132-41. [pmid: 12118972].
15 Pignone M, Rich M, Teutsch SM, et al. Screening for colorectal cancer in adults. Systematic Evidence Review No. 7. AHRQ Pub No. 02-S003. Rockville, MD. Agency for Healthcare Research and Quality. 2002.
16 Winawer SJ, Fletcher RH, Miller L, et al. Colorectal cancer screening: clinical guidelines and rationale. Gastroenterology. Feb. 1997;112(2):594-642. [pmid: 9024315].
17 Winawer S, Fletcher R, Rex D, et al. Colorectal cancer screening and surveillance: clinical guidelines and rationale--update based on new evidence. Gastroenterology. Feb. 2003;124(2):544-60. [pmid: 12557158].
18 Mandel JS, Church TR, Bond JH, et al. The effect of fecal occult-blood screening on the incidence of colorectal cancer. N Engl J Med. Nov. 30. 2000;343(22):1603-7. [pmid: 11096167].
19 Use of mammograms among women aged > or = 40 years--United States, 2000–2005. MMWR Morb Mortal Wkly Rep. Jan. 26. 2007;56(3):49-51. [pmid: 17251897].
20 Warren JL, Klabunde CN, Mariotto AB, et al. Adverse events after outpatient colonoscopy in the Medicare population. Ann Intern Med. Jun. 16. 2009;150(12:):849-57. W152. [pmid: 19528563].
21 Seeff LC, Nadel MR, Klabunde CN, et al. Patterns and predictors of colorectal cancer test use in the adult U.S. population. Cancer. May. 15. 2004;100(10):2093-103. [pmid: 15139050].
22 Pollack LA, Blackman DK, Wilson KM, et al. Colorectal cancer test use among Hispanic and non-Hispanic U.S. populations. Prev Chronic Dis. Apr. 2006;3(2):A50. [pmid: 16539791].
23 Schroy PC, Heeren TC. A comparative study of patient perceptions and screening preferences for stool-based DNA testing (SBDNA), fecal occult blood testing (FOBT), or colonoscopy (CS). Gastroenterology. 2003;124(4 Suppl):A604.
24 Klabunde CN, Lanier D, Breslau ES, et al. Improving colorectal cancer screening in primary care practice: innovative strategies and future directions. J Gen Intern Med. Aug. 2007;22(8):1195-205. [pmid: 17534688].
25 Sheridan SL, Harris RP, Woolf SH. Shared decision making about screening and chemoprevention. a suggested approach from the U.S. Preventive Services Task Force. Am J Prev Med. Jan. 2004;26(1):56-66. [pmid: 14700714].
26 Green L, Kreuter M. Health program planning: an educational and ecological approach. 4th ed. McGraw Hill. NY. 2004.
27 Slattery ML, Kinney AY, Levin TR. Factors associated with colorectal cancer screening in a population-based study: the impact of gender, health care source, and time. Prev Med. Mar. 2004;38(3):276-83. [pmid: 14766109].
28 Coughlin SS, Thompson TD. Colorectal cancer screening practices among men and women in rural and nonrural areas of the United States, 1999. J Rural Health. Spring. 2004;20(2):118-24. [pmid: 15085624].
29 Subramanian S, Klosterman M, Amonkar MM, et al. Adherence with colorectal cancer screening guidelines: a review. Prev Med. May. 2004;38(5):536-50. [pmid: 15066356].
30 Agency for Healthcare Research and Quality. Methods Guide for Comparative Effectiveness REviews, Version 1.0. [Draft posted Oct. 2007]. Rockville, MD. Available at: http://effectivehealthcare.ahrq.gov/repFiles/2007_10D.raftMethodsGuide.pdf. 2007.
31 Owens DK, Lohr KN, Atkins D, et al. Grading the strength of a body of evidence when comparing medical interventions--Agency for Healthcare Research and Quality and the Effective Health Care Program. Journal of clinical epidemiology. 2009:07/13.
32 Jemal A, Siegel R, Ward E, et al. Cancer statistics, 2009. CA Cancer J Clin. Jul-Aug. 2009;59(4):225-49. [pmid: 19474385].
33 Jemal A, Thun MJ, Ries LA, et al. Annual report to the nation on the status of cancer, 1975–2005, featuring trends in lung cancer, tobacco use, and tobacco control. J Natl Cancer Inst. Dec. 3. 2008;100(23):1672-94. [pmid: 19033571].
34 DeLancey JO, Thun MJ, Jemal A, et al. Recent trends in Black-White disparities in cancer mortality. Cancer Epidemiol Biomarkers Prev. Nov. 2008;17(11):2908-12. [pmid: 18990730].
35 Schneider EC, Nadel MR, Zaslavsky AM, et al. Assessment of the scientific soundness of clinical performance measures: a field test of the National Committee for Quality Assurance’s colorectal cancer screening measure. Arch Intern Med. Apr. 28. 2008;168(8):876-82. [pmid: 18443264].
36 Baier M, Calonge N, Cutter G, et al. Validity of self-reported colorectal cancer screening behavior. Cancer Epidemiol Biomarkers Prev. Feb. 2000;9(2):229-32. [pmid: 10698488].
37 Gordon NP, Hiatt RA, Lampert DI. Concordance of self-reported data and medical record audit for six cancer screening procedures. J Natl Cancer Inst. Apr. 7. 1993;85(7):566-70. [pmid: 8455203].
38 Montano DE, Phillips WR. Cancer screening by primary care physicians: a comparison of rates obtained from physician self-report, patient survey, and chart audit. Am J Public Health. Jun. 1995;85(6):795-800. [pmid: 7762712].
39 Schenck AP, Klabunde CN, Warren JL, et al. Data sources for measuring colorectal endoscopy use among Medicare enrollees. Cancer Epidemiol Biomarkers Prev. Oct. 2007;16(10):2118-27. [pmid: 17932360].
40 Schenck AP, Klabunde CN, Warren JL, et al. Evaluation of claims, medical records, and self-report for measuring fecal occult blood testing among Medicare enrollees in fee for service. Cancer Epidemiol Biomarkers Prev. Apr. 2008;17(4):799-804. [pmid: 18381471].
41 Breen N, Wagener DK, Brown ML, et al. Progress in cancer screening over a decade: results of cancer screening from the 1987, 1992, and 1998 National Health Interview Surveys. J Natl Cancer Inst. Nov. 21. 2001;93(22):1704-13. [pmid: 11717331].
42 Peterson NB, Murff HJ, Ness RM, et al. Colorectal cancer screening among men and women in the United States. J Womens Health (Larchmt). Jan‐Feb. 2007;16(1):57-65. [pmid: 17324097].
43 Meissner HI, Breen N, Klabunde CN, et al. Patterns of colorectal cancer screening uptake among men and women in the United States. Cancer Epidemiol Biomarkers Prev. Feb. 2006;15(2):389-94. [pmid: 16492934].
44 Colorectal cancer test use among persons aged > or = 50 years--United States, 2001. MMWR Morb Mortal Wkly Rep. Mar. 14. 2003;52(10):193-6. [pmid: 12653456].
45 Use of colorectal cancer tests--United States, 2002, 2004, and 2006. MMWR Morb Mortal Wkly Rep. Mar. 14. 2008;57(10):253-8. [pmid: 18340331].
46 Shapiro JA, Seeff LC, Thompson TD, et al. Colorectal cancer test use from the 2005 National Health Interview Survey. Cancer Epidemiol Biomarkers Prev. Jul. 2008;17(7):1623-30. [pmid: 18628413].
47 Trends in screening for colorectal cancer--United States, 1997 and 1999. MMWR Morb Mortal Wkly Rep. Mar. 9. 2001;50(9):162-6. [pmid: 11393486].
48 Nease DE Jr, Ruffin MTt, Klinkman MS, et al. Impact of a generalizable reminder system on colorectal cancer screening in diverse primary care practices: a report from the Prompting and Reminding at Encounters for Prevention Project. Med Care. Sep. 2008;46(9 Suppl 1):S68-73. [pmid: 18725836].
49 Lafata JE, Williams LK, Ben-Menachem T, et al. Colorectal carcinoma screening procedure use among primary care patients. Cancer. Oct. 1. 2005;104(7):1356-61. [pmid: 16092119].
50 Bao Y, Fox SA, Escarce JJ. Socioeconomic and racial/ethnic differences in the discussion of cancer screening: “between-“ versus “within-“ physician differences. Health Serv Res. Jun. 2007;42(3 Pt 1):950-70. [pmid: 17489898].
51 Ling BS, Trauth JM, Fine MJ, et al. Informed decision-making and colorectal cancer screening: is it occurring in primary care?. Med Care. Sep. 2008;46(9 Suppl 1):S23-9. [pmid: 18725829].
52 Wackerbarth SB, Tarasenko YN, Joyce JM, et al. Physician colorectal cancer screening recommendations: an examination based on informed decision making. Patient Educ Couns. Apr. 2007;66(1):43-50. [pmid: 17098393].
53 Wolf MS, Baker DW, Makoul G. Physician-patient communication about colorectal cancer screening. J Gen Intern Med. Nov. 2007;22(11):1493-9. [pmid: 17851721].
54 Lafata JE, Divine G, Moon C, et al. Patient-physician colorectal cancer screening discussions and screening use. Am J Prev Med. Sep. 2006;31(3):202-9. [pmid: 16905030].
55 Berkowitz Z, Hawkins NA, Peipins LA, et al. Beliefs, risk perceptions, and gaps in knowledge as barriers to colorectal cancer screening in older adults. J Am Geriatr Soc. Feb. 2008;56(2):307-14. [pmid: 18070002].
56 Cairns CP, Viswanath K. Communication and colorectal cancer screening among the uninsured: data from the Health Information National Trends Survey (United States). Cancer Causes Control. Nov. 2006;17(9):1115-25. [pmid: 17006717].
57 Klabunde CN, Vernon SW, Nadel MR, et al. Barriers to colorectal cancer screening: a comparison of reports from primary care physicians and average-risk adults. Med Care. Sep. 2005;43(9):939-44. [pmid: 16116360].
58 Fenton JJ, Cai Y, Green P, et al. Trends in colorectal cancer testing among Medicare subpopulations. Am J Prev Med. Sep. 2008;35(3):194-202. [pmid: 18619761].
59 Schenck AP, Peacock SC, Klabunde CN, et al. Trends in colorectal cancer test use in the medicare population, 1998–2005. Am J Prev Med. Jul. 2009;37(1):1-7. [pmid: 19423273].
60 Harewood GC, Lieberman DA. Colonoscopy practice patterns since introduction of Medicare coverage for average-risk screening. Clin Gastroenterol Hepatol. Jan. 2004;2(1):72-7. [pmid: 15017635].
61 Robertson RH, Burkhardt JH, Powell MP, et al. Trends in colon cancer screening procedures in the US Medicare and Tricare populations: 1999–2001. Prev Med. Jun. 2006;42(6):460-2. [pmid: 16563479].
62 Prajapati DN, Saeian K, Binion DG, et al. Volume and yield of screening colonoscopy at a tertiary medical center after change in Medicare reimbursement. Am J Gastroenterol. Jan. 2003;98(1):194-9. [pmid: 12526957].
63 Gross CP, Andersen MS, Krumholz HM, et al. Relation between Medicare screening reimbursement and stage at diagnosis for older patients with colon cancer. JAMA. Dec. 20. 2006;296(23):2815-22. [pmid: 17179458].
64 El-Serag HB, Petersen L, Hampel H, et al. The use of screening colonoscopy for patients cared for by the Department of Veterans Affairs. Arch Intern Med. Nov. 13. 2006;166(20):2202-8. [pmid: 17101937].
65 Brounts LR, Lehmann RK, Lesperance KE, et al. Improved rates of colorectal cancer screening in an equal access population. Am J Surg. May. 2009;197(5):609-12. discussion 12–3. [pmid: 19306971].
66 Messina CR, Lane DS, Colson RC. Colorectal cancer screening among users of county health centers and users of private physician practices. Public Health Rep. Jul-Aug. 2009;124(4):568-78. [pmid: 19618794].
67 Benson VS, Patnick J, Davies AK, et al. Colorectal cancer screening: a comparison of 35 initiatives in 17 countries. Int J Cancer. Mar. 15. 2008;122(6):1357-67. [pmid: 18033685].
68 DeBourcy AC, Lichtenberger S, Felton S, et al. Community-based preferences for stool cards versus colonoscopy in colorectal cancer screening. J Gen Intern Med. Feb. 2008;23(2):169-74. [pmid: 18157581].
69 Hawley ST, Volk RJ, Krishnamurthy P, et al. Preferences for colorectal cancer screening among racially/ethnically diverse primary care patients. Med Care. Sep. 2008;46(9 Suppl 1):S10-6. [pmid: 18725820].
70 Schroy PC 3rd, Heeren TC. Patient perceptions of stool-based DNA testing for colorectal cancer screening. Am J Prev Med. Feb. 2005;28(2):208-14. [pmid: 15710277].
71 Weir HK, Thun MJ, Hankey BF, et al. Annual report to the nation on the status of cancer, 1975–2000, featuring the uses of surveillance data for cancer prevention and control. J Natl Cancer Inst. Sep. 3. 2003;95(17):1276-99. [pmid: 12953083].
72 Increased use of colorectal cancer tests--United States, 2002 and 2004. MMWR Morb Mortal Wkly Rep. Mar. 24. 2006;55(11):308-11. [pmid: 16557215].
73 VHA Office of Quality and Performance intranet. website: http://vaww.oqp.med.va.gov/NOTE: This is an internal web site and not available to the public. Accessed August 24, 2009.
74 Walter LC, Lindquist K, Nugent S, et al. Impact of age and comorbidity on colorectal cancer screening among older veterans. Ann Intern Med. Apr. 7. 2009;150(7):465-73. [pmid: 19349631].
75 Fisher DA, Galanko J, Dudley TK, et al. Impact of comorbidity on colorectal cancer screening in the veterans healthcare system. Clin Gastroenterol Hepatol. Aug. 2007;5(8):991-6. [pmid: 17627900].
76 Fisher DA, Judd L, Sanford NS. Inappropriate colorectal cancer screening: findings and implications. Am J Gastroenterol. Nov. 2005;100(11):2526-30. [pmid: 16279910].
77 Mysliwiec PA, Brown ML, Klabunde CN, et al. Are physicians doing too much colonoscopy? A national survey of colorectal surveillance after polypectomy. Ann Intern Med. Aug. 17. 2004;141(4):264-71. [pmid: 15313742].
78 Winawer SJ, Zauber AG, Fletcher RH, et al. Guidelines for colonoscopy surveillance after polypectomy: a consensus update by the US Multi-Society Task Force on Colorectal Cancer and the American Cancer Society. Gastroenterology. May. 2006;130(6):1872-85. [pmid: 16697750].
79 Boolchand V, Olds G, Singh J, et al. Colorectal screening after polypectomy: a national survey study of primary care physicians. Ann Intern Med. Nov. 7. 2006;145(9):654-9. [pmid: 17088578].
80 Krist AH, Jones RM, Woolf SH, et al. Timing of repeat colonoscopy: disparity between guidelines and endoscopists’ recommendation. Am J Prev Med. Dec. 2007;33(6):471-8. [pmid: 18022063].
81 Robertson DJ, Greenberg ER, Beach M, et al. Colorectal cancer in patients under close colonoscopic surveillance. Gastroenterology. Jul. 2005;129(1):34-41. [pmid: 16012932].
82 Laiyemo AO, Pinsky PF, Marcus PM, et al. Utilization and yield of surveillance colonoscopy in the continued follow-up study of the polyp prevention trial. Clin Gastroenterol Hepatol. May. 2009;7(5):562-7. quiz 497. [pmid: 19138760].
83 Collins JF, Lieberman DA, Durbin TE, et al. Accuracy of screening for fecal occult blood on a single stool sample obtained by digital rectal examination: a comparison with recommended sampling practice. Ann Intern Med. Jan. 18. 2005;142(2):81-5. [pmid: 15657155].
84 Nadel MR, Shapiro JA, Klabunde CN, et al. A national survey of primary care physicians’ methods for screening for fecal occult blood. Ann Intern Med. Jan. 18. 2005;142(2):86-94. [pmid: 15657156].
85 Stokamer CL, Tenner CT, Chaudhuri J, et al. Randomized controlled trial of the impact of intensive patient education on compliance with fecal occult blood testing. J Gen Intern Med. Mar. 2005;20(3):278-82. [pmid: 15836533].
86 Miglioretti DL, Rutter CM, Bradford SC, et al. Improvement in the diagnostic evaluation of a positive fecal occult blood test in an integrated health care organization. Med Care. Sep. 2008;46(9 Suppl 1):S91-6. [pmid: 18725839].
87 Etzioni DA, Yano EM, Rubenstein LV, et al. Measuring the quality of colorectal cancer screening: the importance of follow-up. Dis Colon Rectum. Jul. 2006;49(7):1002-10. [pmid: 16673056].
88 Fisher DA, Jeffreys A, Coffman CJ, et al. Barriers to full colon evaluation for a positive fecal occult blood test. Cancer Epidemiol Biomarkers Prev. Jun. 2006;15(6):1232-5. [pmid: 16775188].
89 Rao SK, Schilling TF, Sequist TD. Challenges in the management of positive fecal occult blood tests. J Gen Intern Med. Mar. 2009;24(3):356-60. [pmid: 19130147].
90 Shields HM, Weiner MS, Henry DR, et al. Factors that influence the decision to do an adequate evaluation of a patient with a positive stool for occult blood. Am J Gastroenterol. Jan. 2001;96(1):196-203. [pmid: 11197252].
91 Baig N, Myers RE, Turner BJ, et al. Physician-reported reasons for limited follow-up of patients with a positive fecal occult blood test screening result. Am J Gastroenterol. Sep. 2003;98(9):2078-81. [pmid: 14499791].
92 Levin B, Hess K, Johnson C. Screening for colorectal cancer. A comparison of 3 fecal occult blood tests. Arch Intern Med. May. 12. 1997;157(9):970-6. [pmid: 9140267].
93 Turner B, Myers RE, Hyslop T, et al. Physician and patient factors associated with ordering a colon evaluation after a positive fecal occult blood test. J Gen Intern Med. May. 2003;18(5):357-63. [pmid: 12795734].
94 Klabunde CN, Riley GF, Mandelson MT, et al. Health plan policies and programs for colorectal cancer screening: a national profile. Am J Manag Care. Apr. 2004;10(4):273-9. [pmid: 15124504].
95 Whitlock EP, Lin JS, Liles E, et al. Screening for colorectal cancer: a targeted, updated systematic review for the U.S. Preventive Services Task Force. Ann Intern Med. Nov. 4. 2008;149(9):638-58. [pmid: 18838718].
96 Bressler B, Paszat LF, Chen Z, et al. Rates of new or missed colorectal cancers after colonoscopy and their risk factors: a population-based analysis. Gastroenterology. Jan. 2007;132(1):96-102. [pmid: 17241863].
97 Leaper M, Johnston MJ, Barclay M, et al. Reasons for failure to diagnose colorectal carcinoma at colonoscopy. Endoscopy. Jun. 2004;36(6):499-503. [pmid: 15202045].
98 Haseman JH, Lemmel GT, Rahmani EY, et al. Failure of colonoscopy to detect colorectal cancer: evaluation of 47 cases in 20 hospitals. Gastrointest Endosc. Jun. 1997;45(6):451-5. [pmid: 9199899].
99 Rex DK, Cutler CS, Lemmel GT, et al. Colonoscopic miss rates of adenomas determined by back-to-back colonoscopies. Gastroenterology. Jan. 1997;112(1):24-8. [pmid: 8978338].
100 Pabby A, Schoen RE, Weissfeld JL, et al. Analysis of colorectal cancer occurrence during surveillance colonoscopy in the dietary Polyp Prevention Trial. Gastrointest Endosc. Mar. 2005;61(3):385-91. [pmid: 15758908].
101 Imperiale TF, Glowinski EA, Juliar BE, et al. Variation in polyp detection rates at screening colonoscopy. Gastrointest Endosc. Jun. 2009;69(7):1288-95. [pmid: 19481649].
102 Barclay RL, Vicari JJ, Doughty AS, et al. Colonoscopic withdrawal times and adenoma detection during screening colonoscopy. N Engl J Med. Dec. 14. 2006;355(24):2533-41. [pmid: 17167136].
103 Chen SC, Rex DK. Endoscopist can be more powerful than age and male gender in predicting adenoma detection at colonoscopy. Am J Gastroenterol. Apr. 2007;102(4):856-61. [pmid: 17222317].
104 Barclay RL, Vicari JJ, Greenlaw RL. Effect of a time-dependent colonoscopic withdrawal protocol on adenoma detection during screening colonoscopy. Clin Gastroenterol Hepatol. Oct. 2008;6(10):1091-8. [pmid: 18639495].
105 Shah HA, Paszat LF, Saskin R, et al. Factors associated with incomplete colonoscopy: a population-based study. Gastroenterology. Jun. 2007;132(7):2297-303. [pmid: 17570204].
106 Zimmerman RK, Tabbarah M, Trauth J, et al. Predictors of lower endoscopy use among patients at three inner-city neighborhood health centers. J Urban Health. Mar. 2006;83(2):221-30. [pmid: 16736371].
107 Zapka JG, Puleo E, Vickers-Lahti M, et al. Healthcare system factors and colorectal cancer screening. Am J Prev Med. Jul. 2002;23(1):28-35. [pmid: 12093420].
108 Young WF, McGloin J, Zittleman L, et al. Predictors of colorectal screening in rural Colorado: testing to prevent colon cancer in the high plains research network. The Journal of rural health : official journal of the American Rural Health Association and the National Rural Health Care Association. 2007;(3):238-45.
109 Yip MP, Tu SP, Chun A, et al. Participation in colorectal cancer screening among Chinese Americans. Asian Pac J Cancer Prev. Oct‐Dec. 2006;7(4):645-50. [pmid: 17250445].
110 Yano EM, Soban LM, Parkerton PH, et al. Primary care practice organization influences colorectal cancer screening performance. Health Serv Res. Jun. 2007;42(3 Pt 1):1130-49. [pmid: 17489907].
111 Wee CC, McCarthy EP, Phillips RS. Factors associated with colon cancer screening: the role of patient factors and physician counseling. Prev Med. Jul. 2005;41(1):23-9. [pmid: 15916989].
112 Walsh JM, Kaplan CP, Nguyen B, et al. Barriers to colorectal cancer screening in Latino and Vietnamese Americans. Compared with non-Latino white Americans. J Gen Intern Med. Feb. 2004;19(2):156-66. [pmid: 15009795].
113 Trivers KF, Shaw KM, Sabatino SA, et al. Trends in colorectal cancer screening disparities in people aged 50–64 years, 2000–2005. Am J Prev Med. Sep. 2008;35(3):185-93. [pmid: 18617355].
114 Thorpe LE, Mostashari F, Hajat A, et al. Colon cancer screening practices in New York City, 2003: results of a large random-digit dialed telephone survey. Cancer. Sep. 1. 2005;104(5):1075-82. [pmid: 16044401].
115 Thompson B, Coronado GD, Solomon CC, et al. Cancer prevention behaviors and socioeconomic status among Hispanics and non-Hispanic whites in a rural population in the United States. Cancer Causes Control. Oct. 2002;13(8):719-28. [pmid: 12420950].
116 Thompson B, Coronado G, Neuhouser M, et al. Colorectal carcinoma screening among Hispanics and non-Hispanic whites in a rural setting. Cancer. Jun. 15. 2005;103(12):2491-8. [pmid: 15880744].
117 Thompson B, Coronado G, Chen L, et al. Celebremos la salud! a community randomized trial of cancer prevention (United States). Cancer Causes Control. Jun. 2006;17(5):733-46. [pmid: 16633921].
118 Sun WY, Basch CE, Wolf RL, et al. Factors associated with colorectal cancer screening among Chinese-Americans. Prev Med. Aug. 2004;39(2):323-9. [pmid: 15226041].
119 Shih YC, Zhao L, Elting LS. Does Medicare coverage of colonoscopy reduce racial/ethnic disparities in cancer screening among the elderly?. Health Aff (Millwood). Jul-Aug. 2006;25(4):1153-62. [pmid: 16835198].
120 Shih YC, Elting LS, Levin B. Disparities in colorectal screening between US-born and foreign-born populations: evidence from the 2000 National Health Interview Survey. J Cancer Educ. Jan‐Mar. 2008;23(1):18-25. [pmid: 18444042].
121 Shah M, Zhu K, Potter J. Hispanic acculturation and utilization of colorectal cancer screening in the United States. Cancer Detect Prev. 2006;30(3):306-12. [pmid: 16872756].
122 Schumacher MC, Slattery ML, Lanier AP, et al. Prevalence and predictors of cancer screening among American Indian and Alaska native people: the EARTH study. Cancer Causes Control. Sep. 2008;19(7):725-37. [pmid: 18307048].
123 Schootman M, Jeffe DB, Baker EA, et al. Effect of area poverty rate on cancer screening across US communities. J Epidemiol Community Health. Mar. 2006;60(3):202-7. [pmid: 16476748].
124 Schneider EC, Rosenthal M, Gatsonis CG, et al. Is the type of Medicare insurance associated with colorectal cancer screening prevalence and selection of screening strategy?. Med Care. Sep. 2008;46(9 Suppl 1):S84-90. [pmid: 18725838].
125 Schenck AP, Klabunde CN, Davis WW. Racial differences in colorectal cancer test use by Medicare consumers. Am J Prev Med. Apr. 2006;30(4):320-6. [pmid: 16530619].
126 Rosen AB, Schneider EC. Colorectal cancer screening disparities related to obesity and gender. J Gen Intern Med. Apr. 2004;19(4):332-8. [pmid: 15061742].
127 Pham HH, Schrag D, Hargraves JL, et al. Delivery of preventive services to older adults by primary care physicians. JAMA. Jul. 27. 2005;294(4):473-81. [pmid: 16046654].
128 O’Malley AS, Forrest CB, Mandelblatt J. Adherence of low-income women to cancer screening recommendations. J Gen Intern Med. Feb. 2002;17(2):144-54. [pmid: 11841530].
129 O’Malley AS, Forrest CB, Feng S, et al. Disparities despite coverage: gaps in colorectal cancer screening among Medicare beneficiaries. Arch Intern Med. Oct. 10. 2005;165(18):2129-35. [pmid: 16217003].
130 Nguyen BH, McPhee SJ, Stewart SL, et al. Colorectal cancer screening in Vietnamese Americans. J Cancer Educ. Jan-Mar. 2008;23(1):37-45. [pmid: 18444045].
131 Muus KJ, Baker-Demaray T, McDonald LR, et al. Body mass index and cancer screening in older American Indian and Alaska Native men. J Rural Health. Winter. 2009;25(1):104-8. [pmid: 19166569].
132 Menis M, Kozlovsky B, Langenberg P, et al. Body mass index and up-to-date colorectal cancer screening among Marylanders aged 50 years and older. Prev Chronic Dis. Jul. 2006;3(3):A88. [pmid: 16776889].
133 McQueen A, Vernon SW, Meissner HI, et al. Are there gender differences in colorectal cancer test use prevalence and correlates?. Cancer Epidemiol Biomarkers Prev. Apr. 2006;15(4):782-91. [pmid: 16614124].
134 Matthews BA, Nattinger AB, Venkatesan T, et al. Colorectal cancer screening among midwestern community-based residents: indicators of success. J Community Health. Apr. 2007;32(2):103-20. [pmid: 17571524].
135 Ling BS, Klein WM, Dang Q. Relationship of communication and information measures to colorectal cancer screening utilization: results from HINTS. J Health Commun. 2006;11(Suppl 1):181-90. [pmid: 16641083].
136 Levy BT, Dawson J, Hartz AJ, et al. Colorectal cancer testing among patients cared for by Iowa family physicians. Am J Prev Med. Sep. 2006;31(3):193-201. [pmid: 16905029].
137 Lemon S, Zapka J, Puleo E, et al. Colorectal cancer screening participation: comparisons with mammography and prostate-specific antigen screening. Am J Public Health. Aug. 2001;91(8):1264-72. [pmid: 11499116].
138 Koroukian SM, Xu F, Dor A, et al. Colorectal cancer screening in the elderly population: disparities by dual Medicare-Medicaid enrollment status. Health Serv Res. Dec. 2006;41(6):2136-54. [pmid: 17116113].
139 Koroukian SM, Litaker D, Dor A, et al. Use of preventive services by Medicare fee-for-service beneficiaries: does spillover from managed care matter?. Med Care. May. 2005;43(5):445-52. [pmid: 15838408].
140 Katz ML, James AS, Pignone MP, et al. Colorectal cancer screening among African American church members: a qualitative and quantitative study of patient-provider communication. BMC Public Health. Dec. 15. 2004;4:62. [pmid: 15601463].
141 Jerant AF, Arellanes RE, Franks P. Factors associated with Hispanic/non-Hispanic white colorectal cancer screening disparities. J Gen Intern Med. Aug. 2008;23(8):1241-5. [pmid: 18500503].
142 Janz NK, Wren PA, Schottenfeld D, et al. Colorectal cancer screening attitudes and behavior: a population-based study. Prev Med. Dec. 2003;37(6 Pt 1):627-34. [pmid: 14636796].
143 Hudson SV, Ohman-Strickland P, Cunningham R, et al. The effects of teamwork and system support on colorectal cancer screening in primary care practices. Cancer Detect Prev. 2007;31(5):417-23. [pmid: 18031947].
144 Honda K, Kagawa-Singer M. Cognitive mediators linking social support networks to colorectal cancer screening adherence. J Behav Med. Oct. 2006;29(5):449-60. [pmid: 16958004].
145 Heo M, Allison DB, Fontaine KR. Overweight, obesity, and colorectal cancer screening: disparity between men and women. BMC Public Health. Nov. 8. 2004;4:53. [pmid: 15533259].
146 Gupta S, Tong L, Allison JE, et al. Screening for colorectal cancer in a safety-net health care system: access to care is critical and has implications for screening policy. Cancer Epidemiol Biomarkers Prev. Sep. 2009;18(9):2373-9. [pmid: 19745221].
147 Goel MS, Wee CC, McCarthy EP, et al. Racial and ethnic disparities in cancer screening: the importance of foreign birth as a barrier to care. J Gen Intern Med. Dec. 2003;18(12):1028-35. [pmid: 14687262].
148 Gilbert A, Kanarek N. Colorectal cancer screening: physician recommendation is influential advice to Marylanders. Prev Med. Aug. 2005;41(2):367-79. [pmid: 15917034].
149 Afable-Munsuz A, Liang SY, Ponce NA, et al. Acculturation and colorectal cancer screening among older Latino adults: differential associations by national origin. J Gen Intern Med. Aug. 2009;24(8):963-70. [pmid: 19472016].
150 Ananthakrishnan AN, Schellhase KG, Sparapani RA, et al. Disparities in colon cancer screening in the Medicare population. Arch Intern Med. Feb. 12. 2007;167(3):258-64. [pmid: 17296881].
151 Ata A, Elzey JD, Insaf TZ, et al. Colorectal cancer prevention: adherence patterns and correlates of tests done for screening purposes within United States populations. Cancer Detect Prev. 2006;30(2):134-43. [pmid: 16638628].
152 Atlas SJ, Grant RW, Ferris TG, et al. Patient-physician connectedness and quality of primary care. Ann Intern Med. Mar. 3. 2009;150(5):325-35. [pmid: 19258560].
153 Brawarsky P, Brooks DR, Mucci LA, et al. Effect of physician recommendation and patient adherence on rates of colorectal cancer testing. Cancer Detect Prev. 2004;28(4):260-8. [pmid: 15350629].
154 Carcaise-Edinboro P, Bradley CJ. Influence of patient-provider communication on colorectal cancer screening. Med Care. Jul. 2008;46(7):738-45. [pmid: 18580394].
155 Cardarelli R, Thomas JE. Having a personal health care provider and receipt of colorectal cancer testing. Ann Fam Med. Jan-Feb. 2009;7(1):5-10. [pmid: 19139443].
156 Carlos RC, Fendrick AM, Ellis J, et al. Can breast and cervical cancer screening visits be used to enhance colorectal cancer screening?. J Am Coll Radiol. Oct. 2004;1(10):769-76. [pmid: 17411698].
157 Carlos RC, Fendrick AM, Patterson SK, et al. Associations in breast and colon cancer screening behavior in women. Acad Radiol. Apr. 2005;12(4):451-8. [pmid: 15831418].
158 Christman LK, Abdulla R, Jacobsen PB, et al. Colorectal cancer screening among a sample of community health center attendees. J Health Care Poor Underserved. May. 2004;15(2):281-93. [pmid: 15253379].
159 Coughlin SS, Thompson T. Physician recommendation for colorectal cancer screening by race, ethnicity, and health insurance status among men and women in the United States, 2000. Health Promot Pract. Oct. 2005;6(4):369-78. [pmid: 16210678].
160 de Bosset V, Atashili J, Miller W, et al. Health insurance-related disparities in colorectal cancer screening in Virginia. Cancer Epidemiol Biomarkers Prev. Apr. 2008;17(4):834-7. [pmid: 18398024].
161 Diaz JA, Roberts MB, Goldman RE, et al. Effect of language on colorectal cancer screening among Latinos and non-Latinos. Cancer Epidemiol Biomarkers Prev. Aug. 2008;17(8):2169-73. [pmid: 18708410].
162 Dietrich AJ, Tobin JN, Cassells A, et al. Translation of an efficacious cancer-screening intervention to women enrolled in a Medicaid managed care organization. Ann Fam Med. Jul-Aug. 2007;5(4):320-7. [pmid: 17664498].
163 Etzioni DA, Ponce NA, Babey SH, et al. A population-based study of colorectal cancer test use: results from the 2001 California Health Interview Survey. Cancer. Dec. 1. 2004;101(11):2523-32. [pmid: 15505783].
164 Fenton JJ, Cai Y, Weiss NS, et al. Delivery of cancer screening: how important is the preventive health examination?. Arch Intern Med. Mar. 26. 2007;167(6):580-5. [pmid: 17389289].
165 Fenton JJ, Tancredi DJ, Green P, et al. Persistent racial and ethnic disparities in up-to-date colorectal cancer testing in medicare enrollees. J Am Geriatr Soc. Mar. 2009;57(3):412-8. [pmid: 19175435].
166 Ferrante JM, Ohman-Strickland P, Hudson SV, et al. Colorectal cancer screening among obese versus non-obese patients in primary care practices. Cancer Detect Prev. 2006;30(5):459-65. [pmid: 17067753].
167 Fox SA, Heritage J, Stockdale SE, et al. Cancer screening adherence: does physician-patient communication matter?. Patient Educ Couns. May. 2009;75(2):178-84. [pmid: 19250793].
168 Garman KS, Jeffreys A, Coffman C, et al. Colorectal cancer screening, comorbidity, and follow-up in elderly patients. Am J Med Sci. Oct. 2006;332(4):159-63. [pmid: 17031239].
169 Breuer-Katschinski B, Nemes K, Marr A, et al. Helicobacter pylori and the risk of colonic adenomas. Colorectal Adenoma Study Group. Digestion. 1999;60(3):210-5. [pmid: 10343134].
170 Bagai A, Parsons K, Malone B, et al. Workplace colorectal cancer-screening awareness programs: an adjunct to primary care practice?. J Community Health. Jun. 2007;32(3):157-67. [pmid: 17616009].
171 Patel P, Forjuoh SN, Avots-Avotins A, et al. Identifying opportunities for improved colorectal cancer screening in primary care. Prev Med. Aug. 2004;39(2):239-46. [pmid: 15226031].
172 Brawarsky P, Brooks DR, Mucci LA. Correlates of colorectal cancer testing in Massachusetts men and women. Prev Med. Jun. 2003;36(6):659-68. [pmid: 12744908].
173 Nash D, Azeez S, Vlahov D, et al. Evaluation of an intervention to increase screening colonoscopy in an urban public hospital setting. J Urban Health. Mar. 2006;83(2):231-43. [pmid: 16736372].
174 Zapka JG, Lemon SC, Puleo E, et al. Patient education for colon cancer screening: a randomized trial of a video mailed before a physical examination. Ann Intern Med. Nov. 2. 2004;141(9):683-92. [pmid: 15520425].
175 Myers RE, Sifri R, Hyslop T, et al. A randomized controlled trial of the impact of targeted and tailored interventions on colorectal cancer screening. Cancer. Nov. 1. 2007;110(9):2083-91. [pmid: 17893869].
176 Costanza ME, Luckmann R, Stoddard AM, et al. Using tailored telephone counseling to accelerate the adoption of colorectal cancer screening. Cancer Detect Prev. 2007;31(3):191-8. [pmid: 17646058].
177 Pignone M, Harris R, Kinsinger L. Videotape-based decision aid for colon cancer screening. A randomized, controlled trial. Ann Intern Med. Nov. 21. 2000;133(10):761-9. [pmid: 11085838].
178 Ruffin MTt, Fetters MD, Jimbo M. Preference-based electronic decision aid to promote colorectal cancer screening: results of a randomized controlled trial. Prev Med. Oct. 2007;45(4):267-73. [pmid: 17689600].
179 Tu SP, Taylor V, Yasui Y, et al. Promoting culturally appropriate colorectal cancer screening through a health educator: a randomized controlled trial. Cancer. Sep. 1. 2006;107(5):959-66. [pmid: 16865681].
180 Basch CE, Wolf RL, Brouse CH, et al. Telephone outreach to increase colorectal cancer screening in an urban minority population. Am J Public Health. Dec. 2006;96(12):2246-53. [pmid: 17077394].
181 Dolan JG, Frisina S. Randomized controlled trial of a patient decision aid for colorectal cancer screening. Med Decis Making. Mar-Apr. 2002;22(2):125-39. [pmid: 11958495].
182 Denberg TD, Coombes JM, Byers TE, et al. Effect of a mailed brochure on appointment-keeping for screening colonoscopy: a randomized trial. Ann Intern Med. Dec. 19. 2006;145(12):895-900. [pmid: 17179058].
183 Church TR, Yeazel MW, Jones RM, et al. A randomized trial of direct mailing of fecal occult blood tests to increase colorectal cancer screening. J Natl Cancer Inst. May. 19. 2004;96(10):770-80. [pmid: 15150305].
184 Braun KL, Fong M, Kaanoi ME, et al. Testing a culturally appropriate, theory-based intervention to improve colorectal cancer screening among Native Hawaiians. Prev Med. Jun. 2005;40(6):619-27. [pmid: 15850857].
185 Campbell MK, James A, Hudson MA, et al. Improving multiple behaviors for colorectal cancer prevention among african american church members. Health Psychol. Sep. 2004;23(5):492-502. [pmid: 15367069].
186 Sequist TD, Zaslavsky AM, Marshall R, et al. Patient and physician reminders to promote colorectal cancer screening: a randomized controlled trial. Arch Intern Med. Feb. 23. 2009;169(4):364-71. [pmid: 19237720].
187 Potter MB, Phengrasamy L, Hudes ES, et al. Offering annual fecal occult blood tests at annual flu shot clinics increases colorectal cancer screening rates. Ann Fam Med. Jan-Feb. 2009;7(1):17-23. [pmid: 19139445].
188 Ayanian JZ, Sequist TD, Zaslavsky AM, et al. Physician reminders to promote surveillance colonoscopy for colorectal adenomas: a randomized controlled trial. J Gen Intern Med. Jun. 2008;23(6):762-7. [pmid: 18386103].
189 Jandorf L, Gutierrez Y, Lopez J, et al. Use of a patient navigator to increase colorectal cancer screening in an urban neighborhood health clinic. J Urban Health. Jun. 2005;82(2):216-24. [pmid: 15888638].
190 Roetzheim RG, Christman LK, Jacobsen PB, et al. A randomized controlled trial to increase cancer screening among attendees of community health centers. Ann Fam Med. Jul-Aug. 2004;2(4):294-300. [pmid: 15335126].
191 Roetzheim RG, Christman LK, Jacobsen PB, et al. Long-term results from a randomized controlled trial to increase cancer screening among attendees of community health centers. Ann Fam Med. Mar‐Apr. 2005;3(2):109-14. [pmid: 15798035].
192 Ling BS, Schoen RE, Trauth JM, et al. Physicians encouraging colorectal screening: a randomized controlled trial of enhanced office and patient management on compliance with colorectal cancer screening. Arch Intern Med. Jan. 12. 2009;169(1):47-55. [pmid: 19139323].
193 Dietrich AJ, Tobin JN, Cassells A, et al. Telephone care management to improve cancer screening among low-income women: a randomized, controlled trial. Ann Intern Med. Apr. 18. 2006;144(8):563-71. [pmid: 16618953].
194 Breslow RA, Rimer BK, Baron RC, et al. Introducing the community guide’s reviews of evidence on interventions to increase screening for breast, cervical, and colorectal cancers. Am J Prev Med. Jul. 2008;35(1 Suppl):S14-20. [pmid: 18541183].
195 Brown ML, Klabunde CN, Mysliwiec P. Current capacity for endoscopic colorectal cancer screening in the United States: data from the National Cancer Institute Survey of Colorectal Cancer Screening Practices. Am J Med. Aug. 1. 2003;115(2):129-33. [pmid: 12893399].
196 Seeff LC, Richards TB, Shapiro JA, et al. How many endoscopies are performed for colorectal cancer screening? Results from CDC’s survey of endoscopic capacity. Gastroenterology. Dec. 2004;127(6):1670-7. [pmid: 15578503].
197 Ballew C, Lloyd BG, Miller SH. Capacity for colorectal cancer screening by colonoscopy, Montana, 2008. Am J Prev Med. Apr. 2009;36(4):329-32. [pmid: 19285198].
198 Benuzillo JG, Jacobs ET, Hoffman RM, et al. Rural-urban differences in colorectal cancer screening capacity in Arizona. J Community Health. 2009. Sep. 2.
199 Hur C, Gazelle GS, Zalis ME, et al. An analysis of the potential impact of computed tomographic colonography (virtual colonoscopy) on colonoscopy demand. Gastroenterology. Nov. 2004;127(5):1312-21. [pmid: 15521000].
200 Vijan S, Inadomi J, Hayward RA, et al. Projections of demand and capacity for colonoscopy related to increasing rates of colorectal cancer screening in the United States. Aliment Pharmacol Ther. Sep. 1. 2004;20(5):507-15. [pmid: 15339322].
201 Ladabaum U, Song K. Projected national impact of colorectal cancer screening on clinical and economic outcomes and health services demand. Gastroenterology. Oct. 2005;129(4):1151-62. [pmid: 16230069].
202 Seeff LC, Manninen DL, Dong FB, et al. Is there endoscopic capacity to provide colorectal cancer screening to the unscreened population in the United States?. Gastroenterology. Dec. 2004;127(6):1661-9. [pmid: 15578502].
203 Pickhardt PJ, Hassan C, Laghi A, et al. Is there sufficient MDCT capacity to provide colorectal cancer screening with CT colonography for the U.S. population?. AJR Am J Roentgenol. Apr. 2008;190(4):1044-9. [pmid: 18356453].
204 Fisher JA, Fikry C, Troxel AB. Cutting cost and increasing access to colorectal cancer screening: another approach to following the guidelines. Cancer Epidemiol Biomarkers Prev. Jan. 2006;15(1):108-13. [pmid: 16434595].
205 Framework and tools for evaluating health surveillance systems. Prepared by Health Surveillance Coordinating Committee (HSCC) Population and Public Health Branch Health Canada. Available at http://www.phac-aspc.gc.ca/php‐psp/pdf/i_Surveillance_Evaluation_Framework_v1.pdf. 2004.
206 Hall HI, Van Den Eeden SK, Tolsma DD, et al. Testing for prostate and colorectal cancer: comparison of self-report and medical record audit. Prev Med. Jul. 2004;39(1):27-35. [pmid: 15207983].
207 Fiscella K, Holt K, Meldrum S, et al. Disparities in preventive procedures: comparisons of self-report and Medicare claims data. BMC Health Serv Res. 2006;6:122. [pmid: 17010195].
208 Rauscher GH, Johnson TP, Cho YI, et al. Accuracy of self-reported cancer-screening histories: a meta‐analysis. Cancer Epidemiol Biomarkers Prev. Apr. 2008;17(4):748-57. [pmid: 18381468].
209 Haque R, Chiu V, Mehta KR, et al. An automated data algorithm to distinguish screening and diagnostic colorectal cancer endoscopy exams. J Natl Cancer Inst Monogr. 2005(35):116-8.
210 Pignone M, Scott TL, Schild LA, et al. Yield of claims data and surveys for determining colon cancer screening among health plan members. Cancer Epidemiol Biomarkers Prev. Mar. 2009;18(3):726-31. [pmid: 19273480].
211 Vernon SW, Meissner H, Klabunde C, et al. Measures for ascertaining use of colorectal cancer screening in behavioral, health services, and epidemiologic research. Cancer Epidemiol Biomarkers Prev. Jun. 2004;13(6):898-905. [pmid: 15184243].
212 Fisher DA, Voils CI, Coffman CJ, et al. Validation of a questionnaire to assess self-reported colorectal cancer screening status using face-to-face administration. Dig Dis Sci. Jun. 2009;54(6):1297-306. [pmid: 18726152].
213 Partin MR, Grill J, Noorbaloochi S, et al. Validation of self-reported colorectal cancer screening behavior from a mixed-mode survey of veterans. Cancer Epidemiol Biomarkers Prev. Apr. 2008;17(4):768-76. [pmid: 18381474].
214 Vernon SW, Tiro JA, Vojvodic RW, et al. Reliability and validity of a questionnaire to measure colorectal cancer screening behaviors: does mode of survey administration matter?. Cancer Epidemiol Biomarkers Prev. Apr. 2008;17(4):758-67. [pmid: 18381467].
215 Harewood GC, Wiersema MJ, Melton LJ 3rd. A prospective, controlled assessment of factors influencing acceptance of screening colonoscopy. Am J Gastroenterol. Dec. 2002;97(12):3186-94. [pmid: 12492209].
216 Lieberman D, Nadel M, Smith RA, et al. Standardized colonoscopy reporting and data system: report of the Quality Assurance Task Group of the National Colorectal Cancer Roundtable. Gastrointest Endosc. May. 2007;65(6):757-66. [pmid: 17466195].
217 Rex DK, Petrini JL, Baron TH, et al. Quality indicators for colonoscopy. Am J Gastroenterol. Apr. 2006;101(4):873-85. [pmid: 16635231].
218 von Elm E, Altman DG, Egger M, et al. The Strengthening the Reporting of Observational Studies in Epidemiology (STROBE) statement: guidelines for reporting observational studies. J Clin Epidemiol. Apr. 2008;61(4):344-9. [pmid: 18313558].
219 Altman DG, Schulz KF, Moher D, et al. The revised CONSORT statement for reporting randomized trials: explanation and elaboration. Ann Intern Med. Apr. 17. 2001;134(8):663-94. [pmid: 11304107].
220 Stone EG, Morton SC, Hulscher ME, et al. Interventions that increase use of adult immunization and cancer screening services: a meta-analysis. Ann Intern Med. May. 7. 2002;136(9):641-51. [pmid: 11992299].