# Glossary

Ability to meet projected demand: the ability of current capacity (or projected capacity if known) to meet the projected demand under various demand scenarios, such as screening the entire eligible US population with a specific test.
Acceptability: Willingness of persons and organizations to participate in the monitoring system
Appropriate use (of CRC screening): minimizing overuse and misuse as well as underuse
Compliance: Degree to which a system complies with all relevant legislation, regulations, and policies
Consistency: degree to which reported effect sizes from included studies appear to go in the same direction
Cost: Indirect and direct costs
Current capacity (or current potential volume): the sum of current volume and additional available capacity, where:
  - Current volume is the estimate of the current number of FS or colonoscopy procedures conducted in the present year; and
  - Additional available capacity is the number of additional FS or colonoscopy procedures that could be conducted in the current year.
Data quality: Completeness and validity of the data in the system
Directness: the extent to which evidence links the compared interventions directly to health outcomes
Discussions: discussions of CRC screening between physicians and patients includes a conversation covering such areas as pros and cons of screening options and eliciting patient preferences and is meant as more than simply the physician recommending testing
Flexibility: Ability of the system to accommodate changes in operating conditions or information needs
Followup: clinical procedures and tracking of patients who have received an abnormal colorectal cancer screening result
Lay health advisors: people with no clinical training who serve as educators of peers for various health issues
Monitoring: tracking and data collection of the use and/or quality of colorectal cancer screening (such as with a national surveillance data system)
Overall Strength of Evidence (SOE): reflects a global assessment that takes the required domains (i.e., risk of bias, consistency, prevision, directness) directly into account. Levels of SOE include:
  - High—High confidence that the evidence reflects the true effect. Further research is very unlikely to change our confidence in the estimate of effect.
  - Moderate—Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of effect and may change the estimate.
  - Low—Low confidence that the evidence reflects the true effect. Further research is likely to change our confidence in the estimate of effect and is likely to change the estimate.
  - Insufficient—Evidence either is unavailable or does not permit estimation of an effect.
Patient level intervention terms: - Small media—educational materials provided as videos and/or printed materials such as letters, brochures, and newsletters to inform people about specific diseases or health issues
  - Decision aids—mechanisms or interventions that have been developed to improve communication between health professionals and patients; their goal is to help involve patients in making decisions regarding their health care
  - Group education—workshop or presentation conducted within a specified group setting to deliver educational information or motivation to encourage screening
  - One-on-one interactions—studies in which a provider (e.g., physician, nurse, health educator) works individually with patients to educate them about CRC screening and/or aid them in making decisions about which tests to complete and when to receive screening. These interventions tend to include some concentrated time with a patient to answer questions, address concerns, and help facilitate completion of screening tests.
  - Eliminating structural barriers—interventions that seek to increase screening by removing structural barriers (e.g., offer more screening times or locations, provide transportation to a service, etc.)
  - Patient reminders—provided to patients (e.g., via mailed letters or phone calls) who are due for a rescreening or who have never been screened to prompt people about their need for annual screening (or for screening related to whatever period recommended for the patient)
Precision: degree of certainty surrounding an effect estimate with respect to a given outcome (i.e., for each outcome separately)
Projected capacity: future capacity to conduct FS or colonoscopy under various scenarios such as changes in workforce or changes in the number of facilities that provide procedures.
Quality (of CRC tests): “underuse,” “overuse,” and “misuse” of screening tests rather than test performance
Quality rating: internal validity or risk of bias (of studies)
Risk of bias: degree to which the included studies for any given outcome or comparison have a high likelihood of adequate protection against bias (i.e., good internal validity)
Simplicity: Structure and ease of operation
Stability: Reliability (ability to collect, manage and provide data properly without failure) and availability (ability to be operational when it is needed) of the monitoring system
Surveillance: in terms of data collection, we opted to replace the term ‘surveillance’ with regard to data collection with the term ‘monitoring’. In terms of surveillance of colorectal cancer screening results, because of initial abnormal results, we have used the term ‘followup’ instead.
Surveillance colonoscopy: colonoscopy for patients who have had a previous colonic polyp (and, usually, polypectomy)
Timeliness: Interval between occurrence of an event and reporting of the event.