# Executive Summary

## Introduction

Periodic screening of people at average risk for colorectal cancer (CRC) is recommended by three important national guideline groups, the United States Preventive Services Task Force (USPSTF), the American Cancer Society (ACS), and the U.S. Multi-Society Task Force on Colorectal Cancer (MSTF), as well as multiple professional societies. For CRC screening to contribute to a reduction in CRC mortality without unreasonable harms and costs, however, it must be offered to people who have a reasonable probability of net benefit, and it must be conducted effectively and efficiently. These issues of use and quality are especially salient for CRC screening because it is in some ways more complex (e.g., variation in timing and types of tests, invasiveness of most tests) than other screening programs. Underuse of CRC screening has been a clear problem for some years; evidence is now growing that overuse (i.e., screening people with little potential for net benefit) and misuse (i.e., conducting screening in ways that reduce net benefit) may also be important problems.

The RTI International-University of North Carolina Evidence-based Practice Center (RTI‐UNC EPC) prepared this report, under the auspices of the Agency for Healthcare Research and Quality, for the National Institutes of Health (NIH) State-of-the-Science Conference on Enhancing Use and Quality of Colorectal Cancer Screening, which is scheduled for February 2010. This report is a systematic review of evidence about the use and quality of screening for CRC focusing on four primary key questions (KQs). It also includes an initial background section (KQ 1) on trends and the current situation of use and quality, and it presents a concluding discussion on needed research (KQ 6). The specific KQs of interest were as follows:

- KQ 1. What are the recent trends in the use and quality of CRC screening?
- KQ 2. What factors influence the use of CRC screening?
- KQ 3. Which strategies are effective in increasing the appropriate use of CRC screening and followup?
- KQ 4. What are the current and projected capacities to deliver CRC screening and followup at the population level?
- KQ 5. What are the effective approaches for monitoring the use and quality of CRC screening?
- KQ 6. What research is needed to make the most progress and have the greatest public health impact in promoting the appropriate use of CRC screening?

## Methods

We searched MEDLINE®, the Cochrane Library, and the Cochrane Central Trials Registry for studies published in English from January 1998 through September 2009. We searched data sources using Medical Subject Heading (MeSH) terms when available or key words when appropriate. MeSH terms for our searches included colorectal neoplasms, colonoscopy, sigmoidoscopes (including flexible sigmoidoscopy [FS]); major headings included mass screening; and key terms included stool test, fecal occult blood test (FOBT), and DNA stool).

We used standard EPC methods of dual review of abstracts, full text articles, data abstraction for evidence tables, rating quality of articles, and grading strength of evidence. Specifically, we rated the internal validity of studies as good, fair, or poor. We used the AHRQ EPC program’s approach to grading strength of evidence as high, moderate, low, or insufficient for KQs 3, 4, and 5. We resolved disagreements by consensus.

### KQ 1: Background on Recent Trends in Use and Quality of CRC Screening

This section summarizes trends in the use of CRC screening tests, CRC screening discussions, and the quality of CRC screening. In some cases, data were insufficient to determine trends, but we present current status where possible.

Underuse of both CRC screening and patient-physician discussions of CRC screening is clear. Self-reported screening rates by national surveys, which are likely overestimates of actual screening, have increased from less than 25 percent in the late 1980s to about 50 percent to 60 percent in 2005 to 2006; an even smaller percentage of people had had a discussion about CRC screening with their primary care physician. The increased screening can be attributed entirely to an increase in the use of screening colonoscopy; screening with FOBT and sigmoidoscopy declined over this period. We found no data on the trends of use or quality of fecal immunochemical test, fecal DNA testing, or computed tomographic colonoscopy.

Few health care systems have developed monitoring systems to provide physicians with feedback on CRC screening rates, nor have they provided incentives to physicians for improving screening. The health care system of the Veterans Health Administration (VA), which relies more on FOBT than other modalities for screening and which has developed monitoring and incentive systems, has screening rates above 75 percent.

At the same time as the underuse documented above, screening can be overused when people who are unlikely to benefit are screened: for example, people older than 85 years and/or people with severe comorbidities. Surveillance colonoscopy and, probably, polypectomy for diminutive polyps less than 5mm where benefit is uncertain but increased risk is clear, may also be overused though research on this issue is still needed (i.e., the extent to which removal of small polyps is a greater or lesser harm to the patient compared to ignoring the polyps).

Finally, problems of misuse, screening in such a way as to reduce benefits and/or increase harms, are also clear. These include use of in-office rather than home FOBT; nonreturn of FOBT cards; lack of adequate followup of positive FOBT results; colonoscopy that does not reach the cecum, has too rapid withdrawal time, that misses important lesions, and colonoscopy with high adverse event rates.

## Results

Our initial searches of electronic databases, along with handsearches and an updated search in October 2009 produced 3,029 unduplicated records. Ultimately, for the four main questions, we included the following numbers of articles that were rated either good or fair quality: 72 studies addressing KQ 2, 21 addressing KQ 3, 12 addressing KQ 4, and 8 addressing KQ 5. We excluded studies rated poor quality from our analyses.

### KQ 2: Factors Influencing Colorectal Cancer Screening

We categorized studies examining factors associated with the use of CRC screening tests into five domains: patient factors, physician factors (including physician characteristics, physician-patient connectedness, and physician recommendations about screening), patient-physician communication factors, the periodic health examination, and system factors. We further categorized the patient factors into four groups: patient demographics, access to care, personal health or risk factors, and psychosocial factors.

All studies focused on factors associated with underuse of CRC screening. None focused on factors associated with underuse of CRC discussions or on factors associated with overuse or misuse of CRC screening.

Factors consistently and significantly associated with reduced CRC screening include

- low household income,
- no health insurance,
- being Hispanic or Asian,
- not being acculturated into the United States,
- limited access to care (i.e., lack of a regular source of primary care and no visits in previous year to provider), and
- no physician recommendation to be screened.

Factors positively associated with CRC screening include having private insurance, being non-Hispanic white, having a higher education level, participating in regular screenings for other cancers, having a family history of CRC or personal history of another cancer, having regular access to care, having effective patient-provider communication, and having a physician recommendation for screening. We found two studies that focused on patient factors that seem to influence followup rates after receipt of an abnormal result. We found one study each that examined the association between screening and specific physician characteristics, patient-physician connectedness, and periodic health examinations. Thus, we did not draw conclusions about these relationships because the evidence was insufficient. Studies on system level factors that might influence CRC screening did not consistently measure the same variables but seem to support counseling by nonclinicians, reminder systems, and assisting patients to keep appointments.

### KQ 3: Effective Strategies for Increasing Appropriate Use of Colorectal Cancer Screening

We first categorized studies into three intervention targets: patients, physicians, and health care systems. Following similar categories recently used to develop recommendations for the Task Force on Community Preventive Services (TFCPS), we further divided the patient-level interventions into five categories: (1) patient reminders; (2) small media (with and without decision aids); (3) group education; (4) one-on-one interactions; and (5) eliminating structural barriers. All studies of interventions focused on reducing underuse of CRC screening and/or followup after receiving a positive FOBT. We found one study that examined an intervention to increase patient-physician discussions about CRC screening. No study tested an intervention to reduce overuse or misuse of CRC screening.

Interventions that provided patient reminders led to small to moderate increases in CRC screening, with high strength of evidence (5.0 to 15.0 percentage point increase). Studies of small media (educational print or video messages) to increase CRC screening showed no benefit, with high strength of evidence. Evidence concerning decision aids to increase screening was mixed. With two of three studies showing benefit, some types of decision aids may be effective for increasing screening (14.2 to 23.0 percentage point increase in screening rates reported in the two positive studies; 3.0 percentage point increase in the one negative study), although overall strength of evidence was low. Evidence was also mixed (i.e., low strength of evidence) concerning the effect of group education, with one study showing a negative effect on screening and another finding a small positive effect. One-on-one interactions, especially with intensive contact with patients by a nurse, a health educator, or on the phone, increased screening rates, sometimes to a large degree, with percentage point increases such as 14.6 percentage points in FOBT completion, 20.9 percentage points of any CRC test, and 41.9 percentage points in FOBT completion. Strength of evidence for this type of intervention was high. Interventions that eliminated structural barriers, such as by providing FOBT tests to use at home or providing access to individuals who can help to address barriers, also increased screening rates, with high strength of evidence (absolute rate change from 14.6 to 41.9 percentage points).

Two studies of physician-targeted reminder interventions found either no effect or a very small effect on appropriate screening, with low strength of evidence. More evidence was available for evaluating various system-level interventions (e.g., implemented changes to improve referral of patients for screening or identified a person such as a patient navigator or someone in a similar role (i.e., Prevention Care Manager or PCM) to help patients navigate the health care system). These studies found consistently positive effects on screening (7.0 to 28.2 percentage point difference in screening rates compared to control groups), with high strength of evidence.

### KQ 4: Capacity to Deliver Colorectal Cancer Screening and Followup

Initially, we examined three aspects of this issue: current capacity to conduct CRC screening (six studies in seven articles), projected capacity (five studies), and ability to meet projected demand (i.e., nation’s ability to meet the projected demand under various scenarios, such as screening the entire eligible U.S. population with a specific test). Several modeling studies, using various assumptions, addressed these issues.

These modeling studies found that if the United States were to adopt a colonoscopy-only approach to CRC screening and if everyone were to agree to be screened in this way, colonoscopy capacity would need to be substantially increased to do the “catch-up” screening required to screen people who have not been screened and to continue to screen in a steady state for all eligible people. The strength of evidence for all the data and estimates from these studies is low.

### KQ 5: Effective Approaches for Monitoring CRC Use and Quality

We found no studies that directly answered the question of how CRC screening use and quality have been effectively monitored and tracked in the past decade. Included studies addressed only one specific component of monitoring, namely data quality; we found no studies that described or compared other monitoring system attributes. Overall in our review we found that some national surveys (e.g., the National Health Interview Survey [NHIS], the Behavioral Risk Factor Surveillance System [BRFSS]) monitor self-reported CRC screening by the U.S. population. Current national registries are inadequate to monitor accurately the CRC screening rates of medical practices, and few practices (with the exception of the VA system and the National Committee on Quality Assurance Healthcare Effectiveness Data and Information Set [HEDIS]) monitor their own CRC screening rates or the quality of CRC screening. No current national registries monitor either CRC discussions or overuse or misuse (including adverse events) of CRC screening. Registries for conditions other than CRC may provide some models for CRC screening.

## Discussion

Although recent trends have shown a gradual increase in CRC screening, these increases still leave levels of CRC screening considerably below levels for breast cancer screening. Some differences between the rates for CRC screening and breast cancer screening may occur because of the nature of CRC screening, with several options for screening strategies, each with its own set of preparation and completion difficulties for the patient. The implications of this review are related primarily to the findings specific to the interventions tested to increase screening, and to three cross-cutting themes that underlie our findings: access to CRC screening; communication about CRC screening; and the organization of CRC screening.

### Interventions to Improve Screening

The interventions reviewed in KQ 3 deserve further comment. Although we found high strength of evidence and positive effects for patient reminders, one-on-one interactions, eliminating structural barriers to screening, and system-level interventions, whether any specific set of interventions would effectively increase screening rates across the country remains unclear. First, whether we have the ability to implement these interventions on a broad scale within medical practices, and for the general population, is uncertain. To implement and maintain these interventions properly, an effective monitoring and feedback system (KQ 5) is needed. These systems are not in place in most primary care practices. Second, overcoming the focus in primary care practices on nonpreventive care, and overcoming the time and cost barriers to implementing and maintaining these types of screening systems within busy primary care practices, both present uncertainties. Partly because of the lack of positive incentives and the required time and effort from primary care practices, the durability of interventions that initially seem successful is uncertain. Finally, the cost effectiveness of the sometimes intensive interventions to gain disproportionately small increases in screening is also unknown. Until these more fundamental issues are dealt with, widespread implementation of any interventions may not have a large, sustained effect at reasonable costs (including time and effort of the patient, the physician, and the medical practice).

### Access to CRC Screening

A critical underlying issue in this literature is access to care, a necessary precursor to access to CRC screening. Among the most striking findings from our review of factors associated with lower rates of CRC screening (KQ 2) is that people without health insurance, people with no source of usual care, people with no recent physician visits, and people with lower income status have quite low CRC screening rates. Improved communication can only be effective for people who are connected (KQ 2) to a primary care provider. For CRC screening rates to improve dramatically, providing more standard access to this care for people who will benefit the most is essential.

### Communication About CRC Screening

One positive finding of this report is the overall importance of communication specific to CRC screening between medical staff and patients in improving appropriate CRC screening (i.e., reducing underuse, overuse, and misuse). CRC screening requires a great deal of patient understanding and effort (e.g., knowing which tests to take and when, and how to get them done). Communicating such information to patients and guiding them in making decisions specific to their medical and family history all take time. To make appropriate decisions about individually optimal screening, to carry out the preparation and follow-through correctly, and to obtain screening at recommended intervals all require patient knowledge, motivation, and assistance from medical personnel. When few CRC discussions take place (KQ 1), when many eligible patients do not know that they should be screened (KQ 2), when medical personnel make few recommendations for screening (KQ 2), when many people do not receive periodic health exams [during which time might be devoted to discussions of CRC screening (KQ 2)], and when few intensive one-on-one or system level interventions exist, including those to eliminate barriers, to assist patients to decide, prepare, and follow-through (KQ 3), suboptimal screening rates should not be surprising.

### Organization of CRC Screening and Monitoring

CRC screening in the United States requires the involvement of primary care physicians, most of whom receive no regular feedback on their CRC screening rates, as might occur in the VA or other integrated health care system. Few medical practices involve nonphysician office staff in discussing CRC screening with patients; few reach out to patients who have not been screened or who miss screening appointments. As suggested by the VA’s success with CRC screening (KQ 1), by the association of use of nonphysician staff with higher CRC screening rates (KQ 2), and by randomized controlled trials (RCTs) of organizational change (KQ 3) to improve screening, organizational change supported by monitoring and feedback systems (KQ 5) could have a positive effect on screening. Nonetheless, drawing conclusions on how to reduce overuse and misuse will always be difficult without adequate monitoring of these outcomes.

A second important aspect of organization is external to the primary care practice, and involves coordination of various parts of the health care system involved in CRC screening. Because these parts of the health care system are often fragmented, barriers are set up that patients must navigate to complete screening. These same barriers work against monitoring the progress of patients as they move through the system, and providing assistance to those who are not able to surmount the barriers. Finally, these barriers create problems for providing consistent and timely information to patients, and for establishing systems to reduce overuse and misuse.

### KQ 6: Future Research Directions

The priority for research should be RCTs of interventions to implement appropriate CRC screening (i.e., minimizing underuse, overuse, and/or misuse) and monitoring, which is then linked to improvement initiatives. In our review, we became aware of multiple studies of the operating characteristics of potential new CRC tests. Although improving screening tests is a reasonable research agenda (especially in finding ways to reduce the need for the most invasive and expensive tests), a greater balance with research could help find ways to implement screening programs that we already know are effective. To focus research primarily on developing newer screening tests without placing higher priority on implementation of the effective existing tests leaves people with inadequate screening.

Our review suggests that three steps are required for achieving higher rates of appropriate screening: (1) increasing patient access to care; (2) improving effective communication about screening and screening options between trained educators (physicians or nonphysicians) and patients; and (3) simplifying and coordinating organizational structures to better facilitate patients in completing screening. At least as important as developing newer screening tests is research to test interventions to improve access, communication, and organization of health.

Not only must the organizational and system features needed to increase screening be understood, but research also needs to consider the interaction of system features with characteristics of the population. Several studies testing interventions (KQ3) were implemented within clinic settings, limiting the generalizability of the findings. More needs to be understood about how interventions work in increasing screening among those receiving services through different settings. Since studies show that people who have access to a regular source of care are more likely to be screened (KQ2), research should focus more on those without this facilitator. In addition, access, communication, and organizational requirements to increase appropriate screening will most likely differ depending on the population involved. The most efficient and cost-effective approaches to increase appropriate screening will probably include some tailoring of the intervention to these and other specific populations.

After determination of the effectiveness and cost effectiveness of various interventions, pragmatic trials focused on implementation of successful strategies within different types of health care systems and populations are needed. Different intensities of interventions, and even wholly different interventions, will likely be needed for different populations. Interventions should be targeted at the specific steps that are problems for specific populations (e.g., those who speak other languages than English at home could likely benefit from more basic interventions to increase awareness and discussions, whereas those who are already obtaining screening on an irregular basis may benefit most from patient reminders).

Further, we also need continued research into measuring current volume and projected demand for screening strategies. Finally, we found little evidence that adequate monitoring systems that assess the full spectrum of appropriate CRC screening (including overuse, underuse, and misuse) are in widespread use, and are being used to improve screening. Such monitoring systems are critically important for continued improvement of CRC screening, especially for reduction of overuse and misuse. There is a large and important research agenda in developing and testing interventions to increase discussions of CRC screening, and to reduce overuse and misuse.

Throughout this review, accurately describing results for the outcome of CRC screening has been a major challenge because of the inconsistencies in how it has been measured and/or operationalized. We see a need to develop standard measures for assessing the outcomes (and also for assessing factors associated with screening). While efforts have been completed in the past to standardize related measures for how CRC screening is to be assessed and then to develop valid measures, these measures have not been consistently used in all national surveys or studies, making it difficult to accurately assess current screening rates. Better application of these existing measures would greatly improve the quality of the findings from studies to be done in the future, thereby expanding our understanding of what factors influence CRC screening that can actually be addressed through interventions and policy development.

This need for standard measures and mechanisms for collecting the data directly relates to the findings for KQ 5, in that we found no studies that directly answered the question of how CRC screening use and quality have been effectively monitored and tracked in the past decade. Without more information that is systematically collected through provider practices, hospitals, clinics, and other primary care organizations, our understanding of CRC screening will continue to be less than optimal.

## Conclusions

Our review suggests that the United States is yet some distance from fully realizing the promise of appropriate and high-quality CRC screening. Problems of underuse, overuse, and misuse are not being adequately addressed at present. By focusing our research effort on the issues that matter most—access to screening, communication between patient and medical staff, the organization of care—and by further researching how to implement effective and cost-effective strategies into actual primary care practice, we will have the greatest opportunity to reduce the burden of suffering of CRC for the people of the United States.