# Methods

In this chapter, we document the procedures that the RTI International–University of North Carolina Evidence-based Practice Center (RTI–UNC EPC) used to develop this comprehensive evidence report on use and quality of screening tests for colorectal cancer (CRC). To provide a framework for the review, we first present the key questions and their underlying analytic framework. We then describe our inclusion and exclusion criteria, search and retrieval process, and methods of abstracting relevant information from the eligible articles to generate evidence tables. We also discuss our criteria for rating the quality of individual articles and for grading the strength of the evidence as a whole.

## Technical Expert Panel (TEP)

In designing the study questions and methodology at the outset of this report, we consulted several technical and content experts, seeking broad expertise and perspectives. We identified five technical experts, in addition to the chair for the National Institutes of Health State-of-the-Science Conference on Enhancing Use and Quality of Colorectal Cancer Screening, for a total of six members (Appendix E). The TEP provided assistance throughout the project and contributed to the Agency for Healthcare Research and Quality (AHRQ’s) broader goals of (1) creating and maintaining science partnerships as well as public-private partnerships and (2) meeting the needs of an array of potential customers and users of its products. Thus, the TEP was both an additional resource and a sounding board during the project.

Divergent and conflicting opinions are common; we perceive them as healthy scientific discourse that contributes to a thoughtful, relevant systematic review. Nonetheless, in the end, study questions, design, and/or methodologic approaches do not necessarily represent the views of individual technical and content experts.

To ensure robust, scientifically relevant work, we called on the TEP to provide reactions to work in progress and advice on substantive issues or possibly overlooked areas of research. Specifically, TEP members participated in conference calls and discussions through e-mail to:

- refine the analytic framework at the beginning of the project;
- discuss the preliminary assessment of the literature, including inclusion/exclusion criteria; and
- provide input on the information and categories included in evidence tables.

Because of their extensive knowledge of the literature, including numerous articles authored by TEP members themselves, and their active involvement in the field, we also asked TEP members to participate in the external peer review of the draft report.

## Key Questions and Analytic Framework

Based on the key questions (KQs) described in Chapter 1, we developed an analytic framework to guide our systematic review. To recap, the KQs are as follows:

- KQ 1: Background (recent trends in the use and quality of CRC screening tests);
- KQ 2: Factors influencing use of CRC screening;
- KQ 3: Effective strategies for increasing appropriate use of CRC screening and followup;
- KQ 4: Current and projected capacities to deliver CRC screening and surveillance at the population level;
- KQ 5: Effective approaches for monitoring use and quality of CRC screening; and
- KQ 6: Needed research to make progress and have greatest public health impact in promoting the appropriate use of CRC screening.

Figure 1 depicts how we believe various factors interact to influence the appropriate use of CRC screening tests. The boxes are indicative of factors or outcomes of the process of obtaining appropriate tests; the circles are meant to depict some interaction or decision point in the process (i.e., the interaction between physician and patient and the patient’s decision point). KQs 1–5 are called out in the figure (dotted lines); the societal and health system factors are assumed to affect all steps in the process.

Figure 1 Analytic framework for the appropriate use of colorectal cancer screening

COLO, colonoscopy; CRC, colorectal cancer; CT COLO, computed tomographic colonography; DNA Stool, Deoxyribonucleic acid fecal test; FIT, fecal immunochemical test; FS, flexible sigmoidoscopy; gFOBT, guaiac-based fecal occult blood test; KQ, key question; MD, medical doctor.

Specifically, both KQ 1, which pertains to trends in use and quality of colorectal cancer screening, and KQ 5, which pertains to monitoring the use and quality, are considered to be outcomes of the process depicted in Figure 1. In the remainder of this systematic review, we assess the changes in trends over time and how the use and quality of the specific tests (i.e., colonoscopy, sigmoidoscopy, computed tomography [CT] colonography, and stool tests) are monitored. This includes paying particular attention to issues such as the extent to which overutilization and/or underutilization of tests is evident.21–22

Many factors have been shown in the literature to influence both the use and quality of tests. Although the patient is ultimately the one to decide whether to obtain screening,23 a discussion with the health care provider about screening needs and options can directly affect the decision.24–25 This discussion is depicted in the analytic framework as the point at which an interaction between key patient and provider characteristics occurs to guide the discussion.

As shown in the two boxes on the far left of the analytic framework (Figure 1), both the patient and the provider bring characteristics to this interaction that are immutable yet likely to influence the provider’s recommendations for CRC screening and the patient’s ultimate decision to seek it. Termed “predisposing” by Green and Kreuter, these factors exert their effects before a behavior occurs by increasing or decreasing a person’s or a population’s motivation to undertake that particular behavior.26 Predisposing patient characteristics that may influence the ultimate decision related to CRC screening include

- family history of CRC;
- perceived risk or understanding of whether they are likely to be diagnosed with CRC;
- education level, income, and other socioeconomic factors;27 and
- location of residence (i.e., proximity to screening facilities and/or providers).28

Predisposing physician characteristics that have been shown to influence screening recommendations24,29 include

- perceived effectiveness of each type of CRC screening test;
- physician demographic characteristics such as age, whether solo or group practice, and location of practice; and medical training and awareness of current screening guidelines.

## Literature Search

To identify articles relevant to each KQ we searched three electronic databases— MEDLINE^®^, the Cochrane Library, and the Cochrane Central Trials Registry—for articles published from January 1998 through September 2009. We used either Medical Subject Headings (MeSH or MH) as search terms when available or key words when appropriate. MeSH terms for our searches included colorectal neoplasms, colonoscopy, sigmoidoscopes; major headings included mass screening; and key terms included stool test, FOBT, and DNA stool. The full search strategy of exact search strings is presented in Appendix A.

Our initial searches of electronic databases produced 3,029 unduplicated records. We supplemented our electronic searches by manually searching reference lists of included studies, pertinent review articles, and editorials. Additional included studies were identified from recommendations of members of the TEP and by peer reviewers. We imported all citations into an electronic database (EndNote X.3).

## Study Selection Process

### Inclusion and Exclusion Criteria

As noted in Chapter 1, this systematic review focuses on the use and quality of CRC screening procedures. We developed detailed eligibility criteria with respect to population, interventions, outcomes, time period, and study design (Table 1). We limited eligible studies to those conducted in the United States so that the data would reflect domestic health care concerns, practices, and guidelines. We also restricted our searches to studies published in 1998 or later to ensure that results had relevance to current trends and practice for CRC screening. We excluded studies that (1) were published in languages other than English, (2) did not report information pertinent to the KQs, (3) had fewer than 30 subjects for randomized or nonrandomized controlled trials or fewer than 100 subjects for observational studies, (4) were not original research, or (5) evaluated interventions that were conducted in academic settings that would not be applicable to most practice settings.

Table 1 Inclusion/exclusion criteria

Category | Inclusion Criteria | Exclusion Criteria
Study population | Humans, all races, ethnicities, cultural groups Asymptomatic for CRC and not at increased risk for CRC OR at increased risk for CRC because of a family history of CRC or polyps, or because of a history of polyps at prior colonoscopy | Studies that exclusively focus on CRC screening for patients with a family history Patients with diagnosis of any of the following:; - Genetic diagnosis of FAP or suspected FAP without genetic testing evidence; - Genetic or clinical diagnosis of HNPCC (also known as Lynch syndrome) or individuals at increased risk of HNPCC; - Inflammatory bowel disease, chronic ulcerative colitis, or Crohn’s disease; - Colon and/or rectal cancer; - Other hereditary polyposis syndromes; Studies that assess whether certain groups are at greater risk for CRC than others (e.g., people with comorbidities such as diabetes, liver transplant)
Study outcomes | [underlined: KQ 2]: Factors influencing testing/screening rates only or CRC screening discussions (e.g., predisposing patient and provider characteristics, health system factors, interventions) or quality of CRC screening [underlined: KQ 3]: Interventions focused on changing appropriate CRC screening rates among a specified population and the rates are presented [underlined: KQ 4]: Available number of screening providers and related equipment/facilities and support personnel to conduct the tests (nurses, etc.) [underlined: KQ 5]: Existence and adequacy of systems for monitoring CRC screening, CRC screening discussions, quality of CRC screening | [underlined: KQ 2]: Outcomes of knowledge, risk perception, providers’ attitudes toward testing, and/or their referrals to testing (which include no screening outcome data) [underlined: KQ 3]: Changes in attitudes, beliefs, or intentions to obtain screening [underlined: Other criteria specific to outcomes]: Outcomes not directly addressing at least one KQ Cost-effectiveness, cost/benefit, or cost-utility of CRC screening for both included or excluded procedures Assessment of whether a procedure (usually two procedures compared to each other) is better at diagnosing/more effective than other procedures (usually retrospective) Assessment of different risk factors for CRC (e.g., diet in relation to diagnosis of CRC, calcium supplements, women taking hormone replacement therapy) and relation to incidence and/or mortality Treatment of complications (e.g., perforation) Treatment of CRC itself
Study geography | United States | All other countries
Time period for data collection | 1/1/1998–9/30/2009 | Data collection began before 1/1/1998
Interventions | Colonoscopy Sigmoidoscopy (or FS) CTC (or virtual colonoscopy with only CT) Double Contrast Barium Enema (DCBE)Stool tests:; - DNA stool; - FIT; - gFOBT (including Hemoccult® II and Hemoccult® SENSA®) | Office FOBT (unless described/tested along with one of the included interventions); - MRI colonoscopy (or virtual colonoscopy with MRI); - Genetic testing; - Ultrasound; Any other tests, including:; - Any unapproved tests; - Included procedures combined with others (CTC with stool tagging, CTC with CAD technology); - Carbon dioxide insufflation during colonoscopy; - Whole colonic imaging; - Chromoendoscopy; - PET and/or PET in combination with CTC, etc.; - Bidirectional endoscopy; - Laparoscopy with colonoscopy; - Molecular screening; - Submucosal injection polypectomy; - Upper GI scope/gastroscope; Studies examining the use of any of the included tests for the monitoring or assessment of a condition or disorder (e.g., diverticulitis) and therefore not for screening or surveillance of abnormal screenings for CRC Studies reporting on the use of included procedures in the surveillance of CRC Use of any included procedures to stage cancer (e.g., CTC) Studies testing the differences in sedation, dyes, and bowel cleansing methods during included procedures
Publication language | English | All other languages
Admissible evidence (study design and other criteria) | Original research that provides sufficient detail regarding methods and results to enable use and adjustment of the data and results; relevant outcomes must be able to be abstracted from data presented in the papersEligible study designs:; - RCTs; - Nonrandomized controlled trials; - Observation studies—prospective and retrospective cohort studies, case-control studies, and cross-sectional studies; - Modeling studies; Eligible sample sizes:; - RCTs: N ≥30; - Nonrandomized controlled trials: N ≥ 30; - Observational studies: N ≥ 100 | - Single case reports or small case series; - Systematic reviews; - Ecologic studies; - Historical comparisons; [underlined: KQ 3]: Studies without comparison group (e.g., pre/post only were excluded because they are generally unable to determine whether any changes in outcomes were due to a particular intervention as opposed to secular trends or other changes within a practice or setting)

CAD, computer-aided detection; CRC, colorectal cancer; CT, computed tomography; CTC, computed tomographic colonography; DNA Stool, Deoxyribonucleic acid fecal test; FAP, familial adenomatous polyposis; FIT, fecal immunochemical test; FOBT, fecal occult blood test; FS, flexible sigmoidoscopy; gFOBT, guaiac-based fecal occult blood test; GI, gastrointestinal; FS, flexible sigmoidoscopy; HNPCC, hereditary nonpolyposis colorectal cancer; KQ, key question; MR, magnetic resonance; MRI, magnetic resonance imaging; N, number; PET, positron emission tomography; RCT, randomized controlled trial.

We examined abstracts of all articles to determine whether studies met our eligibility criteria. Two members of our research team reviewed each abstract independently for inclusion or exclusion, using an Abstract Review Form (Appendix B). If one reviewer concluded on the basis of the abstract that the article should be considered in the review, we obtained the full text. Two members of our research team then independently reviewed each full-text article for inclusion or exclusion using a Full Text Review Form (Appendix B). The two relevant reviewers discussed disagreements; when they could not reach consensus, the team met and discussed the article to determine as a group whether the study met eligibility criteria. Articles that did not meet criteria for inclusion are listed in Appendix D along with reasons for exclusion.

KQs 1 and 6, although part of this report, are not part of the systematic review. Therefore, studies described or discussed for those KQs did not have to satisfy final inclusion/exclusion criteria; such articles are not included in the overall number of included studies for the systematic review. We developed a “Background” category for articles that could provide useful information for KQ 1, KQ 6, the introduction, or the discussion.

## Literature Synthesis

### Data Abstraction

We designed and used a structured data abstraction form. Trained reviewers abstracted data from each study and assigned an initial quality rating. A second reviewer read each abstracted article, evaluated the accuracy, completeness, and consistency of the data abstraction, and confirmed the quality rating. If differences in quality ratings could not be resolved by discussion, a third senior reviewer was involved. The full research team met regularly during the article abstraction period to discuss global issues related to the data abstraction process.

The final evidence tables are presented in their entirety in Appendix C. Studies are presented in the evidence tables alphabetically by the last name of the first author. A list of abbreviations and acronyms used in the tables appears at the beginning of Appendix C.

### Rating Quality of Individual Studies

To assess the quality (internal validity or risk of bias) of studies, we used predefined criteria based on those described in the AHRQ Methods Guide for Comparative Effectiveness Reviews (ratings: good, fair, poor).30

Elements of quality assessment for trials included, among others, the methods used for randomization, allocation concealment, and blinding; the similarity of compared groups at baseline; maintenance of comparable groups; overall and differential loss to followup; and the use of intention-to-treat analysis. We assessed observational studies based on the potential for selection bias (methods of selection of subjects and loss to followup), potential for measurement bias (equality, validity, and reliability of ascertainment of outcomes), adjustment for potential confounders, and statistical analysis.

In general terms, a “good” study has the least bias and results are considered to be valid. A “fair” study is susceptible to some bias but probably not sufficient to invalidate its results. The fair-quality category is likely to be broad, so studies with this rating will vary in their strengths and weaknesses. A “poor” rating indicates significant bias (stemming from, e.g., serious errors in design, analysis reporting large amounts of missing information, or discrepancies in reporting) that may invalidate the study’s results.

Studies that met all criteria were rated good quality. The majority of studies received a quality rating of fair. This category includes studies that presumably fulfilled all quality criteria but did not report their methods to an extent that answered all our questions. Thus, the fair-quality category includes studies with quite different strengths and weaknesses. Studies that had a fatal flaw (defined as a methodological shortcoming that leads to a very high probability of bias) in one or more categories were rated poor quality and excluded from our analyses. Poor-quality studies and reasons for that rating are presented in Appendix F.

### Grading Strength of Evidence

We evaluated the overall strength of evidence for the questions addressing the main outcomes of our review (KQs 3, 4, and 5) based on an approach devised for AHRQ’s Method Guide.30–31 Developed to grade the overall strength of a body of evidence, this approach incorporates four key domains: risk of bias, consistency, directness, and precision. It also considers other optional domains that may be relevant for some scenarios, such as a dose-response association, plausible confounding that would decrease the observed effect, strength of association (magnitude of effect), and publication bias. The evaluation of risk of bias includes assessment of study design and aggregate quality of studies.31

We graded evidence as consistent when effect sizes across studies were in the same direction and had a narrow range. When the evidence linked the interventions directly to our outcomes of interest, we graded the evidence as being direct. We graded evidence as being precise when results had a low degree of uncertainty. At least two members of our research team evaluated the overall strength of evidence for each outcome based on a qualitative assessment of strength of evidence for each domain and reconciled all disagreements.

The levels of strength of evidence are shown in Table 2. As mentioned, we present the strength of evidence assessments only for KQs 3, 4, and 5. These are the three KQs that are analytic and required an assessment of the body of literature available for this review. KQ 2 is descriptive and did not lend itself to an assessment of the strength of evidence. The strength of evidence tables appear in Chapter 4 as part of the presentation of results for KQs 3, 4, and 5.

Table 2 Strength of evidence grades and definitions

Grade | Definition
High | High confidence that the evidence reflects the true effect. Further research is very unlikely to change our confidence in the estimate of effect.
Moderate | Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of effect and may change the estimate.
Low | Low confidence that the evidence reflects the true effect. Further research is likely to change our confidence in the estimate of effect and is likely to change the estimate.
Insufficient | Evidence either is unavailable or does not permit estimation of an effect.

Source: Owens et al., 2009^31^

### Applicability

We evaluated the applicability of the evidence based on a qualitative assessment of the population, intensity or quality of treatment, choice of the comparator, outcomes, and timing of followup. We based our parameters for evaluation on guidance provided by AHRQ’s Methods Guide.30 Specifically, we considered whether enrolled populations differ from target populations, whether studied interventions are comparable with those in routine use, whether comparators reflect best alternatives, whether measured outcomes are known to reflect the most important clinical outcomes, and whether followup was sufficient.

## Peer Review

This draft report was subjected to external peer review by eight individuals who were experts in fields relevant to CRC screening or from various stakeholder and user communities (listed in Appendix E). We provided the draft report to them on September 14, 2009. All eight provided thoughtful feedback on the report, including providing us with additional references that we should consider for inclusion in the final report. We reviewed all additional references and included those that were appropriate and within the scope of this report. We also addressed all comments and revised the report accordingly.