# Introduction

Periodic screening of people at average risk for colorectal cancer (CRC) is recommended by three important national guideline groups, the United States Preventive Services Task Force (USPSTF), the American Cancer Society (ACS), and the U.S. Multi-Society Task Force on Colorectal Cancer (MSTF),3–4 as well as multiple professional societies. For CRC screening to contribute to a reduction in CRC mortality without unreasonable harms and costs, however, it must be offered to people who have a reasonable probability of net benefit, and it must be conducted in an effective and efficient manner. These issues of use and quality are especially salient for CRC screening because it is in some ways more complex than other screening programs. We understand “quality” to refer to “underuse,” “overuse,” and “misuse”5 rather than simply test performance. Underuse of CRC screening has been a clear problem for some years; evidence is now growing that overuse (i.e., screening people with little potential for net benefit) and misuse (i.e., conducting screening in ways that reduce net benefit) may also be important problems.

This report is a systematic review of four key questions (KQs) concerning the use and quality of screening for CRC. As part of the first KQ, a background section on trends and the current situation of use and quality are presented. Literature was not systematically reviewed for this KQ but are instead summarized to provide the reader with a sense of the current status of trends in CRC testing. The purpose of the remaining five KQs is to inform recommendations for improving the use and quality of CRC screening. To achieve this goal, we provide information about factors associated with the use of CRC screening (KQ 2), effective strategies for increasing the appropriate use of CRC screening and followup (KQ 3), the current and projected capacity of the US health care system to deliver tests (especially colonoscopy) for the population needing screening (KQ 4), and approaches for monitoring the use and quality of CRC screening (KQ 5). We then conclude the review in Chapter 5 with a discussion that includes recommendations for research needed to make progress and have greatest public health impact in promoting the appropriate use of CRC screening (KQ 6). The RTI International-University of North Carolina Evidence-based Practice Center (RTI-UNC EPC) prepared this report for the National Institutes of Health (NIH) State-of-the-Science Conference on Enhancing Use and Quality of Colorectal Cancer Screening, which is scheduled for February 2010.

## Development of Evidence and Recommendations for CRC Screening

Several screening tests for CRC are in current use, including guaiac-based fecal occult blood test (gFOBT, which can be either high or low sensitivity), fecal immunochemical test (FIT), flexible sigmoidoscopy (FS), and colonoscopy. Two other tests have been used in the past but are less used today: digital rectal examination and double contrast barium enema (DCBE). Two newer tests have been proposed but are not in widespread use: fecal DNA and computed tomographic colonography (CTC).6 This report will focus on the current and newer tests.

Since the early 1990s, four randomized controlled trials (RCTs) of screening with gFOBT7–10 have found a relative reduction of 16 percent to 33 percent in CRC mortality (absolute risk reduction = 2.9 deaths/1,000 over 13 years in the U.S. trial), first appearing 5 to 7 years after start of screening. Although the USPSTF found insufficient evidence to recommend screening in 1989,^11^ before the RCTs had reported, it recommended screening with gFOBT or FS (supported by a good-quality case-control study) in 1996,^12^ after several RCTs were published. The 1996 USPSTF recommendation, however, found insufficient evidence to recommend screening with colonoscopy, noting the lack of RCT evidence to determine the magnitude of benefit. In 2002, the USPSTF broadened its recommendation to include screening with any of several tests, including gFOBT, FS, and colonoscopy. The recommendation for colonoscopy was based on extrapolation of benefits from studies of FOBT and FS.13–15

In 2008, the USPSTF updated its recommendation again, recommending screening with any of several tests, including gFOBT, FIT, FS, and colonoscopy. It recommended that adults ages 76 to 85 not be screened routinely (i.e., screening should be determined by modeling a history of sufficient screening up until that point) and that adults ages 85 years and older not be screened at all. It found insufficient evidence to make any recommendation concerning screening with fecal DNA or CTC.3

The USPSTF placed emphasis on the need for discussion between providers and individual patients to determine the optimal screening strategy. As noted in the 2002 recommendation statement:

The choice of specific screening strategy should be based on patient preferences, medical contraindications, patient adherence, and available resources for testing and follow-up. Clinicians should talk to patients about the benefits and potential harms associated with each option before selecting a screening strategy.13

The MSTF has issued three sets of guidelines over the past 12 years (1997, 2003, and 2008) on screening for CRC; they were joined in the 2008 guideline by the American Cancer Society (ACS) (which had developed its own guidelines over previous years) and the American College of Radiology (ACR). The 1997 guideline recommended screening using one of five options: annual FOBT, FS every 5 years, annual FOBT and FS every 5 years combined, double-contrast barium enema every 5 to 10 years, and colonoscopy every 10 years.16 The 2003 recommendation repeated the same options, noting that “these guidelines offer screening options and encourage the physician and patient to decide together which is the best approach for them.”17 The 2008 recommendation suggested the same tests but added CTC and fecal DNA testing.4 The 2008 guideline departed from the previous MSTF recommendations in that it separated screening tests into those that primarily detect CRC (gFOBT, FIT, fecal DNA) and those that detect both CRC and colonic polyps (FS, colonoscopy, CTC, barium enema). It recommended a test from the latter group most strongly but also approved screening with a test from the former group if the patient refused a test that detects both CRC and polyps. The guideline states “When possible, clinicians should make patients aware of the full range of screening options, but at a minimum they should be prepared to offer patients a choice between a screening test that primarily is effective at early cancer detection and a screening test that that is effective at both early cancer detection and removal of polyps”. (p. 1570)4 Because of the changes and, often, the inconsistencies in the national guidelines, and because of such issues as patient preferences, medical contraindications, patient adherence, and available resources,13 a number of factors can affect whether or not a patient is screened. These factors are described and literature presented under KQ 2 in Chapter 4.

Four issues emerge from this brief review above. First, although only gFOBT has been tested in full RCTs of CRC screening, guideline groups have determined that other tests that find early CRC would also be effective in reducing CRC mortality. This allows a range of screening options, each with its own set of potential benefits and harms.

Second, this range of options has presented problems in making recommendations, making screening for CRC more complex in some ways than screening for such conditions as breast cancer where fewer tests (mammography, clinical breast examination) are recommended. The solution proposed by both the USPSTF and the MSTF has been discussion with patients to make individualized screening decisions. The variation in potential benefits and harms of the range of options, however, makes it unlikely that brief discussions can achieve a truly informed decision. Longer discussions to fully address all related issues are problematic because of the limited time already afforded to the physician to address preventive care during a specific medical appointment.

Third, experts disagree about whether tests that detect polyps in addition to CRC (so-called “structural tests,” such as colonoscopy) should be preferred over tests that primarily detect CRC (“nonstructural tests” such as FOBT and FIT, which are among the tests recommended by the USPSTF). Most of the mortality reduction in the RCTs of gFOBT (over 10 to 15 years of followup) has likely come from detection of early CRC rather than removal of polyps, although polypectomy has been shown to reduce the incidence of CRC by about 20 percent over 18 years of followup.18 In addition, the primary structural test (colonoscopy) carries greater potential harm and cost than non-structural tests. Thus, the evidence is not clear that the net benefits (benefits minus harms) of structural tests are greater than those of non-structural tests.

Fourth, the USPSTF recommends stopping routine CRC screening after age 75 (and all CRC screening after age 85). The MSTF acknowledges that a different screening recommendation may be appropriate for older people, but they delayed comment in the current guideline.4

## Implementation of Guidelines: Use and Quality

Although a substantial range of effective options exists, CRC screening cannot optimally reduce CRC mortality without unreasonable harms and costs unless two conditions are met: (1) screening is used by a large percentage of eligible people and (2) screening minimizes problems of quality such that patients are being screened appropriately, according to current national guidelines (i.e., underuse, overuse, and misuse are addressed). By underuse of CRC screening we mean that people who would likely derive a net benefit (in which benefits exceed risks or harms by a meaningful amount) are not screened at all or not screened at an appropriate frequency. Underuse is a common issue at the beginning of screening programs. Mammography screening for breast cancer, for example, took some years to become widespread; the 2005 Behavioral Risk Factor Surveillance System found that 74.6 percent of women ages 40 years and older reported having had a mammogram within the previous 2 years.19 An important question is whether the greater complexity of CRC screening (e.g., variety of tests, timing of each, benefits/harms of each, invasiveness of most) will result in a lower percentage of eligible people being screened, a concern of special importance for disadvantaged populations where underuse is often most severe. In addition to the underuse of CRC screening tests, there is a parallel underuse of discussions between patients and clinicians about CRC screening, as recommended by both major guideline groups.

By overuse of CRC screening we mean the screening of people (or the use of screening techniques) with a low probability of net benefit. Among the common overuse issues are screening people with severe comorbidities and screening people over age 85 (as both groups would be unlikely on a population level to live long enough to benefit from screening). Another overuse concern is overly frequent surveillance colonoscopy after a previous polypectomy; the natural history of colonic polyps is that only a small percentage progress to invasive cancer, and this progression takes many years. Thus, the frequency of surveillance should be determined by the probability of a patient developing a lesion that needs to be detected to extend life. Finally, although little literature exists on this issue, another potential problem of overuse of polypectomy may involve small polyps less than 5 mm in size. Because the current colonoscopy policy is to remove all polyps regardless of size, removal of small, low-risk polyps may yield little benefit. Yet evidence is clear that any polypectomy increases the risk of such adverse events as colonic bleeding.20

By misuse of CRC screening we mean conducting screening in ways that reduce net benefit for the people being screened. For example, misuse occurs when positive FOBT screening tests are not followed up within a reasonable time by full colon examination (such as colonoscopy). Another misuse problem is high rates of adverse events (e.g., colonic bleeding) from colonoscopy. These adverse events occur more frequently in people who have biopsies or polypectomies and in older people.20 Colonoscopy that misses clinically important lesions is also an example of misuse. This can result from such factors as lack of full insertion of the colonoscope, too rapid withdrawal time, poor bowel preparation, or lack of skill of the colonoscopist.

## Scope of this Report

In Chapter 2, we begin by presenting an overview of the methods used to address each KQ, including a description of the analytical framework used to guide our review. It is in Chapter 2 that we present the inclusion and exclusion criteria used for developing the systematic review. We note that although this report draws on the literature of the effectiveness of CRC screening, it does not review specific benefits and harms of screening. The presented literature notes gaps in the evidence base at appropriate times and states uncertainties where they exist. It does not, for example, examine the evidence of the operating characteristics of various CRC screening tests.

The first KQ, “what are the recent trends in the use and quality of colorectal cancer screening?” is presented in Chapter 3 and provides background information relative to patterns of use of CRC screening tests. The other four KQs entailed formal systematic reviews of the literature and results are presented in Chapter 4. The following are the four KQs for which we systematically reviewed available evidence:

- KQ 2: What factors influence the use of colorectal cancer screening?
  - There are two ways that this information may assist policymakers in improving the use and quality of CRC screening. One way is by uncovering modifiable factors that could be targeted in a future intervention. Another way is to show that problems in use and quality are more prevalent in one population than another. This would allow interventions to be targeted to specific population groups.
- KQ 3: Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup?
  - There are many types of interventions that could, and have been, considered to improve problems in use and quality of CRC screening. Policymakers need to know whether certain ones have been shown to be effective enough to implement immediately, and which ones are most promising for future research.
- KQ 4: What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level?
  - The primary issue here is whether screening capacity is adequate to meet expected demands, assuming that screening rates increase to optimal levels. This is a special concern with colonoscopy, which is used for both screening and surveillance. If colonoscopy capacity is inadequate for a screening policy that prioritizes structural tests, then other approaches will need to be considered.
- KQ 5: What are the effective approaches for monitoring the use and quality of colorectal cancer screening?
  - To improve any health care program, one must be able to measure the expected outcome to determine when various interventions are achieving their intended result. Thus, we need to know whether we have systems in place to monitor adequately appropriate use and quality.

The final KQ, KQ 6, addressed “what research is needed to make the most progress and have the greatest public health impact in promoting the appropriate use of colorectal cancer screening?” and is incorporated into the discussion in Chapter 5.

## Organization of this Report

The remainder of this report describes our methods to review and synthesize the literature (Chapter 2) and then summarizes the background specific to trends in use and quality of screening (KQ 1 in Chapter 3) and presents our systematic review results for KQ 2–5 (Chapter 4). In the discussion (Chapter 5), we summarize the findings and discuss the implications for practice and further research. A complete list of references is located immediately following the discussion chapter, along with a glossary of terms and a list of abbreviations used throughout this report. This report also contains the following appendices: Appendix A contains the exact search strings we used; Appendix B is all of the data abstraction forms used; Appendix C are our evidence tables; Appendix D is a list of our excluded studies; Appendix E lists the members of our Technical Expert Panel as well as our Peer Reviewers of a draft report; Appendix F lists our poor quality studies; and Appendix G contains supplemental information for KQ 4.