# Characteristics of Studies with Poor Internal Validity

To assess the quality (internal validity or risk of bias) of studies, we used predefined criteria based on those described in the AHRQ Methods Guide for Comparative Effectiveness Reviews (ratings: good, fair, poor).1 Elements of quality assessment for trials included, among others, the methods used for randomization, allocation concealment, and blinding; the similarity of compared groups at baseline; maintenance of comparable groups; overall and differential loss to followup; and the use of intention-to‐treat analysis. We assessed observational studies based on the potential for selection bias (methods of selection of subjects and loss to followup), potential for measurement bias (equality, validity, and reliability of ascertainment of outcomes), adjustment for potential confounders, and statistical analysis. In general terms, a “good” study has the least bias and results are considered to be valid. A “fair” study is susceptible to some bias but probably not sufficient to invalidate its results. The fair-quality category is likely to be broad, so studies with this rating will vary in their strengths and weaknesses. A “poor” rating indicates significant bias (stemming from, e.g., serious errors in design, analysis reporting large amounts of missing information, or discrepancies in reporting) that may invalidate the study’s results.

To systematically rate studies, we designed and used a structured data abstraction form. Trained reviewers abstracted data from each study and assigned an initial quality rating. A second reviewer read each abstracted article, evaluated the accuracy, completeness, and consistency of the data abstraction, and confirmed the quality rating. If differences in quality ratings could not be resolved by discussion, a third senior reviewer was involved. The full research team met regularly during the article abstraction period to discuss global issues related to the data abstraction process. The following lists all the studies reviewed and rated as poor quality, with their design and primary reasons for the final rating.

Study | Design | Primary Reasons for Poor Quality Rating
Chan and Vernon, 2008^2^ | RCT | High potential for bias. Study had high overall attrition and high differential attrition between the control and intervention groups.
Cronan et al., 2008 #2836} | Cross-sectional | High potential for selection bias. Reporting of enrollment was inadequate and distinguishing between screening and diagnostic testing was not possible.
Erban et al., 2001^3^ | Cross-sectional | High potential for confounding bias. Baseline differences were not accounted for and reporting of statistical analysis was inadequate.
Farmer et al., 2008^4^ | Cross-sectional | High potential for selection bias. Study had low response rates and high refusal rates. Screening behaviors and frequency of routine check-ups differed between responders and nonresponders
Fisher et al., 2006^5^ | Modeling study | High potential that the model assumptions were invalid. Indirect costs were not included, future increased costs for use of fecal occult blood tests were not included.
Fitzgibbon et al., 2007^6^; Ferreira et al., 2005^7^; Wolf et al., 2005^8^ | RCT | Cointerventions were not avoided and not assessed, making it difficult to determine the actual effect of either intervention. Reporting of randomization and blinding was inadequate
Friedman et al., 2001^9^ | RCT | High potential for selection bias. Study failed to randomize subjects adequately. Serious baseline differences between the groups were highly likely but difficult to assess with information provided.
Friedman and Borum, 2007^10^ | Uncontrolled Experimental study | High potential for selection and confounding biases. Selection methods were inadequate. Study failed to control for confounding in the statistical analysis.
Ganz et al., 2005^11^ | RCT | Reporting was inadequate for method of randomization and whether outcome assessors were blinded. Article does not report baseline screening status or change over time. Statistical methods were inadequate and included no adjustment for baseline screening status.
Goldberg et al., 2004^12^ | RCT | Unable to determine potential for selection bias. Major elements of the study were not reported, including information on randomization process and allocation concealment, blinding of outcome assessors, and comparability of the groups at followup.
Green and Kelly, 2004^13^ | Descriptive/Correlational | High potential for selection bias. Results were potentially biased because the statistical analysis did not include important potential confounders.
Greiner et al., 2005^14^ | Prospective observational | High potential for selection bias. Attrition rate was high, measures were not validated, and the statistical analysis did not include important potential confounders. Comparability of the groups at followup was not reported.
Harewood et al, 2002^15^ | Case-control | High potential for selection and confounding biases. Reporting of baseline differences between the groups was inadequate and inadequate controlling for confounding in the analysis.
Honda, 2004^16^ | Cross-sectional | High potential for selection bias. Response rate was low and the statistical analysis did not include important potential confounders.
James et al., 2002^17^ | Cross-sectional | High potential for selection bias. Statistical methods inadequate to determine which factors are related to CRC screening adherence. Reporting inadequate.
James et al., 2008 #1369} | Prospective cohort | High potential for selection bias. Reporting of response rates and baseline differences was inadequate. Statistical methods were inadequate to determine which factors are related to outcomes.
Juon et al., 2003^18^ | Retrospective cohort | High potential for bias. Reporting was inadequate such that determining whether sample characteristics met inclusion criteria was not possible.
Lane et al., 2008^19^ | RCT | High potential for selection bias. Baseline differences of groups were not reported adequately and the statistical methods used to control for potential differences at baseline were inadequate. The attrition rate was high.
Lawsin et al., 2007^20^ | Cross-sectional | High potential for selection bias. Outcomes measures were not validated. Reporting of statistical methods was inadequate to determine which factors were related to outcomes.
Marcus et al., 2005^21^ | RCT | High potential for selection bias. Reporting was inadequate for numerous elements: randomization process, allocation concealment, blinding, and baseline characteristics of sample. Attrition rate was high.
Matthews et al., 2005^22^ | Cross-sectional | High potential for selection bias. Reporting was inadequate and outcomes were not validated.
Miller et al., 2005^23^ | RCT | High potential for selection bias. Reporting was inadequate. Attrition rate was high.
Patel, 2004^24^ | Cross-sectional | High potential for selection bias. Reporting was inadequate. Potential bias at baseline but difficult to assess with information provided. Outcomes not validated and statistical methods did not adequately control for potential confounders. Attrition rate was high.
Powe et al., 2004^25^; Powe, 2002^26^ | RCT | High potential for selection bias. Numerous elements were not reported, including randomization method and attrition rate.
Samuel et al., 2009^27^ | Cross-sectional | High potential for selection bias. Reporting was inadequate on issues such as characteristics of sample population.
Sarfaty and Feng28 | Prospective cohort | High potential for selection bias. Study had no comparison group. Reporting of measures and statistical methods was inadequate. Important potential confounders were not considered.
Teng et al., 2006^29^ | Observational, cross-sectional | High potential for selection bias. Statistical analysis did not include important potential confounders. Outcomes measures (scales) were not validated in Chinese Americans and have not been pilot tested.
Tessaro et al., 2006^30^ | Cross-sectional | High potential for selection bias. Reporting was inadequate, and baseline differences were not described adequately. Statistical methods were inadequate to determine which factors are related to CRC screening adherence.
Thompson et al., 2006^31^ | RCT | This study was included in KQ2 as a fair quality study but received a poor quality rating as a KQ3 include because there was high potential for selection bias. Reporting was inadequate, Baseline differences were not described adequately.
Walsh et al., 2005^32^ | RCT | High potential for bias because of contamination. Randomization was done at the physician level not the patient level. No allocation concealment was done. Several elements were not reported, including blinding of outcome assessors, information on comparability of the groups at the patient level, and attrition.
Wong, 33 | Cross-sectional | High potential for measurement bias, selection bias and confounding. Reporting was inadequate. Important confounders were not accounted for in the statistical analysis.
Wolf et al., 2001^34^ | Cross-sectional | High potential for selection bias. Analysis did not control for important potential confounding variables.
Wolf et al., 2006^35^ | Observational | High potential for selection bias and confounding. High potential for measurement bias (outcome measures not valid and reliable, and outcome assessors not masked). Insufficient baseline data reported. Statistical analysis did not account for potentially important confounders.
Yepes-Rios et al., 2006^36^ | Cross-sectional | Potential for selection bias. Response rate was very low.

## References

1 Agency for Healthcare Research and Quality. Methods Guide for Comparative Effectiveness REviews, Version 1.0 [Draft posted Oct. 2007]. Rockville, MD. Available at: http://effectivehealthcare.ahrq.gov/repFiles/2007_10DraftMethodsGuide.pdf. 2007.
2 Chan EC, Vernon SW. Implementing an intervention to promote colon cancer screening through e-mail over the Internet: lessons learned from a pilot study. Med Care. Sep. 2008;46(9 Suppl 1):S117-22. [pmid: 18725823].
3 Erban S, Zapka J, Puleo E, et al. Colorectal cancer screening in Massachusetts: measuring compliance with current guidelines. Eff Clin Pract. Jan‐Feb. 2001;4(1):10-7. [pmid: 11234181].
4 Farmer MM, Bastani R, Kwan L, et al. Predictors of colorectal cancer screening from patients enrolled in a managed care health plan. Cancer. Mar 15. 2008;112(6):1230-8. [pmid: 18266204].
5 Fisher JA, Fikry C, Troxel AB. Cutting cost and increasing access to colorectal cancer screening: another approach to following the guidelines. Cancer Epidemiol Biomarkers Prev. Jan. 2006;15(1):108-13. [pmid: 16434595].
6 Fitzgibbon ML, Ferreira MR, Dolan NC, et al. Process evaluation in an intervention designed to improve rates of colorectal cancer screening in a VA medical center. Health Promot Pract. Jul. 2007;8(3):273-81. [pmid: 17606952].
7 Ferreira MR, Dolan NC, Fitzgibbon ML, et al. Health care provider-directed intervention to increase colorectal cancer screening among veterans: results of a randomized controlled trial. J Clin Oncol. Mar 1. 2005;23(7):1548-54. [pmid: 15735130].
8 Wolf MS, Fitzner KA, Powell EF, et al. Costs and cost effectiveness of a health care provider-directed intervention to promote colorectal cancer screening among Veterans. J Clin Oncol. Dec 1. 2005;23(34):8877-83. [pmid: 16314648].
9 Friedman LC, Everett TE, Peterson L, et al. Compliance with fecal occult blood test screening among low-income medical outpatients: a randomized controlled trial using a videotaped intervention. J Cancer Educ. Summer. 2001;16(2):85-8. [pmid: 11440068].
10 Friedman M, Borum ML. Colorectal cancer screening of African Americans by internal medicine resident physicians can be improved with focused educational efforts. J Natl Med Assoc. Sep. 2007;99(9):1010-2. [pmid: 17913110].
11 Ganz PA, Farmer MM, Belman MJ, et al. Results of a randomized controlled trial to increase colorectal cancer screening in a managed care health plan. Cancer. Nov 15. 2005;104(10):2072-83. [pmid: 16216030].
12 Goldberg D, Schiff GD, McNutt R, et al. Mailings timed to patients' appointments: a controlled trial of fecal occult blood test cards. Am J Prev Med. Jun. 2004;26(5):431-5. [pmid: 15165660].
13 Green PM, Kelly BA. Colorectal cancer knowledge, perceptions, and behaviors in African Americans. Cancer Nurs. May–Jun. 2004;27(3):206-15. quiz 16–7. [pmid: 15238806].
14 Greiner KA, James AS, Born W, et al. Predictors of fecal occult blood test (FOBT) completion among low-income adults. Prev Med. Aug. 2005;41(2):676-84. [pmid: 15917068].
15 Harewood GC, Wiersema MJ, Melton LJ 3rd. A prospective, controlled assessment of factors influencing acceptance of screening colonoscopy. Am J Gastroenterol. Dec. 2002;97(12):3186-94. [pmid: 12492209].
16 Honda K. Factors associated with colorectal cancer screening among the US urban Japanese population. Am J Public Health. May. 2004;94(5):815-22. [pmid: 15117706].
17 James AS, Campbell MK, Hudson MA. Perceived barriers and benefits to colon cancer screening among African Americans in North Carolina: how does perception relate to screening behavior?. Cancer Epidemiol Biomarkers Prev. Jun. 2002;11(6):529-34. [pmid: 12050093].
18 Juon HS, Han W, Shin H, et al. Predictors of older Korean Americans' participation in colorectal cancer screening. J Cancer Educ. Spring. 2003;18(1):37-42. [pmid: 12825633].
19 Lane DS, Messina CR, Cavanagh MF, et al. A provider intervention to improve colorectal cancer screening in county health centers. Med Care. Sep. 2008;46(9 Suppl 1):S109-16. [pmid: 18725822].
20 Lawsin C, DuHamel K, Weiss A, et al. Colorectal cancer screening among low-income African Americans in East Harlem: a theoretical approach to understanding barriers and promoters to screening. J Urban Health. Jan. 2007;84(1):32-44. [pmid: 17186375].
21 Marcus AC, Mason M, Wolfe P, et al. The efficacy of tailored print materials in promoting colorectal cancer screening: results from a randomized trial involving callers to the National Cancer Institute's Cancer Information Service. J Health Commun. 2005;10(Suppl 1):83-104. [pmid: 16377602].
22 Matthews BA, Anderson RC, Nattinger AB. Colorectal cancer screening behavior and health insurance status (United States). Cancer Causes Control. Aug. 2005;16(6):735-42. [pmid: 16049812].
23 Miller DP Jr, Kimberly JR Jr, Case LD, et al. Using a computer to teach patients about fecal occult blood screening. A randomized trial. J Gen Intern Med. Nov. 2005;20(11):984-8. [pmid: 16307621].
24 Patel P, Forjuoh SN, Avots-Avotins A, et al. Identifying opportunities for improved colorectal cancer screening in primary care. Prev Med. Aug. 2004;39(2):239-46. [pmid: 15226031].
25 Powe BD, Ntekop E, Barron M. An intervention study to increase colorectal cancer knowledge and screening among community elders. Public Health Nurs. Sep–Oct. 2004;21(5):435-42. [pmid: 15363024].
26 Powe BD. Promoting fecal occult blood testing in rural African American women. Cancer Pract. May–Jun. 2002;10(3):139-46. [pmid: 11972568].
27 Samuel PS, Pringle JP, James NW, et al. Breast, cervical, and colorectal cancer screening rates amongst female Cambodian, Somali, and Vietnamese immigrants in the USA. Int J Equity Health. 2009;8:30. [pmid: 19682356].
28 Sarfaty M, Feng S. Choice of screening modality in a colorectal cancer education and screening program for the uninsured. J Cancer Educ. Spring. 2006;21(1):43-9. [pmid: 16918290].
29 Teng EJ, Friedman LC, Green CE. Determinants of colorectal cancer screening behavior among Chinese Americans. Psychooncology. May. 2006;15(5):374-81. [pmid: 16143960].
30 Tessaro I, Mangone C, Parkar I, et al. Knowledge, barriers, and predictors of colorectal cancer screening in an Appalachian church population. Prev Chronic Dis. Oct. 2006;3(4):A123. [pmid: 16978498].
31 Thompson B, Coronado G, Chen L, et al. Celebremos la salud! a community randomized trial of cancer prevention (United States). Cancer Causes Control. Jun. 2006;17(5):733-46. [pmid: 16633921].
32 Walsh JM, Salazar R, Terdiman JP, et al. Promoting use of colorectal cancer screening tests. Can we change physician behavior?. J Gen Intern Med. Dec. 2005;20(12):1097-101. [pmid: 16423097].
33 Wong N. Investigating the effects of cancer risk and efficacy perceptions on cancer prevention adherence and intentions. Health Commun. Mar. 2009;24(2):95-105. [pmid: 19280453].
34 Wolf RL, Zybert P, Brouse CH, et al. Knowledge, beliefs, and barriers relevant to colorectal cancer screening in an urban population: a pilot study. Fam Community Health. Oct. 2001;24(3):34-47. [pmid: 11563943].
35 Wolf MS, Satterlee M, Calhoun EA, et al. Colorectal cancer screening among the medically underserved. J Health Care Poor Underserved. Feb. 2006;17(1):47-54. [pmid: 16520508].
36 Yepes-Rios M, Reimann JO, Talavera AC, et al. Colorectal cancer screening among Mexican Americans at a community clinic. Am J Prev Med. Mar. 2006;30(3):204-10. [pmid: 16476635].