# Technical Expert Panel Members and Peer Reviewers

Colorectal Cancer Screening Technical Expert Panel (TEP) Members

TEP Member | Affiliation
David Ahlquist, M.D. | Mayo Clinic
James Allison, M.D. | University of California at San Francisco Kaiser Permanente Division of Research
Durado Brooks, M.D., M.P.H. | American Cancer Society
Thomas Imperiale, M.D. | Indiana University School of Medicine
Donald Steinwachs, Ph.D. | Johns Hopkins Bloomberg School of Public Health
Judith Walsh, M.D. | University of California at San Francisco

Colorectal Cancer Screening Peer Reviewers

Peer Reviewers | Affiliation
Dennis Ahnen, M.D. | Denver Department of Veterans Affairs Medical Center and University of Colorado Denver School of Medicine
James Allison, M.D. | University of California at San Francisco Kaiser Permanente Division of Research
Durado Brooks, M.D., M.P.H. | American Cancer Society
Deborah Fisher, M.D., M.H.S. | Durham Veterans Affairs Medical Center Duke University
Robert Fletcher, M.D., M.Sc. | Harvard Medical School
Sujha Subramanian, Ph.D. | RTI International
Judith Walsh, M.D. | University of California at San Francisco
Evelyn Whitlock, M.D., M.P.H. | Kaiser Permanente Northwest