# Excluded Studies

## Study not conducted in US

1. Agrez MV, Coory M, Cockburn J. Population screening for colorectal carcinoma with fecal-occult blood testing: are we sufficiently informed? Cancer. 1998 May 15;82(10):1803–7.
2. Aldridge AJ, Simson JN. Histological assessment of colorectal adenomas by size. Are polyps less than 10 mm in size clinically important? Eur J Surg. 2001 Oct;167(10):777–81.
3. Ang YS, Macaleenan N, Mahmud N, et al. The yield of colonoscopy in average-risk patients with non-specific colonic symptoms. Eur J Gastroenterol Hepatol. 2002 Oct;14(10):1073–7.
4. Arnesen RB, von Benzon E, Adamsen S, et al. Diagnostic performance of computed tomography colonography and colonoscopy: a prospective and validated analysis of 231 paired examinations. Acta Radiol. 2007 Oct;48(8):831–7.
5. Arora A, Singh P. Colonoscopy in patients 80 years of age and older is safe, with high success rate and diagnostic yield. Gastrointest Endosc. 2004 Sep;60(3):408–13.
6. Asao T, Fujita K, Nakamura J, et al. Is carbon dioxide as an insufflation agent for double contrast barium enema still worthwhile after a same-day flexible sigmoidoscopy? Clin Radiol. 2002 Jun;57(6):488–91.
7. Bampton PA, Sandford JJ, Young GP. Applying evidence-based guidelines improves use of colonoscopy resources in patients with a moderate risk of colorectal neoplasia. Med J Aust. 2002 Feb 18;176(4):155–7.
8. Barr DA. Colonoscopy screening in black and white patients. J Am Med Assoc. 2009 Feb 25;301(8):827–8; author reply 8–9.
9. Beaudin DJ. Results of screening first-degree relatives of patients with colorectal cancer: a community practice perspective. Can J Gastroenterol. 2000 Jun;14(6):489–92.
10. Bersani G, Rossi A, Ricci G, et al. Do ASGE guidelines for the appropriate use of colonoscopy enhance the probability of finding relevant pathologies in an open access service? Dig Liver Dis. 2005 Aug;37(8):609–14.
11. Betes Ibanez M, Munoz-Navas MA, Duque JM, et al. Diagnostic value of distal colonic polyps for prediction of advanced proximal neoplasia in an average-risk population undergoing screening colonoscopy. Gastrointest Endosc. 2004 May;59(6):634–41.
12. Borum ML, Shafa S, Hatara MC, et al. The primary care physician may have a more critical role in colorectal cancer screening in African Americans when compared to non-African Americans. J Natl Med Assoc. 2009 Jul;101(7):734.
13. Bressler B, Lo C, Amar J, et al. Prospective evaluation of screening colonoscopy: who is being screened? Gastrointest Endosc. 2004 Dec;60(6):921–6.
14. Bujanda L, Sarasqueta C, Zubiaurre L, et al. Low adherence to colonoscopy in the screening of first-degree relatives of patients with colorectal cancer. Gut. 2007 Dec;56(12):1714–8.
15. Chen CD, Yen MF, Wang WM, et al. A case-cohort study for the disease natural history of adenoma-carcinoma and de novo carcinoma and surveillance of colon and rectum after polypectomy: implication for efficacy of colonoscopy. Br J Cancer. 2003 Jun 16;88(12):1866–73.
16. Chen HS, Sheen-Chen SM. Influence of age and gender on surveillance for colorectal tumors in low-risk asymptomatic population. Anticancer Res. 2002 Jan–Feb;22(1A):399–403.
17. Chiu HM, Lin JT, Wang HP, et al. The impact of colon preparation timing on colonoscopic detection of colorectal neoplasms--a prospective endoscopist-blinded randomized trial. Am J Gastroenterol. 2006 Dec;101(12):2719–25.
18. Chiu HM, Wang HP, Lee YC, et al. A prospective study of the frequency and the topographical distribution of colon neoplasia in asymptomatic average-risk Chinese adults as determined by colonoscopic screening. Gastrointest Endosc. 2005 Apr;61(4):547–53.
19. Ciatto S, Castiglione G. Role of double-contrast barium enema in colorectal cancer screening based on fecal occult blood. Tumori. 2002 Mar‐Apr;88(2):95–8.
20. Citarda F, Tomaselli G, Capocaccia R, et al. Efficacy in standard clinical practice of colonoscopic polypectomy in reducing colorectal cancer incidence. Gut. 2001 Jun;48(6):812–5.
21. Clavel-Chapelon F, Joseph R, Goulard H. Surveillance behavior of women with a reported family history of colorectal cancer. Prev Med. 1999 Feb;28(2):174–8.
22. Cole SR, Young GP. Effect of dietary restriction on participation in faecal occult blood test screening for colorectal cancer. Med J Aust. 2001 Aug 20;175(4):195–8.
23. Consolo P, Luigiano C, Strangio G, et al. Efficacy, risk factors and complications of endoscopic polypectomy: ten year experience at a single center. World J Gastroenterol. 2008 Apr 21;14(15):2364–9.
24. Coughlin SS, Costanza ME, Fernandez ME, et al. CDC-funded intervention research aimed at promoting colorectal cancer screening in communities. Cancer. 2006 Sep 1;107(5 Suppl):1196–204.
25. Davies RJ, Collins CD, Vickery CJ, et al. Reduction in the proportion of patients with colorectal cancer presenting as an emergency following the introduction of fast-track flexible sigmoidoscopy: a three-year prospective observational study. Colorectal Dis. 2004 Jul;6(4):265–7.
26. de Bosset V, Froehlich F, Rey JP, et al. Do explicit appropriateness criteria enhance the diagnostic yield of colonoscopy? Endoscopy. 2002 May;34(5):360–8.
27. Dell'Abate P, Iosca A, Galimberti A, et al. Endoscopic treatment of colorectal benign-appearing lesions 3 cm or larger: techniques and outcome. Dis Colon Rectum. 2001 Jan;44(1):112–8.
28. Denis B, Weiss AM, Peter A, et al. Quality assurance and gastrointestinal endoscopy: an audit of 500 colonoscopic procedures. Gastroenterol Clin Biol. 2004 Dec;28(12):1245–55.
29. Dobrowolski S, Dobosz M, Babicki A, et al. Prophylactic submucosal saline-adrenaline injection in colonoscopic polypectomy: prospective randomized study. Surg Endosc. 2004 Jun;18(6):990–3.
30. Ee HC, Semmens JB, Hoffman NE. Complete colonoscopy rarely misses cancer. Gastrointest Endosc. 2002 Feb;55(2):167–71.
31. Federici A, Giorgi Rossi P, Bartolozzi F, et al. The role of GPs in increasing compliance to colorectal cancer screening: a randomised controlled trial (Italy). Cancer Causes Control. 2006 Feb;17(1):45–52.
32. Federici A, Giorgi Rossi P, Borgia P, et al. The immunochemical faecal occult blood test leads to higher compliance than the guaiac for colorectal cancer screening programmes: a cluster randomized controlled trial. J Med Screen. 2005;12(2):83–8.
33. Federici A, Marinacci C, Mangia M, et al. Is the type of test used for mass colorectal cancer screening a determinant of compliance? A cluster-randomized controlled trial comparing fecal occult blood testing with flexible sigmoidoscopy. Cancer Detect Prev. 2006;30(4):347–53.
34. Fludger S, Turner AM, Harvey RF, et al. Controlled prospective study of faecal occult blood screening for colorectal cancer in Bury, black pudding capital of the world. BMJ. 2002 Dec 21;325(7378):1444–5.
35. Forbes GM, Edwards JT, Foster NM, et al. Randomized single blind trial of two low-volume bowel preparations for screening computed tomographic colonography. Abdominal imaging. 2005(1):48–52.
36. Frew E, Wolstenholme JL, Atkin W, et al. Estimating time and travel costs incurred in clinic based screening: flexible sigmoidoscopy screening for colorectal cancer. J Med Screen. 1999;6(3):119–23.
37. Ginnerup Pedersen B, Rosenkilde M, Christiansen TE, et al. Extracolonic findings at computed tomography colonography are a challenge. Gut. 2003 Dec;52(12):1744–7.
38. Golder S, Vogt W, Lichti H, et al. Acceptance of flexible sigmoidoscopy as a screening examination for colorectal cancer in an outpatient clinic. Int J Colorectal Dis. 2007 Apr;22(4):387–94.
39. Grassini M, Verna C, Niola P, et al. Appropriateness of colonoscopy: diagnostic yield and safety in guidelines. World J Gastroenterol. 2007 Mar 28;13(12):1816–9; discussion 9.
40. Halligan S, Marshall M, Taylor S, et al. Observer variation in the detection of colorectal neoplasia on double-contrast barium enema: implications for colorectal cancer screening and training. Clin Radiol. 2003 Dec;58(12):948–54; discussion 5–7.
41. Hamashima C, Sobue T, Muramatsu Y, et al. Comparison of observed and expected numbers of detected cancers in the research center for cancer prevention and screening program. Jpn J Clin Oncol. 2006 May;36(5):301–8.
42. Harris JK, Froehlich F, Wietlisbach V, et al. Factors associated with the technical performance of colonoscopy: An EPAGE Study. Dig Liver Dis. 2007 Jul;39(7):678–89.
43. Haug U, Hillebrand T, Bendzko P, et al. Mutant-enriched PCR and allele-specific hybridization reaction to detect K-ras mutations in stool DNA: high prevalence in a large sample of older adults. Clin Chem. 2007 Apr;53(4):787–90.
44. Hewitson P, Glasziou P, Irwig L, et al. Screening for colorectal cancer using the faecal occult blood test, Hemoccult. Cochrane Database Syst Rev. 2007(1):CD001216.
45. Hewitson P, Glasziou P, Watson E, et al. Cochrane systematic review of colorectal cancer screening using the fecal occult blood test (hemoccult): an update. Am J Gastroenterol. 2008 Jun;103(6):1541–9.
46. Hoepffner N, Shastri YM, Hanisch E, et al. Comparative evaluation of a new bedside faecal occult blood test in a prospective multicentre study. Aliment Pharmacol Ther. 2006 Jan 1;23(1):145–54.
47. Hoff G, Thiis-Evensen E, Grotmol T, et al. Do undesirable effects of screening affect all-cause mortality in flexible sigmoidoscopy programmes? Experience from the Telemark Polyp Study 1983–1996. Eur J Cancer Prev. 2001 Apr;10(2):131–7.
48. Horiuchi A, Nakayama Y. Improved colorectal adenoma detection with a transparent retractable extension device. The American journal of gastroenterology. 2008(2):341–5.
49. Inns SJ, Wyeth JW. Changing face of colonoscopy: a comparison between audits of colonoscopy at Wellington Hospital from 1987 to 2002. Intern Med J. 2004 Jul;34(7):447–8.
50. Kerr J, Day P, Broadstock M, et al. Systematic review of the effectiveness of population screening for colorectal cancer. N Z Med J. 2007;120(1258):U2629.
51. Khoja S, McGregor SE, Hilsden RJ. Validation of self-reported history of colorectal cancer screening. Can Fam Physician. 2007 Jul;53(7):1192–7.
52. Koch M, Kienle P, Sauer P, et al. Hematogenous tumor cell dissemination during colonoscopy for colorectal cancer. Surg Endosc. 2004 Apr;18(4):587–91.
53. Koga Y, Yasunaga M, Moriya Y, et al. Detection of colorectal cancer cells from feces using quantitative real-time RT-PCR for colorectal cancer diagnosis. Cancer Sci. 2008 Oct;99(10):1977–83.
54. Koss K, Maxton D, Jankowski JA. Faecal dimeric M2 pyruvate kinase in colorectal cancer and polyps correlates with tumour staging and surgical intervention. Colorectal Dis. 2008 Mar;10(3):244–8.
55. Kronborg O, Jorgensen OD, Fenger C, et al. Three randomized long-term surveillance trials in patients with sporadic colorectal adenomas. Scand J Gastroenterol. 2006 Jun;41(6):737–43.
56. Latreille MW, Anderson JC. Colonoscopy screening for detection of advanced neoplasia. N Engl J Med. 2007 Feb 8;356(6):632; author reply 3–4.
57. Leaper M, Johnston MJ, Barclay M, et al. Reasons for failure to diagnose colorectal carcinoma at colonoscopy. Endoscopy. 2004 Jun;36(6):499–503.
58. Lee YC, Wang HP, Chiu HM, et al. Factors determining post-colonoscopy abdominal pain: prospective study of screening colonoscopy in 1000 subjects. J Gastroenterol Hepatol. 2006 Oct;21(10):1575–80.
59. Levi Z, Rozen P, Hazazi R, et al. A quantitative immunochemical fecal occult blood test for colorectal neoplasia. Ann Intern Med. 2007 Feb 20;146(4):244–55.
60. Loeve F, van Ballegooijen M, Snel P, et al. Colorectal cancer risk after colonoscopic polypectomy: a population-based study and literature search. Eur J Cancer. 2005 Feb;41(3):416–22.
61. Malila N, Hakama M, Pukkala E. A 25-year follow-up of a population screened with faecal occult blood test in Finland. Acta Oncol. 2007;46(8):1103–6.
62. Malila N, Oivanen T, Malminiemi O, et al. Test, episode, and programme sensitivities of screening for colorectal cancer as a public health policy in Finland: experimental design. BMJ. 2008;337:a2261.
63. Maruthachalam K, Stoker E, Chaudhri S, et al. Evolution of the two-week rule pathway--direct access colonoscopy vs outpatient appointments: one year's experience and patient satisfaction survey. Colorectal Dis. 2005 Sep;7(5):480–5.
64. McCaffery K, Wardle J, Nadel M, et al. Socioeconomic variation in participation in colorectal cancer screening. J Med Screen. 2002;9(3):104–8.
65. Min BH, Chang DK, Kim DU, et al. Low frequency of bacteremia after an endoscopic resection for large colorectal tumors in spite of extensive submucosal exposure. Gastrointest Endosc. 2008 Jul;68(1):105–10.
66. Morini S, Hassan C, Meucci G, et al. Diagnostic yield of open access colonoscopy according to appropriateness. Gastrointest Endosc. 2001 Aug;54(2):175–9.
67. Mulder SA, Ouwendijk RJ, van Leerdam ME, et al. A nationwide survey evaluating adherence to guidelines for follow-up after polypectomy or treatment for colorectal cancer. J Clin Gastroenterol. 2008 May–Jun;42(5):487–92.
68. Ng ES, Tan CH, Teo DC, et al. Knowledge and perceptions regarding colorectal cancer screening among Chinese--a community-based survey in Singapore. Prev Med. 2007 Nov;45(5):332–5.
69. Olynyk JK, Platell CF, Collett JA. Fecal occult blood and flexible sigmoidoscopy screening for colorectal cancer: modeling the impact on colonoscopy requirements and cancer detection rates. J Gastroenterol Hepatol. 2001 Apr;16(4):389–92.
70. Ore L, Hagoel L, Lavi I, et al. Screening with faecal occult blood test (FOBT) for colorectal cancer: assessment of two methods that attempt to improve compliance. Eur J Cancer Prev. 2001 Jun;10(3):251–6.
71. O'Sullivan I, Orbell S, Rakow T, et al. Prospective research in health service settings: health psychology, science and the 'Hawthorne' effect. J Health Psychol. 2004 May;9(3):355–9.
72. Park SH, Ha HK, Kim MJ, et al. False-negative results at multi-detector row CT colonography: multivariate analysis of causes for missed lesions. Radiology. 2005 May;235(2):495–502.
73. Parker MA, Robinson MH, Scholefield JH, et al. Psychiatric morbidity and screening for colorectal cancer. J Med Screen. 2002;9(1):7–10.
74. Petersen CR, Adamsen S, Gocht-Jensen P, et al. Splenic injury after colonoscopy. Endoscopy. 2008 Jan;40(1):76–9.
75. Pignone MP, Lewis CL. Using quality improvement techniques to increase colon cancer screening. Am J Med. 2009 May;122(5):419–20.
76. Rejchrt S, Bures J, Siroky M, et al. A prospective, observational study of colonic mucosal abnormalities associated with orally administered sodium phosphate for colon cleansing before colonoscopy. Gastrointest Endosc. 2004 May;59(6):651–4.
77. Robinson MH, Hardcastle JD, Moss SM, et al. The risks of screening: data from the Nottingham randomised controlled trial of faecal occult blood screening for colorectal cancer. Gut. 1999 Oct;45(4):588–92.
78. Rostom A, Jolicoeur E, Dube C, et al. A randomized prospective trial comparing different regimens of oral sodium phosphate and polyethylene glycol-based lavage solution in the preparation of patients for colonoscopy. Gastrointest Endosc. 2006 Oct;64(4):544–52.
79. Saito H, Soma Y, Nakajima M, et al. A case-control study evaluating occult blood screening for colorectal cancer with hemoccult test and an immunochemical hemagglutination test. Oncol Rep. 2000 Jul–Aug;7(4):815–9.
80. Sato T, Konishi F, Togashi K, et al. Prospective observation of small "flat" tumors in the colon through colonoscopy. Dis Colon Rectum. 1999 Nov;42(11):1457–63.
81. Sciallero S, Bonelli L, Aste H, et al. Do patients with rectosigmoid adenomas 5 mm or less in diameter need total colonoscopy? Gastrointest Endosc. 1999 Sep;50(3):314–21.
82. Scott RG, Edwards JT, Fritschi L, et al. Community-based screening by colonoscopy or computed tomographic colonography in asymptomatic average-risk subjects. The American journal of gastroenterology. 2004(6):1145–51.
83. Segnan N, Senore C, Andreoni B, et al. Randomized trial of different screening strategies for colorectal cancer: patient response and detection rates. J Natl Cancer Inst. 2005 Mar 2;97(5):347–57.
84. Segnan N, Senore C, Andreoni B, et al. Comparing attendance and detection rate of colonoscopy with sigmoidoscopy and FIT for colorectal cancer screening. Gastroenterology. 2007 Jun;132(7):2304–12.
85. Senore C, Segnan N, Bonelli L, et al. Predicting proximal advanced neoplasms at screening sigmoidoscopy. Dis Colon Rectum. 2004 Aug;47(8):1331–40.
86. Sewitch MJ, Burtin P, Dawes M, et al. Colorectal cancer screening: physicians' knowledge of risk assessment and guidelines, practice, and description of barriers and facilitators. Can J Gastroenterol. 2006 Nov;20(11):713–8.
87. Sewitch MJ, Fournier C, Dawes M, et al. Do physician recommendations for colorectal cancer screening differ by patient age? Can J Gastroenterol. 2007 Jul;21(7):435–8.
88. Shah HA, Paszat LF, Saskin R, et al. Factors associated with incomplete colonoscopy: a population-based study. Gastroenterology. 2007 Jun;132(7):2297–303.
89. Shah J, Gupta S, Rockey DC. Colonoscopy screening in black and white patients. J Am Med Assoc. 2009 Feb 25;301(8):827; author reply 8–9.
90. Smith A, Young GP, Cole SR, et al. Comparison of a brush–sampling fecal immunochemical test for hemoglobin with a sensitive guaiac-based fecal occult blood test in detection of colorectal neoplasia. Cancer. 2006 Nov 1;107(9):2152–9.
91. Soon MS, Kozarek RA, Ayub K, et al. Screening colonoscopy in Chinese and Western patients: a comparative study. Am J Gastroenterol. 2005 Dec;100(12):2749–55.
92. Stewart BT, Keck JO, Duncan AV, et al. Difficult or incomplete flexible sigmoidoscopy: implications for a screening programme. Aust N Z J Surg. 1999 Jan;69(1):19–21.
93. Takahashi Y, Tanaka H, Kinjo M, et al. Sedation-free colonoscopy. Dis Colon Rectum. 2005 Apr;48(4):855–9.
94. Taupin D, Chambers SL, Corbett M, et al. Colonoscopic screening for colorectal cancer improves quality of life measures: a population-based screening study. Health Qual Life Outcomes. 2006;4:82.
95. Thiis-Evensen E, Hoff GS, Sauar J, et al. The effect of attending a flexible sigmoidoscopic screening program on the prevalence of colorectal adenomas at 13-year follow-up. Am J Gastroenterol. 2001 Jun;96(6):1901–7.
96. Thiis-Evensen E, Hoff GS, Sauar J, et al. Patient tolerance of colonoscopy without sedation during screening examination for colorectal polyps. Gastrointest Endosc. 2000 Nov;52(5):606–10.
97. Tifratene K, Eisinger F, Rinaldi Y, et al. Colorectal cancer screening program: cost effectiveness of systematic recall letters. Gastroenterol Clin Biol. 2007 Nov;31(11):929–33.
98. Trevena LJ, Irwig L, Barratt A. Randomized trial of a self-administered decision aid for colorectal cancer screening. J Med Screen. 2008;15(2):76–82.
99. van Gelder RE, Birnie E, Florie J, et al. CT colonography and colonoscopy: assessment of patient preference in a 5-week follow-up study. Radiology. 2004 Nov;233(2):328–37.
100. van Rossum LG, van Rijn AF, Laheij RJ, et al. Random comparison of guaiac and immunochemical fecal occult blood tests for colorectal cancer in a screening population. Gastroenterology. 2008 Jul;135(1):82–90.
101. Viiala CH, Olynyk JK. Outcomes after 10 years of a community-based flexible sigmoidoscopy screening program for colorectal carcinoma. Med J Aust. 2007 Sep 3;187(5):274–7.
102. Vinker S, Nakar S, Rosenberg E, et al. The role of family physicians in increasing annual fecal occult blood test screening coverage: a prospective intervention study. Isr Med Assoc J. 2002 Jun;4(6):424–5.
103. Walleser S, Griffiths A, Lord SJ, et al. What is the value of computered tomography colonography in patients screening positive for fecal occult blood? A systematic review and economic evaluation. Clin Gastroenterol Hepatol. 2007 Dec;5(12):1439–46; quiz 368.
104. Wardle J, Williamson S, McCaffery K, et al. Increasing attendance at colorectal cancer screening: testing the efficacy of a mailed, psychoeducational intervention in a community sample of older adults. Health Psychol. 2003 Jan;22(1):99–105.
105. Yardeni IZ, Melzer E, Smolyarenko V, et al. Combining physostigmine with meperidine for sedation and analgesia during colonoscopy. Endoscopy. 2005 Dec;37(12):1205–10.
106. Yoo TW, Park DI, Kim YH, et al. Clinical significance of small colorectal adenoma less than 10 mm: the KASID study. Hepatogastroenterology. 2007 Mar;54(74):418–21.
107. Yoong KK, Heymann T. Colonoscopy in the very old: why bother? Postgrad Med J. 2005 Mar;81(953):196–7.
108. Yun JY, Ro HJ, Park JB, et al. Diagnostic performance of CT colonography for the detection of colorectal polyps. Korean J Radiol. 2007 Nov–Dec;8(6):484–91.
109. Zappa M, Castiglione G, Giorgi D, et al. Re: Participation in colorectal cancer screening: a review. J Natl Cancer Inst. 1998 Mar 18;90(6):465.
110. Zarychanski R, Chen Y, Bernstein CN, et al. Frequency of colorectal cancer screening and the impact of family physicians on screening behaviour. CMAJ. 2007 Sep 11;177(6):593–7.

## No original research/analysis

1. From the Centers for Disease Control and Prevention. Screening for colorectal cancer-‐United States, 1997. JAMA. 1999 May 5;281(17):1581–2.
2. Colorectal cancer screening. ACS guidelines. CA Cancer J Clin. 1999 Jan–Feb;49(1):4.
3. Colorectal cancer screening. CA Cancer J Clin. 1999 Jan–Feb;49(1):2.
4. Patients need nudge from doctors to get colorectal cancer screening. CA Cancer J Clin. 2000 May–Jun;50(3):136–7.
5. How to stop a silent killer: colorectal cancer screening. State Legis. 2002 Jun;28(6):7.
6. Summaries for patients. What is the best way to test for colorectal cancer? Ann Intern Med. 2005 Jan 18;142(2):I23.
7. StatBite: Maryland residents never screened for colorectal cancer. J Natl Cancer Inst. 2007 Nov 21;99(22):1665.
8. Ahluwalia JS, Miser WF, Bova JG. Virtual colonoscopy: what is its role in cancer screening? J Fam Pract. 2007 Mar;56(3):186–91.
9. Ahmad NA, Hoops TC. The role of colonoscopy for screening of colorectal cancer. Semin Roentgenol. 2000 Oct;35(4):404–8.
10. Ahnen DJ, Lynch KL. Colorectal cancer screening in average- and high-risk groups. Adv Intern Med. 2001;46:77–106.
11. Allison JE, Lawson M. Screening tests for colorectal cancer: a menu of options remains relevant. Curr Oncol Rep. 2006 Nov;8(6):492–8.
12. Anonymous. Summaries for patients. Colorectal cancer screening in patients after polyp removal: a survey of primary care physicians. Ann Intern Med. 2006 Nov 7;145(9):I26.
13. Anonymous. Summaries for patients. Stool DNA and occult blood testing to screen for colorectal neoplasia. Ann Intern Med. 2008 Oct 7;149(7):I20.
14. Ashley OS, Nadel M, Ransohoff DF. Achieving quality in flexible sigmoidoscopy screening for colorectal cancer. Am J Med. 2001 Dec 1;111(8):643–53.
15. Atkinson W. Study aims to improve colorectal cancer screening participation. AHIP Cover. 2008 Mar–Apr;49(2):46–8.
16. Avots-Avotins A. Any screening beneficial. Tex Med. 2001 Apr;97(4):9.
17. Bauerfeind P. Colon tumors and colonoscopy. Endoscopy. 2001 Nov;33(11):949–60.
18. Berg AO. Screening for colorectal cancer: recommendations and rationale. Am J Nurs. 2002 Sep;102(9):107–17.
19. Beydoun HA, Beydoun MA. Predictors of colorectal cancer screening behaviors among average-risk older adults in the United States. Cancer Causes Control. 2008 May;19(4):339–59.
20. Bianchi LK, Burke CA. Understanding current guidelines for colorectal cancer screening: a case-based approach. Cleve Clin J Med. 2008 Jun;75(6):441–8.
21. Blachar A, Sosna J. CT colonography (virtual colonoscopy): technique, indications and performance. Digestion. 2007;76(1):34–41.
22. Bochud M, Burnand B, Froehlich F, et al. 12. Appropriateness of colonoscopy: surveillance after polypectomy. Endoscopy. 1999 Oct;31(8):654–63.
23. Boggs BD, Stephens MM, Wallace R. Clinical Inquiries. How does colonoscopy compare with fecal occult blood testing as a screening tool for colon cancer? J Fam Pract. 2005 Nov;54(11):996–7.
24. Bonanno E, Rulli F, Galata G, et al. Stool test for colorectal cancer screening: what is going on? Surg Oncol. 2007 Dec;16 Suppl 1:S43–5.
25. Bond JH. Fecal occult blood test screening for colorectal cancer. Gastrointest Endosc Clin N Am. 2002 Jan;12(1):11–21.
26. Bond JH. Update on colorectal polyps: management and follow-up surveillance. Endoscopy. 2003 Aug;35(8):S35–40.
27. Bond JH, Levin B. Screening and surveillance for colorectal cancer. Am J Manag Care. 1998 Mar;4(3):431–7; quiz 8–9.
28. Bowie JV, Curbow BA, Garza MA, et al. A review of breast, cervical, and colorectal cancer screening interventions in older women. Cancer Control. 2005 Nov;12 Suppl 2:58–69.
29. Boyle P. Current situation of screening for cancer. Ann Oncol. 2002;13 Suppl 4:189–98.
30. Briskey EN, Pamies RJ. Colorectal cancer: update on recent advances and their impact on screening protocols. J Natl Med Assoc. 2000 May;92(5):222–30.
31. Burke CA, Church JM. Enhancing the quality of colonoscopy: the importance of bowel purgatives. Gastrointest Endosc. 2007 Sep;66(3):565–73.
32. Burke W, Beeker C, Kraft JM, et al. Engaging women's interest in colorectal cancer screening: a public health strategy. J Womens Health Gend Based Med. 2000 May;9(4):363–71.
33. Burkhalter JL. Screening colorectal cancer--rational guidelines. J Miss State Med Assoc. 1998 Oct;39(10):378.
34. Burnand B, Bochud M, Froehlich F, et al. 14. Appropriateness of colonoscopy: screening for colorectal cancer in asymptomatic individuals. Endoscopy. 1999 Oct;31(8):673–83.
35. Carney PA, Hoffman RM, Lieberman DA, et al. Data systems to evaluate colorectal cancer screening practices and outcomes at the population level. Med Care. 2008 Sep;46(9 Suppl 1):S132–7.
36. Carpenter S, Petersen BT, Chuttani R, et al. Polypectomy devices. Gastrointest Endosc. 2007 May;65(6):741–9.
37. Chutkan R. Colonoscopy issues related to women. Gastrointest Endosc Clin N Am. 2006 Jan;16(1):153–63.
38. Cooper GS. Colonoscopy: a tarnished gold standard? Gastroenterology. 2007 Jun;132(7):2588–90.
39. Crespi M, Lisi D. Is colorectal cancer screening by fecal occult blood feasible? Ann Oncol. 2002 Jan;13(1):47–50.
40. Crespi M, Stigliano V, Assisi D. Current trends in screening and secondary prevention of colorectal cancer. Hepatogastroenterology. 2001 Nov–Dec;48(42):1635–40.
41. Dachman AH, Glick S, Yoshida H. Computed tomography colonography and colon cancer screening. Semin Roentgenol. 2003 Jan;38(1):54–64.
42. Davis TC, Dolan NC, Ferreira MR, et al. The role of inadequate health literacy skills in colorectal cancer screening. Cancer Invest. 2001;19(2):193–200.
43. Deshpande N, Weinberg DS. The evolving role of CT colonography. Cancer Invest. 2007 Mar;25(2):127–33.
44. Donovan JM, Syngal S. Colorectal cancer in women: an underappreciated but preventable risk. J Womens Health. 1998 Feb;7(1):45–8.
45. Dykes C, Cash BD. Key safety issues of bowel preparations for colonoscopy and importance of adequate hydration. Gastroenterol Nurs. 2008 Jan–Feb;31(1):30–5; quiz 6–7.
46. Flight IHK, Wilson Carlene L, Griffiths L, et al. Interventions for improving uptake of population-based screening for colorectal cancer using fecal occult blood testing. Cochrane Database of Systematic Reviews. 2004(4).
47. Freeman JL, Klabunde CN, Schussler N, et al. Measuring breast, colorectal, and prostate cancer screening with Medicare claims data. Med Care. 2002 Aug;40(8 Suppl):IV-36–42.
48. Ganiats TG, Young HF. Screening options for colorectal cancer. Am Fam Physician. 1999 Jun;59(11):2979–80.
49. Gazelle GS, McMahon PM, Scholz FJ. Screening for colorectal cancer. Radiology. 2000 May;215(2):327–35.
50. Halligan S, Taylor SA. CT colonography: results and limitations. Eur J Radiol. 2007 Mar;61(3):400–8.
51. Hambrick E. Because you're someone they listen to, push prevention through education about screening. Gastroenterol Nurs. 2001 Mar‐Apr;24(2):51–3.
52. Heher EC, Thier SO, Rennke H, et al. Adverse renal and metabolic effects associated with oral sodium phosphate bowel preparation. Clin J Am Soc Nephrol. 2008 Sep;3(5):1494–503.
53. Kim DH, Pickhardt PJ, Taylor AJ, et al. Imaging evaluation of complications at optical colonoscopy. Curr Probl Diagn Radiol. 2008 Jul‐Aug;37(4):165–77.
54. Klabunde CN, Lanier D, Meissner HI, et al. Improving colorectal cancer screening through research in primary care settings. Med Care. 2008 Sep;46(9 Suppl 1):S1–4.
55. Labianca R, Beretta GD, Mosconi S, et al. Colorectal cancer: screening. Ann Oncol. 2005;16 Suppl 2:ii127–32.
56. Lambert R. Role of endoscopy in the prevention of digestive cancer: application to colorectal cancer. Endoscopy. 1998 Sep;30(7):628–40.
57. Lambert R, Provenzale D, Ectors N, et al. Early diagnosis and prevention of sporadic colorectal cancer. Endoscopy. 2001 Dec;33(12):1042–64.
58. Lance P. Colorectal cancer screening: confusion reigns. Cancer Epidemiol Biomarkers Prev. 2008 Sep;17(9):2205–7.
59. Lanier D. Practice-based research networks: laboratories for improving colorectal cancer screening in primary care practice. Med Care. 2008 Sep;46(9 Suppl 1):S147–52.
60. Lev Z, Kislitsin D, Rennert G, et al. Utilization of K-ras mutations identified in stool DNA for the early detection of colorectal cancer. J Cell Biochem Suppl. 2000;34:35–9.
61. Levin B, Lieberman DA, McFarland B, et al. Screening and surveillance for the early detection of colorectal cancer and adenomatous polyps, 2008: a joint guideline from the American Cancer Society, the US Multi-Society Task Force on Colorectal Cancer, and the American College of Radiology. CA Cancer J Clin. 2008 May–Jun;58(3):130–60.
62. Levin TR. Flexible sigmoidoscopy for colorectal cancer screening: valid approach or shortsighted? Gastroenterol Clin North Am. 2002 Dec;31(4):1015–29, vii.
63. Levin TR, Farraye FA, Schoen RE, et al. Quality in the technical performance of screening flexible sigmoidoscopy: recommendations of an international multi-society task group. Gut. 2005 Jun;54(6):807–13.
64. Lewis C. Colorectal cancer screening. Clin Evid. 2006 Jun(15):681–6.
65. Liangpunsakul S, Rex DK. Colon tumors and colonoscopy. Endoscopy. 2002 Nov;34(11):875–81.
66. Lidofsky S. Detection and prevention of colon cancer: colonoscopy, virtual colonoscopy, and DNA stool tests. Med Health R I. 2005 Mar;88(3):82–5.
67. Lieberman D. Colonoscopy as a mass screening tool. Eur J Gastroenterol Hepatol. 1998 Mar;10(3):225–8.
68. Lieberman D. How to screen for colon cancer. Annu Rev Med. 1998;49:163–72.
69. Lieberman D. Colorectal cancer screening in primary care. Gastroenterology. 2007 Jun;132(7):2591–4.
70. Lieberman D, Nadel M, Smith RA, et al. Standardized colonoscopy reporting and data system: report of the Quality Assurance Task Group of the National Colorectal Cancer Roundtable. Gastrointest Endosc. 2007 May;65(6):757–66.
71. Lin O, Roy Praveen K, Schembre Drew B, et al. Screening sigmoidoscopy and colonoscopy for reducing colorectal cancer mortality in asymtomatic persons. Cochrane Database of Systematic Reviews. 2005(2).
72. Mahon SM. Colorectal cancer screening: a review of the evidence. Clin J Oncol Nurs. 2004 Oct;8(5):536–40.
73. Maxim R. Colorectal cancer screening and prevention. Med Health R I. 1999 Mar;82(3):105–6.
74. McArdle CS. Faecal occult blood testing for colorectal cancer. Ann Oncol. 2002 Jan;13(1):35–9.
75. McMahon PM, Gazelle GS. The case for colorectal cancer screening. Semin Roentgenol. 2000 Oct;35(4):325–32.
76. Meisler JG. Toward optimal health: the experts discuss colon cancer. J Womens Health Gend Based Med. 2000 Nov;9(9):945–50.
77. Misra SP. Colonoscopy. Endoscopy. 2004 Nov;36(11):957–60.
78. Mitka M. Colorectal cancer screening rates still fall far short of recommended levels. JAMA. 2008 Feb 13;299(6):622.
79. Moore G. Screening is key to preventing colorectal cancer. Bus Health. 2001 Jun;19(6):40.
80. Moore KJ. Medicare expands preventive screening benefits. Fam Pract Manag. 2001 Jun;8(6):16.
81. Myers RE. Decision counseling in cancer prevention and control. Health Psychol. 2005 Jul;24(4 Suppl):S71–7.
82. Piper MA. Special report: fecal DNA analysis for colon cancer screening. Technology Evaluation Center Assesssment Program. 2006 Aug;21(6).
83. Pontieri-Lewis V. Colorectal cancer: prevention and screening. Medsurg Nurs. 2000 Feb;9(1):9–13, 20; quiz 14–5.
84. Rawl SM, Menon U, Champion V. Colorectal cancer screening: an overview of current trends. Nurs Clin North Am. 2002 Jun;37(2):225–45, v.
85. Repici A, Tricerri R. Endoscopic polypectomy: techniques, complications and follow-up. Tech Coloproctol. 2004 Dec;8 Suppl 2:s283–90.
86. Rex DK. Maximizing detection of adenomas and cancers during colonoscopy. Am J Gastroenterol. 2006 Dec;101(12):2866–77.
87. Rex DK. Advances in colonoscopic imaging. Rev Gastroenterol Disord. 2006;6 Suppl 1:S28–32.
88. Rose M. Re: Balaban et al.--Low volume bowel preparation for colonoscopy: randomized endoscopist-blinded trial of liquid sodium phosphate versus tablet sodium phosphate. Am J Gastroenterol. 2003 Oct;98(10):2328–9; author reply 9.
89. Rozen P. Cancer of the gastrointestinal tract: early detection or early prevention? Eur J Cancer Prev. 2004 Feb;13(1):71–5.
90. Rubin DT, Dachman AH. Virtual colonoscopy: a novel imaging modality for colorectal cancer. Curr Oncol Rep. 2001 Mar;3(2):88–93.
91. Rubin PH, Waye JD. Colonoscopic polypectomy: a critical review of recent literature. Curr Gastroenterol Rep. 2006 Oct;8(5):430–3.
92. Rubio CA, Jaramillo E, Lindblom A, et al. Classification of colorectal polyps: guidelines for the endoscopist. Endoscopy. 2002 Mar;34(3):226–36.
93. Saliangas K. Screening for colorectal cancer. Tech Coloproctol. 2004 Nov;8 Suppl 1:s10–3.
94. Schlossberg N. Preventing foreseeable tragedy. Gastroenterol Nurs. 2000 Jul–Aug;23(4):141–2.
95. Schnoll-Sussman F, Markowitz AJ, Winawer SJ. Screening and surveillance for colorectal cancer. Semin Oncol. 2000 Oct;27(5 Suppl 10):10–21.
96. Schoen RE. The case for population-based screening for colorectal cancer. Nat Rev Cancer. 2002 Jan;2(1):65–70.
97. Schoen RE. Surveillance after positive and negative colonoscopy examinations: issues, yields, and use. Am J Gastroenterol. 2003 Jun;98(6):1237–46.
98. Schoenfeld P. Flexible sigmoidoscopy by paramedical personnel. J Clin Gastroenterol. 1999 Mar;28(2):110–6.
99. Scotiniotis I, Lewis JD, Strom BL. Screening for colorectal cancer and other GI cancers. Curr Opin Oncol. 1999 Jul;11(4):305–11.
100. Seeff LC, Tangka FK. Can we predict the outcomes of national colorectal cancer screening and can predictions help us plan? Gastroenterology. 2005 Oct;129(4):1339–42.
101. Shim K. Current challenges in cancer screening. Part I. Colon cancer screening. Dis Mon. 2000 Jun;46(6):367–80.
102. Silva AC, Vens EA, Hara AK, et al. Evaluation of benign and malignant rectal lesions with CT colonography and endoscopic correlation. Radiographics. 2006 Jul–Aug;26(4):1085–99.
103. Simon JB. Fecal occult blood testing: clinical value and limitations. Gastroenterologist. 1998 Mar;6(1):66–78.
104. Smith PA. The role of the gastroenterology nurse in colorectal cancer screening. Gastroenterol Nurs. 1999 Sep–Oct;22(5):217–20.
105. Smith TJ, Bear HD. Standard follow-up of colorectal cancer patients: finally, we can make practice guidelines based on evidence. Gastroenterology. 1998 Jan;114(1):211–3.
106. Snover DC, Jass JR, Fenoglio-Preiser C, et al. Serrated polyps of the large intestine: a morphologic and molecular review of an evolving concept. Am J Clin Pathol. 2005 Sep;124(3):380–91.
107. Sosna J, Morrin MM, Copel L, et al. Computed tomography colonography (virtual colonoscopy): update on technique, applications, and future developments. Surg Technol Int. 2003;11:102–10.
108. St John DJ. Screening for rectal cancer. Hepatogastroenterology. 2000 Mar‐Apr;47(32):305–9.
109. Stanley AJ, St John DJ. Faecal occult blood test screening for colorectal cancer--what are we waiting for? Aust N Z J Med. 1999 Aug;29(4):545–51.
110. Steele RJ. Screening for colorectal cancer. Scott Med J. 1999 Jun;44(3):67.
111. Summerton S, Little E, Cappell MS. CT colonography: current status and future promise. Gastroenterol Clin North Am. 2008 Mar;37(1):161–89, viii.
112. Swaroop VS, Larson MV. Colonoscopy as a screening test for colorectal cancer in average-risk individuals. Mayo Clin Proc. 2002 Sep;77(9):951–6.
113. Tan D, Ross WA. Colorectal polyps: clinical significance of endoscopic and pathologic correlation. Am J Clin Pathol. 2008 Apr;129(4):659–60; author reply 60.
114. Tatum P, Mehr D, Easton B. Clinical inquiries. At what age do patients no longer need colorectal cancer screening? J Fam Pract. 2001 Jul;50(7):575–6.
115. Taylor SA, Halligan S, Bartram CI. CT colonography: methods, pathology and pitfalls. Clin Radiol. 2003 Mar;58(3):179–90.
116. Tereschuk D, Paulk D. Colorectal cancer screening modalities, guidelines, and a look at the future. Jaapa. 2002 Jun;15(6):22–8.
117. Thomeer M, Vanbeckevoort D, Bielen D, et al. Virtual colonoscopy: a new screening tool for colorectal cancer? Jbr-Btr. 2001 Aug;84(4):155–63.
118. Tjandra J, Tan Jane JY. Bowel preparation for colonoscopy. Cochrane Database of Systematic Reviews. 2007(1).
119. Tomeo CA, Colditz GA, Willett WC, et al. Harvard Report on Cancer Prevention. Volume 3: prevention of colon cancer in the United States. Cancer Causes Control. 1999 Jun;10(3):167–80.
120. Torres C, Szomstein S, Wexner SD. Virtual colonoscopy in colorectal cancer screening. Surg Innov. 2007 Mar;14(1):27–34.
121. Tracy GE. Make colorectal cancer screening. A part of routine care. S D J Med. 2002 Mar;55(3):104–5.
122. Trowbridge B, Burt RW. Colorectal cancer screening. Surg Clin North Am. 2002 Oct;82(5):943–57.
123. Unal H, Selcuk H, Gokcan H, et al. Malignancy risk of small polyps and related factors. Dig Dis Sci. 2007 Oct;52(10):2796–9.
124. Valev V, Wang G, Vannier MW. Techniques of CT colonography (virtual colonoscopy). Crit Rev Biomed Eng. 1999;27(1–2):1–25.
125. van Dam J, Cotton P, Johnson CD, et al. AGA future trends report: CT colonography. Gastroenterology. 2004 Sep;127(3):970–84.
126. Van Gerpen R. Colorectal cancer. Ala Nurse. 2004 Dec–2005 Feb;31(4):27–30; quiz -1.
127. Vernon SW, Meissner HI. Evaluating approaches to increase uptake of colorectal cancer screening: lessons learned from pilot studies in diverse primary care settings. Med Care. 2008 Sep;46(9 Suppl 1):S97–102.
128. Villavicencio RT, Rex DK. Colonic adenomas: prevalence and incidence rates, growth rates, and miss rates at colonoscopy. Semin Gastrointest Dis. 2000 Oct;11(4):185–93.
129. Volberding P. Looking behind: time for anal cancer screening. Am J Med. 2000 Jun 1;108(8):674–5.
130. Wald C, Scheirey CD, Tran TM, et al. An update on imaging of colorectal cancer. Surg Clin North Am. 2006 Aug;86(4):819–47.
131. Walker CW. Fecal occult blood tests reduce colorectal cancer mortality. Am Fam Physician. 2007 Jun 1;75(11):1652–3.
132. Wallace MB. Improving colorectal adenoma detection: technology or technique? Gastroenterology. 2007 Apr;132(4):1221–3.
133. Waye JD. Follow–up colonoscopy: screen more, survey less, and save. Gastrointest Endosc. 2006 Dec;64(6):955–7.
134. Weinberg DS. In the clinic. Colorectal cancer screening. Ann Intern Med. 2008 Feb 5;148(3):ITC2-1–ITC2-16.
135. Wender RC. Barriers to screening for colorectal cancer. Gastrointest Endosc Clin N Am. 2002 Jan;12(1):145–70.
136. Willis MS, Fuda FS, Chenault CB. Current methods of colorectal cancer screening. MLO Med Lab Obs. 2002 May;34(5):12–6, 9; quiz 20–1.
137. Winawer SJ. Screening of colorectal cancer. Surg Oncol Clin N Am. 2005 Oct;14(4):699–722.
138. Winawer SJ. Screening of colorectal cancer: progress and problems. Recent Results Cancer Res. 2005;166:231–44.
139. Winawer SJ, Zauber AG. The advanced adenoma as the primary target of screening. Gastrointest Endosc Clin N Am. 2002 Jan;12(1):1–9, v.
140. Winawer SJ, Zauber AG, Fletcher RH, et al. Guidelines for colonoscopy surveillance after polypectomy: a consensus update by the US Multi-Society Task Force on Colorectal Cancer and the American Cancer Society. Gastroenterology. 2006 May;130(6):1872–85.
141. Wineman AP. Screening for colorectal cancer. Guidelines for choosing the appropriate test for each patient. Postgrad Med. 2003 Feb;113(2):49–55; quiz 8.
142. Witte TN, Enns R. The difficult colonoscopy. Can J Gastroenterol. 2007 Aug;21(8):487–90.
143. Woolf SH. Overcoming the barriers to change: screening for colorectal cancer. Am Fam Physician. 2000 Mar 15;61(6):1621–2, 8.
144. Yee J. CT screening for colorectal cancer. Radiographics. 2002 Nov–Dec;22(6):1525–31.
145. Yee J. CT colonography: examination prerequisites. Abdom Imaging. 2002 May‐Jun;27(3):244–52.
146. Yee J. Screening CT colonography. Semin Ultrasound CT MR. 2003 Feb;24(1):12–22.
147. Young GP, Cole S. New stool screening tests for colorectal cancer. Digestion. 2007;76(1):26–33.
148. Zapka J. Innovative provider- and health system-directed approaches to improving colorectal cancer screening delivery. Med Care. 2008 Sep;46(9 Suppl 1):S62–7.
149. Zarchy T. Projected national impact of colorectal cancer screening on clinical and economic outcomes and health services demand. Gastroenterology. 2006 Mar;130(3):1012; author reply
150. Zarychanski R, Dhaliwal D. Rates of colorectal cancer screening. CMAJ. 2008 May 20;178(11):1465.
151. Zauber AG. Quality control for flexible sigmoidoscopy: which polyps count? Gastroenterology. 2004 May;126(5):1474–7.
152. Zauber AG, Levin TR, Jaffe CC, et al. Implications of new colorectal cancer screening technologies for primary care practice. Med Care. 2008 Sep;46(9 Suppl 1):S138–46.
153. Ziebert JJ. Colorectal cancer screening: the old and the new. Tex Med. 2001 Feb;97(2):46–8.
154. Zoorob R, Anderson R, Cefalu C, et al. Cancer screening guidelines. Am Fam Physician. 2001 Mar 15;63(6):1101–12.
155. Zuber TJ. Flexible sigmoidoscopy. Am Fam Physician. 2001 Apr 1;63(7):1375–80, 83–8.

## Wrong population/setting

1. Bulmer M, Hartley J, Lee PW, et al. Improving the view in the rectal clinic: a randomised control trial. Ann R Coll Surg Engl. 2000 May;82(3):210–2.
2. Connell W. PRO: Endoscopic surveillance minimizes the risk of cancer. Am J Gastroenterol. 2004 Sep;99(9):1631–3.
3. de Zwart IM, Griffioen G, Shaw MP, et al. Barium enema and endoscopy for the detection of colorectal neoplasia: sensitivity, specificity, complications and its determinants. Clin Radiol. 2001 May;56(5):401–9.
4. DeBourcy AC, Lichtenberger S, Felton S, et al. Community-based preferences for stool cards versus colonoscopy in colorectal cancer screening. J Gen Intern Med. 2008 Feb;23(2):169–74.
5. Deenadayalu VP, Rex DK. Fecal-based DNA assays: a new, noninvasive approach to colorectal cancer screening. Cleve Clin J Med. 2004 Jun;71(6):497–503.
6. Friedman LC, Webb JA, Richards CS, et al. Psychological and behavioral factors associated with colorectal cancer screening among Ashkenazim. Prev Med. 1999 Aug;29(2):119–25.
7. Gluecker TM, Johnson CD, Harmsen WS, et al. Colorectal cancer screening with CT colonography, colonoscopy, and double-contrast barium enema examination: prospective assessment of patient perceptions and preferences. Radiology. 2003 May;227(2):378–84.
8. Holman JR, Marshall RC, Jordan B, et al. Technical competency in flexible sigmoidoscopy. J Am Board Fam Pract. 2001 Nov–Dec;14(6):424–9.
9. Honda K, Gorin SS. Modeling pathways to affective barriers on colorectal cancer screening among Japanese Americans. J Behav Med. 2005 Apr;28(2):115–24.
10. Lewis CL, Brenner AT, Griffith JM, et al. The uptake and effect of a mailed multi-modal colon cancer screening intervention: A pilot controlled trial. Implement Sci. 2008;3:32.
11. Longacre AV, Cramer LD, Gross CP. Screening colonoscopy use among individuals at higher colorectal cancer risk. J Clin Gastroenterol. 2006 Jul;40(6):490–6.
12. Menees SB, Scheiman J, Carlos R, et al. Gastroenterologists utilize the referral for EGD to enhance colon cancer screening more effectively than primary care physicians. Aliment Pharmacol Ther. 2006 Apr 1;23(7):953–62.
13. Murff HJ, Peterson NB, Fowke JH, et al. Colonoscopy screening in African Americans and Whites with affected first-degree relatives. Arch Intern Med. 2008 Mar 24;168(6):625–31.
14. Myers RE, Fishbein G, Hyslop T, et al. Measuring complete diagnostic evaluation in colorectal cancer screening. Cancer Detect Prev. 2001;25(2):174–82.
15. Pickhardt PJ, Taylor AJ, Kim DH, et al. Screening for colorectal neoplasia with CT colonography: initial experience from the 1st year of coverage by third-party payers. Radiology. 2006 Nov;241(2):417–25.
16. Post DM, Katz ML, Tatum C, et al. Determinants of colorectal cancer screening in primary care. J Cancer Educ. 2008;23(4):241–7.
17. Saini SD, Kim HM, Schoenfeld P. Incidence of advanced adenomas at surveillance colonoscopy in patients with a personal history of colon adenomas: a meta-analysis and systematic review. Gastrointest Endosc. 2006 Oct;64(4):614–26.
18. Siddiqui AA, Patel A, Huerta S. Determinants of compliance with colonoscopy in patients with adenomatous colon polyps in a veteran population. Aliment Pharmacol Ther. 2006 Dec;24(11–12):1623–30.
19. Stiegman G. Detection of colorectal lesions with virtual computed tomographic colonography. Tech Coloproctol. 2003 Jul;7(2):119; discussion −20.
20. Stoffel EM, Garber JE, Grover S, et al. Cancer surveillance is often inadequate in people at high risk for colorectal cancer. J Med Genet. 2003 May;40(5):e54.
21. Tabbarah M, Nowalk MP, Raymund M, et al. Barriers and facilitators of colon cancer screening among patients at faith-based neighborhood health centers. J Community Health. 2005 Feb;30(1):55–74.
22. Tagore KS, Levin TR, Lawson MJ. The evolution to stool DNA testing for colorectal cancer. Aliment Pharmacol Ther. 2004 Jun 15;19(12):1225–33.
23. Wang JH, Liang W, Chen MY, et al. The influence of culture and cancer worry on colon cancer screening among older Chinese-American women. Ethn Dis. 2006 Spring;16(2):404–11.
24. Winkleman BJ, Matthews DE, Wiebke EA. Colorectal cancer screening at a Veterans Affairs hospital. Am J Surg. 2003 Nov;186(5):468–71.
25. Zarchy TM, Tsai F, Ramicone E, et al. A risk profile for advanced proximal neoplasms on diagnostic colonoscopy. Dig Dis Sci. 2009 Jan;54(1):151–9.

## Wrong outcomes

1. Baig N, Myers RE, Turner BJ, et al. Physician-reported reasons for limited follow-up of patients with a positive fecal occult blood test screening result. Am J Gastroenterol. 2003 Sep;98(9):2078–81.
2. Bao Y, Fox SA, Escarce JJ. Socioeconomic and racial/ethnic differences in the discussion of cancer screening: "between-" versus "within-" physician differences. Health Serv Res. 2007 Jun;42(3 Pt 1):950–70.
3. Bastani R, Glenn BA, Maxwell AE, et al. Validation of self-reported colorectal cancer (CRC) screening in a study of ethnically diverse first-degree relatives of CRC cases. Cancer Epidemiol Biomarkers Prev. 2008 Apr;17(4):791–8.
4. Beebe TJ, Johnson CD, Stoner SM, et al. Assessing attitudes toward laxative preparation in colorectal cancer screening and effects on future testing: potential receptivity to computed tomographic colonography. Mayo Clin Proc. 2007 Jun;82(6):666–71.
5. Bini EJ, Unger JS, Rieber JM, et al. Prospective, randomized, single-blind comparison of two preparations for screening flexible sigmoidoscopy. Gastrointest Endosc. 2000 Aug;52(2):218–22.
6. Boolchand V, Olds G, Singh J, et al. Colorectal screening after polypectomy: a national survey study of primary care physicians. Ann Intern Med. 2006 Nov 7;145(9):654–9.
7. Brawarsky P, Brooks DR, Mucci LA. Correlates of colorectal cancer testing in Massachusetts men and women. Prev Med. 2003 Jun;36(6):659–68.
8. Brouse CH, Basch CE, Wolf RL, et al. Barriers to colorectal cancer screening: an educational diagnosis. J Cancer Educ. 2004 Fall;19(3):170–3.
9. Burch JA, Soares-Weiser K, St John DJ, et al. Diagnostic accuracy of faecal occult blood tests used in screening for colorectal cancer: a systematic review. J Med Screen. 2007;14(3):132–7.
10. Callcut RA, Kaufman S, Stone-Newsom R, et al. Gender disparities in colorectal cancer screening: true or false? J Gastrointest Surg. 2006 Dec;10(10):1409–17.
11. Chen LA, Santos S, Jandorf L, et al. A program to enhance completion of screening colonoscopy among urban minorities. Clin Gastroenterol Hepatol. 2008 Apr;6(4):443–50.
12. Coombes JM, Steiner JF, Bekelman DB, et al. Clinical outcomes associated with attempts to educate patients about lower endoscopy: a narrative review. J Community Health. 2008 Jun;33(3):149–57.
13. Cooper CP, Williams KN, Carey KA, et al. Advertising campaign on a major internet search engine to promote colorectal cancer screening. BMJ. 2004 May 15;328(7449):1179–80.
14. Cornett D, Barancin C, Roeder B, et al. Findings on optical colonoscopy after positive CT colonography exam. Am J Gastroenterol. 2008 Aug;103(8):2068–74.
15. Costanza ME, Luckmann R, Stoddard AM, et al. Applying a stage model of behavior change to colon cancer screening. Prev Med. 2005 Sep‐Oct;41(3–4):707–19.
16. Dolan JG. Patient priorities in colorectal cancer screening decisions. Health Expect. 2005 Dec;8(4):334–44.
17. Dolan NC, Ferreira MR, Davis TC, et al. Colorectal cancer screening knowledge, attitudes, and beliefs among veterans: does literacy make a difference? J Clin Oncol. 2004 Jul 1;22(13):2617–22.
18. Feingold DL, Forde KA. Colorectal cancer surveillance after age 65 years. Am J Surg. 2003 Apr;185(4):297–300.
19. Fenlon HM, Nunes DP, Schroy PC, 3rd, et al. A comparison of virtual and conventional colonoscopy for the detection of colorectal polyps. N Engl J Med. 1999 Nov 11;341(20):1496–503.
20. Fenton JJ, Reid RJ, Baldwin LM, et al. Influence of primary care use on population delivery of colorectal cancer screening. Cancer Epidemiol Biomarkers Prev. 2009 Feb;18(2):640–5.
21. Fisher DA, Voils CI, Coffman CJ, et al. Validation of a questionnaire to assess self-reported colorectal cancer screening status using face-to-face administration. Dig Dis Sci. 2009 Jun;54(6):1297–306.
22. Ford ME, Havstad SL, Fields ME, et al. Effects of baseline comorbidities on cancer screening trial adherence among older African American men. Cancer Epidemiol Biomarkers Prev. 2008 May;17(5):1234–9.
23. Friedemann-Sanchez G, Griffin JM, Partin MR. Gender differences in colorectal cancer screening barriers and information needs. Health Expect. 2007 Jun;10(2):148–60.
24. Ganz PA, Farmer MM, Belman M, et al. Improving colorectal cancer screening rates in a managed care health plan: recruitment of provider organizations for a randomized effectiveness trial. Cancer Epidemiol Biomarkers Prev. 2003 Sep;12(9):824–9.
25. Geller BM, Skelly JM, Dorwaldt AL, et al. Increasing patient/physician communications about colorectal cancer screening in rural primary care practices. Med Care. 2008 Sep;46(9 Suppl 1):S36–43.
26. Gennarelli M, Jandorf L, Cromwell C, et al. Barriers to colorectal cancer screening: inadequate knowledge by physicians. Mt Sinai J Med. 2005 Jan;72(1):36–44.
27. Gluecker TM, Johnson CD, Wilson LA, et al. Extracolonic findings at CT colonography: evaluation of prevalence and cost in a screening population. Gastroenterology. 2003 Apr;124(4):911–6.
28. Gorin SS. Correlates of colorectal cancer screening compliance among urban Hispanics. J Behav Med. 2005 Apr;28(2):125–37.
29. Griffith JM, Fichter M, Fowler FJ, et al. Should a colon cancer screening decision aid include the option of no testing? A comparative trial of two decision aids. BMC Med Inform Decis Mak. 2008;8:10.
30. Griffith JM, Lewis CL, Brenner AR, et al. The effect of offering different numbers of colorectal cancer screening test options in a decision aid: a pilot randomized trial. BMC Med Inform Decis Mak. 2008;8:4.
31. Guerra CE, Schwartz JS, Armstrong K, et al. Barriers of and facilitators to physician recommendation of colorectal cancer screening. J Gen Intern Med. 2007 Dec;22(12):1681–8.
32. Heresbach D, Manfredi S, D'Halluin P N, et al. Review in depth and meta-analysis of controlled trials on colorectal cancer screening by faecal occult blood test. Eur J Gastroenterol Hepatol. 2006 Apr;18(4):427–33.
33. Imperiale TF, Ransohoff DF, Itzkowitz SH, et al. Fecal DNA versus fecal occult blood for colorectal-cancer screening in an average-risk population. N Engl J Med. 2004 Dec 23;351(26):2704–14.
34. Itzkowitz SH, Jandorf L, Brand R, et al. Improved fecal DNA test for colorectal cancer screening. Clinical gastroenterology and hepatology : the official clinical practice journal of the American Gastroenterological Association. 2007(1):111–7.
35. Janz NK, Lakhani I, Vijan S, et al. Determinants of colorectal cancer screening use, attempts, and non-use. Prev Med. 2007 May;44(5):452–8.
36. Jerant A, Kravitz RL, Rooney M, et al. Effects of a tailored interactive multimedia computer program on determinants of colorectal cancer screening: a randomized controlled pilot study in physician offices. Patient Educ Couns. 2007 Apr;66(1):67–74.
37. Jimbo M, Myers RE, Meyer B, et al. Reasons patients with a positive fecal occult blood test result do not undergo complete diagnostic evaluation. Ann Fam Med. 2009 Jan‐Feb;7(1):11–6.
38. Jonas DE, Russell LB, Sandler RS, et al. Value of patient time invested in the colonoscopy screening process: time requirements for colonoscopy study. Med Decis Making. 2008 Jan–Feb;28(1):56–65.
39. Jones RM, Mongin SJ, Lazovich D, et al. Validity of four self-reported colorectal cancer screening modalities in a general population: differences over time and by intervention assignment. Cancer Epidemiol Biomarkers Prev. 2008 Apr;17(4):777–84.
40. Jorgensen CM, Gelb CA, Merritt TL, et al. Observations from the CDC: CDC's Screen for Life: a National Colorectal Cancer Action Campaign. J Womens Health Gend Based Med. 2001 Jun;10(5):417–22.
41. Kahi CJ, Azzouz F, Juliar BE, et al. Survival of elderly persons undergoing colonoscopy: implications for colorectal cancer screening and surveillance. Gastrointest Endosc. 2007 Sep;66(3):544–50.
42. Kavanagh AM, Giovannucci EL, Fuchs CS, et al. Screening endoscopy and risk of colorectal cancer in United States men. Cancer Causes Control. 1998 Aug;9(4):455–62.
43. Klabunde CN, Frame PS, Meadow A, et al. A national survey of primary care physicians' colorectal cancer screening recommendations and practices. Prev Med. 2003 Mar;36(3):352–62.
44. Klabunde CN, Lanier D, Nadel MR, et al. Colorectal cancer screening by primary care physicians: recommendations and practices, 2006–2007. Am J Prev Med. 2009 Jul;37(1):8–16.
45. Klabunde CN, Schenck AP, Davis WW. Barriers to colorectal cancer screening among Medicare consumers. Am J Prev Med. 2006 Apr;30(4):313–9.
46. Lairson DR, Chang YC, Bettencourt JL, et al. Estimating development cost for a tailored interactive computer program to enhance colorectal cancer screening compliance. J Am Med Inform Assoc. 2006 Sep–Oct;13(5):476–84.
47. Lairson DR, DiCarlo M, Myers RE, et al. Cost-effectiveness of targeted and tailored interventions on colorectal cancer screening use. Cancer. 2008 Feb 15;112(4):779–88.
48. Larkey LK, Lopez AM, Minnal A, et al. Storytelling for promoting colorectal cancer screening among underserved Latina women: a randomized pilot study. Cancer Control. 2009(1):79–87.
49. Larsen IK, Grotmol T, Almendingen K, et al. Impact of colorectal cancer screening on future lifestyle choices: a three-year randomized controlled trial. Clin Gastroenterol Hepatol. 2007 Apr;5(4):477–83.
50. Larson K, Levy J, Rome MG, et al. Public health detailing: a strategy to improve the delivery of clinical preventive services in New York City. Public Health Rep. 2006 May–Jun;121(3):228–34.
51. Lemon SC, Zapka JG, Estabrook B, et al. Screening for colorectal cancer on the front line. Am J Gastroenterol. 2003 Apr;98(4):915–23.
52. Levy BT, Joshi M, Xu Y, et al. Perceptions of Iowa family physicians regarding colorectal cancer screening. Med Care. 2008 Sep;46(9 Suppl 1):S103–8.
53. Lieberman DA, Weiss DG, Harford WV, et al. Five-year colon surveillance after screening colonoscopy. Gastroenterology. 2007 Oct;133(4):1077–85.
54. Lin OS, Kozarek RA, Schembre DB, et al. Screening colonoscopy in very elderly patients: prevalence of neoplasia and estimated impact on life expectancy. JAMA. 2006 May 24;295(20):2357–65.
55. Lipkus IM, Lyna PR, Rimer BK. Colorectal cancer risk perceptions and screening intentions in a minority population. J Natl Med Assoc. 2000 Oct;92(10):492–500.
56. Loeve F, Boer R, Zauber AG, et al. National Polyp Study data: evidence for regression of adenomas. Int J Cancer. 2004 Sep 10;111(4):633–9.
57. Lund JN, Scholefield JH, Grainge MJ, et al. Risks, costs, and compliance limit colorectal adenoma surveillance: lessons from a randomised trial. Gut. 2001 Jul;49(1):91–6.
58. Maheshwari S, Patel T, Patel P. Screening for colorectal cancer in elderly persons: who should we screen and when can we stop? J Aging Health. 2008 Feb;20(1):126–39.
59. Menon U, Belue R, Sugg Skinner C, et al. Perceptions of colon cancer screening by stage of screening test adoption. Cancer Nurs. 2007 May‐Jun;30(3):178–85.
60. Menon U, Champion VL, Larkin GN, et al. Beliefs associated with fecal occult blood test and colonoscopy use at a worksite colon cancer screening program. J Occup Environ Med. 2003 Aug;45(8):891–8.
61. Myers RE, Vernon SW, Tilley BC, et al. Intention to screen for colorectal cancer among white male employees. Prev Med. 1998 Mar‐Apr;27(2):279–87.
62. Nathanson JW, Zisman TL, Julian C, et al. Identification of patients at increased risk for colorectal cancer in an open access endoscopy center. J Clin Gastroenterol. 2008 Oct;42(9):1025–31.
63. Nease DE, Jr., Green LA. ClinfoTracker: a generalizable prompting tool for primary care. J Am Board Fam Pract. 2003 Mar–Apr;16(2):115–23.
64. Nichols C, Holt CL, Shipp M, et al. Physician knowledge, perceptions of barriers, and patient colorectal cancer screening practices. Am J Med Qual. 2009 Mar–Apr;24(2):116–22.
65. Oliveria SA, Christos PJ, Visintainer PF, et al. Patterns of colon cancer screening among companies in the U.S.: a descriptive survey. Am J Health Promot. 1999 Jan–Feb;13(3):146–8.
66. Oxentenko AS, Goel NK, Pardi DS, et al. Colorectal cancer screening education, prioritization, and self-perceived preparedness among primary care residents: data from a national survey. J Cancer Educ. 2007 Winter;22(4):208–18.
67. Partin MR, Grill J, Noorbaloochi S, et al. Validation of self-reported colorectal cancer screening behavior from a mixed-mode survey of veterans. Cancer Epidemiol Biomarkers Prev. 2008 Apr;17(4):768–76.
68. Philips GK, Reinier K, Ashikaga T, et al. Attitudes and beliefs of primary care physicians regarding prostate and colorectal cancer screening in a rural state. J Cancer Educ. 2005 Fall;20(3):167–72.
69. Pickhardt PJ, Hassan C, Laghi A, et al. Clinical management of small (6- to 9-mm) polyps detected at screening CT colonography: a cost-effectiveness analysis. AJR Am J Roentgenol. 2008 Nov;191(5):1509–16.
70. Powell AA, Gravely AA, Ordin DL, et al. Timely follow-up of positive fecal occult blood tests strategies associated with improvement. Am J Prev Med. 2009 Aug;37(2):87–93.
71. Ramakrishnan K, Scheid DC. Selecting patients for flexible sigmoidoscopy. Determinants of incomplete depth of insertion. Cancer. 2005 Mar 15;103(6):1179–85.
72. Rawl SM, Menon U, Champion VL, et al. Do benefits and barriers differ by stage of adoption for colorectal cancer screening? Health Educ Res. 2005 Apr;20(2):137–48.
73. Ringel Y, Dalton CB, Brandt LJ, et al. Flexible sigmoidoscopy: the patients' perception. Gastrointest Endosc. 2002 Mar;55(3):315–20.
74. Rundle AG, Lebwohl B, Vogel R, et al. Colonoscopic screening in average-risk individuals ages 40 to 49 vs 50 to 59 years. Gastroenterology. 2008 May;134(5):1311–5.
75. Sarfaty M, Myers RE. The effect of HEDIS measurement of colorectal cancer screening on insurance plans in Pennsylvania. Am J Manag Care. 2008 May;14(5):277–82.
76. Schoen RE, Pinsky PF, Weissfeld JL, et al. Results of repeat sigmoidoscopy 3 years after a negative examination. JAMA. 2003 Jul 2;290(1):41–8.
77. Schoenfeld PS, Cash B, Kita J, et al. Effectiveness and patient satisfaction with screening flexible sigmoidoscopy performed by registered nurses. Gastrointestinal endoscopy. 1999(2):158–62.
78. Shankaran V, McKoy JM, Dandade N, et al. Costs and cost-effectiveness of a low-intensity patient-directed intervention to promote colorectal cancer screening. J Clin Oncol. 2007 Nov 20;25(33):5248–53.
79. Sharma VK, Corder FA, Fancher J, et al. Survey of the opinions, knowledge, and practices of gastroenterologists regarding colorectal cancer screening and use of the fecal occult blood test. Am J Gastroenterol. 2000 Dec;95(12):3629–32.
80. Shokar NK, Vernon SW, Weller SC. Cancer and colorectal cancer: knowledge, beliefs, and screening preferences of a diverse patient population. Fam Med. 2005 May;37(5):341–7.
81. Singer RB. Fecal occult blood testing and the incidence of colorectal cancer. J Insur Med. 2002;34(2):89–91.
82. Singh H, Kadiyala H, Bhagwath G, et al. Using a multifaceted approach to improve the follow-up of positive fecal occult blood test results. Am J Gastroenterol. 2009 Apr;104(4):942–52.
83. Slattery ML, Edwards SL, Ma KN, et al. Colon cancer screening, lifestyle, and risk of colon cancer. Cancer Causes Control. 2000 Jul;11(6):555–63.
84. Smalley WE, Eisen GM. Colorectal cancer screening 2000: the role of colonoscopy in average-risk individuals. Curr Gastroenterol Rep. 2000 Oct;2(5):406–12.
85. Strum WB. Incidence of advanced adenomas of the rectosigmoid colon three years and five years after negative flexible sigmoidoscopy in 4010 patients. Dig Dis Sci. 2003 Dec;48(12):2278–83.
86. Strum WB. Impact of adenoma size in distal colon on risk for advanced adenoma of the proximal colon. Dig Dis Sci. 2006 Nov;51(11):2064–7.
87. Tangka FK, Subramanian S, Bapat B, et al. Cost of starting colorectal cancer screening programs: results from five federally funded demonstration programs. Prev Chronic Dis. 2008 Apr;5(2):A47.
88. Tiro JA, Vernon SW, Hyslop T, et al. Factorial validity and invariance of a survey measuring psychosocial correlates of colorectal cancer screening among African Americans and Caucasians. Cancer Epidemiol Biomarkers Prev. 2005 Dec;14(12):2855–61.
89. Ubel PA, Jepson C, Baron J, et al. The influence of cost-effectiveness information on physicians' cancer screening recommendations. Soc Sci Med. 2003 Apr;56(8):1727–36.
90. van Stolk RU, Beck GJ, Baron JA, et al. Adenoma characteristics at first colonoscopy as predictors of adenoma recurrence and characteristics at follow-up. The Polyp Prevention Study Group. Gastroenterology. 1998 Jul;115(1):13–8.
91. Vogelaar I, van Ballegooijen M, Schrag D, et al. How much can current interventions reduce colorectal cancer mortality in the U.S.? Mortality projections for scenarios of risk-factor modification, screening, and treatment. Cancer. 2006 Oct 1;107(7):1624–33.
92. Wackerbarth SB, Peters JC, Haist SA. Modeling the decision to undergo colorectal cancer screening: insights on patient preventive decision making. Med Care. 2008 Sep;46(9 Suppl 1):S17–22.
93. Wahab S, Menon U, Szalacha L. Motivational interviewing and colorectal cancer screening: a peek from the inside out. Patient Educ Couns. 2008 Aug;72(2):210–7.
94. Wallace MB, Kemp JA, Trnka YM, et al. Is colonoscopy indicated for small adenomas found by screening flexible sigmoidoscopy? Ann Intern Med. 1998 Aug 15;129(4):273–8.
95. Wardle J, Sutton S, Williamson S, et al. Psychosocial influences on older adults' interest in participating in bowel cancer screening. Prev Med. 2000 Oct;31(4):323–34.
96. Wardle J, Williamson S, Sutton S, et al. Psychological impact of colorectal cancer screening. Health Psychol. 2003 Jan;22(1):54–9.
97. Watts BG, Vernon SW, Myers RE, et al. Intention to be screened over time for colorectal cancer in male automotive workers. Cancer Epidemiol Biomarkers Prev. 2003 Apr;12(4):339–49.
98. Weinberg DS, Turner BJ, Wang H, et al. A survey of women regarding factors affecting colorectal cancer screening compliance. Prev Med. 2004 Jun;38(6):669–75.
99. Wilkins T, LeClair B, Smolkin M, et al. Screening colonoscopies by primary care physicians: a meta-analysis. Ann Fam Med. 2009 Jan–Feb;7(1):56–62.
100. Wolf AM, Schorling JB. Does informed consent alter elderly patients' preferences for colorectal cancer screening? Results of a randomized trial. J Gen Intern Med. 2000 Jan;15(1):24–30.
101. Wolf MS, Baker DW, Makoul G. Physician-patient communication about colorectal cancer screening. J Gen Intern Med. 2007 Nov;22(11):1493–9.
102. Yee J, Kumar NN, Hung RK, et al. Comparison of supine and prone scanning separately and in combination at CT colonography. Radiology. 2003 Mar;226(3):653–61.
103. Zalis ME, Barish MA, Choi JR, et al. CT colonography reporting and data system: a consensus proposal. Radiology. 2005 Jul;236(1):3–9.
104. Zubarik R, Ganguly E, Benway D, et al. Procedure-related abdominal discomfort in patients undergoing colorectal cancer screening: a comparison of colonoscopy and flexible sigmoidoscopy. Am J Gastroenterol. 2002 Dec;97(12):3056–61.

## Wrong study design

1. Armour BS, Friedman C, Pitts MM, et al. The influence of year-end bonuses on colorectal cancer screening. Am J Manag Care. 2004 Sep;10(9):617–24.
2. Bajracharya SM. An assessment of the perceived barriers and strategies to promoting early detection of colorectal cancer: a practitioners' perspective. Int Q Community Health Educ. 2006;26(1):23–44.
3. Baron RC, Rimer BK, Breslow RA, et al. Client-directed interventions to increase community demand for breast, cervical, and colorectal cancer screening a systematic review. Am J Prev Med. 2008 Jul;35(1 Suppl):S34–55.
4. Baron RC, Rimer BK, Coates RJ, et al. Client-directed interventions to increase community access to breast, cervical, and colorectal cancer screening a systematic review. Am J Prev Med. 2008 Jul;35(1 Suppl):S56–66.
5. Beeker C, Kraft JM, Southwell BG, et al. Colorectal cancer screening in older men and women: qualitative research findings and implications for intervention. J Community Health. 2000 Jun;25(3):263–78.
6. Brouse CH, Basch CE, Wolf RL, et al. Barriers to colorectal cancer screening with fecal occult blood testing in a predominantly minority urban population: a qualitative study. Am J Public Health. 2003 Aug;93(8):1268–71.
7. Brown SR, Baraza W, Hurlstone P. Chromoscopy versus conventional endoscopy for the detection of polyps in the colon and rectum. Cochrane Database of Systematic Reviews. 2007(4).
8. Chen ZJ, Kammer D, Bond JH, et al. Evaluating follow-up of positive fecal occult blood test results: lessons learned. J Healthc Qual. 2007 Sep–Oct;29(5):16–20, 34.
9. Christie J, Hooper C, Redd WH, et al. Predictors of endoscopy in minority women. J Natl Med Assoc. 2005 Oct;97(10):1361–8.
10. Christie J, Itzkowitz S, Lihau-Nkanza I, et al. A randomized controlled trial using patient navigation to increase colonoscopy screening among low-income minorities. J Natl Med Assoc. 2008 Mar;100(3):278–84.
11. DiPalma AM, Barnes SE, DiPalma JA. Patient participation in colon cancer screening programs. South Med J. 1998 Apr;91(4):342–4.
12. Dube CE, Fuller BK, Rosen RK, et al. Men's experiences of physical exams and cancer screening tests: a qualitative study. Prev Med. 2005 Jun;40(6):628–35.
13. Flicker MS, Tsoukas AT, Hazra A, et al. Economic impact of extracolonic findings at computed tomographic colonography. J Comput Assist Tomogr. 2008 Jul–Aug;32(4):497–503.
14. Frank D, Swedmark J, Grubbs L. Colon cancer screening in African American women. Abnf J. 2004 Jul–Aug;15(4):67–70.
15. Friedland S, Soetikno RM. Small caliber overtube-assisted colonoscopy. World J Gastroenterol. 2007 Nov 28;13(44):5933–7.
16. Goldsmith G, Chiaro C. Colorectal cancer screening: how to help patients comply. J Fam Pract. 2008 Jul;57(7):E2–7.
17. Halligan S, Altman DG, Taylor SA, et al. CT colonography in the detection of colorectal polyps and cancer: systematic review, meta‐analysis, and proposed minimum data set for study level reporting. Radiology. 2005 Dec;237(3):893–904.
18. Harnik IG. Pyogenic liver abscess presenting after malignant polypectomy. Dig Dis Sci. 2007 Dec;52(12):3524–5.
19. Horimatsu T, Fu KI, Sano Y, et al. Acute appendicitis as a rare complication after endoscopic mucosal resection. Dig Dis Sci. 2007 Jul;52(7):1741–4.
20. Ishibashi K, Hirose K, Kato H, et al. Determining the telomerase activity of exfoliated cells in intestinal lavage solution to detect colorectal carcinoma. Anticancer Res. 1999 Jul‐Aug;19(4B):2831–6.
21. Jepson R, Clegg A, Forbes C, et al. The determinants of screening uptake and interventions for increasing uptake: a systematic review. Health Technol Assess. 2000;4(14):i–vii, 1–133.
22. Katz ML, Tatum C, Dickinson SL, et al. Improving colorectal cancer screening by using community volunteers: results of the Carolinas cancer education and screening (CARES) project. Cancer. 2007 Oct 1;110(7):1602–10.
23. Kelly KM, Phillips CM, Jenkins C, et al. Physician and staff perceptions of barriers to colorectal cancer screening in Appalachian Kentucky. Cancer Control. 2007 Apr;14(2):167–75.
24. Khankari K, Eder M, Osborn CY, et al. Improving colorectal cancer screening among the medically underserved: a pilot study within a federally qualified health center. J Gen Intern Med. 2007 Oct;22(10):1410–4.
25. Kim J, Whitney A, Hayter S, et al. Development and initial testing of a computer-based patient decision aid to promote colorectal cancer screening for primary care practice. BMC Med Inform Decis Mak. 2005;5:36.
26. Lasser KE, Kelly B, Maier J, et al. Discussions about preventive services: a qualitative study. BMC Fam Pract. 2008;9:49.
27. Leung JW, Mann S, Leung FW. Options for screening colonoscopy without sedation: a pilot study in United States veterans. Aliment Pharmacol Ther. 2007 Aug 15;26(4):627–31.
28. Levy BT, Nordin T, Sinift S, et al. Why hasn't this patient been screened for colon cancer? An Iowa Research Network study. J Am Board Fam Med. 2007 Sep–Oct;20(5):458–68.
29. Ling BS, Trauth JM, Fine MJ, et al. Informed decision-making and colorectal cancer screening: is it occurring in primary care? Med Care. 2008 Sep;46(9 Suppl 1):S23–9.
30. Lipkus IM, Green LG, Marcus A. Manipulating perceptions of colorectal cancer threat: implications for screening intentions and behaviors. J Health Commun. 2003 May‐Jun;8(3):213–28.
31. Myers RE, Hyslop T, Sifri R, et al. Tailored navigation in colorectal cancer screening. Med Care. 2008 Sep;46(9 Suppl 1):S123–31.
32. Nash D, Azeez S, Vlahov D, et al. Evaluation of an intervention to increase screening colonoscopy in an urban public hospital setting. J Urban Health. 2006 Mar;83(2):231–43.
33. Natale-Pereira A, Marks J, Vega M, et al. Barriers and facilitators for colorectal cancer screening practices in the Latino community: perspectives from community leaders. Cancer Control. 2008 Apr;15(2):157–65.
34. Nelson RL, Schwartz A. A survey of individual preference for colorectal cancer screening technique. BMC Cancer. 2004 Nov 8;4:76.
35. Palmer RC, Midgette LA, Dankwa I. Colorectal cancer screening and African Americans: findings from a qualitative study. Cancer Control. 2008 Jan;15(1):72–9.
36. Patwardhan MB, Samsa GP, McCrory DC, et al. Cancer care quality measures: diagnosis and treatment of colorectal cancer. Evid Rep Technol Assess (Full Rep). 2006 May(138):1–116.
37. Peterson NB, Dwyer KA, Mulvaney SA, et al. The influence of health literacy on colorectal cancer screening knowledge, beliefs and behavior. J Natl Med Assoc. 2007 Oct;99(10):1105–12.
38. Prajapati DN, Saeian K, Binion DG, et al. Volume and yield of screening colonoscopy at a tertiary medical center after change in Medicare reimbursement. Am J Gastroenterol. 2003 Jan;98(1):194–9.
39. Rauscher GH, Johnson TP, Cho YI, et al. Accuracy of self-reported cancer-screening histories: a meta-analysis. Cancer Epidemiol Biomarkers Prev. 2008 Apr;17(4):748–57.
40. Reissman P, Durst AL. Splenic hematoma. A rare complication of colonoscopy. Surg Endosc. 1998 Feb;12(2):154–5.
41. Rex DK, Chadalawada V, Helper DJ. Wide angle colonoscopy with a prototype instrument: impact on miss rates and efficiency as determined by back-to-back colonoscopies. Am J Gastroenterol. 2003 Sep;98(9):2000–5.
42. Rodriguez SA, Ormseth E, Tsuchida A. Bowel perforation with the variable stiffness colonoscope. Gastrointest Endosc. 2003 Feb;57(2):271–3.
43. Sabatino SA, Habarta N, Baron RC, et al. Interventions to increase recommendation and delivery of screening for breast, cervical, and colorectal cancers by healthcare providers systematic reviews of provider assessment and feedback and provider incentives. Am J Prev Med. 2008 Jul;35(1 Suppl):S67–74.
44. Sarfaty M, Feng S. Uptake of colorectal cancer screening in an uninsured population. Prev Med. 2005 Sep–Oct;41(3–4):703–6.
45. Sarna L, Chang BL. Colon cancer screening among older women caregivers. Cancer Nurs. 2000 Apr;23(2):109–16.
46. Schroy PC, 3rd, Heeren TC. Patient perceptions of stool-based DNA testing for colorectal cancer screening. Am J Prev Med. 2005 Feb;28(2):208–14.
47. Subramanian S, Klosterman M, Amonkar MM, et al. Adherence with colorectal cancer screening guidelines: a review. Prev Med. 2004 May;38(5):536–50.
48. Taplin SH, Haggstrom D, Jacobs T, et al. Implementing colorectal cancer screening in community health centers: addressing cancer health disparities through a regional cancer collaborative. Med Care. 2008 Sep;46(9 Suppl 1):S74–83.
49. Wackerbarth SB, Tarasenko YN, Joyce JM, et al. Physician colorectal cancer screening recommendations: an examination based on informed decision making. Patient Educ Couns. 2007 Apr;66(1):43–50.
50. Zubarik R, Eisen G, Zubarik J, et al. Education improves colorectal cancer screening by flexible sigmoidoscopy in an inner city population. Am J Gastroenterol. 2000 Feb;95(2):509–12.

## Does not address/answer a Key Question

1. Adler GS, Shatto A. Screening for osteoporosis and colon cancer under Medicare. Health Care Financ Rev. 2002 Summer;23(4):189–200.
2. Ahlquist DA, Sargent DJ, Loprinzi CL, et al. Stool DNA and occult blood testing for screen detection of colorectal neoplasia. Ann Intern Med. 2008 Oct 7;149(7):441–50, W81.
3. Berger BM, Schroy PC, 3rd, Rosenberg JL, et al. Colorectal cancer screening using stool DNA analysis in clinical practice: early clinical experience with respect to patient acceptance and colonoscopic follow-up of abnormal tests. Clin Colorectal Cancer. 2006 Jan;5(5):338–43.
4. Blair SL, Sadler GR, Bristol R, et al. Early cancer detection among rural and urban Californians. BMC Public Health. 2006;6:194.
5. Brouse CH, Wolf RL, Basch CE. Facilitating factors for colorectal cancer screening. J Cancer Educ. 2008 Jan–Mar;23(1):26–31.
6. Cameron KA, Francis L, Wolf MS, et al. Investigating Hispanic/Latino perceptions about colorectal cancer screening: a community-based approach to effective message design. Patient Educ Couns. 2007 Oct;68(2):145–52.
7. Carlos RC, Fendrick AM, Abrahamse PH, et al. Colorectal cancer screening behavior in women attending screening mammography: longitudinal trends and predictors. Womens Health Issues. 2005 Nov–Dec;15(6):249–57.
8. Chiaverini L, Fulton JP, Darcy DM. Progress in the control of colorectal cancer in Rhode Island, 1987–2000. Med Health R I. 2002 Jul;85(7):226–8.
9. Chin M, Mendelson R, Edwards J, et al. Computed tomographic colonography: prevalence, nature, and clinical significance of extracolonic findings in a community screening program. Am J Gastroenterol. 2005 Dec;100(12):2771–6.
10. Chong A, Shah JN, Levine MS, et al. Diagnostic yield of barium enema examination after incomplete colonoscopy. Radiology. 2002 Jun;223(3):620–4.
11. Church JM. Warm water irrigation for dealing with spasm during colonoscopy: simple, inexpensive, and effective. Gastrointest Endosc. 2002 Nov;56(5):672–4.
12. Cibula DA, Morrow CB. Determining local colorectal cancer screening utilization patterns. J Public Health Manag Pract. 2003 Jul‐Aug;9(4):315–21.
13. Cram P, Fendrick AM, Inadomi J, et al. The impact of a celebrity promotional campaign on the use of colon cancer screening: the Katie Couric effect. Arch Intern Med. 2003 Jul 14;163(13):1601–5.
14. Deenadayalu VP, Chadalawada V, Rex DK. 170 degrees wide-angle colonoscope: effect on efficiency and miss rates. Am J Gastroenterol. 2004 Nov;99(11):2138–42.
15. Dickey W, Garrett D. Colonoscope length and procedure efficiency. Am J Gastroenterol. 2002 Jan;97(1):79–82.
16. DiPalma JA, Wolff BG, Meagher A, et al. Comparison of reduced volume versus four liters sulfate-free electrolyte lavage solutions for colonoscopy colon cleansing. Am J Gastroenterol. 2003 Oct;98(10):2187–91.
17. Doria-Rose VP, Levin TR, Selby JV, et al. The incidence of colorectal cancer following a negative screening sigmoidoscopy: implications for screening interval. Gastroenterology. 2004 Sep;127(3):714–22.
18. Dulai GS, Farmer MM, Ganz PA, et al. Primary care provider perceptions of barriers to and facilitators of colorectal cancer screening in a managed care setting. Cancer. 2004 May 1;100(9):1843–52.
19. Duncan JE, Sweeney WB, Trudel JL, et al. Colonoscopy in the elderly: low risk, low yield in asymptomatic patients. Dis Colon Rectum. 2006 May;49(5):646–51.
20. Etzioni DA, Yano EM, Rubenstein LV, et al. Measuring the quality of colorectal cancer screening: the importance of follow-up. Dis Colon Rectum. 2006 Jul;49(7):1002–10.
21. Farrar WD, Sawhney MS, Nelson DB, et al. Colorectal cancers found after a complete colonoscopy. Clin Gastroenterol Hepatol. 2006 Oct;4(10):1259–64.
22. Fatima H, Rex DK, Rothstein R, et al. Cecal insertion and withdrawal times with wide-angle versus standard colonoscopes: a randomized controlled trial. Clin Gastroenterol Hepatol. 2008 Jan;6(1):109–14.
23. Fincher RK, Myers J, McNear S, et al. Comfort and efficacy of a longer and thinner endoscope for average risk colon cancer screening. Dig Dis Sci. 2007 Oct;52(10):2892–6.
24. Gohagan JK, Prorok PC, Hayes RB, et al. The Prostate, Lung, Colorectal and Ovarian (PLCO) Cancer Screening Trial of the National Cancer Institute: history, organization, and status. Control Clin Trials. 2000 Dec;21(6 Suppl):251S–72S.
25. Gorin SS, Ashford AR, Lantigua R, et al. Intraurban influences on physician colorectal cancer screening practices. J Natl Med Assoc. 2007 Dec;99(12):1371–80.
26. Haas JS, Fitzmaurice G, Brawarsky P, et al. Association of regional variation in primary care physicians' colorectal cancer screening recommendations with individual use of colorectal cancer screening. Prev Chronic Dis. 2007 Oct;4(4):A90.
27. Harewood GC, Petersen BT, Ott BJ. Prospective assessment of the impact of feedback on colonoscopy performance. Aliment Pharmacol Ther. 2006 Jul 15;24(2):313–8.
28. Harrison M, Singh N, Rex DK. Impact of proximal colon retroflexion on adenoma miss rates. Am J Gastroenterol. 2004 Mar;99(3):519–22.
29. Huang EH, Whelan RL, Gleason NR, et al. Increased incidence of colorectal adenomas in follow-up evaluation of patients with newly diagnosed hyperplastic polyps. Surg Endosc. 2001 Jul;15(7):646–8.
30. Iafrate F, Hassan C, Zullo A, et al. CT colonography with reduced bowel preparation after incomplete colonoscopy in the elderly. Eur Radiol. 2008 Jul;18(7):1385–95.
31. Ikeda Y, Mori M, Miyazaki M, et al. Significance of small distal adenoma for detection of proximal neoplasms in the colorectum. Gastrointest Endosc. 2000 Sep;52(3):358–61.
32. Imperiale TF, Glowinski EA, Lin-Cooper C, et al. Five-year risk of colorectal neoplasia after negative screening colonoscopy. N Engl J Med. 2008 Sep 18;359(12):1218–24.
33. Imperiale TF, Wagner DR, Lin CY, et al. Using risk for advanced proximal colonic neoplasia to tailor endoscopic screening for colorectal cancer. Ann Intern Med. 2003 Dec 16;139(12):959–65.
34. Jain A, Falzarano J, Jain A, et al. Outcome of 5,000 flexible sigmoidoscopies done by nurse endoscopists for colorectal screening in asymptomatic patients. Hawaii Med J. 2002 Jun;61(6):118–20.
35. Jimbo M, Meyer B, Hyslop T, et al. Effectiveness of complete diagnostic examination in clinical practice settings. Cancer Detect Prev. 2006;30(6):545–51.
36. Jonas DE, Russell LB, Sandler RS, et al. Patient time requirements for screening colonoscopy. Am J Gastroenterol. 2007 Nov;102(11):2401–10.
37. Klabunde CN, Riley GF, Mandelson MT, et al. Health plan policies and programs for colorectal cancer screening: a national profile. Am J Manag Care. 2004 Apr;10(4):273–9.
38. Knox L, Hahn RG, Lane C. A comparison of unsedated colonoscopy and flexible sigmoidoscopy in the family medicine setting: an LA Net study. J Am Board Fam Med. 2007 Sep‐Oct;20(5):444–50.
39. Ko CW, Riffle S, Shapiro JA, et al. Incidence of minor complications and time lost from normal activities after screening or surveillance colonoscopy. Gastrointest Endosc. 2007 Apr;65(4):648–56.
40. Kutzner N, Hoffmann I, Linke C, et al. Non‐invasive detection of colorectal tumours by the combined application of molecular diagnosis and the faecal occult blood test. Cancer Lett. 2005 Nov 8;229(1):33–41.
41. Lafata JE, Williams LK, Ben-Menachem T, et al. Colorectal carcinoma screening procedure use among primary care patients. Cancer. 2005 Oct 1;104(7):1356–61.
42. Lagerholm S, Lagerholm S, Dutta S, et al. Non‐invasive detection of c-myc p64, c-myc p67 and c-erbb-2 in colorectal cancer. Scand J Gastroenterol. 2005 Nov;40(11):1343–50.
43. Laiyemo AO, Murphy G, Albert PS, et al. Postpolypectomy colonoscopy surveillance guidelines: predictive accuracy for advanced adenoma at 4 years. Ann Intern Med. 2008 Mar 18;148(6):419–26.
44. Lee SH, Chung IK, Kim SJ, et al. An adequate level of training for technical competence in screening and diagnostic colonoscopy: a prospective multicenter evaluation of the learning curve. Gastrointest Endosc. 2008 Apr;67(4):683–9.
45. Leung FW, Mann SK, Salera R, et al. Options for screening colonoscopy without sedation: sequel to a pilot study in U.S. veterans. Gastrointest Endosc. 2008 Apr;67(4):712–7.
46. Lev R, Healey J. Colon polyp registries and colorectal cancer control. Cancer Detect Prev. 1999;23(6):474–8.
47. Levine JS, Ahnen DJ. Clinical practice. Adenomatous polyps of the colon. N Engl J Med. 2006 Dec 14;355(24):2551–7.
48. Lewis JD, Asch DA, Ginsberg GG, et al. Primary care physicians' decisions to perform flexible sigmoidoscopy. J Gen Intern Med. 1999 May;14(5):297–302.
49. Lewis JD, Capra AM, Achacoso NS, et al. Medical therapy for diabetes is associated with increased use of lower endoscopy. Pharmacoepidemiol Drug Saf. 2007 Nov;16(11):1195–202.
50. Lieberman D, Moravec M, Holub J, et al. Polyp size and advanced histology in patients undergoing colonoscopy screening: implications for CT colonography. Gastroenterology. 2008 Oct;135(4):1100–5.
51. Lin OS, Kozarek RA, Schembre DB, et al. Risk stratification for colon neoplasia: screening strategies using colonoscopy and computerized tomographic colonography. Gastroenterology. 2006 Oct;131(4):1011–9.
52. Ling BS, Moskowitz MA, Wachs D, et al. Attitudes toward colorectal cancer screening tests. J Gen Intern Med. 2001 Dec;16(12):822–30.
53. Lipkus IM, Samsa GP, Dement J, et al. Accuracy of self-reports of fecal occult blood tests and test results among individuals in the carpentry trade. Prev Med. 2003 Nov;37(5):513–9.
54. Lurie JD, Welch HG. Diagnostic testing following fecal occult blood screening in the elderly. J Natl Cancer Inst. 1999 Oct 6;91(19):1641–6.
55. Menon U, Szalacha LA, Belue R, et al. Interactive, culturally sensitive education on colorectal cancer screening. Med Care. 2008 Sep;46(9 Suppl 1):S44–50.
56. Miller DP, Jr., Brownlee CD, McCoy TP, et al. The effect of health literacy on knowledge and receipt of colorectal cancer screening: a survey study. BMC Fam Pract. 2007;8:16.
57. Misra R, Vadaparampil ST. Personal cancer prevention and screening practices among Asian Indian physicians in the United States. Cancer Detect Prev. 2004;28(4):269–76.
58. Molina L, Carlos RC, Mark Fendrick A, et al. Completion of colorectal cancer screening in women attending screening mammography. Acad Radiol. 2004 Nov;11(11):1237–41.
59. Palmer RC, Emmons KM, Fletcher RH, et al. Familial risk and colorectal cancer screening health beliefs and attitudes in an insured population. Prev Med. 2007 Nov;45(5):336–41.
60. Ramakrishnan K, Scheid DC. Predictors of incomplete flexible sigmoidoscopy. J Am Board Fam Pract. 2003 Nov–Dec;16(6):478–84.
61. Robertson DJ, Greenberg ER, Beach M, et al. Colorectal cancer in patients under close colonoscopic surveillance. Gastroenterology. 2005 Jul;129(1):34–41.
62. Sansbury LB, Klabunde CN, Mysliwiec P, et al. Physicians' use of nonphysician healthcare providers for colorectal cancer screening. Am J Prev Med. 2003 Oct;25(3):179–86.
63. Sardinha TC, Nogueras JJ, Ehrenpreis ED, et al. Colonoscopy in octogenarians: a review of 428 cases. Int J Colorectal Dis. 1999 Aug;14(3):172–6.
64. Scheitel SM, Ahlquist DA, Wollan PC, et al. Colorectal cancer screening: a community case-control study of proctosigmoidoscopy, barium enema radiography, and fecal occult blood test efficacy. Mayo Clin Proc. 1999 Dec;74(12):1207–13.
65. Schoen RE, Weissfeld JL, Pinsky PF, et al. Yield of advanced adenoma and cancer based on polyp size detected at screening flexible sigmoidoscopy. Gastroenterology. 2006 Dec;131(6):1683–9.
66. Schoen RE, Weissfeld JL, Trauth JM, et al. A population-based, community estimate of total colon examination: the impact on compliance with screening for colorectal cancer. Am J Gastroenterol. 2002 Feb;97(2):446–51.
67. Schroy PC, 3rd, Lal S, Glick JT, et al. Patient preferences for colorectal cancer screening: how does stool DNA testing fare? Am J Manag Care. 2007 Jul;13(7):393–400.
68. Selby JV, Friedman GD, Quesenberry CP, et al. Ascertainment bias in case-control studies of cancer screening. J Clin Epidemiol. 2001 Feb;54(2):215–6.
69. Sharma VK, Komanduri S, Nayyar S, et al. An audit of the utility of in-patient fecal occult blood testing. Am J Gastroenterol. 2001 Apr;96(4):1256–60.
70. Shehadeh I, Rebala S, Kumar R, et al. Retrospective analysis of missed advanced adenomas on surveillance colonoscopy. Am J Gastroenterol. 2002 May;97(5):1143–7.
71. Simmons DT, Harewood GC, Baron TH, et al. Impact of endoscopist withdrawal speed on polyp yield: implications for optimal colonoscopy withdrawal time. Aliment Pharmacol Ther. 2006 Sep 15;24(6):965–71.
72. Simpson NK, Johnson CC, Ogden SL, et al. Recruitment strategies in the Prostate, Lung, Colorectal and Ovarian (PLCO) Cancer Screening Trial: the first six years. Control Clin Trials. 2000 Dec;21(6 Suppl):356S–78S.
73. Sporea I, Popescu A, Vernic C, et al. How to improve the performances in diagnostic colonoscopy? J Gastrointestin Liver Dis. 2007 Dec;16(4):363–7.
74. Stallings FL, Ford ME, Simpson NK, et al. Black participation in the Prostate, Lung, Colorectal and Ovarian (PLCO) Cancer Screening Trial. Control Clin Trials. 2000 Dec;21(6 Suppl):379S–89S.
75. Thrasher JF, Cummings KM, Michalek AM, et al. Colorectal cancer screening among individuals with and without a family history. J Public Health Manag Pract. 2002 Mar;8(2):1–9.
76. Ullah N, Qureshi K, Hatfield J, et al. Small early tubular adenomas and mixed colonic polyps found on screening flexible sigmoidoscopy do not predict proximal neoplasia in males. Clin Gastroenterol Hepatol. 2004 Mar;2(3):246–51.
77. Vadlamani A, Maher JF, Shaete M, et al. Colorectal cancer in Russian-speaking Jewish emigres: community-based screening. Am J Gastroenterol. 2001 Sep;96(9):2755–60.
78. Van Uitert RL, Summers RM, White JM, et al. Temporal and multiinstitutional quality assessment of CT colonography. AJR Am J Roentgenol. 2008 Nov;191(5):1503–8.
79. Walsh JM, Posner SF, Perez-Stable EJ. Colon cancer screening in the ambulatory setting. Prev Med. 2002 Sep;35(3):209–18.
80. Walsh JM, Terdiman JP. Colorectal cancer screening: scientific review. JAMA. 2003 Mar 12;289(10):1288–96.
81. Wexner SD, Forde KA, Sellers G, et al. How well can surgeons perform colonoscopy? Surg Endosc. 1998 Dec;12(12):1410–4.
82. Winawer SJ. Appropriate intervals for surveillance. Gastrointest Endosc. 1999 Mar;49(3 Pt 2):S63–6.
83. Wolf MS, Rademaker A, Bennett CL, et al. Development of a brief survey on colon cancer screening knowledge and attitudes among veterans. Prev Chronic Dis. 2005 Apr;2(2):A11.
84. Yee J, Akerkar GA, Hung RK, et al. Colorectal neoplasia: performance characteristics of CT colonography for detection in 300 patients. Radiology. 2001 Jun;219(3):685–92.
85. Young GP, Worthley DL. Screening with a fecal multitarget DNA test. Gastroenterology. 2005 Aug;129(2):757–9; discussion 9.
86. Zack DL, DiBaise JK, Quigley EM, et al. Colorectal cancer screening compliance by medicine residents: perceived and actual. Am J Gastroenterol. 2001 Oct;96(10):3004–8.

## Data collection started prior to 1/1/1998)

1. Screening for colorectal cancer--United States, 1997. MMWR Morb Mortal Wkly Rep. 1999 Feb 19;48(6):116–21.
2. Baier M, Calonge N, Cutter G, et al. Validity of self-reported colorectal cancer screening behavior. Cancer Epidemiol Biomarkers Prev. 2000 Feb;9(2):229–32.
3. Blair KA. Cancer screening of older women: a primary care issue. Cancer Pract. 1998 Jul‐Aug;6(4):217–22.
4. Borum ML. Does age influence screening for colorectal cancer? Age Ageing. 1998 Jul;27(4):509–11.
5. Borum ML. Colorectal cancer surveillance in African-American and white patients at an urban university medical center. J Natl Med Assoc. 1999 Sep;91(9):505–8.
6. Brenes GA, Paskett ED. Predictors of stage of adoption for colorectal cancer screening. Prev Med. 2000 Oct;31(4):410–6.
7. Brookhart MA, Patrick AR, Dormuth C, et al. Adherence to lipid-lowering therapy and the use of preventive health services: an investigation of the healthy user effect. Am J Epidemiol. 2007 Aug 1;166(3):348–54.
8. Farraye FA, Wong M, Hurwitz S, et al. Barriers to endoscopic colorectal cancer screening: are women different from men? Am J Gastroenterol. 2004 Feb;99(2):341–9.
9. Goldberg HI, Neighbor WE, Cheadle AD, et al. A controlled time-series trial of clinical reminders: using computerized firm systems to make quality improvement research a routine part of mainstream practice. Health Serv Res. 2000 Mar;34(7):1519–34.
10. Hoffman-Goetz L, Breen NL, Meissner H. The impact of social class on the use of cancer screening within three racial/ethnic groups in the United States. Ethn Dis. 1998 Winter;8(1):43–51.
11. Hsia J, Kemper E, Kiefe C, et al. The importance of health insurance as a determinant of cancer screening: evidence from the Women's Health Initiative. Prev Med. 2000 Sep;31(3):261–70.
12. Kinney AY, Bloor LE, Martin C, et al. Social ties and colorectal cancer screening among Blacks and Whites in North Carolina. Cancer Epidemiol Biomarkers Prev. 2005 Jan;14(1):182–9.
13. Ko CW, Kreuter W, Baldwin LM. Effect of Medicare coverage on use of invasive colorectal cancer screening tests. Arch Intern Med. 2002 Dec 9–23;162(22):2581–6.
14. Lewis JD, Ginsberg GG, Hoops TC, et al. Flexible sigmoidoscopy training and its impact on colorectal cancer screening by primary care physicians. Arch Fam Med. 2000 May;9(5):420–5.
15. Lipkus IM, Lyna PR, Rimer BK. Using tailored interventions to enhance smoking cessation among African-Americans at a community health center. Nicotine Tob Res. 1999 March 1, 1999;1(1):77–85.
16. Lipkus IM, Skinner CS, Dement J, et al. Increasing colorectal cancer screening among individuals in the carpentry trade: test of risk communication interventions. Prev Med. 2005 May;40(5):489–501.
17. Mandelson MT, Curry SJ, Anderson LA, et al. Colorectal cancer screening participation by older women. Am J Prev Med. 2000 Oct;19(3):149–54.
18. Mandelson MT, LaCroix AZ, Anderson LA, et al. Comparison of self-reported fecal occult blood testing with automated laboratory records among older women in a health maintenance organization. Am J Epidemiol. 1999 Sep 15;150(6):617–21.
19. Manfredi C, Czaja R, Freels S, et al. Prescribe for health. Improving cancer screening in physician practices serving low-income and minority populations. Arch Fam Med. 1998 Jul‐Aug;7(4):329–37.
20. Maxwell AE, Bastani R, Warda US. Demographic predictors of cancer screening among Filipino and Korean immigrants in the United States. Am J Prev Med. 2000 Jan;18(1):62–8.
21. McQueen A, Vernon SW, Myers RE, et al. Correlates and predictors of colorectal cancer screening among male automotive workers. Cancer Epidemiol Biomarkers Prev. 2007 Mar;16(3):500–9.
22. Miglioretti DL, Rutter CM, Bradford SC, et al. Improvement in the diagnostic evaluation of a positive fecal occult blood test in an integrated health care organization. Med Care. 2008 Sep;46(9 Suppl 1):S91–6.
23. Montano DE, Phillips WR, Kasprzyk D. Explaining physician rates of providing flexible sigmoidoscopy. Cancer Epidemiol Biomarkers Prev. 2000 Jul;9(7):665–9.
24. Myers RE, Turner B, Weinberg D, et al. Complete diagnostic evaluation in colorectal cancer screening: research design and baseline findings. Prev Med. 2001 Oct;33(4):249–60.
25. Myers RE, Turner B, Weinberg D, et al. Impact of a physician-oriented intervention on follow-up in colorectal cancer screening. Prev Med. 2004 Apr;38(4):375–81.
26. Pinsky PF, Schoen RE, Weissfeld JL, et al. Variability in flexible sigmoidoscopy performance among examiners in a screening trial. Clin Gastroenterol Hepatol. 2005 Aug;3(8):792–7.
27. Ponce NA, Huh S, Bastani R. Do HMO market level factors lead to racial/ethnic disparities in colorectal cancer screening? A comparison between high-risk Asian and Pacific Islander Americans and high-risk whites. Med Care. 2005 Nov;43(11):1101–8.
28. Powe BD, Weinrich S. An intervention to decrease cancer fatalism among rural elders. Oncol Nurs Forum. 1999 Apr;26(3):583–8.
29. Rimer BK, Conaway M, Lyna P, et al. The impact of tailored interventions on a community health center population. Patient Educ Couns. 1999 Jun;37(2):125–40.
30. Ruffin MTt, Gorenflo DW. Interventions fail to increase cancer screening rates in community-based primary care practices. Prev Med. 2004 Sep;39(3):435–40.
31. Shields HM, Weiner MS, Henry DR, et al. Factors that influence the decision to do an adequate evaluation of a patient with a positive stool for occult blood. Am J Gastroenterol. 2001 Jan;96(1):196–203.
32. Stamatakis KA, Simoes EJ, Brownson RC, et al. Factors associated with screening for colorectal cancer in a population-based sample. Mo Med. 2002 Jul;99(7):279–85.
33. Taplin S, Galvin MS, Payne T, et al. Putting population-based care into practice: real option or rhetoric? J Am Board Fam Pract. 1998 Mar‐Apr;11(2):116–26.
34. Thompson NJ, Boyko EJ, Dominitz JA, et al. A randomized controlled trial of a clinic-based support staff intervention to increase the rate of fecal occult blood test ordering. Prev Med. 2000 Mar;30(3):244–51.
35. Tilley BC, Vernon SW, Myers R, et al. The Next Step Trial: impact of a worksite colorectal cancer screening promotion program. Prev Med. 1999 Mar;28(3):276–83.
36. Wallace MB, Kemp JA, Meyer F, et al. Screening for colorectal cancer with flexible sigmoidoscopy by nonphysician endoscopists. Am J Med. 1999 Sep;107(3):214–8.
37. Weinrich SP, Weinrich MC, Atwood J, et al. Predictors of fecal occult blood screening among older socioeconomically disadvantaged Americans: a replication study. Patient Educ Couns. 1998 Jun;34(2):103–14.
38. Weissfeld JL, Ling BS, Schoen RE, et al. Adherence to repeat screening flexible sigmoidoscopy in the Prostate, Lung, Colorectal, and Ovarian (PLCO) Cancer Screening Trial. Cancer. 2002 May 15;94(10):2569–76.
39. Weissfeld JL, Schoen RE, Pinsky PF, et al. Flexible sigmoidoscopy in the PLCO cancer screening trial: results from the baseline screening examination of a randomized trial. J Natl Cancer Inst. 2005 Jul 6;97(13):989–97.
40. Williams RB, Boles M, Johnson RE. A patient-initiated system for preventive health care. A randomized trial in community-based primary care practices. Arch Fam Med. 1998 Jul‐Aug;7(4):338–45.

## Published too late for inclusion

1. Friedberg MW, Coltin KL, Safran DG, et al. Associations between structural capabilities of primary care practices and performance on selected quality measures. Ann Intern Med. 2009 Oct 6;151(7):456–63.