# Evidence Tables

## Acronyms

ACS: American Cancer Society
AHRQ: Agency for Healthcare Research and Quality
AOR: adjusted odds ratio
BRFSS: Behavioral Risk Factor Surveillance Survey
CAD: computer-aided detection
CAHPS: Consumer Assessment of Healthcare Providers and Systems
CCME: Carolina Center for Medical Excellence
CDC: Centers for Disease Control and Prevention
CHIS: California Health Interview Survey
CI: confidence interval
CONSORT: Consolidated Standards of Reporting Trials
CORI: Clinical Outcomes Research Initiative
CPT: current procedural terminology
CRC: colorectal cancer
CT: computed tomography
CTC: computed tomographic colonography
CTS: Community Tracking Study
DCBE: double contrast barium enema
DERS: Direct Endoscopic Referral System
DNA: deoxyribonucleic acid
DRE: digital rectal examination
FAP: familial adenomatous polyposis
FIT: fecal immunochemical test
FSS: fee-for-service
FFS + SUPP: fee-for-service Medicare + supplemental insurance
FIT: fecal immunochemical test
FOBT: fecal occult blood test
FS: flexible sigmoidoscopy
gFOBT: guaiac-based fecal occult blood test
G: group
GI: gastrointestinal
GI: gastroenterologist
HEDIS: Healthcare Effectiveness Data and Information Set
HINTS: Health Information National Trends Survey
HMO: health maintenance organization
HNPCC: hereditary nonpolylposis colorectal cancer
ICD: International Classification of Diseases
iFOBT: immunochemical fecal occult blood test
KQ: key question
LHA: lay health advisors
MCA: managed care activity
MCBS: Medicare Current Beneficiary Survey
MEPS: Medical Expenditure Panel Survey
MeSH: Medical Subject Heading
MMC: Medicare managed care
MMSA: metropolitan or micropolitan statistical areas
MR: magnetic resonance
MRI: magnetic resonance imaging
MSTF: Multi-Society Task Force
MSTF: Multi-Society Task Force
NCI: National Cancer Institute
NCQA: National Committee on Quality Assurance
NHIS: National Health Interview Survey
NIH: National Institutes of Health
N: number
NR: not reported
OMAR: Office of Medical Applications of Research
OR: odds ratio
PCP: primary care physician
PET: positron emission tomography
PHE: periodic health examination
PSA: prostate-specific antigen
PSAs: public service announcements
RCTs: randomized controlled trials
RDD: random digital dialing
RR: relative risk
RTC: Randomized Control Trial
RTI-UNC EPC: RTI International–University of North Carolina Evidence-based Practice Center
SES: socioeconomic status
SI: standard intervention
STROBE: STrengthening the Reporting of OBservational studies in Epidemiology
TEP: Technical Expert Panel
TFCPS: Task Force on Community Preventive Services
TI: tailored intervention
TIP: tailored intervention plus reminder phone call
US: United States
USPSTF: US Preventive Services Task Force
VA: Veterans Administration

Evidence Table 1 KQ 2: What factors influence the use of colorectal cancer screening

STUDY: | Authors, ref ID: Afable-Munsuz A, Liang SY, Ponce NA, Walsh JME.1 Year of publication: 2009 Dates of data collection: 2000–2005 Trial name: NA
OBJECTIVE OR AIM: | This study aimed to examine the relationships between acculturation and CRC screening among older Mexican, Puerto-Rican and Cuban adults.
DESIGN: | Setting: US Study design: Cross-sectional retrospective study Duration (mean followup): NA Overall study size (N enrolled/N analyzed): 38,347
| [underlined: Mexican] | | [underlined: Puerto Rican] | [underlined: Cuban] | [underlined: Black] | [underlined: White]
Sample size: | Sample Size: 2,304 | | Sample Size: 503 | Sample Size: 484 | Sample size: 4,803 | Sample size: 28,306
Describe intervention:
RECRUITMENT: (population-based, clinic-based, volunteer, other) | Population-based; this study used data from the 2000, 2003 and 2005 National Health Interview Survey (NHIS)
INCLUSION CRITERIA: | Latinos 50 years and older, never diagnosed with CRC, and who were surveyed in the 2000, 2003 and 2005 National Health Interview Survey (NHIS)
EXCLUSION CRITERIA: | NA
POPULATION CHARACTERISTICS: | [underlined: Mexican] | | [underlined: Puerto Rican] | | | [underlined: Cuban]
Mean age & range (years): | NR | | NR | | | NR
Sex (% female):
Race:
Other:
•Conducted interview in English only | 58% | | 60% | | | 25%
• Born in the U.S. | 56% | | 21% | | | 5%
| [underlined: Mexican] | | [underlined: Puerto Rican] | | | [underlined: Cuban]
Attrition/Drop-out (not available for endpoint measurement): | NA | | NA | | | NA
Adherence:
Contamination:
Response Rates (e.g. for surveys):
STATISTICAL ANALYSES: | Describe: • Authors examined bivariate and adjusted relationships between acculturation measures and all three CRC screening outcomes. • Authors used chi-square tests to examine unadjusted associations between nativity and language of interview and the three outcomes. • Using logistic regression, models containing nativity, language of interview and all covariates were estimated to assess the independent contributions of each on the three outcomes.
ASSESSMENT OF EXPOSURES AND POTENTIAL CONFOUNDERS: | • Authors also analyze key covariates, including demographic variables (age, sex) and socio-economic factors known as predisposing variables (income status, education), enabling factors or those related to health-care access (type of insurance and usual source of care) and health-care need factors (number of chronic diseases), which is a count variable ranging from 0 to 6, of whether the respondent reported having diabetes, hypertension, ulcer, arthritis, any cardiovascular disease and any respiratory illness.
OUTCOME ASSESSMENT: | Outcome Measures: • Authors measured acculturation with US nativity and language of interview, and examined three different CRC screening outcomes: fecal occult blood test (FOBT) in the past year, up-to-date endoscopy and any up-to-date CRC screening. • Three CRC screening outcomes, available in the NHIS, were investigated: (1) whether individuals had undergone FOBT in the past year, (2) whether individuals had received a sigmoidoscopy in the last 5 years or colonoscopy in the last 10 years and (3) whether individuals had received any up-to-date CRC screening (or met the criterion for no. 1 or 2).
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | Outcomes:
KQ2 - What factors influence the use of colorectal cancer screening? | | | FOBT in past year | | UTD endoscopy | Any UTD screening
KQ2 - What factors influence the use of colorectal cancer screening? | Mexico | | 10.9 | | 23.6 | 29.0
KQ2 - What factors influence the use of colorectal cancer screening? | Puerto Rico | | 13.9 | | 28.5 | 35.5
KQ2 - What factors influence the use of colorectal cancer screening? | Cuba | | 11.2 | | 30.6 | 36.8
KQ2 - What factors influence the use of colorectal cancer screening? | Non-Hispanic Black | | 14.6 | | 29.3 | 36.2
KQ2 - What factors influence the use of colorectal cancer screening? | Non-Hispanic White | | 16.8 | | 38.3 | 45.3
KQ2 - What factors influence the use of colorectal cancer screening? | Screening outcomes by nativity and language of interview Results suggest “differential relationships between acculturation and CRC screening by national origin”. Among Mexicans, the authors observed a positive relationship between US nativity and endoscopy and overall UTD status. Among Puerto Ricans, US nativity was associated with a lower likelihood of FOBT use. • Nativity and language of interview were not significant correlates of any up-to-date CRC screening among Puerto Ricans and Cubans. Mexicans born in the U.S. had higher odds of reporting any UTD screening. (OR=1.4, 95% CI 1.0–1.9) • Higher family income (95% CI: 200–399% FPL (1.3, 6.0) and a greater number of chronic conditions (95% CI: 1.3, 2.0) were significantly associated with a higher likelihood of any up-to-date CRC screening among Cubans. • For FOBT, the study’s acculturation measures were only significant among Puerto Ricans. • It is notable that higher educational level (some college 95% CI: 1.6, 5,5) and a greater number of chronic conditions (95% CI: 1.2, 1.6) were also significant and positively related to having received an FOBT in the past year among Puerto Ricans. • Among Mexicans, having a usual source of care (95% CI: 1.4, 3.5) and a greater number of chronic conditions (95% CI: 1.2, 1.4) were significant and positive correlates of FOBT in the past year. • Among Cubans, male gender (95% CI: 1.0, 2.5) was the only significant, positive correlate of the outcome. • English language was positively associated with FOBT in past year (AOR, 2.5; 95% CI, 1.1, 5.4) • US born among Mexicans was positively associated with endoscopy (AOR, 1.5; 95% 1.1, 2.2) and negatively associated with FOBT among Puerto Ricans (AOR, 0.3; 95% CI, 0.2, 0.7)
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | Outcomes: NA
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | NA
QUALITY RATING: | Good
Quality Assessment-Internal Validity for Observational Studies
| | Yes | | No | | Other (CD, NR, NA)
Were the groups similar at baseline regarding the most important prognostic indicators? | | | | | | NR
Were the drop-out or response rates acceptable (≤ 20%)? [If between 20% and 60%, check other and explain.] | | | | | | NA
Were the differential drop-out or response rates acceptable (≤ 15%)? | | | | | | NA
Were intervention/exposure measures valid, reliable, and equally applied? | | | | | | NA
Were the outcome assessors blinded to the intervention or exposure status of subjects? | | | | | | NA
Were outcome measures valid, reliable, and equally applied? | | X
Does the analysis control for baseline differences? | | X
Were important potential confounding and modifying variables taken into account in the design and analysis (e.g., through matching, stratification, or statistical adjustment)? | | X
Were the statistical methods used to assess the abstracted outcomes appropriate? | | X
Quality Rating (Good, Fair, or Poor): Good
STUDY: | Authors, ref ID: Ananthakrishnan, A.N., et al.2 Year of publication: 2007 Dates of data collection: 2002–2003 Trial name: NA
OBJECTIVE OR AIM: | To identify sex, age, socioeconomic, and racial/ethnic disparities in colon cancer screening practices in Medicare beneficiaries in Illinois, New York, and Florida since institution of the expanded coverage.
DESIGN: | Setting: Medicare claims data Study design: Cross-sectional retrospective Duration (mean followup): No follow-up Overall study size (N enrolled/N analyzed): 596,470
| [underlined: Florida] | | [underlined: Illinois] | | | [underlined: New York]
Sample size: | Sample size: 228,853 | | Sample size: 161,867 | | | Sample size: 205,750
Describe intervention: | No intervention, Medicare claims data | | No intervention, Medicare claims data | | | No intervention, Medicare claims data
RECRUITMENT: (population-based, clinic-based, volunteer, other) | Claims-based; Medicare physician/supplier file, which is derived from Medicare Part B claims for physician services, and the denominator file; a one-fifth sample of eligible subjects enrolled in both Parts A and B, exclusively receiving their care through the Medicare fee-for-service system in each of the 3 states of New York, Florida, and Illinois during 2002 and 2003, was identified.
INCLUSION CRITERIA: | Age 65+
EXCLUSION CRITERIA: | Individuals with a personal history of colon polyps (ICD-9 codes V12.72, 211.3, and 211.4), colon cancer (ICD-9 V10.05 and V10.06), or inflammatory bowel disease (ICD-9 555.x, 556.x, 558.2, and 558.9); subjects older than 90 years or with missing data on race/ethnicity or sex
POPULATION CHARACTERISTICS: | [underlined: Florida] | | [underlined: Illinois] | | | [underlined: New York]
Mean age & range (years): | Age: 27.4% 65–69, 27.8% 70–74, 23.4% 75–79, 21.5% 80+ | | Age: 28.1% 65–69, 27.4% 70–74, 22.9% 75–79, 21.7% 80+ | | | Age: 26.4% 65–69, 27.3% 70–74, 23.3% 75–79, 23% 80+
Sex (% female): | Sex: 58.2% female | | Sex: 60.8% female | | | Sex: 61.2% female
Race: | Race: 90.8% White, 5.4% Black, .5% Pacific Islander, .4% Asian, 2.9% Hispanic, .1% Native American | | Race: 90% White, 7.9% Black, .6% Pacific Islander, .6% Asian, .8% Hispanic, .1% Native American | | | Race: 87.6% White, 7.9% Black, 1.1% Pacific Islander, 1.1% Asian, 2.2% Hispanic, .1% Native American
Other:
Attrition/Drop-out (not available for endpoint measurement): | NA
Adherence:
Contamination:
Response Rates (e.g. for surveys):
STATISTICAL ANALYSES: | Describe: Authors calculated the percentages of patients who had undergone any colorectal cancer screening procedure, and for each individual test authors analyzed the screening practices by age group, sex, race/ethnicity, educational achievement, per capita income level, and state of residence using univariate analysis. All variables showing a significant association (P<.05) with the outcome were included in the final multivariate model to arrive at adjusted estimates. In addition, authors analyzed interactions between the demographic variables (age, sex, and race/ethnicity) and the socioeconomic markers (educational achievement and per capita income level) and between the various demographic variables. Interactions that were statistically significant (P<.05) were included in the final model.
ASSESSMENT OF EXPOSURES AND POTENTIAL CONFOUNDERS: | NR
OUTCOME ASSESSMENT: | Outcome Measures: Screening procedures were identified using the following Health Care Financing Administration Common Procedure Coding System and Current Procedural Terminology codes: colonoscopy (44388, 44389, 44392, 44393, 44394, 45378, 45380, 45383, 45384, 45385, G0105, and G0121), sigmoidoscopy (45300, 45305, 45308, 45309, 45315, 45320, 45330, 45331, 45333, 45338, 45339, and G0104), DCBE (74270, 74280, G0106, G0120, and G0122), and FOBT (G0107 and G0328). Authors considered the procedures to be screening tests if they were coded using the relevant Health Care Financing Administration Common Procedure Coding System codes or using the appropriate ICD-9 codes for screening (V76.51 and V76.51).
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | Outcomes: Overall screening for colon cancer varied by race/ethnicity, income level, and educational achievement but not by sex. An equal proportion (18.3%) of men and women had undergone a screening colon test. Blacks (9.7%) and Hispanics (8.1%) had lower rates of colon cancer screening compared with whites (19.3%). Individuals living in ZIP codes with a higher per capita income were more likely to undergo a colon screening test than were those living in ZIP codes with a lower per capita income (21.0% and 14.6% in the highest and lowest tertiles, respectively). Patients 80+ years were less likely to have received any CRC test than other age groups, regardless of income (RR range, 0.84–0.90). There was a significant interaction between age group and sex (P<.001) and between income level and sex (P<.05) for all screening tests and in an analysis restricted to screening colonoscopy alone. There was also a significant interaction between race/ethnicity and both sex and income level for screening colonoscopy (P<.05).
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | Outcomes: NR
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Outcomes: NR
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Outcomes: NR
QUALITY RATING: | Fair
Quality Assessment-Internal Validity for Observational Studies
| | Yes | | No | | Other (CD, NR, NA)
Were the groups similar at baseline regarding the most important prognostic indicators? | | X
Were the drop-out or response rates acceptable (≤ 20%)? [If between 20% and 60%, check other and explain.] | | | | | | NA
Were the differential drop-out or response rates acceptable (≤ 15%)? | | | | | | NA
Were intervention/exposure measures valid, reliable, and equally applied? | | | | | | NA
Were the outcome assessors blinded to the intervention or exposure status of subjects? | | | | | | NA
Were outcome measures valid, reliable, and equally applied? | | X
Does the analysis control for baseline differences? | | X
Were important potential confounding and modifying variables taken into account in the design and analysis (e.g., through matching, stratification, or statistical adjustment)? | | X
Were the statistical methods used to assess the abstracted outcomes appropriate? | | X
Quality Rating (Good, Fair, or Poor): Fair
STUDY: Colorectal cancer prevention: Adherence patterns and correlates of tests done for screening purposes within United States populations | Authors, ref ID: Ata et al.3 Year of publication: 2006 Dates of data collection: data from NHIS 2000 sample Trial name: data from NHIS used for this study
OBJECTIVE OR AIM: | In this study, they estimate the use of the tests recommended for CRC preventive screening using an outcome variable accounting for adherence to: (1) any combination of recommended tests (2) within their respective time guidelines and (3) done specifically for screening purposes. They also examine the effect of race/ethnicity, and other documented and potential predictors, on the test usage based upon our outcome variable. They also compare the influence of predictor variables between and within racial/ethnic groups with a goal of guiding screening adherence improvement strategies.
DESIGN: | Setting: United States, NHIS 2000 Study design: cross-sectional, modeling (kq2) Duration (mean follow-up): no follow-up data reported Overall study size (N enrolled/N analyzed):
Sample size: | sample of 12,498 people, representing an age-appropriate population of 72.3 million
Describe intervention: NA
RECRUITMENT: (population-based, clinic-based, volunteer, other) | Population based
INCLUSION CRITERIA: | The study included only those people who were 50 years or more in age.
EXCLUSION CRITERIA: | The study excluded people who reported ever having cancer of the colon or rectum.
POPULATION CHARACTERISTICS: | NR
Mean age & range (years):
Sex (% female):
Race:
Other:
Attrition/Drop-out (not available for endpoint measurement): | NA
Adherence:
Contamination:
Response Rates (e.g. for surveys): | Annual response rate of the NHIS is greater than 90% of the eligible households in the sample
STATISTICAL ANALYSES: | Descriptive statistics and a multiple logistic regression model with all the independent variables was used to estimate the odds of compliance for each of the predictor variables while controlling for the other variables.
ASSESSMENT OF EXPOSURES AND POTENTIAL CONFOUNDERS: | (a) socio-demographics: age, gender, marital status, education, annual family income, region, and size of metropolitan statistical area (MSA) of residence; (b) healthcare access and utilization: having health insurance, a usual source of healthcare, and time since last visit to a doctor; (c) health risk and health status: family history of any cancer, a personal history of other cancers and perceived health status; (d) behavioral/lifestyle: smoking, body mass index (BMI), and exercise.
OUTCOME ASSESSMENT: | (1) any combination of recommended tests (2) done within their respective time guidelines, and (3) specifically for screening purposes.
Results
KQ2 - What factors influence the use of colorectal cancer screening? | Hispanics less likely to be adherent for timescreening in unadjusted and adjusted models Table Comparison of multivariate adjusted OR’s and 95% CI for ‘time only’ and ‘time-screening’ adherence (NHIS 2000)
KQ2 - What factors influence the use of colorectal cancer screening? | Variable | | Adherent for time and purpose (n=9575)
KQ2 - What factors influence the use of colorectal cancer screening? | | | (%) | (CI for %) | OR | (CI or OR)
KQ2 - What factors influence the use of colorectal cancer screening? | Overall population | | 25.8 | (24.9, 26.7) | - | -
KQ2 - What factors influence the use of colorectal cancer screening? | Race
KQ2 - What factors influence the use of colorectal cancer screening? | Non-Hispanic White | | 27.3 | (26.3, 28.3) | 1.00 | Referent
KQ2 - What factors influence the use of colorectal cancer screening? | Hispanics | | 15.8 | (13.5, 18.5) | 0.73 | (0.58, 0.92)
KQ2 - What factors influence the use of colorectal cancer screening? | Non-Hispanic Black | | 22.7 | (20.1, 25.6) | 1.13 | (0.95, 1.35)
KQ2 - What factors influence the use of colorectal cancer screening? | Age (y)
KQ2 - What factors influence the use of colorectal cancer screening? | 50–54 | | 19.7 | (17.9, 21.7) | 1.00 | Referent
KQ2 - What factors influence the use of colorectal cancer screening? | 55–59 | | 25.6 | (23.3, 27.9) | 1.51 | (1.24, 1.84)
KQ2 - What factors influence the use of colorectal cancer screening? | 60–64 | | 26.7 | (24.4, 29.1) | 1.70 | (1.41, 2.05)
KQ2 - What factors influence the use of colorectal cancer screening? | 65–69 | | 30.9 | (28.5, 33.5) | 2.14 | (1.75, 2.62)
KQ2 - What factors influence the use of colorectal cancer screening? | 70–74 | | 30.5 | (27.9, 33.3) | 2.20 | (1.80, 2.70)
KQ2 - What factors influence the use of colorectal cancer screening? | >=75 | | 26.5 | (24.4, 28.6) | 2.08 | (1.70, 2.53)
KQ2 - What factors influence the use of colorectal cancer screening? | Gender
KQ2 - What factors influence the use of colorectal cancer screening? | Female | | 23.9 | (22.8, 25.1) | 1.00 | Referent
KQ2 - What factors influence the use of colorectal cancer screening? | Male | | 28.0 | (26.6, 29.5) | 1.16 | (1.03, 1.31)
KQ2 - What factors influence the use of colorectal cancer screening? | Marital status
KQ2 - What factors influence the use of colorectal cancer screening? | Married, living with spouse | | 28.7 | (27.4, 30.0) | 1.26 | (1.11, 1.44)
KQ2 - What factors influence the use of colorectal cancer screening? | Rest of population | | 20.9 | (19.8, 22.1) | 1.00 | Referent
KQ2 - What factors influence the use of colorectal cancer screening? | A usual place of health care
KQ2 - What factors influence the use of colorectal cancer screening? | No | | 9.5 | (7.5, 11.9) | 1.00 | Referent
KQ2 - What factors influence the use of colorectal cancer screening? | Yes | | 27.1 | (26.1, 28.1) | 1.61 | (1.17, 2.21)
KQ2 - What factors influence the use of colorectal cancer screening? | Time since last doctor visit
KQ2 - What factors influence the use of colorectal cancer screening? | <= 6 mos | | 28.9 | (27.8, 30.0) | 7.59 | (4.40, 13.10)
KQ2 - What factors influence the use of colorectal cancer screening? | > 6 mos – 1 yr | | 22.9 | (20.3, 25.8) | 5.86 | (3.33, 10.3)
KQ2 - What factors influence the use of colorectal cancer screening? | > 1–2 yrs | | 11.2 | (8.4, 14.7) | 2.76 | (1.48, 5.17)
KQ2 - What factors influence the use of colorectal cancer screening? | > 2 yrs | | 3.7 | (2.3, 5.9) | 1.00 | Referent
KQ2 - What factors influence the use of colorectal cancer screening? | Family h/o ca
KQ2 - What factors influence the use of colorectal cancer screening? | No | | 23.8 | (22.4, 25.3) | 1.00 | Referent
KQ2 - What factors influence the use of colorectal cancer screening? | Yes | | 30.6 | (29.3, 32.0) | 1.27 | (1.13, 1.43)
KQ2 - What factors influence the use of colorectal cancer screening? | h/o other cancer
KQ2 - What factors influence the use of colorectal cancer screening? | No | | 24.9 | (24.0, 25.9) | 1.00 | Referent
KQ2 - What factors influence the use of colorectal cancer screening? | Yes | | 32.3 | (29.6, 35.0) | 1.08 | (0.93, 1.25)
KQ2 - What factors influence the use of colorectal cancer screening? | Perceived health status
KQ2 - What factors influence the use of colorectal cancer screening? | Excellent | | 30.1 | (28.1, 32.1) | 1.00 | Referent
KQ2 - What factors influence the use of colorectal cancer screening? | Very good | | 27.7 | (26.1, 29.4) | 0.90 | (0.77, 1.04)
KQ2 - What factors influence the use of colorectal cancer screening? | Good | | 24.6 | (23.0, 26.3) | 0.83 | (0.70, 0.97)
KQ2 - What factors influence the use of colorectal cancer screening? | Fair | | 21.1 | (19.1, 23.4) | 0.77 | (0.63, 0.94)
KQ2 - What factors influence the use of colorectal cancer screening? | Poor | | 20.1 | (17.2, 23.3) | 0.73 | (0.56, 0.96)
KQ2 - What factors influence the use of colorectal cancer screening? | Smoking status
KQ2 - What factors influence the use of colorectal cancer screening? | Non-smoker | | 25.1 | (23.8, 26.5) | 1.00 | Referent
KQ2 - What factors influence the use of colorectal cancer screening? | Smoker | | 18.2 | (16.3, 20.3) | 0.89 | (0.73, 1.07)
KQ2 - What factors influence the use of colorectal cancer screening? | Quitter | | 30.9 | (29.3, 32.6) | 1.11 | (0.98, 1.27)
KQ2 - What factors influence the use of colorectal cancer screening? | BMI
KQ2 - What factors influence the use of colorectal cancer screening? | Underweight | | 17.6 | (13.3, 22.8) | 0.81 | (0.55, 1.19)
KQ2 - What factors influence the use of colorectal cancer screening? | Normal | | 25.5 | (24.0, 27.0) | 1.00 | Referent
KQ2 - What factors influence the use of colorectal cancer screening? | Overweight | | 27.6 | (26.1, 29.2) | 1.07 | (0.95, 1.21)
KQ2 - What factors influence the use of colorectal cancer screening? | Obese | | 26.6 | (24.7, 28.5) | 1.14 | (0.99, 1.32)
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and follow- up? | NA
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | NA
QUALITY RATING: | Good
Quality Assessment-Internal Validity for Observational Studies
| | Yes | | No | | Other (CD, NR, NA)
Were the groups similar at baseline regarding the most important prognostic indicators? | | | | | | NA
Were the drop-out or response rates acceptable (≤20%)? [If between 20% and 60%, check other and explain.] | | X | | | | As mentioned, response rate to NHIS > 90%
Were the differential drop-out or response rates acceptable (≤15%)? | | | | | | NA
Were intervention/exposure measures valid, reliable, and equally applied? | | X
Were the outcome assessors blinded to the intervention or exposure status of subjects? | | | | | | NA
Were outcome measures valid, reliable, and equally applied? | | X | | | | Self-report, so may overestimate screening. However, detailed questions about reasons for test make this less likely.
Does the analysis control for baseline differences? | | X
Were important potential confounding and modifying variables taken into account in the design and analysis (e.g., through matching, stratification, or statistical adjustment)? | | X
Were the statistical methods used to assess the abstracted outcomes appropriate? | | X
Quality Rating (Good, Fair, or Poor): Good
STUDY: | Authors, ref ID: Atlas4 Year of publication: 2009 Dates of data collection: 2003 to 2005 Trial name: NR
OBJECTIVE OR AIM: | To determine whether patient–physician connectedness affects measures of clinical performance
DESIGN: | Setting: Academic network of 4 community health centers and 9 hospital-affiliated primary care practices. Massachusetts General Hospital Primary Care Network Study design: Population-based retrospective cohort study Duration (mean followup): Overall study size (N enrolled/N analyzed): 155,590
| [underlined: Physician connected] | | [underlined: Practice connected] | | | [underlined: Unconnected]
Sample size (all patients): | 92,315 | | 53,669 | | | 9,606
Sample size (colorectal patients only): | 31,215 | | 6,453 | | | NA
Describe intervention: | NA
RECRUITMENT: (population-based, clinic-based, volunteer, other) | Clinic based
INCLUSION CRITERIA: | All patients with a visit to 1 of these practices from 1/1/03 to 12/31/05 using billing records.
EXCLUSION CRITERIA: | Younger than 18 years, had died, or were registered as having a PCP outside of the network. CRC screening measure included only patients age 52–69 without total colectomy.
POPULATION CHARACTERISTICS: | [underlined: Physician connected] | | [underlined: Practice connected] | | | [underlined: Unconnected]
Mean age & range (years): | 52 (SD 16.4) | | 39.9 (15.0) | | | 51.6 (15.1)
Sex (% female): | 58.1 | | 56.6 | | | 49.4
Race:
White | 81.2 | | 69.5 | | | 67.3
Hispanic | 7.0 | | 11.2 | | | 12.7
Black | 4.7 | | 6.5 | | | 6.4
Asian | 4.1 | | 5.6 | | | 3.8
Other | 1.8 | | 4.2 | | | 4.5
Attrition/Drop-out (not available for endpoint measurement): | NA
Adherence:
Contamination:
Response Rates (e.g. for surveys):
STATISTICAL ANALYSES: | To account for repeated measures of patients from the same physician, the authors used generalized estimating equations techniques with compound symmetry correlation structure. Because of the variability among practices, practice was included as a fixed effect in each model. The authors compared proportions of completed performance tests among physician-connected and practice- connected patients.
ASSESSMENT OF EXPOSURES AND POTENTIAL CONFOUNDERS: | A validated algorithm was used to connect patients to either 1 of 181 physicians or 1 of 13 practices in which they received most of their care. Patients were classified as “physician-connected”, “practice-connected”, or “unconnected”. Only patients in the first 2 groups were analyzed. The algorithm primarily uses the PCP designee field from the hospital registration system, combined with a logistic regression model that uses patient age, times since most recent visit, in state residency, and physician practice style (categorized as the proportion of all visits by patients registered ot he physician). Confounders included age, sex, race/ethnicity, insurance status, and number of visits over 3 years.
OUTCOME ASSESSMENT: | Outcome Measures: colonoscopy within 10 years; FS or BE within 5 years, home FOBT within 1 year for patients age 52–69 years
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | Adjusted rates of CRC screening rates: Physician connected patients: 72.1% (95% CI, 70.5–73.7) Practice connected patients: 58.0% (95% CI, 56.7–59.4) P < 0.001
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | NA
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | NA
QUALITY RATING: | Good
Quality Assessment-Internal Validity for Observational Studies
| | Yes | | No | | Other (CD, NR, NA)
Were the groups similar at baseline regarding the most important prognostic indicators?
Were the drop-out or response rates acceptable (≤20%)? [If between 20% and 60%, check other and explain.] | | | | | | NA
Were the differential drop-out or response rates acceptable (≤15%)? | | X | | | | NA
Were intervention/exposure measures valid, reliable, and equally applied? | | x
Were the outcome assessors blinded to the intervention or exposure status of subjects? | | | | | | NR
Were outcome measures valid, reliable, and equally applied? | | x
Does the analysis control for baseline differences? | | x
Were important potential confounding and modifying variables taken into account in the design and analysis (e.g., through matching, stratification, or statistical adjustment)? | | x
Were the statistical methods used to assess the abstracted outcomes appropriate? | | x
Quality Rating (Good, Fair, or Poor): Good
STUDY: | Authors, ref ID: Berkowitz, Z., et al.5 Year of publication: 2008 Dates of data collection: October 2002 to April 2003 Trial name: NA
OBJECTIVE OR AIM: | To assess beliefs and perceptions of risk about colorectal cancer (CRC) and gaps in knowledge about screening in adults aged 65 to 89.
DESIGN: | Setting: United States Study design: Cross-sectional retrospective Duration (mean followup): No follow-up Overall study size (N enrolled/N analyzed): 1,148
| All
Sample size: | Sample size: 1,148 (583 not up to date with screening)
Describe intervention: | Intervention: Telephone survey
RECRUITMENT: (population-based, clinic-based, volunteer, other) | Population-based
INCLUSION CRITERIA: | No history of CRC, adults aged 65 to 89
EXCLUSION CRITERIA: | NR
POPULATION CHARACTERISTICS: | [underlined: All]
Mean age & range (years): | Age range: 65–89
Sex (% female):
Race:
Other:
| [underlined: All]
Attrition/Drop-out (not available for endpoint measurement): | response rate for the screening phase of the study was 55% and for the interview phase was 62.8%, resulting in an overall response rate of 34.5%
Adherence:
Contamination:
Response Rates (e.g. for surveys):
STATISTICAL ANALYSES: | Describe: A separate logistic regression model for each covariate was used to calculate the odds ratios and P-values for being up to date with CRC screening, after adjusting for age groups. Multivariate logistic regression analysis was performed to determine the effect of demographic and healthcare characteristics, selected covariates of beliefs and risk perceptions, and knowledge about CRC screening on being up to date with screening.
ASSESSMENT OF EXPOSURES AND POTENTIAL CONFOUNDERS:
OUTCOME ASSESSMENT: | Outcome Measures: Whether a person had an FOBT in the past year or a colonoscopy/sigmoidoscopy in the past 10 years. Secondary Outcome: Reasons for Not Being Up to Date with Colorectal Cancer Screening According to Test Type and Age Group: Health Information National Trends Survey 2003
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | Outcomes: In the multivariate analysis, not being up to date with CRC screening was associated with being aged 65 to 74, not visiting a provider in the previous year, not being able to cite even one test to detect colon cancer, perceiving that arranging to check for colon cancer is difficult or not having an opinion about it, and not having an opinion about the cost of the test (P < 0.03 for each covariate). Older patients were more likely than younger patients to be up to date with CRC screening (AOR, 1.92; 95% CI, 1.32–2.79; P < 0.001) People who perceived their health to be excellent or very good were no more or less likely to be up-to-date with CRC screening than those who are in fair or poor health (P = 0.11) Respondents who believed that it is not easy to arrange to be tested (AOR, 0.47; 95% CI, 0.25–0.91) or that the tests Are too expensive (AOR, of disagreeing with test being too expensive = 1.25; 95% CI, 0.80–1.97); or had a lack of knowledge about the number of available tests (AOR, 0.28; 95% CI, 0.19–0.42) were less likely to report being screened (P values at 0.03 or better) Reasons for not being screened: No recommendation received for 65–74 year olds: FOBT: 87.5% (95% CI, 76.7–93.7%); FS/colonoscopy: 79.1% (95% CI, 69.3–86.4%) For those 75–89 years: FOBT: 84.4% (95% CI, 70.6–92.3%); FS/colonoscopy: 75.9% (95% CI, 64.1–86.2%)
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | Outcomes: NA
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Outcomes: NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Outcomes: NA
QUALITY RATING: | Fair
Quality Assessment-Internal Validity for Observational Studies
| | Yes | | No | | Other (CD, NR, NA)
Were the groups similar at baseline regarding the most important prognostic indicators? | | | | | | NA
Were the drop-out or response rates acceptable (≤20%)? [If between 20% and 60%, check other and explain.] | | | | | | Response rate for the screening phase of the study was 55% and for the interview phase was 62.8%, resulting in an overall response rate of 34.5%
Were the differential drop-out or response rates acceptable (≤15%)? | | | | | | NA
Were intervention/exposure measures valid, reliable, and equally applied? | | | | | | NA
Were the outcome assessors blinded to the intervention or exposure status of subjects? | | | | | | NA
Were outcome measures valid, reliable, and equally applied? | | X
Does the analysis control for baseline differences? | | X
Were important potential confounding and modifying variables taken into account in the design and analysis (e.g., through matching, stratification, or statistical adjustment)? | | X
Were the statistical methods used to assess the abstracted outcomes appropriate? | | X
Quality Rating (Good, Fair, or Poor): Fair
STUDY: | Authors, ref ID: Cardarelli, R., and Thomas, J.6 Year of publication: 2009 Dates of data collection: 2004 Trial name: NA
OBJECTIVE OR AIM: | To assess the relationship between having a personal health care provider and receiving colorectal cancer testing
DESIGN: | Setting: United States – 2004 Behavioral Risk Factor Surveillance System data Study design: secondary analysis of cross-sectional data Duration (mean followup): NA Overall study size (N enrolled/N analyzed): 144,897 analyzed in descriptive statistics, 120,221 analyzed in multiple regression models
Sample size: Describe intervention: | N = 144,897 (descriptive stats) N = 120, 221 (multiple regression models)
| NA
RECRUITMENT: (population-based, clinic-based, volunteer, other) | NA (secondary data analysis; however, the BRFSS participants are a random sample)
INCLUSION CRITERIA: | BRFSS includes civilian, noninstitutionalized adults (1 per household). The dataset in the current study only includes participants who are 50 years or older.
EXCLUSION CRITERIA: | NR (no maximum age selected)
| Variable | | 1 PHP N = 116,349 | >1 PHP n = 15,087 | No PHP n = 13,461 | Total n = 144,897
| Age, mean (SD), y | | 64.7 (10.5) | 66.2 (10.6) | 61.6 (9.9) | 4.6 (10.5)
| Female, % | | 55.8 | 54.3 | 43.6 | 54.5
| Non-Hispanic white | | 80.2 | 77.3 | 65.6 | 78.5
| Non-Hispanic African American | | 8.0 | 8.6 | 10.2 | 8.3
| Non-Hispanic Other | | 3.0 | 3.2 | 3.9 | 3.1
| Non-Hispanic multiracial | | 1.2 | 1.7 | 1.5 | 1.2
| Hispanic | | 7.6 | 9.1 | 18.8 | 8.8
| Education level, %
| Not graduate high school | | 12.4 | 15.2 | 21.8 | 13.5
| High school graduate or greater | | 87.6 | 84.8 | 78.2 | 86.5
| Income, %
| <$25,000 | | 30.6 | 35.7 | 47.2 | 32.7
| ≥$25,000 | | 69.4 | 64.3 | 52.8 | 67.3
| Health Insurance, %
| Yes | | 94.6 | 95.2 | 67.1 | 92.1
| No | | 5.4 | 4.8 | 32.9 | 7.9
| Up-to-date CRC testing, %
| Yes | | 59.3 | 62.5 | 26.9 | 56.6
| No | | 40.7 | 37.5 | 73.1 | 43.4
Attrition/Drop-out (not available for endpoint measurement): | BRFSS 2004 mean response rates = 52.7%
Adherence:
Contamination:
Response Rates (e.g. for surveys):
STATISTICAL ANALYSES: | Descriptive statistics calculated using weighted population percentages. χ2 statistics and analyses of variance tested for differences between having a personal health care provider and categorical and continuous variables. Univariate logistic regression analyses used to determine association between dependent and independent variables. Multiple logistic regression analysis used to control for potentially confounding covariates. Unadjusted and adjusted odds ratios and 95% confidence intervals calculated for the univariate and multiple logistic regression analyses, respectively. Tests for collinearity conducted, and no collinear relationships were identified in the final model.\
ASSESSMENT OF EXPOSURES AND POTENTIAL CONFOUNDERS: | Multiple logistic regression analysis was used to control for potentially confounding covariates. Covariates: age sex race/ethnicity education level annual household income level having health insurance
OUTCOME ASSESSMENT: | The outcome of interest was derived from responses to the CRC screening section of the BRFSS. Respondents asked 4 questions and were considered to be up-to-date if they had a FOBT within the previous year or had a sigmoidoscopy or colonoscopy within the previous 10 years. Responses dichotomized as either “testing up-to-date” or “testing not up-to-date.”
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | Having at least 1 personal health care provider significantly predicted up-to-date CRC testing in both the univariate (OR = 3.96; 95% CI 3.56–4.41) and multiple regression models (OR = 2.91; 95% CI 2.58–3.28). Age (OR = 1.04, 95% CI, 1.04–1.04), sex (female as referent group, OR = 1.13, 95% CI, 1.06–1.20), race/ethnicity, education (HS+ as referent group, OR = 0.72, 95% CI, 0.65–0.81), income ($25,000+ referent group, OR = 0.69, 95% CI, 0.64–0.74), and health insurance (No health insurance as referent group, OR = 1.84, 95% CI, 1.62–2.08) were also significantly associated with up-to-date CRC testing. Although covariates were significant predictors, having a personal health care provider had the highest odds of predicting being up-to-date for CRC testing.
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | NA
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | NA
QUALITY RATING: | Fair
Quality Assessment-Internal Validity for Observational Studies
| | Yes | | No | | Other (CD, NR, NA)
Were the groups similar at baseline regarding the most important prognostic indicators? | | | | | | NA
Were the drop-out or response rates acceptable (≤20%)? [If between 20% and 60%, check other and explain.] | | | | | | NA - The response rate for the overall BRFSS was 52.7% - but I chose NA because the current study is secondary analyses of the BRFSS data collected in 2004
Were the differential drop-out or response rates acceptable (≤15%)? | | | | | | NA
Were intervention/exposure measures valid, reliable, and equally applied? | | X
Were the outcome assessors blinded to the intervention or exposure status of subjects? | | | | | | NR
Were outcome measures valid, reliable, and equally applied? | | X
Does the analysis control for baseline differences? | | | | | | NA
Were important potential confounding and modifying variables taken into account in the design and analysis (e.g., through matching, stratification, or statistical adjustment)? | | X
Were the statistical methods used to assess the abstracted outcomes appropriate? | | X
Quality Rating (Good, Fair, or Poor): Fair
STUDY: | Authors, ref ID: Cairns and Viswanath et al.7 Year of publication: 2006 Dates of data collection: 2002–2003 Trial name: NR
OBJECTIVE OR AIM: | To examine the role of communication factors and insurance, with a specific focus on the uninsured to examine disparities in CRC screening.
DESIGN: | Setting: Subgroup analysis of HINTS (a random sample survey of cancer communication behaviors) Study design: Retrospective database analysis of HINTS Duration (mean follow-up): NR Overall study size (N enrolled/N analyzed): 1,253
Sample size: | 1,253
Describe intervention: | NA
RECRUITMENT: (population-based, clinic-based, volunteer, other) | Population-based
INCLUSION CRITERIA: | Age 50–64
EXCLUSION CRITERIA: | For “ever screened” for CRC (or screening status), respondents (a) who had CRC, and because not all respondents received all survey questions (b) those respondents who did not receive the CRC question set.
POPULATION CHARACTERISTICS: | NR
Mean age & range (years):
Sex (% female):
Race:
Other:
Attrition/Drop-out (not available for endpoint measurement): | NA
Adherence:
Contamination:
Response Rates (e.g. for surveys): | NR
STATISTICAL ANALYSES: | Describe: Survey was conducted by telephone using a list-assisted random-digit-dial sample.. African Americans and Hispanics were oversampled; therefore screening rates by demographic and health care access characteristics are presented using weighted data that adjusts for this oversampling. All other analyses used unweighted data, because the enormous sample sizes generated by weighting make it difficult to assess statistical significance in small subpopulation analyses, and create difficulty in modeling with logistic regression. All analyses were conducted using SPSS version 12.0. CRC screening status was examined by demographic variables (age, sex, race/ethnicity) and indicators of SES (education, income, employment status and residence in urban or rural counties) that have been identified in the literature as associated with screening behavior in particular and characteristics associated with health services and health access more generally. To provide background on screening rates within subpopulations in the sample, CRC screening status was examined by demographic variables and usual provider status using crosstabulations, chi-square tests, and Kendall’s tau-b correlation coefficients. Because age distributions were not normal, they compared age of the screened and never screened using the nonparametric Mann-Whitney test. To answer first research question (Is insurance status associated with CRC screening, both ever having been screened, and with regard to FOBT being on schedule and repeating screening?), examined CRC screening status by insurance status with a cross-tabulation, chi-square test, and a logistic regression model with insurance status (y/n) as the binomial independent predictor and screening status (ever screened = y/n) as the dependent variable. On schedule and repeat screening with FOBT were assessed for the overall sample and by insurance status. On schedule screening was based on the USPSTF recommended time interval of every year for FOBT; the proportion that received FOBT within the year before the survey (among those who received FOBT) was used to assess on schedule screening with FOBT. To assess whether being on schedule for this test was related to insurance status crosstabulations and chi-square tests were used. To assess repeat screening frequencies were produced of when (categorical time intervals) respondents received another FOBT before their most recent. For patterns in screening behavior, they authors produced cross-tabulations and chi-square tests for the timing of the most recent FOBT against the timing of another FOBT before the most recent, overall and by insurance status. To address the 2^nd^ research question (To what extent are communication factors such as attention to health in the media, experiences with providers and cancer information seeking related to CRC screening among the uninsured?), authors assessed the relationship between: media attention measures, information seeking, patient–provider interaction (CAHPS measures), and provider recommendation, and screening status among the uninsured by using cross-tabulations, chi-square tests, and Kendall’s tau-b correlation coefficients. To examine the 3rd research question (Is provider recommendation, another measure of communication, associated with screening among the uninsured?), and because the chi-square statistic was significant for provider recommendation, authors generated a logistic regression model with screening status for the uninsured as the dependent variable (ever screened = y/n) and provider recommendation as the independent variable (y/n). The other communication measures were not significant at the bivariate level, and were therefore excluded from the final model. To answer the 4^th^ research question (What are the reasons that deter the uninsured from undergoing CRC screening?), authors examined the reasons reported by the uninsured for not undergoing screening. For the uninsured never screened, they combined all reported reasons for not receiving any of the tests and determined which accounted for the largest proportion of identified barriers: lack of awareness, provider recommendation, no problems or symptoms, and insurance or cost.
ASSESSMENT OF EXPOSURES AND POTENTIAL CONFOUNDERS: | HINTS survey collected information on: demographic variables, access to health care, health status, health behaviors, knowledge of CRC screening guidelines, beliefs about cancer risk, beliefs about colorectal cancer test use, beliefs about cancer in general, “cancer worry”, “degree to which participants paid attention to any health or medical topics via television, radio, newspapers, magazines, or the Internet”, trust in information from these sources, trust in healthcare providers/family/friends for cancer information, cancer information seeking behavior For this study: Independent variables of interest for analysis: lack of insurance & communication Dependent variables: (a) ever screened, and for FOBT, (b) on schedule and repeat screening.
OUTCOME ASSESSMENT: | Outcome Measures: CRC screening
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | Outcomes: In the sample, 71.2% of respondents reported having undergone at least one kind of CRC screening Proportion of uninsured who have been screened lower than those who were insured (49% vs. 73%) Screening strongly associated with SES; screening rates increased as income and education increased and decreased as county of residence became more rural Whites (74.5%) were most likely to have been screened compared to African Americans (59.6%) and Hispanics (46.6%) Screening rates were higher among insured, and insurance status was a significant predictor in a simple logistic regression model, with the uninsured 64% (95% CI: 0.2451, 0.536) less likely to be screened than the insured No significant association between timing of most recent FOBT and insurance status, but a greater proportion of the uninsured had received only their first FOBT (no prior) compared to the insured More insured respondents repeated FOBT screening (2 consecutive tests), with a 10.7% point disparity between insured and uninsured There was no statistically significant relationship between any of the communication measures (attention to health in the media, cancer information seeking, and patient-provider interactions) and screening status No communication measures were significantly related to CRC screening status Almost 91% of the uninsured who have received provider recommendation have undergone screening vs. about 13% of those who did not receive a recommendation by their provider In a simple logistic regression model, this parameter was significant (P < 0.001) and the uninsured without a recommendation were 98.5% (95% CI: 0.003, 0.083) less likely to have ever received CRC screening than those who did This parameter was also significant (P < 0.001) when the model was run for the insured (n = 630), with the insured who did not receive a provider recommendation 92% (95% CI: 0.054, 0.119) less likely to have been screened for CRC Primary reasons reported by the uninsured never screened for not receiving all tests were lack of awareness (35%), lack of provider recommendation (19%), no problems/symptoms (9%), and financial barriers (3%); in 21%, no reason reported 36.1% of uninsured received a recommendation versus 62.5% for the insured
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and follow- up? | Outcomes: NA
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Outcomes: NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Outcomes: NA
QUALITY RATING: | Good
Quality Assessment-Internal Validity for Observational Studies
| | Yes | | No | | Other (CD, NR, NA)
Were the groups similar at baseline regarding the most important prognostic indicators? | | | | | | CD
Were the drop-out or response rates acceptable (≤20%)? [If between 20% and 60%, check other and explain.] | | | | | | NA
Were the differential drop-out or response rates acceptable (≤15%)? | | | | | | NA
Were intervention/exposure measures valid, reliable, and equally applied? | | | | | | NA
Were the outcome assessors blinded to the intervention or exposure status of subjects? | | | | X
Were outcome measures valid, reliable, and equally applied? | | X
Does the analysis control for baseline differences? | | X
Were important potential confounding and modifying variables taken into account in the design and analysis (e.g., through matching, stratification, or statistical adjustment)? | | X
Were the statistical methods used to assess the abstracted outcomes appropriate? | | X
Quality Rating (Good, Fair, or Poor): Good
STUDY: | Authors, ref ID: Carcaise-Edinboro et al.8 Year of publication: 2008 Dates of data collection: 2004 Trial name: NA
OBJECTIVE OR AIM: | The relationship between patient-provider communication and socioeconomic variables on the receipt of CRC screening using data from the Medical Expenditure Panel Survey.
DESIGN: | Setting: 2004 Medical Expenditure Panel Survey (MEPS) Study design: Cross-sectional Duration (mean follow-up): One-time data collection, no follow-up Overall study size (N enrolled/N analyzed): 8,488
| [underlined: All]
Sample size: | Sample size: 8,488
Describe intervention: | Intervention: 2004 Medical Expenditure Panel Survey (MEPS)
RECRUITMENT: (population-based, clinic-based, volunteer, other) | Population-based; 2004 Medical Expenditure Panel Survey (MEPS)
INCLUSION CRITERIA: | Age 50+
EXCLUSION CRITERIA: | NR
POPULATION CHARACTERISTICS: | [underlined: All]
Mean age & range (years): | NR
Sex (% female):
Race:
Other:
| [underlined: All]
Attrition/Drop-out (not available for endpoint measurement): | NR
Adherence:
Contamination:
Response Rates (e.g. for surveys):
STATISTICAL ANALYSES: | Describe: • Authors examined CRC screening status by patient-provider communication and demographic variables using cross tabulations and x2 tests. • Using logistic regression models, authors estimated the effects of the patients’ primary language and patient-provider communication on 3 CRC screening dependent variables.
ASSESSMENT OF EXPOSURES AND POTENTIAL CONFOUNDERS: | NR
OUTCOME ASSESSMENT: | Outcome Measures: Dependent measures were receipt of CRC screening, fecal occult blood testing, and colonoscopy or sigmoidoscopy.
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | Outcomes: • For the CAHPS patient-provider communication measures, a response of “sometimes,” “usually,” or “always” compared with the response of “never” for “adequate time with their healthcare provider” was positively and significantly associated with increased screening by all methods, with the exception of FOBT. • Patients who reported that their provider adequately explained patient healthcare needs as “sometimes,” “usually,” or “always,” relative to patients who reported their provider “never” adequately explained healthcare needs were significantly more likely to receive CRC screening by FOBT. “Adequate provider explanation of patients’ healthcare needs” was not independently significantly associated with other forms of CRC screening. • Race or ethnicity was not significantly associated with CRC screening in the final model. CRC screening by any method: • Subjects who reported that they sometimes, usually, or always have enough time with the provider were 2.61 (95% CI, 1.55–4.38) to 2.99 (95% CI, 1.83–4.88) times more likely than those who reported they never have enough time For FOBT: • Subjects who reported that their provider sometimes, usually, or always adequately explains information were 3.67 (95% CI, 1.16–1.6) to 6.42 (95% CI, 2.15–19.1) times more likely than those who reported provider never explains adequately. Logistic regression results for CRC, OR, 95% CI – controlled for age, living area, health status, insurance, income, language, source of care, race, ethnicity, sex:
KQ2 - What factors influence the use of colorectal cancer screening? | Independent variable | | | Screened with either c-scope/s-scope or fobt
KQ2 - What factors influence the use of colorectal cancer screening? | Enough time with provider
KQ2 - What factors influence the use of colorectal cancer screening? | Never | | | 1.0
KQ2 - What factors influence the use of colorectal cancer screening? | Sometimes | | | 2.61 (1.55–4.38)
KQ2 - What factors influence the use of colorectal cancer screening? | Usually | | | 2.99 (1.83–4.88)
KQ2 - What factors influence the use of colorectal cancer screening? | always | | | 2.65 (1.62–4.31)
KQ2 - What factors influence the use of colorectal cancer screening? | Provider adequately explains | | | Screened with fobt
KQ2 - What factors influence the use of colorectal cancer screening? | Never | | | 1.0
KQ2 - What factors influence the use of colorectal cancer screening? | Sometimes | | | 3.67 (1.16–11.6)
KQ2 - What factors influence the use of colorectal cancer screening? | Usually | | | 6.42 (2.16–19.1)
KQ2 - What factors influence the use of colorectal cancer screening? | Always | | | 6.09 (2.01–18.4)
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | Outcomes: NA
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Outcomes: NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Outcomes: NA
QUALITY RATING: | Fair
Quality Assessment-Internal Validity for Observational Studies
| | Yes | | No | | Other (CD, NR, NA)
Were the groups similar at baseline regarding the most important prognostic indicators? | | | | | | NA
Were the drop-out or response rates acceptable (≤20%)? [If between 20% and 60%, check other and explain.] | | | | | | NR
Were the differential drop-out or response rates acceptable (≤15%)? | | | | | | NA
Were intervention/exposure measures valid, reliable, and equally applied? | | | | | | NA
Were the outcome assessors blinded to the intervention or exposure status of subjects? | | | | | | NA
Were outcome measures valid, reliable, and equally applied? | | X
Does the analysis control for baseline differences? | | X
Were important potential confounding and modifying variables taken into account in the design and analysis (e.g., through matching, stratification, or statistical adjustment)? | | X
Were the statistical methods used to assess the abstracted outcomes appropriate? | | X
Quality Rating (Good, Fair, or Poor): Fair
STUDY: Can breast and cervical cancer screening visits be used to enhance colorectal cancer screening? | Authors, ref ID: Carlos et al.9 Year of publication: 2004 Dates of data collection: 2000 BRFSS data used Trial name: NA
OBJECTIVE OR AIM: | Data from the BRFSS were analyzed to identify potential relationships that would allow interventions to enhance colorectal cancer screening
DESIGN: | Setting: United States Study design: cross-sectional Duration (mean follow-up): no f/u data Overall study size (N enrolled/N analyzed): 2,788 women aged 50 or older participated in the 2000 BRFSS
| [underlined: All]
Sample size: | 1300 respondents, 1488 non-respondents
Describe intervention: | NA
RECRUITMENT: (population-based, clinic-based, volunteer, other) | Population based
INCLUSION CRITERIA: | Women 50 years of age or older who participated in the 2000 BRFSS survey and lived in 1 of 5 states that administered the colorectal cancer module (CO, IL, MA, OH, UT)
EXCLUSION CRITERIA: | NA
POPULATION CHARACTERISTICS:
Mean age & range (years): | Mean age: 64 years
Sex (% female): | Sex: 100% female
Race:
Other: | Table. Sociodemographic characteristics of women who did and did not respond to colon cancer screening questions
Other: | | | Respondents | | | Nonrespondents
Other: | Characteristic | | n (%) | | | n (%)
Other: | Number | | 1300 (46.6) | | | 1488 (53.4)
Other: | Age (y) | | 1300 | | | 1486
Other: | Mean (range) | | 64 (50–99) | | | 64 (50–97)
Other: | ≥50 to <60 | | 546 (42.0) | | | 632 (42.5)
Other: | ≥60 to <70 | | 366 (28.2) | | | 383 (25.8)
Other: | ≥70 to <80 | | 251 (19.3) | | | 307 (20.7)
Other: | ≥80 to <90 | | 121 (9.3) | | | 141 (9.5)
Other: | ≥90 | | 16(1.2) | | | 23 (1.5)
Other: | Race
Other: | Nonwhite and non-Hispanic | | 118(9.1) | | | 160 (10.8)
Other: | Income* | | 1058 | | | 1139
Other: | <$25,000 | | 396 (37.4) | | | 410 (36.0)
Other: | $25,000–$49,999 | | 385 (36.4) | | | 363 (32.9)
Other: | $50,000–$74,999 | | 149 (14.1) | | | 168 (14.7)
Other: | ≥$75,000 | | 128 (12.1) | | | 198 (17.4)
Other: | Educational level achieved’ | | 1298 | | | 1486
Other: | Attended elementary school or less | | 48 (3.5) | | | 74 (5.0)
Other: | Attended at least some high school | | 567 (43.7) | | | 593 (39.9)
Other: | Attended at least some college or technical school | | 686 (52.9) | | | 819 (55.1)
Other: | Employment status’ | | 1297 | | | 1486
Other: | Unemployed | | 40(3.1) | | | 29 (2.0)
Other: | Employed or self-employed | | 505 (38.9) | | | 651 (43.8)
Other: | Student or homemaker | | 171 (13.2) | | | 82 (5.5)
Other: | Retired | | 522 (40.2) | | | 629 (42.3)
Other: | Unable to work | | 59 (4.5) | | | 95 (6.4)
Other: | Have health insurance’ | | 1201 (92.4) | | | 1415 (95.1)
Other: | Cancer screening adherence
Other: | Colorectal cancer | | 324 (24.9)
Other: | Cervical cancer | | 743 (57.2) | | | 829 (55.7)
Other: | Breast cancer’ | | 1022 (78.6) | | | 1261 (84.7)
Other: | *Denotes a statistically significant difference p < 0.05.
Attrition/Drop-out (not available for endpoint measurement): | NA
Adherence:
Contamination:
Response Rates (e.g. for surveys): | 47% of women surveyed responded to colorectal cancer items!
STATISTICAL ANALYSES: | Adherence to the ACS recommendations for CRC screening was considered the primary outcome. Breast and cervical ca screening adherence used as independent predictors of crc screening adherence. First, univariate analysis evaluated using chi-square. Multivariate analysis subsequently performed.
ASSESSMENT OF EXPOSURES AND POTENTIAL CONFOUNDERS: | age, race, educational level, employment status, income, state of origin, health care coverage status obtained through telephone interview as part of fixed component of the BRFSS
OUTCOME ASSESSMENT: | Participants asked if they had ever had FOBT, s-scope, c-scope. Those who had undergone test were asked when their last test was performed Participants also asked about breast and cervical cancer screening
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | Correlates of colon cancer screening adherence
KQ2 - What factors influence the use of colorectal cancer screening? | Variable
KQ2 - What factors influence the use of colorectal cancer screening? | Demographics Age (y) | | Unadjusted OR (95% el) | | | Adjusted OR (95% el)
KQ2 - What factors influence the use of colorectal cancer screening? | ≥50 to <60 | | 0.50 (0.38–0.66)
KQ2 - What factors influence the use of colorectal cancer screening? | ≥60 to <70 | | 1.12 (0.85–1.48) | | | 1.81 (1.16–2.83)*
KQ2 - What factors influence the use of colorectal cancer screening? | ≥70 to <80 | | 2.04 (1.55–2.74) | | | 3.44 (1.73–6.87)*
KQ2 - What factors influence the use of colorectal cancer screening? | ≥80 to <90 | | 1.09 (0.72–’1.67) | | | 2.12 (0.95–4.74)
KQ2 - What factors influence the use of colorectal cancer screening? | ≥90 | | 1.82 (0.66–5.05) | | | 3.16 (0.68–14.7)
KQ2 - What factors influence the use of colorectal cancer screening? | Nonwhite and non-Hispanic | | 1.03 (0.67–1.59) | | | 0.93 (0.54–1.61)
KQ2 - What factors influence the use of colorectal cancer screening? | Income
KQ2 - What factors influence the use of colorectal cancer screening? | <$25,000 | | 1.06 (0.79–1.41)
KQ2 - What factors influence the use of colorectal cancer screening? | $25,000–$49,999 | | 1.09 (0.82–1.47) | | | 1.14 (0.79–1.66)
KQ2 - What factors influence the use of colorectal cancer screening? | $50,000–$74,999 | | 0.83 (0.54–1.26) | | | 1.12 (0.66–1.91)
KQ2 - What factors influence the use of colorectal cancer screening? | ≥ $75,000 | | 0.89 (0.57–1.39) | | | 1.21 (0.69–2.14)
KQ2 - What factors influence the use of colorectal cancer screening? | Educational level achieved
KQ2 - What factors influence the use of colorectal cancer screening? | Attended elementary school or less | | 1.70 (0.97–3.17)
KQ2 - What factors influence the use of colorectal cancer screening? | Attended at least some high school | | 1.09 (0.84–1.40) | | | 0.65 (0.29–1.45)
KQ2 - What factors influence the use of colorectal cancer screening? | Attended at least some college or technical school | | 0.88 (0.66–1.10) | | | 0.50 (0.22–1.14)
KQ2 - What factors influence the use of colorectal cancer screening? | Employment status
KQ2 - What factors influence the use of colorectal cancer screening? | Unemployed | | 0.87 (0.41–1.84)
KQ2 - What factors influence the use of colorectal cancer screening? | Employed or self-employed | | 0.60 (0.46–0.79)* | | | 0.63 (0.24–1.69)
KQ2 - What factors influence the use of colorectal cancer screening? | Student or homemaker | | 0.76 (0.50–1.17) | | | 0.50 (0.17–1.46)
KQ2 - What factors influence the use of colorectal cancer screening? | Retired | | 1.85 (1.44–2.39)* | | | 0.79 (0.28–2.20)
KQ2 - What factors influence the use of colorectal cancer screening? | Unable to work | | 1.02 (0.56–1.87) | | | 0.70 (0.21–2.28)
KQ2 - What factors influence the use of colorectal cancer screening? | Have health insurance | | 3.12 (1.60–6.07)* | | | 2.72 (1.23–6.01)*
KQ2 - What factors influence the use of colorectal cancer screening? | Adherence to non-colorectal cancer-related screening
KQ2 - What factors influence the use of colorectal cancer screening? | Adherent to Pap smear | | 0.59 (0.45–0.75)* | | | 2.09 (1.18–3.72)*
KQ2 - What factors influence the use of colorectal cancer screening? | Adherent to mammography | | 2.37 (1.65–3.41)* | | | 1.89 (1.21–2.92)*
KQ2 - What factors influence the use of colorectal cancer screening? | Note: OR = odds ratio; CI - confidence interval. P < 0.01.
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and follow- up? | Outcomes: NA
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Outcomes: NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | NA
QUALITY RATING: | Fair
Quality Assessment-Internal Validity for Observational Studies
| | Yes | | No | | Other (CD, NR, NA)
Were the groups similar at baseline regarding the most important prognostic indicators? | | X | | | | Responders, nonresponders similar
Were the drop-out or response rates acceptable (≤ 20%)? [If between 20% and 60%, check other and explain.] | | | | | | I don’t see the BRFSS response rate, but I think it was relatively low. Also, only 47% of women participating completed the CRC screening items
Were the differential drop-out or response rates acceptable (≤ 15%)? | | | | | | See above
Were intervention/exposure measures valid, reliable, and equally applied? | | X
Were the outcome assessors blinded to the intervention or exposure status of subjects? | | | | | | NA
Were outcome measures valid, reliable, and equally applied? | | X | | | | Self report, however
Does the analysis control for baseline differences? | | X
Were important potential confounding and modifying variables taken into account in the design and analysis (e.g., through matching, stratification, or statistical adjustment)? | | X
Were the statistical methods used to assess the abstracted outcomes appropriate? | | X
Quality Rating (Good, Fair, or Poor): Fair
STUDY: | Authors, ref ID: Carlos, R.C., et al.10 Year of publication: 2005 Dates of data collection: 2001 Trial name: NA
OBJECTIVE OR AIM: | To better understand screening behaviors among women, data from the Behavioral Risk Factors Surveillance Survey (BRFSS) were analyzed to identify potential relationships that would allow interventions to enhance CRC screening.
DESIGN: | Setting: U.S. Study design: Cross sectional, secondary data analysis Duration (mean followup): No follow-up, 2001 Overall study size (N enrolled/N analyzed): 52,478
| [underlined: All]
Sample size: | Sample size: 52,478
Describe intervention: | No intervention
RECRUITMENT: (population-based, clinic-based, volunteer, other) | Population-based; BRFFS
INCLUSION CRITERIA: | Women 50 years and older who participated in the BRFSS 2001 survey
EXCLUSION CRITERIA: | NR
POPULATION CHARACTERISTICS: | [underlined: All]
Mean age & range (years): | Mean age: 65 Age range: 50–99
Sex (% female): | 100% female
Race: | Race: 82% White, Non-Hispanic; 7% Black, non-Hispanic; 6% Hispanic, 1% Multiracial, non-Hispanic,
Other: | 3% Other
| [underlined: All]
Attrition/Drop-out (not available for endpoint measurement): | 97.6% responded to CRC screening items
Adherence:
Contamination:
Response Rates (e.g. for surveys):
STATISTICAL ANALYSES: | Describe: • Each potential variable was first screened for its association with cancer screening adherence. • The univariate analysis was evaluated using X^2^ test when the variables were categorical variables (e.g., employment status). • Multivariate analysis was subsequently performed using stepwise regression analysis.
ASSESSMENT OF EXPOSURES AND POTENTIAL CONFOUNDERS: | NR
OUTCOME ASSESSMENT: | Outcome Measures: Participants were asked if they had ever had a fecal occult blood test (FOBT), sigmoidoscopy, or colonoscopy. Considered the patient compliant if she had an FOBT within the past year or sigmoidoscopy or colonoscopy within the past 5 years.
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | Outcomes: Significant demographic factors associated with increased adherence to CRC screening included women 60–69 years old (unadjusted OR, 1.50; P < .01) and 70–79 years old (unadjusted OR, 1.39; P < .01) and being white non-Hispanic (unadjusted OR, 1.34; P < .01). As income and level of education achieved increased, the likelihood of CRC screening adherence increased (P < .01). Increased screening rates with females who reported adherence to mammograms (AOR, 2.42; P < 0.01) and Pap smears (AOR, 1.70; P < 0.01) Females who perceived their health as good were less likely to adhere to CRC screening than other females (AOR, 0.79; 95% CI, 0.66–0.93; P < 0.01) Women who were Hispanic or of other racial/ethnic descent were less likely to have undergone CRC screening (P < .01). Those women who were employed or self-employed were also less likely to have undergone CRC screening, compared with women who were retired (P < .01). Having health insurance (unadjusted OR, 2.70; P < .01) and the presence of a personal physician (unadjusted OR, 2.89; P < .01) significantly increased the probability of CRC screening. Being a current smoker (unadjusted OR, 0.58; P < .01) reduced the probability of CRC screening.
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | Outcomes: NA
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Outcomes: NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Outcomes: NA
QUALITY RATING: | Fair
Quality Assessment-Internal Validity for Observational Studies
| | Yes | | No | | Other (CD, NR, NA)
Were the groups similar at baseline regarding the most important prognostic indicators? | | | | | | NA
Were the drop-out or response rates acceptable (≤ 20%)? [If between 20% and 60%, check other and explain.] | | X
Were the differential drop-out or response rates acceptable (≤ 15%)? | | | | | | NA
Were intervention/exposure measures valid, reliable, and equally applied? | | | | | | NA
Were the outcome assessors blinded to the intervention or exposure status of subjects? | | | | | | NA
Were outcome measures valid, reliable, and equally applied? | | X | | | | Sigmoidoscopy and colonoscopy were grouped, so they used the 5-year window for both… this may underestimate those who had colonoscopies in the past 10 years
Does the analysis control for baseline differences? | | X
Were important potential confounding and modifying variables taken into account in the design and analysis (e.g., through matching, stratification, or statistical adjustment)? | | X
Were the statistical methods used to assess the abstracted outcomes appropriate? | | X
Quality Rating (Good, Fair, or Poor): Fair
STUDY: Colorectal cancer screening among a sample of community health center attendees | Authors, ref ID: Christman et al.11 Year of publication: 2004 Dates of data collection: 2002 Trial name:
OBJECTIVE OR AIM: | To determine the rate of colorectal cancer screening in patients attending a sample of community health centers, medical records of 1,176 patients from eight community health centers were abstracted.
DESIGN: | Setting: community health centers in FL Study design: cross-sectional, medical record abstraction Duration (mean follow-up): no f/u data Overall study size (N enrolled/N analyzed): 1,176 medical records from 8 CHC’s
| [underlined: Overall]
Sample size: | 1176
Describe intervention: | NA
RECRUITMENT: (population-based, clinic-based, volunteer, other) | Clinics were recruited from among the 16 CHCs participating in a county-funded health plan in Hillsborough County, Florida
INCLUSION CRITERIA: | Clinics were eligible if (1) they provided primary medical care 5 days a week, (2) the majority of the clinic staff agreed to participate, and (3) the clinic was expected to continue operating in the same fashion for the following 24 months A patient’s records were eligible to be abstracted if both of the following criteria were met: (1) the patient was 50–75 years of age and (2) the patient was established in the clinic (defined as having made at least one visit 12 months or more before the sampled visit)
EXCLUSION CRITERIA: | Refusal to participate, not open 5 days/week, uncertain if they would operate in a continuous fashion over the 2 year period of the grant
POPULATION CHARACTERISTICS: Mean age & range (years): Sex (% female): Race: Other: | Table. Clinical characteristics of study sample (n = 1176)
POPULATION CHARACTERISTICS: Mean age & range (years): Sex (% female): Race: Other: | Clinical characteristics | | n | | | %
POPULATION CHARACTERISTICS: Mean age & range (years): Sex (% female): Race: Other: | Gender
POPULATION CHARACTERISTICS: Mean age & range (years): Sex (% female): Race: Other: | Male | | 251 | | | 21.3
POPULATION CHARACTERISTICS: Mean age & range (years): Sex (% female): Race: Other: | Female | | 925 | | | 78.7
POPULATION CHARACTERISTICS: Mean age & range (years): Sex (% female): Race: Other: | Race/ethnicity African American | | 341 | | | 29
POPULATION CHARACTERISTICS: Mean age & range (years): Sex (% female): Race: Other: | White | | 569 | | | 48.4
POPULATION CHARACTERISTICS: Mean age & range (years): Sex (% female): Race: Other: | Hispanic | | 266 | | | 22.6
Attrition/Drop-out (not available for endpoint measurement): | NA
Adherence:
Contamination:
Response Rates (e.g. for surveys):
STATISTICAL ANALYSES: | The t-test and chi-square test, multivariate predictors of colorectal screening using multiple logistic regression. Logistic regression models examined the log odds of having obtained any one of the three colorectal screening tests within the recommended interval. All abstracted variables, including an indicator variable for primary care clinic attended, were eligible for inclusion in the final logistic regression model. The final logistic model consisted of those variables remaining statistically significant at the 0.05 level using a step-wise variable selection algorithm. For predictors of screening odds ratios and 95% confidence intervals. To determine the effects of gender-specific variables (such as estrogen replacement therapy or having had a PSA screening), logistic models separately by gender.
ASSESSMENT OF EXPOSURES AND POTENTIAL CONFOUNDERS: | Date of birth; Gender; Marital status; Race; Insurance status; Primary language; # of visits in the previous 12 months; # of chronic illnesses listed by physician in chart; chronic illness info for the Charlson Comorbidity Index; # of current medications; smoking status; whether pt had a health maintenance visit in the previous 12 months; personal/family h/o breast, cervical, or colorectal cancer screening For women only: h/o hysterectomy, h/o abnormal pap smears, h/o benign breast disease, taking estrogen replacement therapy
OUTCOME ASSESSMENT: | Evidence of the patient having undergone any colorectal screening tests within the recommended interval from the time of their audited visit.
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | Table. Logistic regression of colorectal cancer screening predictors (n = 1168)
KQ2 - What factors influence the use of colorectal cancer screening? | Patients screened for colorectal cancer
KQ2 - What factors influence the use of colorectal cancer screening? | Characteristic | | n | | % | P
KQ2 - What factors influence the use of colorectal cancer screening? | Gender | | | | | 0.09
KQ2 - What factors influence the use of colorectal cancer screening? | Male | | 98/251 | | 39
KQ2 - What factors influence the use of colorectal cancer screening? | Female | | 416/925 | | 45
KQ2 - What factors influence the use of colorectal cancer screening? | Race | | | | | 0.003
KQ2 - What factors influence the use of colorectal cancer screening? | White | | 228/569 | | 40.1
KQ2 - What factors influence the use of colorectal cancer screening? | African American | | 175/341 | | 51.3
KQ2 - What factors influence the use of colorectal cancer screening? | Hispanic | | 111/266 | | 41.7
KQ2 - What factors influence the use of colorectal cancer screening? | Marital status | | | | | 0.48
KQ2 - What factors influence the use of colorectal cancer screening? | Married | | 147/324 | | 45.4
KQ2 - What factors influence the use of colorectal cancer screening? | Unmarried | | 367/852 | | 43.1
KQ2 - What factors influence the use of colorectal cancer screening? | Primary language | | | | | 0.31
KQ2 - What factors influence the use of colorectal cancer screening? | English | | 414/931 | | 44.5
KQ2 - What factors influence the use of colorectal cancer screening? | Non-English | | 100/245 | | 40.8
KQ2 - What factors influence the use of colorectal cancer screening? | Smoking status | | | | | 0.4
KQ2 - What factors influence the use of colorectal cancer screening? | Smoker | | 137/328 | | 41.8
KQ2 - What factors influence the use of colorectal cancer screening? | Nonsmoker | | 377/848 | | 44.5
KQ2 - What factors influence the use of colorectal cancer screening? | Health insurance | | | | | 0.48
KQ2 - What factors influence the use of colorectal cancer screening? | County program | | 293/690 | | 42.5
KQ2 - What factors influence the use of colorectal cancer screening? | Medicaid | | 86/180 | | 47.8
KQ2 - What factors influence the use of colorectal cancer screening? | Medicare | | 104/228 | | 45.6
KQ2 - What factors influence the use of colorectal cancer screening? | Other | | 31/78 | | 39.7
KQ2 - What factors influence the use of colorectal cancer screening? | Family history of colorectal cancer | | | | | 0.008
KQ2 - What factors influence the use of colorectal cancer screening? | Yes | | 24/37 | | 64.9
KQ2 - What factors influence the use of colorectal cancer screening? | No | | 490/1,139 | | 43
KQ2 - What factors influence the use of colorectal cancer screening? | Checkup in past year | | | | | <0.0001
KQ2 - What factors influence the use of colorectal cancer screening? | Yes | | 326/627 | | 52
KQ2 - What factors influence the use of colorectal cancer screening? | No | | 188/549 | | 34.2
KQ2 - What factors influence the use of colorectal cancer screening? | Charlson comorbidity index score | | | | | 0.49
KQ2 - What factors influence the use of colorectal cancer screening? | 0 | | 185/423 | | 43.7
KQ2 - What factors influence the use of colorectal cancer screening? | 1 | | 130/275 | | 47.3
KQ2 - What factors influence the use of colorectal cancer screening? | 2 | | 113/266 | | 42.5
KQ2 - What factors influence the use of colorectal cancer screening? | 3+ | | 86/212 | | 40.6
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and follow- up? | Outcomes: NA
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Outcomes: NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Outcomes: NA
QUALITY RATING: | Good
Quality Assessment-Internal Validity for Observational Studies
| | Yes | | No | | Other (CD, NR, NA)
Were the groups similar at baseline regarding the most important prognostic indicators? | | | | | | NA
Were the drop-out or response rates acceptable (≤20%)? [If between 20% and 60%, check other and explain.] | | X
Were the differential drop-out or response rates acceptable (≤15%)? | | | | | | NA
Were intervention/exposure measures valid, reliable, and equally applied? | | X
Were the outcome assessors blinded to the intervention or exposure status of subjects? | | | | X
Were outcome measures valid, reliable, and equally applied? | | X
Does the analysis control for baseline differences? | | X
Were important potential confounding and modifying variables taken into account in the design and analysis (e.g., through matching, stratification, or statistical adjustment)? | | X
Were the statistical methods used to assess the abstracted outcomes appropriate? | | X
Quality Rating (Good, Fair, or Poor): Good
STUDY: | Authors, ref ID: Coughlin, S. and Thompson, T.12 Year of publication: 2005 Dates of data collection: 2000 Trial name: NA
OBJECTIVE OR AIM: | The objective was to determine the proportion of persons who had not received a provider recommendation to get a colorectal cancer screening test according to several characteristics related to socioeconomic status and access to health care.
DESIGN: | Setting: United States Study design: Cross-sectional (National Health Interview Survey) Duration (mean followup): One-year data collection Overall study size (N enrolled/N analyzed): 12,477/11,480
| [underlined: All]
Sample size: | Sample size: 11,480
Describe intervention: | Intervention: None, survey
RECRUITMENT: (population-based, clinic-based, volunteer, other) | Population-based
INCLUSION CRITERIA: | Men and women aged 50 years or older who did not have a history of colorectal cancer
EXCLUSION CRITERIA: | Among the persons who did not receive a recent colorectal cancer screening test, a small number of respondents (n = 14) were excluded whose race was neither White, African American, American Indian/Alaska Native, nor Asian/Pacific Islander. An additional 89 persons (for fecal occult blood test [FOBT]) or 62 per sons (for endoscopy) were excluded because they had missing information about reason for not having a recent test.
POPULATION CHARACTERISTICS:
Mean age & range (years): | NR
Sex (% female):
Race:
Other:
| [underlined: All]
Attrition/Drop-out (not available for endpoint measurement): | Overall response rate of 72.1%
Adherence:
Contamination:
Response Rates (e.g. for surveys):
STATISTICAL ANALYSES: | Describe: The descriptive analyses were stratified according to race and ethnicity. A multivariate analysis of predictors of a physician recommendation for each colorectal cancer test was carried out using logistic regression techniques
ASSESSMENT OF EXPOSURES AND POTENTIAL CONFOUNDERS: | NR
OUTCOME ASSESSMENT: | Outcome Measures: Each adult respondent was asked whether he or she had ever had a sigmoidoscopy, colonoscopy, or proctoscopy and, if so, when they had had their most recent test. For the purposes of this analysis, recent fecal occult blood test use was defined as within the past year and recent flexible sigmoidoscopy or colonoscopy use was defined as within the past 10 years. Lack of doctor recommendation for CRC exams among persons ≥ 50 yrs with no history of CRC, National Health Interview Survey, 2000
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | Outcomes: Among the men and women who had not had a recent FOBT, reported reasons for not having had one included “no reason/never thought about it” 51.4% (95% CI 50.0–52.9); “doctor didn’t order it” 22.9% (95% CI 21.7–24.1); “didn’t need it/didn’t know I needed this type of test” 12.3% (95% CI 11.4–13.3); “haven’t had any problems” 7.5% (95% CI 6.7–8.3); “put it off” 2.0% (95% CI 1.6–2.4); “too expensive/no insurance” 0.5% (95% CI 0.3–0.6); “too painful, unpleasant, or embarrassing” 0.3% (95% CI 0.2–0.5); and “don’t have doctor” 0.4% (95% CI 0.2–0.5). Among the men and women who had a doctor visit in the past year but who had not had a recent FOBT (n =8,039), about 94.6% (95% CI 94.0–95.2) reported that their doctor had not recommended the test in the past year. Among the persons who had not had a recent endoscopy, the reported reasons for not having had a sigmoidoscopy or colonoscopy included “no reason/never thought about it” 50.1% (95% CI 48.5–51.7); “doctor didn’t order it” 21.6% (95% CI 20.4–22.9); “didn’t need it/didn’t know I needed this type of test” 12.4% (95% CI 11.4–13.5); “haven’t had any problems” 9.9% (95% CI 8.9–10.9); “put it off” 1.7% (95% CI 1.4–2.1); “too expensive/no insurance” 1.0% (95% CI 0.8–1.3); “too painful, unpleasant, or embarrassing” 1.3% (95% CI 1.0–1.6); and “don’t have doctor” 0.4% (95% CI 0.3–0.6). Those persons with no insurance were much more likely to report “never thought about it,” “too expensive/no insurance,” and “don’t have doctor” as the reason for no endoscopy compared to those with health insurance. After adjustment for age, the factors associated with not receiving a doctor recommendation to get a FOBT in this same sample of men and women included the number of children in the household, having very good health status, having no activity limitations, fewer physician visits in the past year, and residence in the South or outside an MSA. Multivariate Regression: The factors that were positively associated with a doctor recommendation to get a FOBT included female sex, having activity limitations, living in an MSA, or residence outside of the southern United States. Doctor Didn’t Recommend FOBT: No., 8,039; %, 94.6; 95% CI, 94.0–95.2; Doctor Didn’t Recommend Endoscopy: No., 6,404; %, 93.5; 95% CI, 92.8–94.2; The results continue to describe differences in whether a physician recommendation was based on a number of additional factors. Sample includes persons who had a doctor visit in the past year but who had not had a home FOBT within the past year or endoscopy within the past 10 years.
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | Outcomes: NA
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Outcomes: NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Outcomes: NA
QUALITY RATING: | Fair
Quality Assessment-Internal Validity for Observational Studies
| | Yes | | No | | Other (CD, NR, NA)
Were the groups similar at baseline regarding the most important prognostic indicators? | | | | | | NA
Were the drop-out or response rates acceptable (≤20%)? [If between 20% and 60%, check other and explain.] | | | | | | Overall response rate of 72.1%
Were the differential drop-out or response rates acceptable (≤15%)? | | | | | | NA
Were intervention/exposure measures valid, reliable, and equally applied? | | | | | | NA
Were the outcome assessors blinded to the intervention or exposure status of subjects? | | | | | | NA
Were outcome measures valid, reliable, and equally applied? | | X
Does the analysis control for baseline differences? | | X
Were important potential confounding and modifying variables taken into account in the design and analysis (e.g., through matching, stratification, or statistical adjustment)? | | X
Were the statistical methods used to assess the abstracted outcomes appropriate? | | X
Quality Rating (Good, Fair, or Poor): Fair
STUDY: | Authors, ref ID: Diaz, J.A., Roberts, M.B., Goldman, R.E., Weitzen, S., Eaton, C.B.13 Year of publication: 2008 Dates of data collection: 2006 Trial name: NA
OBJECTIVE OR AIM: | To examine the relationship between preferred language use (English versus Spanish) and self-reported receipt of CRC screening tests among Latinos and non-Latinos.
DESIGN: | Setting: Data from the Centers for Disease Control’s 2006 Behavioral Risk Factor Surveillance System (BRFSS) Study design: Cross-sectional analysis Duration (mean followup): NA Overall study size (N enrolled/N analyzed): 99,895
| [underlined: Non-Latino responding-in-English] | | [underlined: Latino responding-in-English] | | | [underlined: Latino responding-in-Spanish]
Sample size: | Sample size: 94,346 | | Sample size: 3,660 | | | Sample size: 1,889
Describe intervention: | Responded to BRFFS | | Responded to BRFFS | | | Responded to BRFFS
RECRUITMENT: (population-based, clinic-based, volunteer, other) | Population-based
INCLUSION CRITERIA: | Adults at least age 50 years
EXCLUSION CRITERIA: | States that had data on fewer than 50 surveys completed in Spanish were excluded and U.S. territories were excluded
POPULATION CHARACTERISTICS: | [underlined: Non-Latino responding-in-English] | | [underlined: Latino responding-in-English] | | | [underlined: Latino responding-in-Spanish]
Mean age & range (years): | Mean age: 64.2 | | Mean age: 61.6 | | | Mean age: 61.3
Sex (% female): | Sex: 54.1% | | Sex: 55.6% | | | Sex: 54.1%
Race:
Other:
Attrition/Drop-out (not available for endpoint measurement): | NR
Adherence:
Contamination
Response Rates (e.g. for surveys):
STATISTICAL ANALYSES: | Describe: • Respondent characteristics were calculated using standard means for continuous variables and proportions/frequencies for categorical variables. • x2 tests were used to examine the relationships between the outcome of interest, receipt of CRC screening tests, and ethnicity/language category as well as each potential confounder. • Logistic regression was used to estimate crude odds ratios (OR) between the three ethnicity/language categories and the receipt of CRC screening tests and to calculate crude ORs between potential confounder variables and receipt of CRC screening tests. • Variables were considered to be confounders and, hence, included in a final multivariable logistic model, if the OR for the ethnicity/language variable adjusted for each potential confounder resulted in at least a 10% difference from the crude unadjusted OR.
ASSESSMENT OF EXPOSURES AND POTENTIAL CONFOUNDERS: | The presence of an identified health care provider, smoking status, and respondent’s perceived general health.
OUTCOME ASSESSMENT: | Outcome Measures: Respondents were considered to have been tested for CRC if they reported completing FOBT testing within the past 1 year or lower endoscopy within the past 10 years.
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | Outcomes: • There were no significant differences in reported test receipt among groups of non-Hispanic/Latino race/ethnicity subgroups • Overall, 61.6% of non-Latinos versus 43.6% of Latinos reported having received at least one screening test. • In the adjusted model, compared with non-Latinos, Latinos as a group were less likely to report having received CRC screening tests, either FOBT and/or lower endoscopy [adjusted OR, 0.74; 95% confidence interval (CI), 0.65–0.85]. • In the adjusted model, both Latinos responding-in-English (OR, 0.84; 95% CI, 0.73–0.98) and Latinos responding-in-Spanish (OR, 0.57; 95% CI, 0.44–0.74) were less likely to report receiving CRC screening tests compared with non-Latinos. • Latinos responding-in-Spanish were 36% less likely than Latinos responding-in-English to report having been screened (OR, 0.64; 95% CI, 0.48–0.84). • Among those with a health care provider and medical insurance, Latinos responding-in-English (OR, 0.83; 95% CI, 0.71–0.98) and Latinos responding in-Spanish (OR, 0.56; 95% CI, 0.41–0.75) were less likely to report test use compared with non-Latinos. • In the low SES strata, compared with non-Latinos, Latinos responding-in-English (OR, 0.70; 95% CI, 0.54–0.91) and Latinos responding in-Spanish (OR, 0.50; 95% CI, 0.39–0.65) were again less likely to report CRC test use. In the higher SES strata, although no longer statistically significant among Latinos responding-in-English (OR, 0.84; 95% CI, 0.70–1.0), Latinos responding-in-Spanish remained less likely to report screening compared with non-Latinos (OR,0.39; 95% CI, 0.24–0.64)
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | Outcomes: NA
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Outcomes: NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Outcomes: NA
QUALITY RATING: | Good
Quality Assessment-Internal Validity for Observational Studies
| | Yes | | No | | Other (CD, NR, NA)
Were the groups similar at baseline regarding the most important prognostic indicators? | | X
Were the drop-out or response rates acceptable (≤20%)? [If between 20% and 60%, check other and explain.] | | | | | | NR
Were the differential drop-out or response rates acceptable (≤15%)? | | | | | | NR
Were intervention/exposure measures valid, reliable, and equally applied? | | | | | | NA
Were the outcome assessors blinded to the intervention or exposure status of subjects? | | | | | | NA
Were outcome measures valid, reliable, and equally applied? | | X | | | | The 5-year flexible sigmoidoscopy was not included
Does the analysis control for baseline differences? | | X
Were important potential confounding and modifying variables taken into account in the design and analysis (e.g., through matching, stratification, or statistical adjustment)? | | X
Were the statistical methods used to assess the abstracted outcomes appropriate? | | X
Quality Rating (Good, Fair, or Poor): Good
STUDY: | Authors, ref ID: Etzioni, D., et al. 14 Year of publication: 2004 Dates of data collection: 2001 Trial name: NA
OBJECTIVE OR AIM: | The authors used the 2001 California Health Interview Survey (CHIS 2001) to evaluate 1) rates of CRC test use, 2) predictors of the receipt of tests, and 3) reasons for nonuse of CRC tests.
DESIGN: | Setting: California Study design: Cross-sectional study Duration (mean followup): One year Overall study size (N enrolled/N analyzed): 22,343
| [underlined: All]
Sample size: | Sample size: 22,343
Describe intervention: | Intervention: None, survey (CHIS)
RECRUITMENT: (population-based, clinic-based, volunteer, other) | Population-based, California (California Health Interview Survey)
INCLUSION CRITERIA: | Individuals age 50+ years without a personal history of CRC
EXCLUSION CRITERIA: | Respondents for whom receipt of a colorectal test could not be determined as a result of having responded “refused” or “don’t know” to questions concerning testing.
POPULATION CHARACTERISTICS | [underlined: All]
Mean age & range (years): | Age: 54.7% 50–64, 45.3% 65+
Sex (% female): | Sex: 59.9% Female
Race: | Race: 80.4% White, 6.4% Latino, 4.5% Asian, 4.7% African Americna, 2.6% Other, 1.5% American Indian/Alaska Native
Other:
| [underlined: All]
Attrition/Drop-out (not available for endpoint measurement): | NA
Adherence:
Contamination:
Response Rates (e.g. for surveys): | 63.7%
STATISTICAL ANALYSES | Describe: Weighted multivariate logistic regression was used to analyze each respondent’s likelihood of undergoing CRC testing. Two regression models were estimated, 1 for respondents ages 50–64 years and 1 for respondents age >65 years, to account for age-related differences in health insurance coverage.
ASSESSMENT OF EXPOSURES AND POTENTIAL CONFOUNDERS: | NR
OUTCOME ASSESSMENT: | Outcome Measures: Survey respondents were considered tested if an FOBT was performed in the 12 months prior to the interview or if either a flexible sigmoidoscopy or colonoscopy was performed within 5 years prior to the interview.
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | Outcomes: • Men in both age groups were more likely to be tested than women. This effect was greater in respondents ages 50–64 years (RR, 1.28; 95% CI, 1.23–1.32) than in respondents age > 65 years (RR, 1.19; 95% CI, 1.15–1.23). Among respondents age > 65 years, increasing age was associated positively with screening (RR for 5-year interval, 1.49; 95% CI, 1.43–1.57). • In respondents age > 65 years, this effect reversed direction—older respondents were less likely to be screened (RR for 5-year interval, 0.91; 95% CI, 0.88–0.94). • Among adults age ≥65 years, Latinos were the only racial/ethnic group that was significantly less likely than whites to have received recent testing (RR, 0.84; 95% CI, 0.77–0.92 for 50–64 yrs, RR, 0.62; 95% CI 0.37–0.92 for 65+ yrs). • Respondents living below the FPL were significantly less likely to be tested than the highest income group (RR, 0.81; 95% CI, 0.72–0.91). • Health insurance status was a significant predictor of likelihood of testing in both age groups. Uninsured individuals with a USOC, however, were much less likely to have received testing than individuals who had employer-based insurance with a USOC (RR, 0.61; 95% CI, 0.53–0.69). Uninsured with no USOC less likely to be screened than any of the other groups of individuals (RR 0.32; 95% CI 0.23–0.43 for 50–64; RR, 0.08; 95% CI, 0.00–1.21 for 65+). • Respondents who reported visiting a physician 1 or more times in past year were more likely to report being current with screening (RR range 1.41–1.77) • Among adults age ≥65 years, individuals with fair or poor health status were less likely to be tested than individuals with good, very good, or excellent health status (RR, 0.92; 95% CI, 0.88–0.96). • Individuals age > 65 years who were recent immigrants to the U.S. (0–50% of lifetime in the U.S.) were less likely to be tested than lifetime U.S. residents (RR, 0.86; 95% CI, 0.76–0.97). • Reported reasons for not having endoscopic testing differed by race and ethnicity. Asians and Latinos were significantly more likely than whites to report that they were not tested because of an absence of symptoms or perceived health problems (Asians, 31%; Latinos, 29%; whites, 16%; P < 0.001). The same groups were less likely than whites to report that they were not tested because the endoscopic examination was painful or embarrassing (Asians, 3%; Latinos, 3%; whites, 8%; P < 0.001) or because their physician did not tell them the test was needed (Asians, 21%; Latinos, 22%; whites, 28%; P < 0.001). • The reasons reported for not undergoing endoscopic examination also varied by gender. • The reasons identified for not having an FOBT were similar to the reasons for not undergoing endoscopic screening tests, with lack of physician recommendation the most common reason reported by all groups.
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | Outcomes: NA
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Outcomes: NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Outcomes: NA
QUALITY RATING: | Fair
Quality Assessment-Internal Validity for Observational Studies
| | Yes | | No | | Other (CD, NR, NA)
Were the groups similar at baseline regarding the most important prognostic indicators? | | | | | | NA
Were the drop-out or response rates acceptable (≤20%)? [If between 20% and 60%, check other and explain.] | | | | | | NR
Were the differential drop-out or response rates acceptable (≤15%)? | | | | | | NA
Were intervention/exposure measures valid, reliable, and equally applied? | | | | | | NA
Were the outcome assessors blinded to the intervention or exposure status of subjects? | | | | | | NA
Were outcome measures valid, reliable, and equally applied? | | X
Does the analysis control for baseline differences? | | X
Were important potential confounding and modifying variables taken into account in the design and analysis (e.g., through matching, stratification, or statistical adjustment)? | | X
Were the statistical methods used to assess the abstracted outcomes appropriate? | | X
Quality Rating (Good, Fair, or Poor): Fair
STUDY: | Authors, ref ID: Fenton, J.J., et al.15 Year of publication: 2007 Dates of data collection: 2002–2003 Trial name: NA
OBJECTIVE OR AIM: | Determine the association between receipt of a periodic health examination (PHE) and completion of cancer testing in enrollees in a prepaid health plan who were eligible for CRC, breast cancer, or prostate cancer screening
DESIGN: | Setting: Clinic Study design: Retrospective cohort study Duration (mean followup): No follow-up, compared 2000–2001 screening rates to those of 2002–2003. Overall study size (N enrolled/N analyzed): 64,288 patients
| [underlined: PHE] | | | | [underlined: No PHE]
Sample size: | Sample size: 33,708 | | | | Sample size: 30,580
Describe intervention: | Intervention: Received a periodic health examination between 2002–2003
RECRUITMENT: (population-based, clinic-based, volunteer, other) | Participants were enrolled in Group Health Cooperative, a mixed-model health plan that serves approximately 450 000 enrollees in Washington State.
INCLUSION CRITERIA: | Enrolled in Group Health Cooperative, 52 to 78 years on January 1, 2002, eligible for CRC, breast cancer, or prostate cancer screening in 2002–2003 based on health care data from previous enrollment years, no personal history of CRC, 1 or more primary care visits from 2002–2003
EXCLUSION CRITERIA: | Received no primary care visits during the study period; Sigmoidoscopy, colonoscopy, or barium enema, 1997–2001; Any positive fecal occult blood test results, 1997–2001; Known indications for surveillance colonoscopy, 1997–2001
POPULATION CHARACTERISTICS: | [underlined: PHE] | | | | [underlined: No PHE]
Mean age & range (years): | Age range: 52–78 | | | | Age range: 52–78
Sex (% female): | 60.1% female | | | | 47% female
Race:
Other:
| [underlined: Group 1]
Attrition/Drop-out (not available for endpoint measurement): | NA
Adherence:
Contamination:
Response Rates (e.g. for surveys): | NA
STATISTICAL ANALYSES: | Describe • Used multivariate logistic regression to estimate adjusted incidence differences and relative incidences of testing in patients who did and did not receive a PHE. • In adjusted models, authors set covariates to sample means to enable model-based equivalents to direct adjustment and estimated confidence intervals (CIs) using bootstrap procedures. • Modeled completion of testing as a function of PHE receipt while adjusting for age (5-year categories), sex (for CRC testing), comorbidity (Charlson comorbidity index score of 0, 1, 2, or >3), number of outpatient visits (quintiles), baseline PHE receipt, baseline number of target organ cancer tests (0, 1, or >2), benign prostatic hyperplasia diagnosis in 2000–2003 (for prostate cancer testing), and significant interactions between PHE receipt and covariates as identified by likelihood ratio tests (P < 0.05). • Used the models to estimate adjusted cancer testing incidences among participants who did and did not receive a PHE stratified by age, sex (for CRC testing), and the number of outpatient visits. • Of those who received a PHE, 57.2% received CRC testing vs. 17.2% of those who did not receive a PHE
ASSESSMENT OF EXPOSURES AND POTENTIAL CONFOUNDERS: | •“If patients often receive opportunistic prevention outside of preventive visits, one might expect the association between PHE receipt and cancer testing to weaken in patients with more outpatient visits.” •An association between the PHE and cancer screening could arise if patients schedule PHEs to request the desired screening.
OUTCOME ASSESSMENT: | Outcome Measures: • Completion of any colorectal cancer testing in 2002–2003 • A PHE was defined as any outpatient encounter in 2002–2003 having either (1) an evaluation and management code indicating “initial evaluation” (codes 99386–7) or “reevaluation and management of a healthy individual” (codes 99396–7) or (2) an International Classification of Diseases, Ninth Revision, Clinical Modification, code signifying either a general medical (code V700 or V708-9) or a gynecologic (code V723) examination.
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | Outcomes: • Of those received a PHE, 57.2% received CRC testing vs. 17.2% of those who did not receive a PHE. • The incidence of CRC testing was more than 3 times higher in patients who received PHEs than in those who did not (adjusted relative incidence, 3.47; 95% CI, 3.34–3.59; P < 0.001) • Stratified by the number of outpatient visits, there remained substantial differences in adjusted cancer testing incidences between patients who did and did not receive PHEs, even among those in the highest quintile of visits.
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | Outcomes: NA
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Outcomes: NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Outcomes: NA
QUALITY RATING: | Fair
Quality Assessment-Internal Validity for Observational Studies
| | Yes | | No | | Other (CD, NR, NA)
Were the groups similar at baseline regarding the most important prognostic indicators? | | | | | | Somewhat
Were the drop-out or response rates acceptable (≤20%)? [If between 20% and 60%, check other and explain.] | | | | | | NA
Were the differential drop-out or response rates acceptable (≤15%)? | | | | | | NA
Were intervention/exposure measures valid, reliable, and equally applied? | | X
Were the outcome assessors blinded to the intervention or exposure status of subjects? | | | | | | NR
Were outcome measures valid, reliable, and equally applied? | | X
Does the analysis control for baseline differences? | | | | X
Were important potential confounding and modifying variables taken into account in the design and analysis (e.g., through matching, stratification, or statistical adjustment)? | | X
Were the statistical methods used to assess the abstracted outcomes appropriate? | | X
Quality Rating (Good, Fair, or Poor): Fair
STUDY: | Authors, ref ID: Fenton et al.(#3677} Year of publication: 2009 Dates of data collection: 1995–2003 Trial name: Persistent Racial and Ethnic Disparities in Up–to-Date Colorectal Cancer Testing in Medicare Enrollees
OBJECTIVE OR AIM: | To assess whether greater colonoscopy use among white as compared with nonwhite Medicare enrollees since Medicare established coverage for colorectal cancer screening has been associated with a widening in white versus nonwhite disparities in up-to-date CRC testing status
DESIGN: | Setting: Medicare claims (Surveillance, Epidemiology, and End Results (SEER) regions in nine states, representing 14% of the US population Study design: cross-sectional (serial) Duration (mean follow up): NA Overall study size (N enrolled/N analyzed): 60,450
Sample size: Describe intervention: | Demographics from a single six-month sample (January 1, 2000 to June 30, 2000) N=60,450 Age 70 74 years 50.9% Age 75–79 years 49.1% Female 58.7% Male 41.3% White 85.8% (n=51,865) Black 6.7% (n=4,042) Asian/Pacific Islander 4.7% (n=2,845) Hispanic 2.8% (n=60,450) Intervention: NA
RECRUITMENT: (population-based, clinic-based, volunteer, other) | Groups were created every six months from July 1995 to December 2003 from the annual random 5% sample of Medicare enrollees in SEER regions; data were obtained from 12 registries in nine states.
INCLUSION CRITERIA: | Part A and Part B Medicare fee-for-service enrollees aged 70–79 years
EXCLUSION CRITERIA: | Age > 80 years; history of colon cancer (excluded only during the year of diagnosis and for subsequent years); “Native American,” “missing,” or “other” designation for race; Medicaid managed care enrollees
POPULATION CHARACTERISTICS: | NA
Mean age & range (years):
Sex (% female):
Race:
Other:
Attrition/Drop-out (not available for endpoint measurement): | Groups were identified every six months from July 1995 to December 2003. For each six-month period, more than 104,000 Medicare enrollees between the ages of 70–79 were considered for inclusion (range 104,906 to 109,002). For each six-month period, the number included in the analysis fell between 55.7% in late 2002 to 65% in late 1995.
Adherence:
Contamination:
Response Rates (e.g. for surveys):
STATISTICAL ANALYSES: | Describe: • Conditional prediction was used to estimate and compare race- and ethnicity-specific trends while adjusting for independent variables • To model binary outcome of up-to-date status, generalized estimating equations were used to perform repeated-measures logistic regression in which the referent group was whites during the first observation period. The model included indicator variables for each race and covariates, which were fixed at the mean values observed across the entire sample. • Two sensitivity analyses were conducted to assess the effect of alternate definitions of “up-to‐ date” status
ASSESSMENT OF EXPOSURES AND POTENTIAL CONFOUNDERS: | NA
OUTCOME ASSESSMENT: | Outcome Measures: Overall up-to-date status Up-to-date status per test method
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | Outcomes: • The percent of Medicare enrollees who were up to date with CRC testing increased significantly for all racial and ethnic categories from mid-1995 through 2003 • White vs. non-white differences persisted, but did not widen from late 1995 to late 2003. The difference in up-to-date status narrowed for each non-white group. The difference between whites and Hispanics did not change until late 2003 when it dropped from 15.7% to 14.1% • In each racial and ethnic group, the percentage of up-to-date by FOBT and the percentage of up-to‐ date by sigmoidoscopy declined from mid 1995 through 2003. • The percentage of up-to-date by colonoscopy increased during the study period. • Disparities in the overall up-to-date status changed little during the study period • Whites exhibited a greater decline in up-to-date status for FOBT and sigmoidoscopy than other racial and ethnic groups. Whites showed a greater increase in up-to-date status for colonoscopy than other racial/ethnic groups
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | NA
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | NA
QUALITY RATING: | Fair
Quality Assessment-Internal Validity for Observational Studies
| | Yes | | No | | Other (CD, NR, NA)
Were the groups similar at baseline regarding the most important prognostic indicators? | | | | | | NA
Were the drop-out or response rates acceptable (≤ 20%)? [If between 20% and 60%, check other and explain.] | | | | | | NA
Were the differential drop-out or response rates acceptable (≤ 15%)? | | | | | | NA
Were intervention/exposure measures valid, reliable, and equally applied? | | | | | | NA
Were the outcome assessors blinded to the intervention or exposure status of subjects? | | | | | | NA
Were outcome measures valid, reliable, and equally applied? | | X
Does the analysis control for baseline differences? | | X
Were important potential confounding and modifying variables taken into account in the design and analysis (e.g., through matching, stratification, or statistical adjustment)? | | X
Were the statistical methods used to assess the abstracted outcomes appropriate? | | X | | | | There is no statement regarding the statistical significance of the changes/differences reported in the results.
Quality Rating (Good, Fair, or Poor): Fair
STUDY: | Authors, ref ID: Ferrante et al.16 Year of publication: 2006 Dates of data collection: April 2003 – December 2004 Trial name: NA
OBJECTIVE OR AIM: | The objective of this study was to examine whether obesity is associated with lower rates of colorectal cancer screening among patients in primary care practices.
DESIGN: | Setting: 22 family medicine practices (20 group practices; 2 solo practices) located in New Jersey and eastern Pennsylvania Study design: Cross-sectional retrospective (medical record chart abstraction) Duration (mean follow-up): NA Overall study size (N enrolled/N analyzed): 1297 patients eligible for colorectal cancer screening from the total patient population of 2034.
| All
Sample size: | 1297
Describe intervention: | Colorectal cancer screening was documented by searching the medical record for any documentation of the tests being done including: progress reports, preventative flow sheets, lab tests, X-rays, and consultant reports. Patients were considered to have been screened according to guidelines (1=yes, 0=no) if they had documentation in the medical record of having received one of the following tests in the recommended time period based on recommendations from the American Cancer Society (ACS): (1) FOBT within 1 year, (2) sigmoidoscopy within 5 years, (3) colonoscopy within 10 years, or (4) double contrast barium enema within 5 years
RECRUITMENT: population-based, clinic-based, volunteer, other) | Clinic-based; Participating practices generated lists of patients seen in the office during the previous 12 months using ICD-9 codes for asthma, coronary heart disease, diabetes, hypertension, and any reason. Within each practice about 100 patients were randomly selected (20 from each list of patients, based on power calculation requirements for ULTRA (Using Learning Teams for Reflective Adaptation)). In practices where there were not 20 patients with a particular ICD-9 code, all patients with the code were used. For all patients, one nurse chart auditor from the research team noted the dates of relevant cancer screenings using a standardized abstraction form
INCLUSION CRITERIA: | Patients aged 50 years and over.
EXCLUSION CRITERIA: | Patients were excluded if they were deceased at the time of the audit, below 18 years of age or no longer a patient of the practice.
POPULATION CHARACTERISTICS: | [underlined: Group 1 (non-obese)] | | [underlined: Group 2 (obese)] | | | [underlined: Overall]
Mean age & range (years): | 68.71 (60.8%) | | 63.47 (39.2%) | | | 66.65 (100%)
Sex (% female): | 60% female | | 40% female | | | 49.3% female
Race: | NR | | NR | | | 80% White, 9% African-American, 3% Pacific Islander, 4% Hispanic, 8% Other
Other: | 70.9% colonoscopy, 25% FOBT, 11.1% sigmoidoscopy, 2.9% barium enema | | 75.2% colonoscopy, 16.8% FOBT, 13.1% sigmoidoscopy, 1.5% barium enema | | | 72.4% colonoscopy, 22.1% FOBT, 11.8% sigmoidoscopy, 2.4% barium enema 64% private insurance, 25% Medicare, 4% Medicaid, 7% uninsured
| [underlined: Group 1] | | [underlined: Group2] | | | Overall
Attrition/Drop-out (not available for endpoint measurement): | NA | | NA | | | NA
Adherence:
Contamination:
Response Rates (e.g. for surveys):
STATISTICAL ANALYSES: | Describe: • Obese and non-obese patients were compared with respect to potential confounding variables by calculating frequencies or means with standard deviations, depending on whether the variable was categorical or continuous, respectively, for each group of patients. • Significant differences between the two groups were determined by Chi square tests or t-tests. • Conducted bivariate analysis to assess the relationship between each of the independent variables with colorectal cancer screening. • Conducted multivariate analysis to control for potential confounders. • Hierarchical logistic regression was used to account for clustering of patients within practices to examine whether obesity status of the patient was associated with differences in CRC screening. • Controlled for effects of age, gender, number of visits in the last 2 years, number of co-morbidities and number of years attending the practice. • Generalized estimating equations were used for estimation, using an exchangeable correlation structure for the working correlation matrix. • Analyzed data separately for men and women to see if obesity-related screening rates differed by gender. • Computed adjusted odds ratios and 95% confidence intervals.
ASSESSMENT OF EXPOSURES AND POTENTIAL CONFOUNDER | • Controlled for effects of age, gender, number of visits in the last 2 years, number of co-morbidities and number of years attending the practice. • Did not have data on SES of patients but used health insurance as a crude indicator. The relatively homogenous population of predominately white suburban patients made it less likely that the associations found in this study would be confounded by SES.
OUTCOME ASSESSMENT: | Outcome Measures: Patients (obese and non-obese) were considered to have been screened according to guidelines (1=yes, 0=no) if they had documentation in the medical record of having received one of the following tests in the recommended time period based on recommendations from the American Cancer Society (ACS): (1) FOBT within 1 year, (2) sigmoidoscopy within 5 years, (3) colonoscopy within 10 years, or (4) double contrast barium enema within 5 years.
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | Outcomes: • 31% of non-obese patients were screened for CRC compared with 27% of obese patients (P = 0.12). • 34% of male patients were screened for CRC compared with 25% of female patients (P = 0.0010). • Patients who were screened for CRC had higher mean number of visits in the past 2 years compared with those who were not screened (P = 0.0179). • After controlling for age, gender, total number of comorbidities, number of visits in the past 2 years and number of years attending the practice, obese patients had 25% decreased odds of being screened for CRC compared to non-obese patients (AOR 0.75′ 95% CI, 0.62–0.91), P = 0.004. • Despite more frequent visits, obese patients were less likely to be screened for CRC. • After control for age, obesity, total number of co-morbidities, and number of visits in the past 2 years, men had 53% increased odds of receiving CRC screening compared to women (P = 0.001). • After adjusting for other covariates, each 1-unit increase in number of visits in the past 2 years was associated with a 4% increase in odds of receiving CRC screening (P = 0.006). • Stratified analysis showed no interaction with obesity and gender in CRC screening (P = 0.7922). • Odds of screening when obese versus non-obese for men and women were 0.73 (95% CI: 0.55, 0.97) and 0.77 (95% CI: 0.57, 1.05), respectively.
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and follow- up? | Outcomes: NA
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Outcomes: NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Outcomes: NA
QUALITY RATING: | Fair
Quality Assessment-Internal Validity for Observational Studies
| | Yes | | No | | Other (CD, NR, NA)
Were the groups similar at baseline regarding the most important prognostic indicators? | | | | | | NA
Were the drop-out or response rates acceptable (≤ 20%)? [If between 20% and 60%, check other and explain.] | | | | | | they reviewed 1297 or over 2000 eligible charts
Were the differential drop-out or response rates acceptable (≤ 15%)? | | | | | | NA
Were intervention/exposure measures valid, reliable, and equally applied? | | X
Were the outcome assessors blinded to the intervention or exposure status of subjects? | | | | X | | one nurse reviewed charts and was not blinded
Were outcome measures valid, reliable, and equally applied? | | X | | | | Patients (obese and non-obese) were considered to have been screened according to guidelines (1 = yes, 0 = no) if they had documentation in the medical record of having received one of the following tests in the recommended time period based on recommendations from the American Cancer Society (ACS): (1) FOBT within 1 year, (2) sigmoidoscopy within 5 years, (3) colonoscopy within 10 years, or (4) double contrast barium enema within 5 years
Does the analysis control for baseline differences? | | X
Were important potential confounding and modifying variables taken into account in the design and analysis (e.g., through matching, stratification, or statistical adjustment)? | | X
Were the statistical methods used to assess the abstracted outcomes appropriate? | | X
Quality Rating (Good, Fair, or Poor): Fair
STUDY: | Authors, ref ID: Fisher, D.A., et al.17 Year of publication: 2006 Dates of data collection: March 1, 2000 and February 28, 2001 Trial name: NA
OBJECTIVE OR AIM: | The primary aim of this study was to explore the factors associated with undergoing a full colon evaluation (FCE) for a positive fecal occult blood test (FOBT) in a single Veterans Affairs center. (of note, the sample size calculation, and primary question, was based on testing for a difference between subjects by race)
DESIGN: | Setting: Durham Veterans Affairs Medical Center (Durham, NC) Study design: Cross-sectional, retrospective medical record review of patients with + FOBT Duration (mean followup): 12 months Overall study size (N enrolled/N analyzed): 538
| [underlined: Overall]
Sample size: | Sample size: 538
Describe intervention: | NA (not an intervention study)
RECRUITMENT: (population-based, clinic-based, volunteer, other) | Clinic-based (Durham Veterans Affairs Medical Center (Durham, NC))
INCLUSION CRITERIA: | Had a positive FOBT that was ordered from a primary care clinic between March 1, 2000 and February 28, 2001 and if they were at least 50 years of age
EXCLUSION CRITERIA: | Patients who had undergone colonoscopy or DCBE within the prior 5 years and those who died within 12 months of the FOBT result date; are other than Caucasian or African American
POPULATION CHARACTERISTICS: | [underlined: Overall]
Mean age & range (years): | Mean Age: 67.2 (range NR)
Sex (% female): | Sex: 1.9% female
Race: | Race: 58% White, 28.6% Black, 13.4% Missing
Other:
Attrition/Drop-out (not available for endpoint measurement): | NA
Adherence:
Contamination:
Response Rates (e.g. for surveys): | NA
STATISTICAL ANALYSES: | Describe: • Descriptive statistics were computed for age, gender, race, marital status, appointment adherence, and referral to gastroenterology. • They conducted bivariate analyses of predictor variable with our primary outcome of FCE • For these unadjusted analyses, they used x2 tests (or exact tests) to examine differences by race, adherence, and referral to gastroenterology in the proportion of patients with FCE within 12 months. • A two-sample t test was used to examine differences in age between those who had a FCE and those that did not. • For the adjusted analysis they used logistic regression models to evaluate factors associated with FCE within 12 months. Factors were included in the logistic regression model if the bivariate association with FCE was significant (P < 0.05).
ASSESSMENT OF EXPOSURES AND POTENTIAL CONFOUNDERS: | Regressions included factors in the model if the bivariate association with FCE was significant (included race, referral for GI, and no show/cancel variables; did not include gender or marital status) SES, education, and whether subjects have other sources of care (besides the VA) were not included To avoid bias resulting from potential seasonal variation in patient evaluation (such as housestaff turnover), they evaluated the medical records of all patients over a 12-month consecutive period who met our inclusion criteria
OUTCOME ASSESSMENT: | Outcome Measures: • The primary outcome, full colon evaluation, was defined as having a colonoscopy or double-contrast barium enema plus flexible sigmoidoscopy completed within 12 months. • As a secondary outcome, FCE was defined as colonoscopy or DCBE alone.
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | Outcomes: • 77% of subjects were referred to gastroenterology • Ultimately, 44% underwent FCE within 12 months • In the unadjusted analysis, referral to gastroenterology consult was strongly associated with full colon evaluation (FCE) (P < 0.001). • 57% (237 of 415) of the subjects referred for gastroenterology consult underwent FCE within 12 months compared with 0% (0 of 123) of the subjects who were not referred for gastroenterology consult. • In both the unadjusted and adjusted analyses, adherence to follow-up appointments was associated with FCE (P < 0.001); adjusted OR for no show/cancel 0.06, 95% CI: 0.03, 0.13. • Although the subjects with missing race seemed less likely to undergo FCE than those with a recorded race data, they found no association between Blacks vs. Whites and performance of FCE (adjusted OR 1.14, 95% CI: 0.75, 1.75) • Blacks were as likely to receive full colon examination as whites (AOR, 1.14; 95% CI, 0.57–1.75)
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | Outcomes:
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Outcomes:
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Outcomes:
QUALITY RATING: | Fair
Quality Assessment-Internal Validity for Observational Studies
| | Yes | | No | | Other (CD, NR, NA)
Were the groups similar at baseline regarding the most important prognostic indicators? | | | | | | NA
Were the drop-out or response rates acceptable (≤ 20%)? [If between 20% and 60%, check other and explain.] | | | | | | NA
Were the differential drop-out or response rates acceptable (≤ 15%)? | | | | | | NA
Were intervention/exposure measures valid, reliable, and equally applied? | | X
Were the outcome assessors blinded to the intervention or exposure status of subjects? | | | | | | NR
Were outcome measures valid, reliable, and equally applied? | | X
Does the analysis control for baseline differences? | | X
Were important potential confounding and modifying variables taken into account in the design and analysis (e.g., through matching, stratification, or statistical adjustment)? | | X (some were) | | X | | Several were not considered: such as SES, education, and whether subjects have other sources of care
Were the statistical methods used to assess the abstracted outcomes appropriate? | | X
Quality Rating (Good, Fair, or Poor): Fair
STUDY: | Authors, ref ID: Fox et al.18 Year of publication: 2009 Dates of data collection: not reported Trial name: Cancer screening adherence: Does physician-patient communication matter?
OBJECTIVE OR AIM: | To examine the separate contributions of patients and physicians to their communication regarding cancer screening. To formulate a conceptual framework to explicate whether and how communication between physicians and their patients influenced patient behavior. To test the hypothesis that physician-patient communication regarding cancer screening promoted patient adherence to cancer screening recommendations.
DESIGN: | Setting: community-based primary care facilities Study design: cross-sectional survey Duration (mean follow up): NA Overall study size (N enrolled/N analyzed): after a phased identification and selection process, 63 physicians and 904 of their patients were surveyed
Sample size: | 63 physicians 904 patients
Describe intervention: | Intervention: NA
RECRUITMENT: population-based, clinic-based, volunteer, other) | Physicians: • Phase 1: 1,096 board certified physicians in general internal medicine, family practice, general practice, or obstetrics and gynecology were identified via professional and local telephone directories • Phase 2: All physicians identified in Phase 1 were sent a survey • Phase 3: A portion of survey respondents (n= 81) were randomly selected for a pilot study • Phase 4: Based on pilot study results, OB/GYN physicians were excluded from further participation along with the physicians who responded to the pilot study • Phase 5: A second screening survey was sent to the remaining physicians to obtain more detailed eligibility information • Phase 6 – The remaining physicians (207) were randomly assigned to one of ten “out of area” physicians who asked them to participate in the study. 63 physicians agreed to participate. Patients: • Phase 1: Participating physicians identified female patients between the ages of 50 – 80 years who had been seen by the physician in the past 3 months. (n = 3092) • Phase 2: Each patient received a letter from her physician that included information about the study and a passive consent form. (remaining n = 2103) • Phase 3: Patients were contacted by telephone to determine final eligibility and complete a survey. 904 patients were surveyed. Note: While the initial numbers are large, the final sample sizes are much smaller. It is possible that the participating physicians are a highly select group and may not generally represent their peers. Although, statistical methods were used to account for the distribution of physicians based on certain demographic characteristics, this does not account for other differences that might have influence. Also, physicians initially identified a group of their own patients who would be contacted to participate in the study. There is no description of the criteria the physicians used other than a time period. In the end, there is no explanation of the distribution of patients among the physicians and if any specific physicians have more patients enrolled in the study than other physicians. A clear description of the inclusion/exclusion criteria is not provided for either group. Statistical methods might limit any of these possible effects, but the authors do not provide a clear explanation in the methodology, so it is difficult to determine if they appropriately adjusted for these. There is one comment about using statistical methods to account for interclass correlation.
INCLUSION CRITERIA: | Physicians: board certified in general internal medicine, family practice, or general practice; returned a survey; agreed to participate; met “other eligibility criteria.” (detailed eligibility criteria were not reported) Patients: female; between the ages of 50 – 80 years; been seen by a physician in the past 3 months; passively consented to participate; met “other eligibility criteria,” completed a telephone survey. (detailed eligibility were not reported)
EXCLUSION CRITERIA: | Not described
POPULATION CHARACTERISTICS: | Participating female patients | | | Participating Physicians
Mean age & range (years): | Median age 64 years | | | Median age 49 years
Sex (% female): | Female 100% | | | Male 91%
Race: Other: | Race/Ethnicity • White: n= 603 (67%) • Asian/Pacific Islander: n= 41 (5%) • African American: n= 101 (11%) • Hispanic: n= 144 (16%) • Other: n=8 (1%)SES • Annual household income >$15,000: n=599 (72%) • Education: high school diploma or more: n= 725 (80%) Health Insurance HMO, IPA: n= 394 (45%) Other (PPO, Fee- for-service, MediCal, MediCare, other): n= 453 (51%) No insurance: n= 38 (4%) | | | Race/Ethnicity • White: n= 41 (65%) • Asian/Pacific Islander: n= 17 (27%) • African American: n= 2 (3%) • Hispanic: n= 1 (2%) • Other: n=2 (3%) Medical Specialty • Family Practice/Gen Med: n=35 (56%) • General Internal Med: n=28 (44%) Practice Setting • Private solo practice: n=35 (56%) • Private group practice: n= 27 (43%) • Public practice: n= 1 (2%)
Attrition/Drop-out (not available for endpoint measurement): | Physicians After initially identifying 1,096 physicians, the researchers ended up with 63 physicians after the final phase of selection and recruitment. The article states that this represents a 44% recruitment rate after accounting for the multi-phase process. | | | Patients After initially identifying 3,092 patients, the researchers ended up with 904 patients. The article states that this represents an estimated 51% recruitment rate across all phases.
Adherence: | | | | Patients After initially identifying 3,092 patients, the researchers ended up with 904 patients. The article states that this represents an estimated 51% recruitment rate across all phases.
Contamination: | | | | Patients After initially identifying 3,092 patients, the researchers ended up with 904 patients. The article states that this represents an estimated 51% recruitment rate across all phases.
Response Rates (e.g. for surveys): | | | | Patients After initially identifying 3,092 patients, the researchers ended up with 904 patients. The article states that this represents an estimated 51% recruitment rate across all phases.
STATISTICAL ANALYSES: | Describe: • Multilevel logistic regression using SAS GLIMMIX macro to model patient use of mammography and FOBT was used to account for the interclass correlation due to the hierarchical structure of the CMC data. • Sensitivity analyses performed to address issues of comparability for both models • Analyses controlled for a number of physician and patient characteristics
ASSESSMENT OF EXPOSURES AND POTENTIAL CONFOUNDERS: | See note above
OUTCOME ASSESSMENT: | Outcome Measures: (Excluding mammography related outcomes) • % of patients reporting some discussion with their physician about FOBT for CRC screening. • Perceived level of physician’s enthusiasm • % of patients who received FOBT
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | Outcomes: (Excluding mammography related outcomes) • 42% of patients reported some discussion with their physician about FOBT for CRC screening. • 20% of patients reported their physicians had a high level of enthusiasm about FOBT • 29% of patients received FOBT (compared to 81% receiving a mammography) Patients who perceived a low level of enthusiasm from provider were more likely to complete FOBT than those who reported no discussion (AOR, 6.426; P < 0.0001); no significant relationship to screening for patients who perceived high enthusiasm.
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | NA
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | NA
QUALITY RATING: | Fair
Quality Assessment-Internal Validity for Observational Studies
| | Yes | | No | | Other (CD, NR, NA)
Were the groups similar at baseline regarding the most important prognostic indicators? | | | | | | NA
Were the drop-out or response rates acceptable (≤20%)? [If between 20% and 60%, check other and explain.] | | | | | | See note above
Were the differential drop-out or response rates acceptable (≤15%)? | | | | | | See note above
Were intervention/exposure measures valid, reliable, and equally applied? | | | | | | CD
Were the outcome assessors blinded to the intervention or exposure status of subjects? | | | | | | NA
Were outcome measures valid, reliable, and equally applied? | | X
Does the analysis control for baseline differences? | | X
Were important potential confounding and modifying variables taken into account in the design and analysis (e.g., through matching, stratification, or statistical adjustment)? | | | | | | CD
Were the statistical methods used to assess the abstracted outcomes appropriate? | | | | | | CD
Quality Rating (Good, Fair, or Poor): Fair
STUDY: | Authors, ref ID: Garman et al.19 Year of publication: 2006 Dates of data collection: 2000-2001 Trial name: NR
OBJECTIVE OR AIM: | To examine the relationship between comorbid disease and performance of complete colon examination by colonoscopy or double contrast barium enema (DCBE) after positive screening FOBT in patients≥ 70 years of age.
DESIGN: | Setting: Single VA Center Study design: Retrospective medical record review Duration (mean follow-up): 12 months Overall study size (N enrolled/N analyzed): 266
Sample size: | 266
Describe intervention:
RECRUITMENT: (population-based, clinic-based, volunteer, other) | Clinic-based (VA)
INCLUSION CRITERIA: | ≥70 years, positive screening of FOBT, seen at Durham VA
EXCLUSION CRITERIA: | Patients were excluded if they had a FOBT performed for purposes other than screening or if they died within a 1‐year follow-up period.
POPULATION CHARACTERISTICS:
Mean age & range (years):
Sex (% female): | Mean Age: 75 (70 – 87); Sex (% female): 2%; White: 63%; Black: 24%
Race: White | Cardiovascular disease: 14%; Depression: 8%; Pulmonary disease: 24%
Other: Black
Attrition/Drop-out (not available for endpoint measurement): | NA
Adherence:
Contamination:
Response Rates (e.g. for surveys):
STATISTICAL ANALYSES: | Describe: For analysis, a Charlson score of 3 was used as a cut-off point, given the known high mortality in those with Charlson scores of 3 to 4.11; data on vision impairment, hearing impairment, hip fracture, and incontinence was also collected as these have been included in prior assessments of function in geriatric patients; a history of deep venous thrombosis and depression were also included, as they have been associated with worse outcomes for patients with CRC.
ASSESSMENT OF EXPOSURES AND POTENTIAL CONFOUNDERS: | Comorbidity (based on Charlson Comorbidity index)
OUTCOME ASSESSMENT: | Outcome Measures:
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | Outcomes: 193/266 (73%) referred for evaluation of positive FOBT 109 (41%) underwent a colonoscopy or DCBE w/i 12 months of +FOBTNo relationship between age and completion of full colon exam No association found between Charlson score and referral to gastroenterology for follow-up (P = 0.28) No association found between Charlson score and performance of complete colon exam (P = 0.38) No difference differences within comborbidty groups based on comorbidity Average time to full colon examination: 255 days
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and follow-up? | Outcomes: NA
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Outcomes: NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Outcomes: NA
QUALITY RATING: | Fair
Quality Assessment-Internal Validity for Observational Studies
| | Yes | | No | | Other (CD, NR, NA)
Were the groups similar at baseline regarding the most important prognostic indicators? | | | | | | NA
Were the drop-out or response rates acceptable (≤20%)? [If between 20% and 60%, check other and explain.] | | | | | | NA
Were the differential drop-out or response rates acceptable (≤15%)? | | | | | | NA
Were intervention/exposure measures valid, reliable, and equally applied? | | X
Were the outcome assessors blinded to the intervention or exposure status of subjects? | | | | X
Were outcome measures valid, reliable, and equally applied? | | X
Does the analysis control for baseline differences?
Were important potential confounding and modifying variables taken into account in the design and analysis (e.g., through matching, stratification, or statistical adjustment)? | | X
Were the statistical methods used to assess the abstracted outcomes appropriate? | | X
Quality Rating (Good, Fair, or Poor): Fair
STUDY: | Authors, ref ID: Gilbert, A., Kanarek, N.20 Year of publication: 2005 Dates of data collection: 2002 Trial name: NA
OBJECTIVE OR AIM: | The primary objective of this study was to determine the predictors of colorectal cancer screening use in Maryland.
DESIGN: | Setting: Telephone survey Study design: Secondary data analysis of cohort survey study Duration (mean followup): One-time data collection Overall study size (N enrolled/N analyzed): 2,994 respondents analyzed
| [underlined: 50-64 Years] | | | [underlined: 65+ Years]
Sample size: | Sample size: 1,730 | | | Sample size: 1,264
Describe intervention: | Intervention: None, survey | | | Intervention: None, survey
RECRUITMENT: (population-based, clinic-based, volunteer, other) | Population-based; Maryland Cancer Survey
INCLUSION CRITERIA: | English-speaking Marylanders age 40 and older residing in private residences
EXCLUSION CRITERIA: | Don’t know’ or ‘refused’ responses for most covariates
POPULATION CHARACTERISTICS: | [underlined: 50-64 Years] | | | [underlined: 65+ Years]
Mean age & range (years): | Sex: 50.83% female | | | Sex: 58.91% female
Sex (% female): | Race: 71.93% White, 22.32% Black, 5.75% Other | | | Race: 80.15% White, 16,56% Black, 3.29% Other
Race:
Other:
| [underlined: All]
Attrition/Drop-out (not available for endpoint measurement): | Response rate was 38.4%; completion rate was 65.4%
Adherence:
Contamination:
Response Rates (e.g. for surveys):
STATISTICAL ANALYSES: | Describe: In initial multivariate analyses, there was a significant interaction for age and health insurance. Thus, age groups were considered in separate models (50–64 years and 65+ years). Unweighted multiple logistic regression analysis was performed by age category (50–64 years and 65+ years) for (1) FOBT within the past year, (2) sigmoidoscopy within the past 5 years, (3) colonoscopy within the past 10 years, and (4) screening colonoscopy within the past 10 years.
ASSESSMENT OF EXPOSURES AND POTENTIAL CONFOUNDERS: | NR
OUTCOME ASSESSMENT: | Outcome Measures: CRC screening outcomes were defined as (1) FOBT within the past year, (2) sigmoidoscopy within the past 5 years, or (3) colonoscopy within the past 10 years.
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | Outcomes: Model results for persons aged 50–64 (FOBT) The only significant predictor of FOBT use was clinician recommendation for the test (OR = 36.89; 95% CI:27.06– 50.29; P < 0.001). Sigmoidoscopy use was significantly lower among Blacks when compared to Whites (OR = 0.57; 95% CI: 0.35–0.93; P = 0.026). Rural residents are less likely have had a timely sigmoidoscopy than urban residents (OR = 0.61; 95% CI: 0.42–0.88; P = 0.009). Persons in fair health are less likely to have had a timely sigmoidoscopy than those in excellent, very good, or good health (OR = 0.49; 95% CI: 0.27–0.89; P = 0.019). Current smokers are less likely to have had a timely sigmoidoscopy than non-smokers (OR = 0.39; 95% CI: 0.22–0.69; P = 0.001). Reporting a family history of CRC significantly increases the odds of colonoscopy use (OR = 2.56; 95% CI: 1.78– 3.68; P < 0.001). Independently, reporting having a clinician recommendation for the test raised the odds of colonoscopy by more than 30:1 (OR = 31.76; 95% CI: 21.14–47.73; P < 0.001). Usual source of care was also important and positively associated with colonoscopy use (OR = 2.83; 95% CI: 1.52– 5.27; P = 0.001). Women have decreased odds of screening colonoscopy use (OR = 0.66; 95% CI: 0.51–0.86; P = 0.002). Individuals of Black race or Hispanic ethnicity have increased odds of screening colonoscopy use (OR = 1.87; 95% CI: 1.34– 2.62; P < 0.001 and OR = 2.26; 95% CI: 1.05–4.88; P = 0.038, respectively). Those in annual income brackets of $25,000–49,999 and $75,000+ (compared to b$25,000) have increased odds of screening colonoscopy use (OR = 1.66; 95% CI: 1.01–2.73; P = 0.05 and OR = 1.81; 95% CI: 1.09–3.01; P = 0.02, respectively). Family history of CRC improves the odds of screening colonoscopy (OR = 2.71; 95% CI: 1.93–3.81; P < 0.001). Clinician recommendation significantly raised the odds of screening colonoscopy (OR = 18.26; 95% CI: 11.27–29.57; P < 0.001). Usual source of care was also positively associated with screening colonoscopy use (OR = 3.10; 95% CI: 1.41–6.83; P = 0.005). Model results for persons aged 65+ Blacks were more likely to have had a timely FOBT than Whites (OR = 2.20; 95% CI: 1.38–3.51; P = 0.001). Those with poor health status had almost 4 times the odds of FOBT use (OR = 3.75; 95% CI: 1.87–7.52; P < 0.001). Those who reported a clinician recommendation for FOBT had over 26 times the odds of use (OR = 26.73; 95% CI: 19.25–37.11; P < 0.001). Having a usual source of care improves the odds of having a timely FOBT (OR = 3.28; 95% CI: 1.06–10.17; P = 0.039). An annual income of $50,000–$74,999 compared to b$25,000 significantly improves the odds of sigmoidoscopy use (OR = 2.64; 95% CI: 1.30–5.37; P = 0.008). Clinician recommendation for the test improves sigmoidoscopy use by more than 11:1 (OR = 11.62; 95% CI: 5.04–26.76; P < 0.001). Current smokers have a borderline statistically significant decreased odds of colonoscopy use (OR = 0.59; 95% CI: 0.35–1.01; P = 0.055). Current drinkers also have a decreased odds of colonoscopy use (OR = 0.74; 95% CI: 0.55– 0.99; P = 0.045). Reporting having a family history of CRC improves the odds of colonoscopy (OR = 2.23; 95% CI: 1.48–3.38; P < 0.001). Reporting having a clinician recommendation for colonoscopy significantly increases the odds of use by more than 20:1 (OR = 21.71, 95% CI: 14.87–31.72; P < 0.001). Family history of CRC increases the odds of screening colonoscopy use (OR = 2.60; 95% CI: 1.83–3.72; P < 0.001). Clinician recommendation for colonoscopy significantly improves the odds of screening colonoscopy (OR = 8.70; 95% CI: 5.82–12.99; P < 0.001). Ever had recommendation for FOBT, 50–64 years (N = 1730): Yes, 38.86 [1.37]; No, 61.14 [1.37] Ever had recommendation for FOBT, 65+ years (N = 1264): Yes, 44.64 [1.59]; No, 55.36 [1.59] Ever had recommendation for sigmoidoscopy or colonoscopy, 50–64 years (N = 1730): Yes, 60.00 [1.39]; No, 40.00 [1.39] Ever had recommendation for sigmoidoscopy or colonoscopy, 65+ years (N = 1264): Yes, 70.55 [1.46]; No, 29.55 [1.46] Those who ever had physician recommendation were more likely to have completed the FOBT (AOR, 70.72; 95% CI, 66.56-77.45); FS (AOR 17.41; 95% CI, 14.9-20.25); or colonoscopy (AOR 57.32; 95% CI, 53.82- 60.75).
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | Outcomes: NA
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Outcomes: NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Outcomes: NA
QUALITY RATING: | Fair
Quality Assessment-Internal Validity for Observational Studies
| | Yes | | No | | Other (CD, NR, NA)
Were the groups similar at baseline regarding the most important prognostic indicators? | | | | | | NA
Were the drop-out or response rates acceptable (≤20%)? [If between 20% and 60%, check other and explain.] | | | | | | Response rate was 38.4%; completion rate was 65.4%
Were the differential drop-out or response rates acceptable (≤15%)? | | | | | | NA
Were intervention/exposure measures valid, reliable, and equally applied? | | | | | | NA
Were the outcome assessors blinded to the intervention or exposure status of subjects? | | | | | | NA
Were outcome measures valid, reliable, and equally applied? | | X
Does the analysis control for baseline differences? | | X
Were important potential confounding and modifying variables taken into account in the design and analysis (e.g., through matching, stratification, or statistical adjustment)? | | X
Were the statistical methods used to assess the abstracted outcomes appropriate? | | X
Quality Rating (Good, Fair, or Poor): Fair
STUDY: | Authors, ref ID: Goel, S.M., Wee, C.C., McCarthy, E.P., Davis, R.B., Ngo-Metzger, Q., Philips, R.S.21 Year of publication: 2003 Dates of data collection: 1998 Trial name: NA
OBJECTIVE OR AIM: | To determine whether foreign birthplace explains some racial/ethnic disparities in cancer screening
DESIGN: | Setting: Home-based survey Study design: Cross-sectional study Duration (mean followup): No follow-up, one-time survey Overall study size (N enrolled/N analyzed): 32,440
| [underlined: Foreign-born] | | | [underlined: U.S. born]
Sample size: | Sample size: 4,963 | | | Sample size: 27,441
Describe intervention: | No intervention; survey | | | No intervention; survey
RECRUITMENT: (population-based, clinic-based, volunteer, other) | Population-based; National Health Interview Survey and Sample Adult and Sample Adult Prevention modules
INCLUSION CRITERIA: | Non-institutionalized, completed NHIS
EXCLUSION CRITERIA: | NR
POPULATION CHARACTERISTICS: | [underlined: Foreign-born] | | | [underlined: U.S.-born]
Mean age & range (years): | Age: 25% <30, 26% 30–39, 20% 40–49, 13% 50–59, 8% 60–69, 6% 70–79, 3% 80+ | | | Age: 22% <30, 21% 30–39, 21% 40–49, 14% 50–59, 10% 60–69, 8% 70–79, 4% 80+
Sex (% female):
Race: | Race: 28% White (non-Hispanic), 7% Black, 45% Hispanic, 29% AAPI | | | Race: 82% White (non-Hispanic), 12% Black, 5% Hispanic, 1% AAPI
Other: | Sex: 51% female | | | Sex: 52% female
| [underlined: Overall]
Attrition/Drop-out (not available for endpoint measurement): | 74% response rate
Adherence:
Contamination:
Response Rates (e.g. for surveys):
STATISTICAL ANALYSES: | Describe: independent variables of interest = race/ethnicity and foreign birth The authors conducted bivariable analyses comparing baseline characteristics between foreign-born and U.S.-born individuals, and compared screening rates across race/ethnicity and birthplace; used x2 statistics for all categorical variables and a t-test for continuous variables; described the association between race/ethnicity and cancer screening by fitting multivariable logistic regression models for each outcome of interest.
ASSESSMENT OF EXPOSURES AND POTENTIAL CONFOUNDERS: | Authors adjusted for potential confounders previously described in the literature, including sociodemographic characteristics (age, marital status, region of residence, education, annual household income) and illness burden (self-reported health status, smoking status, concurrent illnesses, BMI, and hospitalizations in the past year).
OUTCOME ASSESSMENT: | Outcome Measures: The authors considered respondents screened if they reported FOBT in the previous year. An individual was considered screened if proctoscopy (sigmoidoscopy) was completed in the previous 5 years.
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | Outcomes: • The authors found significant differences by race/ethnicity and by birthplace in screening for all analyses performed (P < .05). • Compared to white respondents, blacks, Hispanics, and AAPIs were generally less likely to undergo FOBTs and sigmoidoscopies. • Similarly, compared with U.S.-born respondents, foreign-born respondents were also less likely to be screened with all forms of cancer screening. • Black respondents were as likely to report FOBT and sigmoidoscopy as whites. Hispanic respondents were significantly less likely to report FOBT or sigmoidoscopy. AAPI respondents were less likely to report all screening outcomes; however, the difference for FOBT was not statistically significant. • After adjusting for sociodemographic characteristics and illness burden, there were no significant differences in cancer screening in U.S.-born nonwhite respondents compared with U.S.-born white respondents. • Foreign-born black respondents were significantly less likely to report FOBT; however, after further adjustment for access to care, this difference was attenuated and no longer significant (AOR, 0.51; 95% CI, 0.21 to 1.21). • Foreign-born Hispanic respondents were significantly less likely to report FOBT and sigmoidoscopy. After further adjustment for access to care, differences were attenuated and were no longer statistically significant for FOBT(AOR, 0.84; 95% CI, 0.60 to 1.18) or sigmoidoscopy (AOR, 0.80; 95% CI, 0.57 to 1.10). • Foreign-born AAPI respondents were significantly less likely to report all screening procedures. However, differences for FOBT (AOR, 0.73; CI, 0.45 to 1.19) and sigmoidoscopy (AOR, 0.74; 95% CI, 0.45 to 1.21) were attenuated and no longer statistically significant. • Before adjustment, foreign-born Hispanic respondents were as likely to report FOBT, but significantly less likely to report sigmoidoscopy compared with U.S.-born Hispanic respondents. Differences for sigmoidoscopy use were substantially attenuated after adjustment and were no longer statistically significant. • Foreign-born AAPI respondents were also significantly less likely to report FOBT than U.S.-born AAPI respondents, before and after adjustment for sociodemographic characteristics and illness burden. After additional adjustment for access to care, the association between foreign birth and FOBT was substantially attenuated, and was no longer statistically significant
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | Outcomes: NA
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Outcomes: NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Outcomes: NA
QUALITY RATING: | Good
Quality Assessment-Internal Validity for Observational Studies
| | Yes | | No | | Other (CD, NR, NA)
Were the groups similar at baseline regarding the most important prognostic indicators? | | | | X | | There were several significant differences between sociodemographic categories for U.S.- and foreign-born
Were the drop-out or response rates acceptable (≤ 20%)? [If between 20% and 60%, check other and explain.] | | | | | | Combined response rate for all portions of the survey was 74%
Were the differential drop-out or response rates acceptable (≤ 15%)? | | | | | | NR
Were intervention/exposure measures valid, reliable, and equally applied? | | | | | | NA
Were the outcome assessors blinded to the intervention or exposure status of subjects? | | | | | | NA
Were outcome measures valid, reliable, and equally applied? | | X
Does the analysis control for baseline differences? | | X
Were important potential confounding and modifying variables taken into account in the design and analysis (e.g., through matching, stratification, or statistical adjustment)? | | X
Were the statistical methods used to assess the abstracted outcomes appropriate? | | X
Quality Rating (Good, Fair, or Poor): Good
STUDY: | Authors, ref ID: Gupta S, et al.22 Year of publication: 2009 Dates of data collection: 2002–2006 Trial name: Screening for Colorectal Cancer in a Safety Net Health Care System: Access to Care is Critical and Has Implications for Screening Policy
OBJECTIVE OR AIM: | To determine (a) the size of the potential screen-eligible population ages 50 – 75, (b) the rate of screening over 5 years among individuals ages 54 – 75, and (c) the potential predictors of screening including sex, race/ethnicity, insurance status, frequency of out patient visits, and socioeconomic status.
DESIGN: | Setting: Electronic administrative records review of patients in a “safety-net” health care system (The Tarrant County Hospital District John Peter Smith Hospital Health Network) Study design: cross-sectional (the authors describe it as a cohort study) Duration (mean followup): retrospectively reviewed 5 years of electronic administrative records Overall study size (N enrolled/N analyzed): • Age-eligible individuals in 2006 = 31,166 • Potential screen-eligible population in 2006 = 28,708 • Number of patients analyzed = 20,416
Sample size:: | N = 20,416
Describe intervention | Intervention: NA Reviewed administrative records for evidence of CRC screening between 2002 – 2006
RECRUITMENT: (population-based, clinic-based, volunteer, other) | Identified potentially eligible patients in the JPS health system database.
INCLUSION CRITERIA: | • Age 50 – 75 (ages 50 – 53 were excluded for the final analysis) • Alive as of 2006
EXCLUSION CRITERIA: | • History of inflammatory bowel disease, polyps, or colon cancer • Age 50 – 53 in 2006
POPULATION CHARACTERISTICS: | N = 20,416
Mean age & range (years): | Median age = 60 years
Sex (% female): | Women = 59%
Race: | White = 43.7% African-American = 27.7% Hispanic = 23.4% Other = 5.2%
Other: • • | Primary Language spoken English = 82% Spanish = 12.5% Other = 5.6% Insurance status in 2006 None = 20.5% JPS Connection = 39.9% Medicare, Medicaid, private, or other = 39.6% Median household income = $35,419
Attrition/Drop-out (not available for endpoint measurement):
Adherence:
Contamination:
Response Rates (e.g. for surveys):
STATISTICAL ANALYSES: | Describe: • Descriptive statistics, including proportions with 95% CIs for estimates of rates of screening • Univariate and multivariate logistic regression to identify any association between potential predictors of screening participation, and the primary outcome, the presence or absence of CRC screening completion. • Cochran-Armitage trend test used to investigate trend between screening and years of insurance coverage.
ASSESSMENT OF EXPOSURES AND POTENTIAL CONFOUNDERS: | Model included: age, sex, race/ethnicity, primary language, income, proportion of individuals living in poverty (zip code), insurance, whether seen as an outpt in 2006
OUTCOME ASSESSMENT: | Outcome Measures: Size of potential screen-eligible population Rate of screening completion Predictors of screening completion Screening participation defined as: FOBT in 2005 or 2006/any BE, FS or colonscopy from 2002–2006
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | Outcomes: • 22% of those screen-eligible individuals aged 54 – 75 years had records of CRC screening completion (defined as FOBT in 2005 or 2006, or any colonoscopy, flexible sigmoidoscopy, or barium enema between 2002 – 2006). • Independent predictors of screening completion used in multiple logistic regression analysis were: age, gender, race/ethnicity, primary language, measures of SES, insurance status, and presence of two or more outpatient visits. The statistically significant associations were: ○ Female vs. male, OR = 1.25 (1.16 – 1.35) ○ Hispanic vs. White, OR = 1.2 (1.07 – 1.34) ○ Any health insurance vs. none, OR = 2.57 (2.23 – 2.98) ○ JPS insurance vs. none, OR = 2.55 (2.21 – 2.95) ○ Two or more outpatient visits in 2006, OR = 3.53 (3.15 – 3.97)
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | NA
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | NA
QUALITY RATING: | Fair
Quality Assessment-Internal Validity for Observational Studies
| | Yes | | No | | Other (CD, NR, NA)
Were the groups similar at baseline regarding the most important prognostic indicators? | | | | | | NA – cross sectional retrospective records review, no comparison groups
Were the drop-out or response rates acceptable (≤ 20%)? [If between 20% and 60%, check other and explain.] | | | | | | NA
Were the differential drop-out or response rates acceptable (≤ 15%)? | | | | | | NA
Were intervention/exposure measures valid, reliable, and equally applied? | | x
Were the outcome assessors blinded to the intervention or exposure status of subjects? | | | | | | NR Likely yes as this is administrative record review
Were outcome measures valid, reliable, and equally applied? | | | | x | | Screening vs. diagnostic exams were not distinguished. Used ICD9 codes to verify screening status, however the investigators only had access to records of procedures performed within the JPS system, other health records were not available for review.
Does the analysis control for baseline differences? | | X | | | | The analysis adjusted for age category, race, primary language, sex, insurance status, presence of two or more out patient visits in 2006, household income, and proportion living in poverty in 5-percentage point increments
Were important potential confounding and modifying variables taken into account in the design and analysis (e.g., through matching, stratification, or statistical adjustment)? | | | | | | Several factors were controlled for in the analysis. There could be some effect from unmeasured confounders such as comorbidity.
Were the statistical methods used to assess the abstracted outcomes appropriate? | | X
Quality Rating (Good, Fair, or Poor): Fair
STUDY: | Authors, ref ID: Heo, M., et al.23 Year of publication: 2004 Dates of data collection: 2001 Trial name: NA
OBJECTIVE OR AIM: | To estimate the association between body-mass index (BMI: kg/m2) and colorectal cancer (CRC) screening among US adults aged ≥ 50 years.
DESIGN: | Setting: United States Study design: Cross-sectional Duration (mean followup): One-time data collection, one year Overall study size (N enrolled/N analyzed): 84,284
| [underlined: All]
Sample size: | Sample size: 84,284
Describe intervention: | Intervention: None, survey (BRFFS)
RECRUITMENT: (population-based, clinic-based, volunteer, other) | Population-based (BRFFS)
INCLUSION CRITERIA: | Age 50+
EXCLUSION CRITERIA: | Respondents (n = 250; .3%) with BMI's <18.5 ("underweight") were omitted from the analyses.
POPULATION CHARACTERISTICS: | [underlined: All]
Mean age & range (years): | Mean age: 65
Sex (% female): | Sex: 61.8% Female
Race: | Race: 82.3% white, 17.7% Non-white
Other:
Attrition/Drop-out (not available for endpoint measurement): | NR
Adherence:
Contamination:
Response Rates (e.g. for surveys):
STATISTICAL ANALYSES: | Describe: Multivariate logistic regression to estimate BMI screening associations by entering the BMI-defined categories and potential confounders into the model as either continuous (e.g., age [including polynomials up to the third order]) or dichotomous variables (e.g., health insurance). To evaluate whether sex moderated the BMI-screening association, ran adjusted logistic models that also included BMI × sex interaction terms. Finally, because the authors observed a significant BMI × sex interaction, they then analyzed the data for men and women separately.
ASSESSMENT OF EXPOSURES AND POTENTIAL CONFOUNDERS: | This study has limitations including: the BRFSS, a telephone survey, is prone to measurement error; because the BRFSS is an observational study, the BMI-screening associations could be due to residual confounding or confounding from unmeasured variables; the cross-sectional design did not allow testing causal inferences; and people without telephones, approximately 3% of the US population, are not surveyed through BRFSS.
OUTCOME ASSESSMENT: | Outcome Measures: BRFSS codes FOBT responses as: 'within past year', 'within past 2 years', 'within past 5 years', '5 or more years ago', 'don't know/not sure', or 'refused'. SIG is coded as: 'within past year', 'within past 2 years', 'within past 5 years', 'within past 10 years', '10 or more years ago', 'don't know/not sure', or 'refused'.
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | Outcomes: BMI was not associated with obtaining a FOBT (AOR's ranged from 0.90 to 0.98). Compared to normal weight adults, however, those in the overweight (OR = 1.15, 95%CI 1.02–1.31), obesity class I (1.21, 95%CI 1.09–1.35), II (1.17, 95%CI 1.04–1.44) and III (1.27, 95%CI 1.05–1.58) categories were more likely to have obtained a screening SIG within the previous 5 years (P's < 0.05). The interaction effect between sex and BMI categories on FOBT was not significant (x2(4) = 8.64, P=.071). However, the interaction effect between sex and BMI categories on SIG screening was significant, (x2(4) = 114.03, P <.0001). BMI was not associated with obtaining a FOBT for either sex (OR's ranged from 0.87 to 1.05). Compared to normal weight men, men in the overweight (1.25, 95%CI 1.05–1.51) and obesity class I (1.21 95%CI 1.03–1.75) categories were significantly more likely to have obtained a screening SIG. In contrast, obesity class I (0.86 95%CI 0.78–0.94) and II (0.88 95%CI 0.79–0.99) women were less likely to have obtained a screening SIG compared to normal weight women
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | Outcomes: NA
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Outcomes: NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Outcomes: NA
QUALITY RATING: | Fair
Quality Assessment-Internal Validity for Observational Studies
| | Yes | | No | | Other (CD, NR, NA)
Were the groups similar at baseline regarding the most important prognostic indicators? | | | | | | NA
Were the drop-out or response rates acceptable (≤ 20%)? [If between 20% and 60%, check other and explain.] | | | | | | NR
Were the differential drop-out or response rates acceptable (≤ 15%)? | | | | | | NA
Were intervention/exposure measures valid, reliable, and equally applied? | | | | | | NA
Were the outcome assessors blinded to the intervention or exposure status of subjects? | | | | | | NA
Were outcome measures valid, reliable, and equally applied? | | X
Does the analysis control for baseline differences? | | X
Were important potential confounding and modifying variables taken into account in the design and analysis (e.g., through matching, stratification, or statistical adjustment)? | | X
Were the statistical methods used to assess the abstracted outcomes appropriate? | | X
Quality Rating (Good, Fair, or Poor): Fair
STUDY: | Authors, ref ID: Honda, K., Kagawa-singer, M.24 Year of publication: 2006 Dates of data collection: NR Trial name: NA
OBJECTIVE OR AIM: | The study aims are to (1) develop and test a model explaining how socioenvironmental and personal factors are related to colorectal cancer screening adherence, and (2) determine the relative importance of normative (subjective norms) and attitudinal variables (perceived benefits and perceived behavioral control) for explaining colorectal cancer screening adherence for this particular ethnic group.
DESIGN: | Setting: US Study design: Cross-sectional, retrospective (survey) Duration (mean followup): No follow-up Overall study size (N enrolled/N analyzed): 341
| [underlined: All]
Sample size: | Sample size: 341
Describe intervention: | Intervention: None; mailed survey in English and Japanese
RECRUITMENT: (population-based, clinic-based, volunteer, other) | Population-based
INCLUSION CRITERIA: | Japanese names (both first- and surname), age (over 50), and geographic location (NY, NJ, CT)
EXCLUSION CRITERIA: | Did not provide demographic information
POPULATION CHARACTERISTICS: | [underlined: All]
Mean age & range (years): | Age range: 50–92 Mean age: 64
Sex (% female): | Sex: 63% female
Race: | Ethnicity: Asian (Japanese American)
Other:
Attrition/Drop-out (not available for endpoint measurement): | Response rate: 59%
Adherence:
Contamination:
Response Rates (e.g. for surveys):
STATISTICAL ANALYSES: | Describe: The first step involved using confirmatory factor analysis (CFA) to test an overall measurement model. The second step involved using SEM to test a structural model. The squared multiple correlation (R^2^) value was reported for the endogeneous variable to evaluate effectiveness of the model in explaining the variance observed in the sample’s screening behavior. Paths with nonsignificant t values were removed because no substantively meaningful interpretation can be provided for the parameter estimates
ASSESSMENT OF EXPOSURES AND POTENTIAL CONFOUNDERS: | NR
OUTCOME ASSESSMENT: | Outcome Measures: (1) never had any of three screening tests, (2) had at least one of three screening tests, but not appropriate frequency, and (3) had any of three screening tests with an appropriate frequency
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | Outcomes: Results confirm the existence of a single latent construct underlying each of the measures of emotional family support, emotional friend support, and provider-patient communication in this population. Cronbach’s alpha for the latent variables were as follows: Provider-Patient Communication, 0.945; Emotional Support From Family, 0.914; Emotional Support From Friends, 0.883. Five background variables (education, acculturation, marital status, frequency of contact with family, frequency of contact with close friends) were not significant and were dropped from the “full” to the “trimmed” model. The structural equations suggest that not all cognitive factors are significant in colorectal cancer screening adherence. Subjective norms among family and friends (γ = 0.20), perceived benefits (γ = 0.14), but not subjective norms among providers and perceived behavioral control, had significant impacts on colorectal cancer screening adherence. Among sociodemographics and social network variables, regular access (γ = 0.26), emotional friends support (γ = 0.15), income (γ = 0.14), and provider patient communication (γ = 0.12) had direct impacts on adherence, with the indirect effect of provider patient communication via increased perceived benefits leading the total effect of 0.14.
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | Outcomes: NA
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Outcomes: NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Outcomes: NA
QUALITY RATING: | Fair
Quality Assessment-Internal Validity for Observational Studies
| | Yes | | No | | Other (CD, NR, NA)
Were the groups similar at baseline regarding the most important prognostic indicators? | | | | | | NA
Were the drop-out or response rates acceptable (≤ 20%)? [If between 20% and 60%, check other and explain.] | | | | | | Response rate: 59%--actually only 37.8% once taken into account those that were excluded or were unusable; only 341/900 analyzed
Were the differential drop-out or response rates acceptable (≤ 15%)? | | | | | | NA
Were intervention/exposure measures valid, reliable, and equally applied? | | | | | | NA
Were the outcome assessors blinded to the intervention or exposure status of subjects? | | | | | | NA
Were outcome measures valid, reliable, and equally applied? | | X
Does the analysis control for baseline differences? | | X
Were important potential confounding and modifying variables taken into account in the design and analysis (e.g., through matching, stratification, or statistical adjustment)? | | X
Were the statistical methods used to assess the abstracted outcomes appropriate? | | X
Quality Rating (Good, Fair, or Poor): Fair
STUDY: | Authors, ref ID: Hudson, S.V., et al.25 Year of publication: 2007 Dates of data collection: April 2003 through December 2004 Trial name: NA
OBJECTIVE OR AIM: | This study examines whether primary care practices that involve staff in general forms of health education have higher CRC screening rates than practices that do not.
DESIGN: | Setting: Chart audit of practices Study design: Cross-sectional retrospective analysis Duration (mean followup): No followup, data collected over 20 months, 2003–2004 Overall study size (N enrolled/N analyzed): 22 practices, 795 patients
Sample size: | Sample size: 22 practices, 795 patients
Describe intervention: | Charts were audited to extract CRC screening
RECRUITMENT: (population-based, clinic-based, volunteer, other) | No individual recruitment of patients; Within each practice, 20 patients were randomly selected from each list of patients. In cases where there were fewer than 20 patients in the practice with a particular diagnosis code, all patients with the diagnosis code were used.
INCLUSION CRITERIA: | Suburban practices were that had medical records with at least 10 years of data,
EXCLUSION CRITERIA: | If patients were deceased at the time of the audit, below age 18 or no longer a patient of the practice.
POPULATION CHARACTERISTICS: | [underlined: Population]
Mean age & range (years): | Age range: 50–70 Mean age: 59.3
Sex (% female): | Sex: 45% female
Race: | Practices averaged 86% Caucasian patients
Other:
Attrition/Drop-out (not available for endpoint measurement): | NA
Adherence:
Contamination:
Response Rates (e.g. for surveys):
STATISTICAL ANALYSES: | Describe: Descriptive statistics were used to summarize rates of screening and teamwork indicators as well as other patient and practice-level socio-demographic information. Generalized estimating equations were used to examine the effects of the practice indicators of teamwork, while controlling for additional practice-level covariates and patient-level covariates
ASSESSMENT OF EXPOSURES AND POTENTIAL CONFOUNDERS: | Our sample was drawn mainly from a pool of patients with known chronic diseases (i.e., asthma, coronary artery disease, diabetes, hypertension). Though reflective of common diseases that affect many patients eligible for preventive colorectal cancer screening, this sample may over represent patients with chronic disease and under represent others in the general patient population.
OUTCOME ASSESSMENT: | Outcome Measures: CRC screening, any procedure (URPSTF)
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | Outcomes: Four of the 22 practices indicated that they used Health Risk Assessments (HRA’s) for diet, physical activity and tobacco; however, the use of HRA’s was not significantly associated with CRC screening (z = −0.44, P = 0.6625) Practices using nursing staff for diet, physical activity and tobacco counseling had significantly higher CRC screening rates than those not using nursing or health educator staff for such counseling (z = 7.30, P < 0.0001) Practices using patient reminder systems had significantly higher CRC screening rates despite the fact that these systems were not specifically targeting CRC screening (z = 4.96, P < 0.0001). CRC screening rates: Use of nonclinician staff for counseling: Yes: 54.1%; No: 27.2% [AOR, 2.96 (95% CI, 2.21–3.96)] Reminder systems: Yes: 39.9%; No: 19.6% [AOR, 2.57 (95% CI, 1.77–3.74)]
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | Outcomes: 31.3% of patients up to date for CRC screening
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Outcomes: NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Outcomes: NA
QUALITY RATING: | Fair
Quality Assessment-Internal Validity for Observational Studies
| | Yes | | No | | Other (CD, NR, NA)
Were the groups similar at baseline regarding the most important prognostic indicators? | | | | X
Were the drop-out or response rates acceptable (≤ 20%)? [If between 20% and 60%, check other and explain.] | | | | | | NA
Were the differential drop-out or response rates acceptable (≤ 15%)? | | | | | | NA
Were intervention/exposure measures valid, reliable, and equally applied? | | X
Were the outcome assessors blinded to the intervention or exposure status of subjects? | | X
Were outcome measures valid, reliable, and equally applied? | | X
Does the analysis control for baseline differences? | | X
Were important potential confounding and modifying variables taken into account in the design and analysis (e.g., through matching, stratification, or statistical adjustment)? | | X
Were the statistical methods used to assess the abstracted outcomes appropriate? | | X | | | | Always concerned about unadjusted confounders
Quality Rating (Good, Fair, or Poor): Fair
STUDY: | Authors, ref ID: Janz et al.26 Year of publication: 2003 Date of data collection: 2001 Trial name:
OBJECTIVE OR AIM: | Assess attitudes and practices regarding CRC screening.
DESIGN: | Setting: Telephone survey of general population Study design: Cross-sectional, retrospective opulation-based random-digit-dialing telephone survey Duration (mean followup): None Overall study size (N enrolled/N analyzed): 355
| [underlined: Population]
Sample size: | Sample size: 355
Describe intervention:
RECRUITMENT: (population-based, clinic-based, volunteer, other) | Population-based; purchased random phone numbers and addresses
INCLUSION CRITERIA: | Age 50–79, residents of Genessee County, Michigan, household telephone number
EXCLUSION CRITERIA: | Prior history of colorectal cancer, colorectal surgery to remove polyp, inflammatory bowel disorder, or familial adenomatous polyposis.
POPULATION CHARACTERISTICS: | [underlined: Population]
Mean age & range (years): | Age range: 50–79
Sex (% female): | Sex: 55% female
Race: | Race: 48% Black; 52% White
Other:
| [underlined: Population]
Attrition/Drop-out (not available for endpoint measurement): | Response rate = 69%
Adherence:
Contamination:
Response Rates (e.g. for surveys):
STATISTICAL ANALYSES: | Describe: Demographic variables and variables measuring respondents’ familiarity with or use of screening methods were analyzed using two-way contingency tables with accompanying x2 statistics which test the null hypothesis of no difference among race-gender groups. Logistic regression models were used to test whether dimensions represented in the Health Belief Model were significantly related to CRC screening status while controlling for relevant sociodemographic and related factors.
ASSESSMENT OF EXPOSURES AND POTENTIAL CONFOUNDERS: | Across all three screening procedures, two consistent barriers were the personal beliefs that the test was “not needed” or would be “embarrassing.” Other barriers were unique to a specific screening test; for example, 25% reported that a barrier to FOBT was “not knowing how to perform the self-test,” and 11% reported concern with “bleeding or tearing” with colonoscopy. About 30% of participants reported that pain was a barrier to flexible sigmoidoscopy and colonoscopy. Moreover, a cluster of emotional reactions to these tests may also serve as barriers to action. For each test, significant numbers of respondents indicated “anxiety about the procedure” and “fear of the results.” Ten percent of the respondents considered cost a barrier to flexible sigmoidoscopy; that number dropped to 7% for colonoscopy.
OUTCOME ASSESSMENT: | Outcome Measures: Attitudes and practices related to CRC screening.
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | Outcomes: • Significantly high percentages of white respondents than black respondents were aware of the screening precedures for both endoscopic procedures (P < 0.05). • There was considerable attenuation as one move from knowledge of any screening procedure to having had the particular screening test. There was further reduction between having ever been screened and adherence to recommended screening guidelines. • Adherence to the recommended screening interval was lowest in black females for the three procedures: 21.8% for FOBT, 20.5% for flexible sigmoidoscopy, and 12.8% for colonoscopy. • Black males reported greater rates of prior and current screening than white males for both flexible sigmoidoscopy and colonoscopy. • Males reported high screening percentages. • The only significant differences among gender and race subgroups were observed for “having heard of a flexible sigmoidoscopy” (P = 0.011); “having heard of a colonoscopy” (P = 0.001); and “having ever had a flexible sigmoidoscopy” (P = 0.037) • Looking at adherence according to American Cancer Society, the following percentages of groups were adherent: black males (37.8%); white males (24.8%); black females (19.2%); and white females (26.5%) • Between 54 and 65% of respondents indicated that their physician had recommended FOBT, and over 92% of those subjects reported having had the test. (P = NR, OR = NR) • There were no significant differences at the P < 0.05 level between race and gender subgroups in either the percentage reporting a physician recommendation or the percentage screened among those reporting such a recommendation. • Increasing age was significantly associated with a greater likelihood of obtaining a flexible sigmoidoscopy or colonoscopy. • A family history of colorectal cancer was significantly associated with an increased odds ratio for having a colonoscopy in the recommended interval (OR= 3.02, 95% CI =1.29, 7.09). • Respondents considering themselves at higher risk for colorectal cancer compared to other persons their age were 1.24 times (95% CI 1.01, 1.52) more likely to have had a flexible sigmoidoscopy in the recommended interval.
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | NA
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | NA
QUALITY RATING: | Fair
Quality Assessment-Internal Validity for Observational Studies
| | Yes | | No | | Other (CD, NR, NA)
Were the groups similar at baseline regarding the most important prognostic indicators? | | | | | | NA
Were the drop-out or response rates acceptable (≤ 20%)? [If between 20% and 60%, check other and explain.] | | | | | | Response rate was 69%.
Were the differential drop-out or response rates acceptable (≤ 15%)? | | | | | | NA
Were intervention/exposure measures valid, reliable, and equally applied? | | X
Were the outcome assessors blinded to the intervention or exposure status of subjects? | | | | X | | People doing interview knew predictive factors and outcome
Were outcome measures valid, reliable, and equally applied? | | | | | | NA
Does the analysis control for baseline differences? | | X
Were important potential confounding and modifying variables taken into account in the design and analysis (e.g., through matching, stratification, or statistical adjustment)? | | X
Were the statistical methods used to assess the abstracted outcomes appropriate? | | X
Quality Rating (Good, Fair, or Poor): Fair
STUDY: | Authors, ref ID: Jerant, AF, et al.27 Year of publication: 2008 Dates of data collection: 1999–2005 Trial name: NR
OBJECTIVE OR AIM: | To examine factors associated with disparities in CRC screening between whites and Hispanic national origin subgroups.
DESIGN: | Setting: US Study design: Cross-sectional, secondary data analysis of survey data Duration (mean followup): One-time data collection each year, 1999–2005 Overall study size (N enrolled/N analyzed): 22,419
| [underlined: All]
Sample size: | Sample size: 22,419 (18,733 White, 2,779 Mexican, 336 Cuban, 376 Puerto Rican, 195 Dominican)
Describe intervention: | Intervention: None; used MEPS data
RECRUITMENT: (population-based, clinic-based, volunteer, other) | Population-based
INCLUSION CRITERIA: | Respondents aged >50 years self-identifying as non-Hispanic white or Hispanic
EXCLUSION CRITERIA: | Individuals not of Mexican, Cuban, Puerto Rican, or Dominican origin
POPULATION CHARACTERISTICS: | [underlined: White] | | [underlined: Mexican] | [underlined: Cuban] | [underlined: Puerto Rican] | [underlined: Dominican]
Mean age & range (years): | Age: 23.1% 50–54, 19.4% 55–59, 14.9% 60–64, 22.6% 65–74, 20% 75+ | | Age: 29.1% 50–54, 21.7% 55–59, 13.5% 60–64, 22.1% 65–74, 13.6% 75+ | 22.3% 50–54, 13.7% 55–59, 10.4% 60–64, 28.5% 65–74, 25.2% 75+ | 23.9% 50–54, 25.3% 55–59, 22.6% 60–64, 18.9% 65–74, 9.2% 75+ | 30.7% 50–54, 23.4% 55–59, 16.1% 60–64, 19.4% 65–74, 10.4% 75+
Sex (% female): | Sex: 53.8% female | | Sex: 53.8% female | Sex: 52% female | Sex: 60.4% female | Sex: 60.5% female
Race:
Other:
| [underlined: All]
Attrition/Drop-out (not available for endpoint measurement): | Response rate about 65%
Adherence:
Contamination:
Response Rates (e.g. for surveys):
STATISTICAL ANALYSES: | Describe: • Analyses incorporated the longitudinal strata and primary sampling units and were weighted to yield appropriate standard errors and estimates representative of the U.S. civilian, non-institutionalized adult population. (DR note: this was cross sectional study.) • Four main models were constructed to determine the relationship between CRC screening and Hispanic national origin subgroup using a series of logistic regression analyses with CRC screening as the dependent variable in the models. • The modeling sequence was designed to adjust first for relatively fixed demographic characteristics, then basic socioeconomic factors common to all persons, then access factors common to all persons, and, finally, language, a factor of specific relevance to Hispanics in this analysis.
ASSESSMENT OF EXPOSURES AND POTENTIAL CONFOUNDERS: | Nonetheless, the data regarding geographic region by ethnicity presented in Table 1 suggest the potential for confounding even by broad geographic region, and our models adjusted for such confounding.
OUTCOME ASSESSMENT: | Outcome Measures: Dependent variable: self-report of up to date CRC screening, defined as fecal occult blood testing within 2 years and/or lower endoscopy at any time
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | Outcomes: • Total unadjusted screening rates: Non-Hispanic whites: 55.9%, Mexican: 35.2%, Cuban: 51.0%, Puerto Rican: 45.7%, Dominican: 28.5% • Adjusted for age, gender, region and year: Mexican: (AOR, 0.46; 95% CI, 0.40–0.53), Puerto Rican: (AOR, 0.65; 95% CI, 0.47–0.91), Dominican: (AOR, 0.30; 95% CI, 0.19–0.45) • Adjusted for above plus income and education: Mexican: (AOR, 0.70; 95% CI, 0.60–0.81), Dominican: (AOR, 0.44; 95% CI, 0.28–0.69) • Adjusted for above plus insurance, usual source of care, health status: Mexican: (AOR, 0.79; 95% CI, 0.69‐ 0.91), Dominican: (AOR, 0.54; 95% CI, 0.32–0.91) • Compared with non-Hispanic whites, all Hispanic national origin subgroups except people of Cuban origin were significantly less likely to report up to date CRC screening, after adjustment for age, sex, region, and year (Mexican: OR .46, 95% CI: .40, .53, P = 0.00; Puerto Rican: OR. .65, 95% CI .47, .91, P = 0.01; Dominican: OR .30, 95% CI .19, .45, P = 0.00) • With additional adjustment for socioeconomics, the effect for people of Puerto Rican origin became non‐ significant (Mexican: OR .70, 95% CI .60, .81, P = 0.00; Dominican: OR .44, 95% CI .28, .69, P = 0.00). • With further adjustment for access (insurance status, and availability of a usual source of care, there was a further non-significant attenuation of disparities (Mexican: OR .79, 95% CI .69, .91, P = 0.00; Dominican OR .54, 95% CI .32, .91, P = 0.02). • The final model, including language revealed further attenuation of the disparity between non-Hispanic whites and Hispanics (with no remaining statistically significant disparity), while people of Cuban origin had higher adjusted screening rates (Cuban: OR 1.57, 95% CI 1.15, 2.14, P = 0.01).
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | NA
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | NA
QUALITY RATING: | Good
Quality Assessment-Internal Validity for Observational Studies
| | Yes | | No | | Other (CD, NR, NA)
Were the groups similar at baseline regarding the most important prognostic indicators? | | | | | | Population demographics vary based on country of origin.
Were the drop-out or response rates acceptable (≤ 20%)? [If between 20% and 60%, check other and explain.] | | | | | | Response rate about 65%
Were the differential drop-out or response rates acceptable (≤ 15%)? | | | | | | NA
Were intervention/exposure measures valid, reliable, and equally applied? | | | | | | NA
Were the outcome assessors blinded to the intervention or exposure status of subjects? | | | | | | NA
Were outcome measures valid, reliable, and equally applied? | | X
Does the analysis control for baseline differences? | | X
Were important potential confounding and modifying variables taken into account in the design and analysis (e.g., through matching, stratification, or statistical adjustment)? | | X
Were the statistical methods used to assess the abstracted outcomes appropriate? | | X
Quality Rating (Good, Fair, or Poor): Good
STUDY: | Authors, ref ID: Jerant, A.F., et al.28 Year of publication: 2008 Dates of data collection: 2001–2005 Trial name: NR
OBJECTIVE OR AIM: | To address these limitations in the literature, the authors examined the correlates of CRC screening among all 4 major US racial/ethnic categories (non-Hispanic white, Asian, black, and Hispanic individuals) using linked data from the 2001–2005 Medical Expenditure Panel Survey (MEPS) and the 2000–2004 NHIS.
DESIGN: | Setting: USA; Medical Expenditure Panel Survey and the National Health Interview Survey Study design: Cross-sectional) Duration (mean followup): One-time data analysis Overall study size (N enrolled/N analyzed): 22973/21,433
| [underlined: All]
Sample size: | Sample size: 22,973 (no missing data = 21,433)
Describe intervention: | Intervention: None; Medical Expenditure Panel Survey and the National Health Interview Survey
RECRUITMENT: (population-based, clinic-based, volunteer, other) | Population-based survey
INCLUSION CRITERIA: | Civilian, noninstitutionalized population, age 50+
EXCLUSION CRITERIA: | NR
POPULATION CHARACTERISTICS: | [underlined: All]
Mean age & range (years): | Age: 23.6% 50–54, 19.7% 55–59, 14.8% 60–64, 22.2%, 65–74, 19.6% 75+
Sex (% female): | Sex: 54.1% female
Race: | Race: 68% White (non-Hispanic), 3.4 Asian, 13.7% Black, 14.9% Hispanic
Other:
Attrition/Drop-out (not available for endpoint measurement): | MEPS point-in-time response rates for the 5 panels of public use data that the authors used were as follows: 2000, 70.5%; 2001, 71.4%; 2002, 69.2%; 2003, 68.9%; 2004, 68.2%; and 2005, 66.5%.
Adherence:
Contamination:
Response Rates (e.g. for surveys):
STATISTICAL ANALYSES: | Describe: They constructed 3 sets of analyses with 4 sequential logistic regression models to determine the relationship between CRC screening and race/ethnicity (non-Hispanic white, Asian, black, and Hispanic) using CRC screening as the dependent variable in all the models. Model 1: adjusted only for basic demographics (age, sex, MSA residence, and region of US) Model 2: adjusted for SES (annual income and educ level) Model 3: included also access to care (insurance, USOC) and self-rated health Model 4: incl also language spoken at home and nativity
ASSESSMENT OF EXPOSURES AND POTENTIAL CONFOUNDERS: | Modeling included potential confounders noted above
OUTCOME ASSESSMENT: | Outcome Measures: CRC screening; respondents were considered to be up-to-date for screening if they reported FOBT in the previous 2 years or endoscopic testing at any time Combined, FOBT alone, endoscopy alone
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | Outcomes: After adjustment for age, sex, MSA residence, region, and year, (MODEL 1) compared with non-Hispanic whites, all minorities, and especially Asians and Hispanics, were significantly less likely to report up-to-date CRC screening. With additional socioeconomic adjustment (MODEL 2), the disparities in CRC screening were attenuated for Hispanics and blacks (and, for blacks, eliminated for FOBT) relative to non-Hispanic whites, but there was little change in Asian/non-Hispanic white disparities. The gradient in screening was steepest for educational level, with the most educated group (16+ years of schooling) having adjusted odds ratios of greater than 2.00 relative to the least educated group (less than 9 years of schooling) Adjustment for access and self-rated health (MODEL 3) further attenuated Hispanic/non-Hispanic white screening disparities but had little effect on Asian/non-Hispanic white disparities. For FOBT, blacks were more likely to report being up-to-date than were non-Hispanic whites. Those with worse self-rated health, availability of some insurance, and a usual source of care were more likely to report screening. With the inclusion of language and nativity MODEL 4), Hispanic/non-Hispanic white [underlined: disparities were attenuated such that they were no longer statistically significant], whereas Asian/non-Hispanic white disparities were attenuated but remained significant. Speaking English at home and being born in the continental United States were associated with greater CRC screening. Analyses that included language and nativity separately suggested that language, rather than nativity, was the main driver of the attenuation in disparities. Absolute rates for screening among blacks were 25.5% for FOBT; 38.3% for endoscopy; and 48.2% for the combined tests; among non-Hispanic whites, rates were 25.8%, 49.0, and 57.2%, respectively Initial analysis (adjusted for demographics) showed blacks to be significantly less likely than non-Hispanic whites to have CRC tests (unadjusted OR 0.72; 95% CI, 0.65–0.80) Further adjustment to the model (i.e., when foreign birth, language spoken at home are taken into account) eliminated these differences. Unadjusted screening rates: Asians: 14.8% FOBT; 27.5% endoscopy; 33.8% combined FOBT and endoscopy Non-Hispanic whites: 25.8% FOBT; 49.0% endoscopy; 57.2% combined FOBT and endoscopy Adjusted for age, gender, region: AOR, 0.41; 95% CI, 0.33–0.50 Adjusted for above plus income and education: AOR, 0.42; 95% CI, 0.34–0.52 Adjusted for above plus insurance, usual source of care, health status: AOR, 0.44; 95% CI, 0.35–0.55 Adjusted for above plus language spoken at home, nativity: AOR, 0.63; 95% CI, 0.49–0.81 Respondents who reported speaking English at home were more likely to report being screened than those who did not (AOR, 1.84; 95% CI, 1.52–1.33 for combined screening with FOBT or endoscopy) Those born in the US were also more likely to be screened than those who were not (AOR, 1.16; 95% CI, 1.01–1.33)
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | Outcomes: NA
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Outcomes: NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Outcomes: NA
QUALITY RATING: | Good
Quality Assessment-Internal Validity for Observational Studies
| | Yes | | No | | Other (CD, NR, NA)
Were the groups similar at baseline regarding the most important prognostic indicators?
Were the drop-out or response rates acceptable (≤ 20%)? [If between 20% and 60%, check other and explain.] | | | | | | MEPS point-in-time response rates for the 5 panels of public use data that we used were as follows: 2000, 70.5%; 2001, 71.4%; 2002, 69.2%; 2003, 68.9%; 2004, 68.2%; and 2005, 66.5%.
Were the differential drop-out or response rates acceptable (≤ 15%)? | | X
Were intervention/exposure measures valid, reliable, and equally applied? | | | | | | NA
Were the outcome assessors blinded to the intervention or exposure status of subjects? | | | | | | NA
Were outcome measures valid, reliable, and equally applied? | | X
Does the analysis control for baseline differences? | | X
Were important potential confounding and modifying variables taken into account in the design and analysis (e.g., through matching, stratification, or statistical adjustment)? | | X
Were the statistical methods used to assess the abstracted outcomes appropriate? | | X
Quality Rating (Good, Fair, or Poor): Good Reviewer #1 initials: BLM Reviewer #2 initials: DR Comments (explain poor quality ratings):
STUDY: | Authors, ref ID: Katz, M., et al.29 Year of publication: 2004 Dates of data collection: Focus group: 1998; Survey October 1998 to October 1999 Trial name: WATCH (Wellness for African Americans Through Churches) Project
OBJECTIVE OR AIM: | The authors sought to determine the relationship between the general quality of self-rated patient-provider communication and the completion of CRC screening.
DESIGN: | Setting: Rural churches in North Carolina Study design: Cohort survey study Duration (mean followup): One-year data collection Overall study size (N enrolled/N analyzed): 397 analyzed
| [underlined: All]
Sample size: | Sample size: 397
Describe intervention: | Intervention: None, focus group and telephone survey of church members
RECRUITMENT: (population-based, clinic-based, volunteer, other) | Church-based
INCLUSION CRITERIA: | Age 50+
EXCLUSION CRITERIA: | Deceased, no longer living in the state, medically incapable, phone number no longer working
POPULATION CHARACTERISTICS: | [underlined: All]
Mean age & range (years):
Sex (% female): | Sex: 73,8% female
Race: | Race: 98% African American
Other: | Mean age: 63 years
| [underlined: All]
Attrition/Drop-out (not available for endpoint measurement): | Adjusted response rate: 66%
Adherence:
Contamination:
Response Rates (e.g. for surveys):
STATISTICAL ANALYSES: | Describe: Analyses of data from this study included factor analysis, analysis of variance, and logistic regression. Logistic regression analyses were performed to evaluate whether the level of perceived patient-provider communication was significantly related to CRC screening behavior in this population. Sociodemographic variables were identified as potential covariates if there was plausible theoretical or empirical evidence that the variable might be associated with the communication variable or with CRC screening. Only the sex of the participant, receiving healthcare at a doctor's office versus a clinic/emergency room, and knowledge of CRC risk were significantly associated with communication and only these three covariates were entered into the initial logistic model.
ASSESSMENT OF EXPOSURES AND POTENTIAL CONFOUNDERS: | Participants were categorized as having "good" communication if they perceived receiving enough information from their provider, being involved in medical decisions, and thinking that their provider understood their health needs almost all the time or always. This was self-rated
OUTCOME ASSESSMENT: | Outcome Measures: Participants were considered to have been screened within the recommended time period if they had a FOBT within the preceding year, and sigmoidscopy within the preceding 5 years.
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | Outcomes: After adjustment for the sex of the participant and source of healthcare, quality of communication (good vs fair/poor as rated by patient) remained significantly associated with completion of a CRC test (OR= 1.95; 95% CI= 1.29, 2.94; P = 0.002). CRC screening results by communication:
KQ2 - What factors influence the use of colorectal cancer screening? | | | CRC screening in recommended time (%) | | | P value
KQ2 - What factors influence the use of colorectal cancer screening? | Poor and fair communication
KQ2 - What factors influence the use of colorectal cancer screening? | Inadequate knowledge (n=40) | | 15.0 | | | 0.654
KQ2 - What factors influence the use of colorectal cancer screening? | Adequate knowledge (n=54) | | 18.5
KQ2 - What factors influence the use of colorectal cancer screening? | Good communication
KQ2 - What factors influence the use of colorectal cancer screening? | Inadequate knowledge (n=124) | | 27.4 | | | 0.012
KQ2 - What factors influence the use of colorectal cancer screening? | Adequate knowledge (n=173) | | 41.6
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | Outcomes: NA
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Outcomes: NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Outcomes: NA
QUALITY RATING: | Fair
Quality Assessment-Internal Validity for Observational Studies
| | Yes | | No | | Other (CD, NR, NA)
Were the groups similar at baseline regarding the most important prognostic indicators? | | | | | | NA
Were the drop-out or response rates acceptable (≤ 20%)? [If between 20% and 60%, check other and explain.] | | | | | | Adjusted response rate: 66%
Were the differential drop-out or response rates acceptable (≤ 15%)? | | | | | | NA
Were intervention/exposure measures valid, reliable, and equally applied? | | | | | | NA
Were the outcome assessors blinded to the intervention or exposure status of subjects? | | | | | | NA
Were outcome measures valid, reliable, and equally applied? | | X
Does the analysis control for baseline differences? | | X
Were important potential confounding and modifying variables taken into account in the design and analysis (e.g., through matching, stratification, or statistical adjustment)? | | X
Were the statistical methods used to assess the abstracted outcomes appropriate? | | X
Quality Rating (Good, Fair, or Poor): Fair Reviewer #1 initials: BLM Reviewer #2 initials: MJG Comments (explain poor quality ratings):
STUDY: | Authors, ref ID: Klabunde et al.30 Year of publication: 2005 Dates of data collection: 1999–2000 Trial name: NA
OBJECTIVE OR AIM: | The authors sought to compare barriers to CRC screening reported by primary care physicians (PCPs) and by average-risk adults, and to examine characteristics of average-risk adults who identified lack of provider recommendation as a major barrier to CRC screening.
DESIGN: | Setting: Surveys of doctors (PCPs) and patients (from NHIS) Study design: Secondary data analysis, comparison study, cross-sectional Duration (mean follow-up): No follow-up, data collected 1999–2000 Overall study size (N enrolled/N analyzed): 1,235 PCPs, 6,497 adults
| [underlined: Primary Care Physicians (PCPs]) | | | [underlined: Patients]
Sample size: | Sample size: 1,235 | | | Sample size: 6,497
Describe intervention: | Intervention: Survey of Colorectal Cancer Screening Practices (SCCSP) | | | Intervention: National Health Interview Survey (NHIS)
RECRUITMENT: (population-based, clinic-based, volunteer, other) | Population-based; Survey of Colorectal Cancer Screening Practices (SCCSP) and National Health Interview Survey (NHIS)
INCLUSION CRITERIA: | NHIS respondents age 50+ at average risk for CRC; SCCSP: PCPs (family/general practitioners, general internists, obstetrician/gynecologists)
EXCLUSION CRITERIA: | Respondents who reported having a personal or family history (ie, one or more first-degree relatives) of CRC
POPULATION CHARACTERISTICS: | NR
Mean age & range (years):
Sex (% female):
Race:
Other:
Attrition/Drop-out (not available for endpoint measurement): | [underlined: All]
Adherence: | 2 surveys with response rates exceeding 70%
Contamination:
Response Rates (e.g. for surveys):
STATISTICAL ANALYSES: | Describe: They used contingency tables with x2 tests to assess sociodemographic and health care access factors associated with average-risk adults not current with CRC screening and reporting lack of physician recommendation as their main reason. They entered variables that showed a statistically significant association in bivariate analyses at a P value of, 0.20 into 2 logistic regression models to further assess potential predictors in multivariate analyses.
ASSESSMENT OF EXPOSURES AND POTENTIAL CONFOUNDERS: | NR
OUTCOME ASSESSMENT: | Outcome Measures: Measured barriers to CRC screening identified by PCPs and average-risk adults who were not current with screening.
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | Outcomes: PCPs more often identified patient-related (80%) than health care system-related (68%) factors as major barriers. Similarly, average-risk adults who were not current with CRC screening more often identified patient-related (77%) than system-related (22%) barriers as the main reason they were not current with testing, for both FOBT and colorectal endoscopy. Although a majority of PCPs (56%) identified patient embarrassment or anxiety about CRC screening tests as a major barrier, #1% of adults indicated this as their main reason for not being current with screening. Of the system-related barriers, PCPs more often identified cost/lack of insurance coverage as a major barrier (46%) than did adults (>1%). 37% of PCPs identified failure of PCPs to actively recommend CRC screening to their patients as a major barrier, compared to approximately 20% of adults. PCPs; N, 1235; %, 67.6; 95% CI, 65.0–70.2; Adults Aged 50 or Older Who had not Been Tested Ever or Recently for FOBT: N, 6497; %, 21.6; 95% CI, 20.2–23.0 or CRE: N, 6497; %, 22.2; 95% CI, 20.9–23.6; 37% of PCPs identified failure of PCPs to actively recommend CRC screening to their patients as a major barrier, compared to approximately 20% of adults.
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and follow-up? | Outcomes: NA
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Outcomes: NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Outcomes: NA
QUALITY RATING: | Fair
Quality Assessment-Internal Validity for Observational Studies
| | Yes | | No | | Other (CD, NR, N/A)
Were the groups similar at baseline regarding the most important prognostic indicators? | | | | | | N/A
Were the drop-out or response rates acceptable (≤20%)? [If between 20% and 60%, check other and explain.] | | | | | | 2 surveys with response rates exceeding 70%
Were the differential drop-out or response rates acceptable (≤15%)? | | | | | | N/A
Were intervention/exposure measures valid, reliable, and equally applied? | | | | | | N/A
Were the outcome assessors blinded to the intervention or exposure status of subjects? | | | | | | N/A
Were outcome measures valid, reliable, and equally applied? | | X
Does the analysis control for baseline differences? | | X
Were important potential confounding and modifying variables taken into account in the design and analysis (e.g., through matching, stratification, or statistical adjustment)? | | X
Were the statistical methods used to assess the abstracted outcomes appropriate? | | X
Quality Rating (Good, Fair, or Poor): Fair Reviewer #1 initials: BLM Reviewer #2 initials: Comments (explain poor quality ratings):
STUDY: | Authors, ref ID: Koroukian, S.M., et al.31 Year of publication: 2005 Dates of data collection: 1998–1999 Trial name: NA
OBJECTIVE OR AIM: | The authors sought to study colorectal cancer screening among Medicare FFS beneficiaries in relation to levels of Medicare managed care activity (MCA).
DESIGN: | Setting: US Study design: Cross-sectional study Duration (mean followup): No follow-up, data from 1998–19999 Overall study size (N enrolled/N analyzed): 23 million (2,655 counties)
| [underlined: Low MCA] | | [underlined: Moderate MCA] | | | [underlined: High MCA]
Sample size: | Sample size: 2027 counties | | Sample size: 449 counties | | | Sample size: 179 counties
Describe intervention: | No intervention | | No intervention | | | No intervention
RECRUITMENT: (population-based, clinic-based, volunteer, other) | Population-based; 1999 population-based Outpatient Standard Analytic File (SAF) and Physician/Supplier Part B (SAF) file, 1999 Denominator file, and 1998 ARF
INCLUSION CRITERIA: | Medicare beneficiaries age 65+, counties in contiguous states and Hawaii with more than 1000 beneficiaries, or those in which total enrollment in Medicare FFS exceeded 10,000 months
EXCLUSION CRITERIA: | 8 counties without gastroenterologists or primary care physicians, as well as 36 unique area codes found in Medicare files but not in the Area Resource File (ARF); claims that carried—at the procedure level—additional diagnosis codes indicating symptoms (eg, abdominal distension, or anemia) or previous conditions, such as Crohn disease, for which surveillance was indicated; barium enema
POPULATION CHARACTERISTICS: | [underlined: Low MCA] | | [underlined: Moderate MCA] | | | [underlined: High MCA]
Mean age & range (years): | Age: 27.5% 65–69, 26% 70–74, 21% 75–79, 14% 80–854, 11% 85+ | | Age: 25% 65–69, 26% 70–74, 22% 75–79, 15% 80–84, 12% 85+ | | | Age: 23% 65–69, 26% 70–74, 23% 75–79, 13% 80–84, 13% 85+
Sex (% female): | Sex: 60% female | | Sex: 61% female | | | Sex: 61% female
Race: | Race: 91% White, 7% Black, 2% Other | | Race: 88% White, 9% Black, 3% Other | | | Race: 85% White, 6% Black, 9% Other
Other:
| [underlined: All]
Attrition/Drop-out (not available for endpoint measurement): | NA
Adherence:
Contamination:
Response Rates (e.g. for surveys):
STATISTICAL ANALYSES: | Describe: Conducted descriptive analyses to study the demographic profile and physician supply by MCA level and tested the presence of bivariate associations between categorical variables using x2 statistics. The authors used the individual as the unit of analysis, and obtained adjusted odds ratios (AORs) by employing multilevel logistic regression models to assess the likelihood of undergoing CRC screening procedure given the MCA level, after controlling for individual- and county-level characteristics.
ASSESSMENT OF EXPOSURES AND POTENTIAL CONFOUNDERS: | NR
OUTCOME ASSESSMENT: | Outcome Measures: Procedure codes for FOBT, sigmoidoscopy, and colonoscopy.
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | Outcomes: Positive association between CRC screening and greater level of MCA, adjusting for county-level sociodemographic attributes and physician resources. Greater level of MCA associated with CRC screening: High vs. low MCA: • FOBT: AOR, 1.10 (95% CI, 1.04–1.16) • Colonoscopy: AOR, 1.07 (95% CI, 1.03–1.10) • FS: AOR, 0.98 (95% CI, 0.93–1.03) No absolute screening rates given. Moderate MCA was not associated with increased use of FLEX but was positively associated with FOBT and both measures of colonoscopy. No consistent association between CRC screening and level of MCA
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | Outcomes: NA
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Outcomes: NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Outcomes: NA
QUALITY RATING: | Fair
Quality Assessment-Internal Validity for Observational Studies
| | Yes | | No | | Other (CD, NR, NA)
Were the groups similar at baseline regarding the most important prognostic indicators?
Were the drop-out or response rates acceptable (≤20%)? [If between 20% and 60%, check other and explain.] | | | | | | NA
Were the differential drop-out or response rates acceptable (≤15%)? | | X | | | | NA
Were intervention/exposure measures valid, reliable, and equally applied? | | | | X
Were the outcome assessors blinded to the intervention or exposure status of subjects? | | X
Were outcome measures valid, reliable, and equally applied? | | X
Does the analysis control for baseline differences? | | X
Were important potential confounding and modifying variables taken into account in the design and analysis (e.g., through matching, stratification, or statistical adjustment)? | | X
Were the statistical methods used to assess the abstracted outcomes appropriate? | | X | | | | But probably inadequate
Quality Rating (Good, Fair, or Poor): Fair Reviewer #1 initials: BLM Reviewer #2 initials: RPH Comments (explain poor quality ratings):
STUDY: | Authors, ref ID: Koroukian, S.M., et al.32 Year of publication: 2006 Dates of data collection: 1999 and 1998 Trial name: NA
OBJECTIVE OR AIM: | To assess the disparities in CRC screening between elderly dual Medicare-Medicaid enrollees (duals) and non-duals.
DESIGN: | Setting: 1999 Medicare Denominator File, the Medicare Outpatient Standard Analytic Files, Physician Supplier part B files, 1998 Area resource File. Study design: Cross-sectional study Duration (mean followup): No follow-up Overall study size (N enrolled/N analyzed): 23 million Medicare beneficiaries
| [underlined: Duals] | | | [underlined: Non-duals]
Sample size: | 2.5 million | | | 20.2 million
Describe intervention: | No intervention
RECRUITMENT: (population-based, clinic-based, volunteer, other) | Population-based
INCLUSION CRITERIA: | Duals: Age 65+, reside in contiguous states and Hawaii, enrolled in Medicare for the entire calendar year, and receiving care exclusively through the fee-for-service system Non-duals: No history of enrollment in the stat buy-in program for Part A and Part B, reside in county with more than 1,000 beneficiaries or 10,000 FFS months of enrollment in Medicare, whichever is more
EXCLUSION CRITERIA: | Duals: Not enrolled in the state buy-in program for Part A and Part B for all 12 months of the study year.
POPULATION CHARACTERISTICS: | [underlined: Duals] | | | [underlined: Non-duals]
Mean age & range (years): | Age: 22% 65–69, 23% 70–74, 20% 75–79, 15% 80–84, 19% 85+ | | | Age: 26% 65–69, 27% 70–74, 22% 75–79, 14% 80–84, 11% 85+
Sex (% female): | Sex: 74% female | | | Sex: 41% female
Race: | Race: 63% Caucasian, 21% African American, 16% Other | | | Race: 92% Caucasian, 5% African American, 3% Other
Other:
Attrition/Drop-out (not available for endpoint measurement): | NR
Adherence:
Contamination:
Response Rates (e.g. for surveys):
STATISTICAL ANALYSES: | Describe: Used x2 statistics to test for statistical significance in bivariate associations. Conducted stratified analyses and compared the proportions of duals and non-duals undergoing various screening modalities with demographic categories. Calculated the age-race-sex adjusted rates of screening for duals and non-duals using the direct adjustment method. Hierarchical logistic regression models Adjusted Ors were used to assess likelihood of undergoing CRC screening after controlling for individual- and county-level characteristics.
ASSESSMENT OF EXPOSURES AND POTENTIAL CONFOUNDERS: | NR
OUTCOME ASSESSMENT: | Outcome Measures: Procedure codes for FOBT, flexible sigmoidoscopy, and colonoscopy.
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | Outcomes: Duals were significantly less likely to undergo CRC screening (P < 0.001) and was consistent across all age, race, and sex strata, and procedural modalities. For all screening modalities, older age and African American race were associated with lower likelihood of undergoing screening Men were less likely to undergo FOBT (OR = 0.72, CI: 0.68, 0.76), more likely to undergo flexible sigmoidoscopy (OR=1.17, CI: 1.12, 1.22) or colonoscopy (OR=1.19, 1.15, 1.23). Use of CRC screening services decrease if dual enrollment in Medicare-Medicaid: FOBT (AOR, 0.48; 95% CI, 0.45–0.51), FS (AOR, 0.55; 95% CI, 0.49–0.61), FS or colonoscopy (AOR, 0.60; 95% CI, 0.54–0.67), colonoscopy (AOR, 0.85; 95% CI, 0.80–0.89
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | Outcomes: NA
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Outcomes: NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Outcomes: NA
QUALITY RATING: | Fair
Quality Assessment-Internal Validity for Observational Studies
\
| | Yes | | No | | Other (CD, NR, NA)
Were the groups similar at baseline regarding the most important prognostic indicators?
Were the drop-out or response rates acceptable (≤20%)? [If between 20% and 60%, check other and explain.] | | | | | | NA
Were the differential drop-out or response rates acceptable (≤15%)? | | X | | | | NA
Were intervention/exposure measures valid, reliable, and equally applied? | | | | | | NA
Were the outcome assessors blinded to the intervention or exposure status of subjects? | | | | | | NA
Were outcome measures valid, reliable, and equally applied? | | X
Does the analysis control for baseline differences? | | X
Were important potential confounding and modifying variables taken into account in the design and analysis (e.g., through matching, stratification, or statistical adjustment)? | | X
Were the statistical methods used to assess the abstracted outcomes appropriate? | | X
Quality Rating (Good, Fair, or Poor): Fair Reviewer #1 initials: BLM Reviewer #2 initials: DJH Comments (explain poor quality ratings):
STUDY: | Authors, ref ID: Lemon, S., et al. 33 Year of publication: 2001 Dates of data collection: June-August 1998 Trial name: NA
OBJECTIVE OR AIM: | The relation of personal characteristics, health and lifestyle behaviors, and cancer screening practices to current colorectal cancer (CRC) screening was assessed and compared with those factors’ relation to current mammography screening in women and prostate-specific antigen (PSA) screening in men.
DESIGN: | Setting: State Study design: Cross-sectional survey Duration (mean followup): None Overall study size (N enrolled/N analyzed): 954
| [underlined: All]
Sample size: | N = 954
Describe intervention: | Intervention: None, random digit dial survey
RECRUITMENT: (population-based, clinic-based, volunteer, other) | Population-based; random digit dial
INCLUSION CRITERIA: | Massachusetts residents 50 years and older who were cognitively able, resided in a home with a working telephone number, and had never been diagnosed with CRC
EXCLUSION CRITERIA: | Men ever diagnosed with prostate cancer and women ever diagnosed with breast cancer
POPULATION CHARACTERISTICS: | [underlined: All]
Mean age & range (years): | Age: 52.6% 50–64, 27.8% 65–74, 19.6% 75–84
Sex (% female): | Sex: 56.6% female
Race: | Race: 91% White, 9% Other
Other:
| [underlined: All]
Attrition/Drop-out (not available for endpoint measurement): | Among 1747 eligible persons contacted, 1119 (64%) completed the survey; 954 analyzed
Adherence:
Contamination:
Response Rates (e.g. for surveys):
STATISTICAL ANALYSES: | Describe: Univariate analyses were used to describe the study sample and screening prevalence. Both in the total sample and in the analyses stratified by sex, bivariate x2 statistics and odds ratios, with 95% confidence intervals, were used to document the crude relationship between each independent variable and CRC screening status. Logistic regression was used to model the association between each outcome measure and health and lifestyle behavior.
ASSESSMENT OF EXPOSURES AND POTENTIAL CONFOUNDERS: | Personal characteristics were considered potential confounders if they were marginally associated with the outcome or the exposure variables in bivariate analyses or were strongly associated in prior literature. Variables included: Demos (age, race, ethnicity, gender, marital status, education) Health factors (family history) Access (income, insurance, regular check-ups) Health/risk behavior (vitamin supplement use, screening practices, smoking)
OUTCOME ASSESSMENT: | Outcome Measures: • Patient experiences with FOBT, colonoscopy, and sigmoidoscopy • Persons were considered currently screened on the basis of recent guidelines15 if they reported having had 1 or more of the following: (1) a fecal occult blood test within the previous year; (2) flexible sigmoidoscopy within the previous 5 years; (3) colonoscopy within the previous 10 years; (4) a double contrast barium enema within the previous 10 years. This definition included those who received a CRC test for screening as well as for diagnostic reasons.
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | Outcomes: • While neither sex nor education had an independent effect, an interaction between education and sex emerged. Compared with men with a college degree or higher, those with less than a high school diploma (OR=0.11; 95% CI=0.04, 0.32; p=.001) and men with high school diplomas or some college or trade school (OR=0.31; 95% CI=0.15, 0.64; p=.002) were less likely to be currently screened. • Family history of CRC was an independent predictor of screening (OR=1.98; 95% CI= 1.02, 3.86; P = 0.04). • Compared with those with private, non-HMO insurance, members of Medicare HMO plans were significantly more likely to be currently screened (OR=2.25; 95% CI=1.13, 4.46; p=.02). • Men and women who were currently screened for PSA and mammography, respectively, were more likely to be screened for CRC than those who were not (OR=4.40; 95% CI=2.94, 6.58; p<.001). • Those who had a regular checkup (OR=3.07; 95% CI=2.00, 4.71; p<.001) and vitamin supplement users (OR=1.87; 95% CI=1.27, 2.77; p=.02) had higher screening rates.
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | NA
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | NA
QUALITY RATING: | Fair
Quality Assessment-Internal Validity for Observational Studies
| | Yes | | No | | Other (CD, NR, NA)
Were the groups similar at baseline regarding the most important prognostic indicators? | | | | | | NA
Were the drop-out or response rates acceptable (≤ 20%)? [If between 20% and 60%, check other and explain.] | | | | | | Among 1747 eligible persons contacted, 1119 (64%) completed the survey
Were the differential drop-out or response rates acceptable (≤ 15%)? | | | | | | NA
Were intervention/exposure measures valid, reliable, and equally applied? | | | | | | NA
Were the outcome assessors blinded to the intervention or exposure status of subjects? | | | | | | NA
Were outcome measures valid, reliable, and equally applied? | | X
Does the analysis control for baseline differences? | | X
Were important potential confounding and modifying variables taken into account in the design and analysis (e.g., through matching, stratification, or statistical adjustment)? | | X
Were the statistical methods used to assess the abstracted outcomes appropriate? | | X
Quality Rating (Good, Fair, or Poor): Fair
STUDY: | Authors, ref ID: Levy, B.T., et al.34 Year of publication: 2006 Dates of data collection: chart reviews were conducted from May to September 2004 Trial name:
OBJECTIVE OR AIM: | The purpose of this study was to examine patient and physician factors associated with documented CRC testing according to national guidelines.
DESIGN: | Setting: Cross-sectional study Study design: Secondary data analysis Duration (mean followup): 2004–2006 Overall study size (N enrolled/N analyzed): 511
Sample size: | 511
Describe intervention: | NA
RECRUITMENT: (population-based, clinic-based, volunteer, other) | Clinic-based; Participating physicians provided lists of their patients aged 55 to 80 years.
INCLUSION CRITERIA: | 55–80 years
EXCLUSION CRITERIA: | Physicians: Patients primarily below age 50
POPULATION CHARACTERISTICS:
Mean age & range (years): | Age range: 55–80; Mean age: 68.1
Sex (% female): | NR
Race: | 99% White
Attrition/Drop-out (not available for endpoint measurement): | Overall: 59% returned study materials
Adherence:
Contamination:
Response Rates (e.g. for surveys):
STATISTICAL ANALYSES: | Describe: The generalized estimating equations (GEE) approach in SAS PROC GENMOD was used to calculate odds ratios (ORs) and 95% confidence intervals (CIs) for potential predictors of screening, taking into account random effects due to physicians
ASSESSMENT OF EXPOSURES AND POTENTIAL CONFOUNDERS:
OUTCOME ASSESSMENT: | Outcome Measures: • The main outcome variable was whether a patient was up-to-date with CRC as determined by medical record review. • “Up-to-date” was defined as any of the following within the time interval noted from the initial mailing date: five take-home hemoccult tests within the previous 5.5 years, FS within the previous 5.5 years, barium enema within the previous 5.5 years, or colonoscopy within the previous 10.5 years. • The overall CRC testing rate was defined as (number of patients with up-to-date CRC testing)/(total number of patients).
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | Outcomes: • Overall, 76% of patients stated that their physician had ever recommended CRC testing, with 71% reporting that they had completed at least one of the CRC tests. • Based on medical record review, 55% of patients had physician documentation of a CRC screening discussion, 64% had completed at least one CRC test ever, 54% had completed at least one CRC test in the past 5.5 years, and 46% were up-to-date with CRC screening. • Not including hemoccults, of the 234 patients up-to-date with screening, 90 (38%) were truly screened and 144 (62%) were tested because of symptoms. • Results, Patient self-report, Hemoccult X 3, Doc ever recommend?, 265 (51.9); Completed Recommended test?, 231 (45.2) vs Medical record review, Hemoccult X 3, MD recommended, 87 (17.0); At least one test ever completed, 183 (35.8); Up-to-date with test, 5 (1.0); Proportion of current tests done for screening, unable to calculate; Patient self-report, FS, Doc ever recommend?, 129 (25.2); Completed Recommended test?, 114 (22.3) vs Medical record review, FS, MD recommended, 61 (11.9); At least one test ever completed, 80 (15.7); Up-to-date with test, 25 (4.9); Proportion of current tests done for screening, 15 (60.0); Patient self-report, Colonoscopy, Doc ever recommend?, 295 (57.7); Completed recommended test?, 263 (51.5) vs Medical record review, Colonoscopy, MD recommended, 220 (43.1); At least one test ever completed, 225 (44.0); Up-to-date with test, 208 (40.7); Proportion of current tests done for screening, 60 (28.9), Patient self-report, Any colon cancer screening test, Doc ever recommend?, 389 (76.1); Completed recommended test?, 360 (70.5) vs Medical record review, Any colon cancer screening test, MD recommended, 279 (54.6); At least one test ever completed, 328 (64.2); Up-to-date with test, 234 (45.8); Proportion of current tests done for screening, 90 (38.5) (not including hemoccults); Physician Predictors, Patient recalls MD recommendation, No, 218 (20.6); Yes, 283 (64.7); OR (95% CI), 6.4 (4.2–9.6); P <0.001; MD documented CRC discussion, No, 232 (14.7); Yes, 279 (71.7); OR (95% CI), 14.1 (8.5–23.3); P <0.001; Patient Perceptions/Satisfied with: Doctor’s discussions of screening importance; Low, 123 (27.6); High, 310 (59.7); OR (95% CI), 3.6 (2.5–5.3); P <0.001; MD Doctor’s discussion of screening options; Low, 152 (33.6); High, 266 (60.5); OR (95% CI), 2.8 (1.8–4.5); P <0.001; MD Input into the screening decision; Low, 144 (34.0); High, 261 (61.7) OR (95% CI), 2.9 (2.0–4.3); P <0.001; MD Comfort in asking doctor questions about CRC screening; Low, 76 (26.3); High, 400 (52.5); OR (95% CI), 3.1 (1.7–5.4); P <0.001; MD; Satisfied with doctor’s discussions of screening importance: CRC testing (up-to-date), N, 511; OR (95% CI), 3.3 (2.2–4.8); P <0.001; Asymptomatic screening, N, 367; OR (95% CI), 3.0 (1.8–5.1); P <0.001; Diagnostic testing, N, 421; OR (95% CI), 3.8 (2.5–5.7); P <0.001
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | NA
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | NA
QUALITY RATING: | Fair
Quality Assessment-Internal Validity for Observational Studies
| | Yes | | No | | Other (CD, NR, NA)
Were the groups similar at baseline regarding the most important prognostic indicators? | | | | | | Yes, if you consider the statistic adjustments made
Were the drop-out or response rates acceptable (≤ 20%)? [If between 20% and 60%, check other and explain.] | | | | | | 59% returned study materials
Were the differential drop-out or response rates acceptable (≤ 15%)? | | | | | | NA
Were intervention/exposure measures valid, reliable, and equally applied? | | X | | | | NA
Were the outcome assessors blinded to the intervention or exposure status of subjects? | | | | | | NA
Were outcome measures valid, reliable, and equally applied? | | X | | | | They looked for 5 FOBT within 5.5 years to be up-to-date, rather than 1 in the past 1 year.
Does the analysis control for baseline differences? | | X
Were important potential confounding and modifying variables taken into account in the design and analysis (e.g., through matching, stratification, or statistical adjustment)? | | X
Were the statistical methods used to assess the abstracted outcomes appropriate? | | X
Quality Rating (Good, Fair, or Poor): Fair
STUDY: | Authors, ref ID: Ling, B.S., et al.35 Year of publication: 2006 Dates of data collection: 2002–2003 Trial name: Health Information National Trends Survey (HINTS)
OBJECTIVE OR AIM: | Assessed the association between provider–patient interaction with colorectal cancer screening utilization and compared the information seeking patterns, sources of information, trust in cancer information, and Internet usage among respondents who were up to date with colorectal cancer screening with those who were not.
DESIGN: | Setting: Telephone survey Study design: Cross-sectional, econdary data analysis Duration (mean followup): 2002–2003 administration of the HINTS Overall study size (N enrolled/N analyzed): 2,670 respondents
Sample size: | 2,670 respondents
Describe intervention:
RECRUITMENT: (population-based, clinic-based, volunteer, other) | List-assisted random digit dialing
INCLUSION CRITERIA: | 51 years and greater
EXCLUSION CRITERIA: | Those 50 or younger; prior personal history of CRC
POPULATION CHARACTERISTICS: | [underlined: Sample]
Mean age & range (years): | Age: 51+; 39.6% 51–60, 29.3% 61–70, 30.1% 71+
Sex (% female): | Sex: 63.1% female
Race: | Race: 80% White, 10.5% African American, 9.5% Other
Other:
Attrition/Drop-out (not available for endpoint measurement): | Overall response rate 62.8%
Adherence:
Contamination:
Response Rates (e.g. for surveys):
STATISTICAL ANALYSES: | Describe: Descriptive statistics were generated for all variables as frequencies or means. Chi-square tests were conducted to assess for significant differences in the primary outcome variable with regard to the categorical variables The association between continuous variables and the primary outcome was assessed using the nonparametric Wilcoxon rank-sum test. For those communication=information-related items found significantly associated with colorectal cancer screening behavior, logistic regression models were used to assess for adjusted effect after controlling for all respondent characteristics.
ASSESSMENT OF EXPOSURES AND POTENTIAL CONFOUNDERS: | NR
OUTCOME ASSESSMENT: | Outcome Measures: Provider-patient interaction, information seeking, channel reliance, channel credibility, internet usage, and colon cancer screening behavior measures The primary outcome variable was colorectal cancer screening defined as being up to date or not.
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | Outcomes: No statistically significant differences were seen between the up-to-date and not-up-to-date groups for each of the provider–patient interaction items (“the provicer always: listens carefully, explains things, shows respect, spends enough time, involves patients in decisions”. Conversely, for information seeking, the up-to-date group had a statistically significant higher percentage who had sought cancer information (52.9% vs. 36.8%, P<.001) and had others do the information search (21.9% vs. 12.5%, P<.001). Significant differences were seen in the percentage of respondents between the groups in the desire for cancer information from personalized reading materials (p<.05) and publications (P<.001). As for trust in cancer information from specific sources, an overwhelming percentage trusted the doctor in both the up-to-date (95.4%) and not-up-to-date (88.4%) groups, with a significant difference seen between the groups (P<.001). When asked about Internet usage, among those who go on-line, 63% in the up-to-date group use it to look up cancer information compared with the 54.8% who are not up to date (P<.01). Logistic regression models showed that having trust in cancer information from the doctor was most predictive for being up to date (OR 2.08, 95% CI 1.49–2.94). Other items remaining significantly associated with being up to date included the following: searched for cancer information, had others search for cancer information, desired cancer information from personalized reading materials or a publication, and used the Internet for cancer information. Trust in MD associated with greater screening. Other interaction items not significant.
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | Outcomes: NA
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Outcomes: NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Outcomes: NA
QUALITY RATING: | Fair
Quality Assessment-Internal Validity for Observational Studies
| | Yes | | No | | Other (CD, NR, NA)
Were the groups similar at baseline regarding the most important prognostic indicators? | | | | | | NA
Were the drop-out or response rates acceptable (≤ 20%)? [If between 20% and 60%, check other and explain.] | | | | | | response rate 62.8%
Were the differential drop-out or response rates acceptable (≤ 15%)? | | | | | | NA
Were intervention/exposure measures valid, reliable, and equally applied? | | X | | | | NA
Were the outcome assessors blinded to the intervention or exposure status of subjects? | | | | | | NA
Were outcome measures valid, reliable, and equally applied? | | X
Does the analysis control for baseline differences? | | X
Were important potential confounding and modifying variables taken into account in the design and analysis (e.g., through matching, stratification, or statistical adjustment)? | | X
Were the statistical methods used to assess the abstracted outcomes appropriate? | | X
Quality Rating (Good, Fair, or Poor): Fair Reviewer #1 initials: BLM Reviewer #2 initials: MJG Comments (explain poor quality ratings):
STUDY: | Authors, ref ID: Matthews, B., et al.36 Year of publication: 2007 Dates of data collection: Spring 2005 Trial name: NA
OBJECTIVE OR AIM: | The purpose of this study was to examine potential indicators of success in a geographic area of the US that has previously shown relatively high CRC screening rates. Our goal was to survey a representative sample of approximately 1050 age-appropriate southeastern Wisconsin residents regarding their health beliefs, behaviors, and current CRC screening status.
DESIGN: | Setting: Wisconsin, telephone survey Study design: Cohort survey study Duration (mean followup): No follow-up Overall study size (N enrolled/N analyzed): 1,068 interviews completed/1,033 interviews analyzed
| [underlined: All]
Sample size: | Sample size: 1,033
Describe intervention: | Intervention: None, survey
RECRUITMENT: (population-based, clinic-based, volunteer, other) | Population-based, random digit dial
INCLUSION CRITERIA: | Age between 50–79, English proficiency, and informed consent for research participation.
EXCLUSION CRITERIA: | Only one person per household, previous diagnosis of CRC
POPULATION CHARACTERISTICS: | [underlined: All]
Mean age & range (years): | Age: 52.9% 50–64, 47.1% 65–79
Sex (% female): | Sex: 56.1% female
Race: | Race: 9.3% Other, 90.7% White
Other:
| [underlined: All]
Attrition/Drop-out (not available for endpoint measurement): | Simple response rate of 88% Using CASRO formula the response rate was 60.7%.
Adherence:
Contamination:
Response Rates (e.g. for surveys):
STATISTICAL ANALYSES: | Describe: Contingency tables (v2) were used to test bivariate relations; logistic regression was used to generate multivariate models. Because of the large number of potential indicators, authors used bivariate analysis to identify variables to be included in multivariate analyses
ASSESSMENT OF EXPOSURES AND POTENTIAL CONFOUNDERS: | Variables included: Demographics (county of residence, age, gender, race, education) Health care (have regular MD, freq of visits, annual physicals, MD recomm for screening) Health factors (screening behavior, family/personal history, exercise, eating) Access (health insurance) Care behavior/pscyho (worries about cancer) KABRs (knowledge of CRC, beliefs, locus of control)
OUTCOME ASSESSMENT: | Outcome Measures: FOBT within 12 months preceding the survey, FS within 5 years, or CS within 10 years
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | Outcomes: Adults 65 to 79 were more than twice as likely to report up-to-date test use as adults age 50 to 64 (OR = 2.38; 95%CI = 1.76–3.21) Respondents who reported visiting a physician regularly were more likely to report being current with screening (AOR 2.02; 95% CI, 1.49–2.74) Respondents were more likely to be screened if they believed the tests are safe (AOR, 1.39; 95% CI, 1.09–1.78); that it’s irresponsible not to get tested (AOR, 2.16; 95% CI, 1.67–2.78); or had a positive attitude about screening in general (AOR, 2.35; 95% CI, 1.76–3.13); P-values 0.05 or better Respondents were less likely to be screened if they had anxiety about the tests (AOR, 0.50; 95% CI, 0.49–0.64) or believed that if they are healthy, they don’t need to be tested (AOR, 0.58; 95% CI, 0.42–0.79); P-values 0.05 or better The odds of up-to-date screening test use increased twofold among individuals who reported visiting their physicians on a regular basis (OR = 2.11; 95% CI = 1.41–3.16), for those at higher risk for CRC because of familial or personal risk factors (OR = 2.26, 95% CI = (1.47–3.49), and among those who reported using their physicians as their primary source of health information (OR = 2.27, 95% CI = 1.33–3.90). The odds of up-to-date screening test use increased about 68% among individuals who participated in other cancer screening tests such as breast or prostate cancer exams (OR = 1.68, 95% CI = (1.20–2.37). Adherence, as reflected by compliant attitudes toward physician recommendation to test for CRC (OR 2.54, 95% CI = 1.75–3.67), and responsibility to test for CRC by age 55 showed the strongest effects, increasing the odds of current testing by about 150% to 140%, respectively, compared to non-current test use. The odds of current testing decreased about 40% among respondents reporting greater anxiety about CRC testing procedures (OR = 1.40 , 95% CI = 1.02–1.92) and about 48% among those who thought there was no reason for healthy people to test for CRC (OR = 0.52, 95% CI = 0.35–0.77).
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | Outcomes: NA
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Outcomes: NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Outcomes: NA
QUALITY RATING: | Fair
Quality Assessment-Internal Validity for Observational Studies
| | Yes | | No | | Other (CD, NR, NA)
Were the groups similar at baseline regarding the most important prognostic indicators? | | | | | | NA
Were the drop-out or response rates acceptable (≤ 20%)? [If between 20% and 60%, check other and explain.] | | | | | | Simple response rate of 88% Using CASRO formula the response rate was 60.7%.
Were the differential drop-out or response rates acceptable (≤ 15%)? | | | | | | NA
Were intervention/exposure measures valid, reliable, and equally applied? | | | | | | NA
Were the outcome assessors blinded to the intervention or exposure status of subjects? | | | | | | NA
Were outcome measures valid, reliable, and equally applied? | | X
Does the analysis control for baseline differences? | | | | | | NA
Were important potential confounding and modifying variables taken into account in the design and analysis (e.g., through matching, stratification, or statistical adjustment)? | | X
Were the statistical methods used to assess the abstracted outcomes appropriate? | | X
Quality Rating (Good, Fair, or Poor): Fair Reviewer #1 initials: BLM Reviewer #2 initials: DJH Comments (explain poor quality ratings):
STUDY: Are there gender differences in colorectal cancer test use prevalence and correlates | Authors, ref ID: McQueen, et al.37 Year of publication: 2006 Dates of data collection: Data from 2002 to 2003 HINTS used Trial name: data from HINTS used
OBJECTIVE OR AIM: | Addressed the following questions: (a) Are prevalence rates for lifetime, recent, and repeat FOBT and endoscopy similar for males and females? (b) Are the demographic, health status, access to health care, and health behavior correlates of FOBT and endoscopy use previously reported in the literature similar for males and females? (c) Are the patterns of these correlates similar to findings from other national surveys? (d) Are psychosocial variables in the HINTS, including knowledge, cancer-related beliefs, and cancer communication, associated with FOBT and endoscopy use, and are the associations similar for males and females?
DESIGN: | Setting: US Study design: cross sectional; HINTS was a cross-sectional study conducted from 2002 to 2003 using random digit dialing Duration (mean followup): data collected for 1 year, no follow-up data reported Overall study size (N enrolled/N analyzed): 2686
Sample size: | Of the 6,369 telephone surveys completed by adults ages >= 18 years, 2,734 were ages >=50 years. Of those, 2,686 had no personal history of colon or rectal cancer and comprised the sample used in this report
Describe intervention: NA | NA
RECRUITMENT: (population-based, clinic-based, volunteer, other) | Population based through telephone interviews: random digit dialing
INCLUSION CRITERIA: | One adult (>=18 years) per household was eligible to participate.
EXCLUSION CRITERIA: | Personal history of colon or rectal cancer
POPULATION CHARACTERISTICS: Mean age & range (years): Sex (% female): Race: Other: | 63% were female and 74% were non-Hispanic White. The average age was 64.4 years old (SD = 10.4 years) and ranged from 50 to 95 years
Attrition/Drop-out (not available for endpoint measurement): | Telephone interviewers were able to reach 19,509 households. The final response rate for an initial screening interview was 55%, calculated according to the guide of Standard Definitions published by the American Association for Public Opinion Research. The final response rate for the full HINTS interview was 62.8%. Full details of the sampling plan are reported elsewhere
Adherence:
Contamination:
Response Rates (e.g. for surveys):
STATISTICAL ANALYSES: | Telephone exchanges were geographically stratified to oversample from exchanges estimated to have 15% African American and Hispanic residents. Final data were weighed to be nationally representative. Stratified analyses by gender instead of testing interactions with gender to explore differences in the patterns of associations. Descriptive analyses were conducted using SAS and Survey Data Analysis (SUDAAN) to report both observed sample sizes and weighed percentages Prevalence of Colorectal Cancer Test Use: Examined colorectal cancer test use prevalence rates by gender for lifetime, recent, and repeat use of home FOBT, sigmoidoscopy, and colonoscopy alone and in combination, as well as whether any of the three tests had been completed. Used 95% confidence intervals (95% CI) to compare the rates for males and females. Prevalence estimates were age adjusted. The denominator for repeat colorectal cancer test use was restricted to respondents who would be eligible to complete two screening tests (i.e., two FOBTs within 2 years or two endoscopy tests within 20 years). Conducted analyses using SUDAAN software and a replicate weight jackknife estimate of variance to account for the sampling design and to calculate appropriate population estimates; therefore, the results reflect weighed and design-adjusted data. Additionally, reasons for not completing a colorectal cancer test have been previously reported but have not been examined for gender differences. Identifying gender-specific and test-specific barriers to colorectal cancer test use may be important for future interventions designed to increase colorectal cancer test use. To explore whether reasons for not being tested differed by gender, conducted descriptive analyses with a subset of respondents who had seen a health care provider in the past year but had not had a colorectal cancer test within recommended time intervals. Respondents could give multiple reasons for not having had a FOBT or endoscopy. Categorized responses into patient- or system level factors following Klabunde et al. (25). Correlates of Colorectal Cancer Test Use. Used multivariable logistic regression analysis with SUDAAN to examine correlates of colorectal cancer test use by gender and test type (FOBT and endoscopy), thereby creating four regression models (one for each combination). Two dependent variables were home FOBT use in the past year and recent endoscopy (i.e., sigmoidoscopy or colonoscopy in the past 10 years). The reference group for both variables was no colorectal cancer test of any type within recommended intervals. Used ORs and 95% CIs to summarize the results. CIs for males and females that do not overlap may suggest gender differences. Analysis Strategy. To facilitate comparison with other national surveys, used a two-step analysis procedure for all four regression models. In step 1, examined variables measuring demographics, access to health care, health status, and health behaviors that have been previously examined with nationally representative samples and explored whether their associations with colorectal cancer test use differed by gender. Correlates that were statistically significant (P < 0.05) in at least one of the four models in step 1 were retained in all step 2 regression models. In step 2, added variables from the HINTS that have not been previously examined in national surveys (i.e., knowledge, beliefs, and cancer communication). Family history of cancer has been consistently associated with colorectal cancer test use in the literature and was retained in step 2, although it was not statistically significant in step 1. Because results did not change when this variable was removed from analyses, chose to retain it to enable comparisons with other studies. Effect estimates with cell sizes V 5 were not presented. “Don’t know” or missing responses were included when the percent of missing data was large and potentially meaningful (e.g., income and perceived risk) or when “don’t know” was similar in meaning to a valid “no opinion” response choice (e.g., cancer beliefs).
ASSESSMENT OF EXPOSURES AND POTENTIAL CONFOUNDERS: | HINTS survey collected information on: demographic variables, access to health care, health status, health behaviors, knowledge of CRC screening guidelines, beliefs about cancer risk, beliefs about colorectal cancer test use, beliefs about cancer in general, “cancer worry”, “degree to which participants paid attention to any health or medical topics via television, radio, newspapers, magazines, or the Internet”, trust in information from these sources, trust in healthcare providers/family/friends for cancer information, cancer information seeking behavior
OUTCOME ASSESSMENT: | To assess colorectal cancer test use, individuals were first read a description of one of three test types (home FOBT, sigmoidoscopy, and colonoscopy) and asked whether they had ever heard of the test (no/yes). Respondents who had heard of the test were then asked whether they had ever had the test (lifetime use: no/yes), when the test was completed, and when the next-to-last test was completed. Persons who reported experience with both sigmoidoscopy and colonoscopy were asked to report when their most recent endoscopic test was completed. The survey did not distinguish which endoscopy test was the most recent and so responses reflected either procedure. Individuals were considered currently adherent to guidelines for colorectal cancer testing if they reported having a home FOBT within the past year or endoscopy within the past 10 years. Use of double contrast barium enema was not assessed in the HINTS.
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | Females reported slightly higher lifetime (ever) and recent use of FOBT than males (17.1% lifetime and 9.3% recent for female; and 12.1% lifetime and 5.2% recent for male) Males and females who visited a physician 1 or more times in the previous year were more likely to be screened by endoscopy than those with no visits in the prior year (AOR 5.12; 95% CI, 2.54–10.29 and OR 4.89; 95% CI, 1.79–13.37, respectively; P < 0.05) “Not having a doctor” was associated with not being screened for CRC in both males (AOR, 0.1; 95% CI, 0.0–0.5 for FOBT and OR, 0.5; 95% CI, 0.1–1.9 for endoscopy) and females (AOR, 0.2; 95% CI, 0.1–0.8 for FOBT and OR, 0.5; 95% CI, 0.2–1.4 for endoscopy) Males and females were more likely to be screened if they understood the appropriate time intervals for FOBT (AOR, 5.42; 95% CI, 2.52–11.66 for males and AOR, 5.25; 95% CI, 3.23–8.52 for female) and endoscopy (AOR, 4.69; 95% CI, 2.55–8.65 and AOR, 3.18; 95% CI, 2.26–4.47, respectively) Females were more likely to be screened if they believed they were more likely than others to be diagnosed with CRC (AOR, 2.53; 95% CI, 1.43–4.46 for endoscopy); if they believed CRC testing leads to early detection (AOR, 3.03; 95% CI, 1.03–8.93 for FOBT); or if they had a fear of finding cancer (AOR, 1.78; 95% CI, 1.18–2.68) Males and females were less likely to be screened if they didn’t know if the tests were too expensive (0.43; 95% CI, 0.24–0.78 and 0.46; 95% CI, 0.30–0.71 for endoscopy, respectively) Females were also less likely to be screened with FOBT if they believed it was too expensive (AOR, 0.55; 95% CI, 0.32–0.93) or didn’t know the costs (AOR, 0.46; 95% CI, 0.27–0.79) All P values < 0.05
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | Outcomes: NA
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Outcomes: NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Outcomes: NA
QUALITY RATING: | Good
Quality Assessment-Internal Validity for Observational Studies
| | Yes | | No | | Other (CD, NR, NA)
Were the groups similar at baseline regarding the most important prognostic indicators? | | | | | | n/a
Were the drop-out or response rates acceptable (≤ 20%)? [If between 20% and 60%, check other and explain.] | | X | | | | As mentioned, response rate for full HINTS interview as >60%
Were the differential drop-out or response rates acceptable (≤ 15%)? | | | | | | n/a
Were intervention/exposure measures valid, reliable, and equally applied? | | X
Were the outcome assessors blinded to the intervention or exposure status of subjects? | | | | | | n/a
Were outcome measures valid, reliable, and equally applied? | | X | | | | Self-report may have overestimated screening, but this was equal across all participants
Does the analysis control for baseline differences? | | X
Were important potential confounding and modifying variables taken into account in the design and analysis (e.g., through matching, stratification, or statistical adjustment)? | | X
Were the statistical methods used to assess the abstracted outcomes appropriate? | | X
Quality Rating (Good, Fair, or Poor): good Reviewer #1 initials: MJG Reviewer #2 initials: DJH Comments (explain poor quality ratings):
STUDY: | Authors, ref ID: Messina, CR, et al.38 Year of publication: 2009 Dates of data collection: October 2004 – January 2005 (Group 1), April 2004 – July 2004 (Group 2) Trial name: NA
OBJECTIVE OR AIM: | To examine the use of CRC screening exam modalities among county health centers and private physician offices, where both were located in the same geographic area.
DESIGN: | Setting: telephone survey of Suffolk County, New York residents Study design: Cross-sectional Duration (mean follow-up): NA Overall study size (N enrolled/N analyzed): N = 1070 enrolled and analyzed
| [underlined: Group 1 (County Health Center Patient)] | | [underlined: Group 2 (Private Physician Patient)]
Sample size: | n = 570 | | n = 570
Describe intervention: | NA (no intervention – cross-sectional telephone survey) | | NA
RECRUITMENT: (population-based, clinic-based, volunteer, other) | Population-based – details: Group 1: The authors randomly selected participants from sampling frame of adults who were age-eligible for CRC screening and who received primary care at Suffolk county health centers. They stratified random sample selection by health center to balance proportions of participants from each. Group 2: The authors obtained data for the random population-based private physician patient sample as part of our NCI-funded Reducing Barriers to Colorectal Cancer Screening Project. They oversampled adults aged 65–75 years and conducted random selection in blocks stratified on gender and age group.
INCLUSION CRITERIA: | Group 1: (1) be without a prior diagnosis of CRC, colonic polyps, or other colorectal diagnoses requiring surveillance rather than screening in the general population (e.g., UC or Crohn’s); (2) not be too impaired to answer questions; (3) consent to the telephone survey; (4) speak either English or Spanish; (5) age-eligible for CRC screening; and (6) receive care at the county health centers. Group 2: Same as above but only included English speaking participants
EXCLUSION CRITERIA: | Group1: none listed Group 2: none listed
POPULATION CHARACTERISTICS: | [underlined: Group 1] | | [underlined: Group 2]
Mean age & range (years): | Age 52–64 (vs. 65–75): 76% (n =382) | | Age 52–64 (vs. 65–75): 48% (n =270)
Sex (% female): | Female: 68% | | Female: 59%
Race: | Race/ethnicity White (non-Hispanic): 47% Hispanic: 29% African American (non-Hispanic): | | Race/ethnicity White (non-Hispanic): 94% Hispanic: <1% African American (non-Hispanic):
Other: | 20% Other: 5% Education <HS: 34% HS graduate: 32% Post HS/trade school/technical school/some college: 22% ≥ College degree: 10% Annual household income <$15,000: 50% $15,000–$24,999: 25% $25,000–$44,999: 16% ≥ $45,000: 9% Medical insurance coverage No insurance: 44% Medicare/Medicaid: 49% Other commercial: 6% HMO: 2% Survey language English (vs. Spanish): 80% | | 4% Other: 2% Education <HS: 4% HS graduate: 29% Post HS/trade school/technical school/some college: 29% ≥ College degree: 38% Annual household income <$15,000: 5% $15,000–$24,999: 7% $25,000–$44,999: 17% ≥ $45,000: 71% Medical insurance coverage No insurance: 3% Medicare/Medicaid: 5% Other commercial: 59% HMO: 33% Survey language English (vs. Spanish): 100%
| [underlined: Group 1] | | [underlined: Group 2] | | | Overall
Attrition/Drop-out (not available for endpoint measurement): | NA | | NA
Adherence:
Contamination:
Response Rates (e.g. for surveys): | Response Rate: 52% | | Response Rate: 47%
STATISTICAL ANALYSES: | Describe: Bivariate cross-tabular analyses and Chi-square tests of association were used to examine the relationship between source of primary care, participant characteristics, CRC screening, and barriers to screening. Bivariate analyses stratified by age group identified potential confounders. Logistic regression analyses were used to evaluate the probability of reporting recent screening for each screening modality separately, for the health center and private practice patient samples. All participant characteristics were included in the multivariate model. They computed odds ratios from maximum-likelihood parameter estimates, and calculated 95% confidence intervals. They reported the Nagelkerke R^2^ as an indicator of the usefulness of the explanatory variables to predict CRC screening.
ASSESSMENT OF EXPOSURES AND POTENTIAL CONFOUNDERS: | Multivariate logistic regression controlled for potential covariate effects of sociodemographic, health status and screening barrier variables
OUTCOME ASSESSMENT: | Outcome Measures: They determined CRC screening exam use by responses to questions asking whether the participant had ever had FOBT, sigmoidoscopy, or colonoscopy, and the date of each most recent exam. They based screening intervals for FOBT and sigmoidoscopy on guidelines from the ACS, the Interdisciplinary Task Force, and the U.S. Preventive Services Task Force
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | Outcomes: • Overall (considering the three screening modalities), the private physician patient sample reported higher CRC screening than the county health center registrants (70% vs. 55%, P < 0.001). While a greater proportion of county health center registrants reported an FOBT in the past year (37% vs. 31%, P < 0.042), private patients were more likely to report a recent endoscopy (59% vs. 33%, P < 0.001). • For the most part, the authors did not find CRC screening disparities associated with any of the sociodemographic variables or self-reported health status in adjusted analyses. Exceptions to this are as follows: • County health center participants with a college education were significantly more likely to report recent sigmoidoscopy than those with less than a college education (AOR = 3.23, 95% CI (1.08 – 9.64), P = 0.04). • Among county health center participants, other commercial/HMO insurance coverage was associated with significantly with lower odds of FOBT (OAR = 0.35, 95% CI (0.14 – 0.91) P = 0.02), while Medicare/Medicaid significantly with greater odds of sigmoidoscopy (OAR = 2.72, 95% CI (1.18 – 6.25) P = 0.02) or colonoscopy (OAR = 2.11, 95% CI (1.17 – 3.80) P =0.01), compared with no coverage. • African American (vs. white) adults (OAR = 0.17, 95% CI (0.05 – 0.52), P < 0.001) and those with a high school education (OAR = 0.40, 95% CI (0.21 – 0.73), P < 0.001) were significantly less likely to report recent colonoscopy. • No physician recommendation and other perceived barriers to screening contributed to decreased CRC screening among county health center and private physician office participants. • Results of multivariate logistic regression models describing screening barriers associated with recent CRC screening among users of private physician offices • CHC patients less frequently cited no physician recommendation as a barrier to FOBT, but more frequently cited no recommendation as a barrier to FS and colonoscopy, compared with PPO patients (p<0.02)
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and follow-up? | NA
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | NA
QUALITY RATING: | Fair
Quality Assessment-Internal Validity for Observational Studies
| | Yes | | No | | Other (CD, NR, NA)
Were the groups similar at baseline regarding the most important prognostic indicators? | | X
Were the drop-out or response rates acceptable (≤ 20%)? [If between 20% and 60%, check other and explain.] | | | | | | X – The response rates were 47% for private physician participants and 52% for CHC participants, indicating a possibility of selection bias. Those who didn’t participate in the survey could differ in a significant way from those who did.
Were the differential drop-out or response rates acceptable (≤15%)? | | | | | | NA
Were intervention/exposure measures valid, reliable, and equally applied? | | | | | | NA
Were the outcome assessors blinded to the intervention or exposure status of subjects? | | | | | | NA
Were outcome measures valid, reliable, and equally applied? | | | | | | Used validated, NHIS survey items and CRC screening behavior/attitudinal questions piloted prior to this study
Does the analysis control for baseline differences? | | X
Were important potential confounding and modifying variables taken into account in the design and analysis (e.g., through matching, stratification, or statistical adjustment)? | | X
Were the statistical methods used to assess the abstracted outcomes appropriate? | | X
Quality Rating (Good, Fair, or Poor): Fair
STUDY: | Authors, ref ID: Muus, K, et al.39 Year of publication: 2009 Dates of data collection: 2004–2005 Trial name: NA
OBJECTIVE OR AIM: | To describe the prevalence of FOBT testing (and PSA testing for prostate cancer) within the past year by age and rurality and to determine whether or not BMI is associated with receipt of FOBT (and PSA) among American Indian and Alaska Native men.
DESIGN: | Setting: National survey of American Indian and Alaska Native men conducted by the National Resource Center on Native American Aging Study design: secondary analysis of cross-sectional data Duration (mean followup): NA Overall study size (N enrolled/N analyzed): 2447
Sample size: | N = 2447
Describe intervention: | No intervention; survey only
RECRUITMENT: (population-based, clinic-based, volunteer, other) | Population-based convenience sample recruited through tribal service areas
INCLUSION CRITERIA: | Complete records for all model covariates, self-report of never having been diagnosed with colorectal cancer (or prostate cancer)
EXCLUSION CRITERIA: | NR
POPULATION CHARACTERISTICS: | FOBT in Past Year | | No FOBT in Past Year
Mean age & range (years): | Age 55–64 34% 65–74: 40% ≥75: 27% | | Age 55–64 42% 65–74: 39% ≥75: 19%
Sex (% female): | Male: 100% | | Male: 100%
Race: | Race: 100% American Indian or Alaska Native | | Race: 100% American Indian or Alaska Native
Other: | Residence Urban: 20% Large rural: 20% Small rural: 18% Isolated rural: 43% | | Residence Urban: 20% Large rural: 17% Small rural: 17% Isolated rural: 46%
Attrition/Drop-out (not available for endpoint measurement): | NA
Adherence:
Contamination:
Response Rates (e.g. for surveys): | NR
STATISTICAL ANALYSES: | Describe: The authors compared the frequency distributions for all independent variables by screening status, and assessed the association of FOBT testing by creating a logistic regression model that modeled the log-odds of FOBT receipt within the past year as a functional BMI category and the covariates.
ASSESSMENT OF EXPOSURES AND POTENTIAL CONFOUNDERS: | Covariates were derived from the literature as potential confounders and included in the logistic regression model. Covariates included were: age, marital status, education, limitations in activities of daily living, smoking status, health insurance coverage, and rurality of residence
OUTCOME ASSESSMENT: | Outcome Measures: FOBT assessed through the question, “How long has it been since you had your last blood stool test using a home kit?”
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | Outcomes: • Having an FOBT was associated with higher age (P < .001), being married (P < .001), being unemployed during the past year(P < .001), having a regular health care provider (P < .001), having health insurance (P < .01), having higher numbers of limitations in activities of daily living (P < .001), and being a non-smoker (P < .001). • Prevalence of FOBT use in past year in urban areas did not differ by age. In rural regions, men aged 65 and older showed a higher prevalence of recent FOBTs than younger men. • Adjusted screening odds ratios for FOBT screening in past year by BMI category showed that (using underweight, BMI < 18.5, as the reference group in logistic regression models) BMI was not associated with FOBT screening (data below).
KQ2 - What factors influence the use of colorectal cancer screening? | BMI Category | | OR | | | 95% CI -
KQ2 - What factors influence the use of colorectal cancer screening? | Underweight | | 1 | | | (0.5, 2.0)
KQ2 - What factors influence the use of colorectal cancer screening? | Healthy | | 1 | | | (0.5, 2.0)
KQ2 - What factors influence the use of colorectal cancer screening? | Overweight | | 1 | | | (0.5, 2.2)
KQ2 - What factors influence the use of colorectal cancer screening? | Obese I | | 1 | | | (0.4, 1.9)
KQ2 - What factors influence the use of colorectal cancer screening? | Obese II | | 0.9 | | | (0.3, 1.8)
KQ2 - What factors influence the use of colorectal cancer screening? | Obese III | | 0.8
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | NA
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | NA
QUALITY RATING: | Fair
Quality Assessment-Internal Validity for Observational Studies
| | Yes | | No | | Other (CD, NR, NA)
Were the groups similar at baseline regarding the most important prognostic indicators? | | | | | | NA
Were the drop-out or response rates acceptable (≤ 20%)? [If between 20% and 60%, check other and explain.] | | | | | | NR – They report that 94 out of 243 regional tribal service areas agree to participate, but they do not report anything at the individual participant level
Were the differential drop-out or response rates acceptable (≤15%)? | | | | | | NR
Were intervention/exposure measures valid, reliable, and equally applied? | | X
Were the outcome assessors blinded to the intervention or exposure status of subjects? | | | | | | NR
Were outcome measures valid, reliable, and equally applied? | | | | X | | Self-reported of FOBT status in past year is subject to recall and social desirability bias
Does the analysis control for baseline differences? | | | | | | NA
Were important potential confounding and modifying variables taken into account in the design and analysis (e.g., through matching, stratification, or statistical adjustment)? | | X
Were the statistical methods used to assess the abstracted outcomes appropriate? | | X
Quality Rating (Good, Fair, or Poor): Fair
STUDY: | Authors, ref ID: Nguyen et al.40 Year of publication: 2008 Dates of data collection: July to October 2004 Trial name: NA
OBJECTIVE OR AIM: | Describe the baseline colorectal screening rates among participants in an on-going intervention study designed to increase such screening in Vietnamese Americans aged 50 to 74, identifies factors associated with screening, and recommends educational strategies to increase screening rates in this population.
DESIGN: | Setting: Telephone interview Study design: Baseline survey Duration (mean followup): only a one-time call Overall study size (N enrolled/N analyzed): 867
Sample size: | 867
Describe intervention: | NA (Telephone survey
RECRUITMENT: (population-based, clinic-based, volunteer, other) | A cross-sectional sample was drawn from a sampling frame consisting of all individuals in the study area telephone directories with Vietnamese surnames previously used in a number of Vietnamese American studies
INCLUSION CRITERIA: | 1) self-identified as Vietnamese or Vietnamese American, 2) aged 50 to 74, 3) lived in Alameda or Santa Clara Counties, California or Harris County, Texas, and intended to stay in this study area for 2 years, and 4) understood either English or Vietnamese.
EXCLUSION CRITERIA: | Anyone not fitting inclusion criteria and those who already completed interviews.
POPULATION CHARACTERISTICS: | [underlined: Sample]
Mean age & range (years): | Range: 50–74 [29% 50–54; 22% 55–59; 22% 60–64; 27% 65–74]
Sex (% female): | 47%
Race: | 100% Vietnamese or Vietnamese American
| [underlined: Sample]
Attrition/Drop-out (not available for endpoint measurement): | The remaining call attempts reached 1,044 eligible respondents, of which 894 agreed to complete the interview for a response rate of 86%.
Adherence:
Contamination:
Response Rates (e.g. for surveys):
STATISTICAL ANALYSES: | Describe: Frequency distributions were tabulated for demographics, health care characteristics, knowledge and attitudes, and colorectal screening rates. Multiple logistic regression models were developed to identify factors associated with such screening. The demographics, healthcare characteristics, and knowledge and attitudes were selected to be independent variables in the models because these variables were found to be associated with cancer screening test utilization among Vietnamese Americans in previous studies
ASSESSMENT OF EXPOSURES AND POTENTIAL CONFOUNDERS: | NR
OUTCOME ASSESSMENT: | Outcome Measures: The dependent variables were colorectal cancer screening test 1) recognition, 2) receipt, 3) currency, and 4) intention.
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | Outcomes: • Factors positively associated with ever having been screened were being in the older age group (65 to 74 years), residing in California, having private or public insurance, having a regular place of care, having a personal doctor, having heard of colon polyps, worrying about colon cancer, thinking might develop colon cancer, thinking need FOBT and sigmoidoscopy/colonoscopy even if feel healthy, and thinking sigmoidoscopy/colonoscopy preparation troublesome. All significant. • Factors negatively associated included having annual household income less than $20,000, being employed, having a Vietnamese doctor, and thinking sigmoidoscopy/colonoscopy painful. All significant • In general, the rates of colorectal screening recognition, receipt, currency, and intention were low. 48% had ever had: FOBT, 20% Sigmoidoscopy, 26% Colonoscopy, 62% any test • 25% were up-to-date on FOBT, 16% were up-to-date on FS, and 23% were up-to-date on colonoscopy
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | Outcomes: NA
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Outcomes: NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Outcomes: NA
QUALITY RATING: | Fair
Quality Assessment-Internal Validity for Observational Studies
| | Yes | | No | | Other (CD, NR, NA)
Were the groups similar at baseline regarding the most important prognostic indicators? | | | | | | NA
Were the drop-out or response rates acceptable (≤20%)? [If between 20% and 60%, check other and explain.] | | X
Were the differential drop-out or response rates acceptable (≤15%)? | | | | | | NA
Were intervention/exposure measures valid, reliable, and equally applied? | | | | | | NA
Were the outcome assessors blinded to the intervention or exposure status of subjects? | | | | | | NA
Were outcome measures valid, reliable, and equally applied? | | X
Does the analysis control for baseline differences? | | X
Were important potential confounding and modifying variables taken into account in the design and analysis (e.g., through matching, stratification, or statistical adjustment)? | | X
Were the statistical methods used to assess the abstracted outcomes appropriate? | | X
Quality Rating (Good, Fair, or Poor): Fair Reviewer #1 initials: BLM Reviewer #2 initials: DJH Comments (explain poor quality ratings):
STUDY: | Authors, ref ID: O’Malley et al.41 Year of publication: 2002 Dates of data collection: January 2000 - March 2000 Trial name: NA
OBJECTIVE OR AIM: | Examine the effects of primary care, health insurance, and HMO participation on adherence to regular breast, cervical, and colorectal cancer screening
DESIGN: | Setting: low income communities in DC Study design: RDD and targeted telephone survey Duration (mean follow-up): NA Overall study size (N enrolled/N analyzed): 1205 in sample
Sample size: | 1205
Describe intervention: | NA
RECRUITMENT: (population-based, clinic-based, volunteer, other) | List of telephone numbers to obtain a 25% RDD (from phone exchanges in low income census tracts) and 75% targeted listed households
INCLUSION CRITERIA: | female, over 40 years, residing in DC in low income areas
EXCLUSION CRITERIA:
POPULATION CHARACTERISTICS:
Mean age & range (years): | 64.8 years (16.3% 41–49 years)
Sex (% female): | 100%
Race: | 82.7% Black
Other: | 26.5% living as married 84.8% had a regular doctor 13.2% uninsured
Attrition/Drop-out (not available for endpoint measurement): | NA
Adherence:
Contamination:
Response Rates (e.g. for surveys): | 85%
STATISTICAL ANALYSES: | Describe: chi-square and log reg
ASSESSMENT OF EXPOSURES AND POTENTIAL CONFOUNDERS: | Age, household income, race/ethnicity, education, work status, marital status, family size, health status, cancer knowledge/attitudes and beliefs, insurance status and plan type, features of primary care and patient-clinician relationship
OUTCOME ASSESSMENT: | Outcome Measures: adherence to FOBT use--for this, 990 is the sample size since that’s only women 52 and older (they say that’s to allow those 50–52 time to get one)
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | Outcomes: factors statistically significant with self-reported FOBT in the past 2 years (P < 0.01): no regular site of care or regular clinician going to a provider that provides less comprehensive care reported low levels of compassion, trust or communication in the physician/pt relationship all insurance levels
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and follow-up? | Outcomes: NA
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Outcomes: NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Outcomes: NA
QUALITY RATING: | Fair
Quality Assessment-Internal Validity for Observational Studies
| | Yes | | No | | Other (CD, NR, N/A)
Were the groups similar at baseline regarding the most important prognostic indicators? | | | | | | N/A
Were the drop-out or response rates acceptable (≤20%)? [If between 20% and 60%, check other and explain.] | | X | | | | 85% response rate
Were the differential drop-out or response rates acceptable (≤15%)? | | | | | | N/A
Were intervention/exposure measures valid, reliable, and equally applied? | | | | | | N/A
Were the outcome assessors blinded to the intervention or exposure status of subjects? | | | | | | NR
Were outcome measures valid, reliable, and equally applied? | | | | | | some were used before but it's unclear which and they did little to control for confounders
Does the analysis control for baseline differences? | | | | X
Were important potential confounding and modifying variables taken into account in the design and analysis (e.g., through matching, stratification, or statistical adjustment)? | | X
Were the statistical methods used to assess the abstracted outcomes appropriate? | | X
Quality Rating (Good, Fair, or Poor): Fair Reviewer #1 initials: DJH Reviewer #2 initials: LCM Comments (explain poor quality ratings):
STUDY: | Authors, ref ID: O’Malley AS et al.42 Year of publication:2005 Dates of data collection: Used the year 2000 Medicare Current Beneficiary Survey (MCBS) data Trial name:NA
OBJECTIVE OR AIM: | To (1) quantify the size of any racial differences in the receipt of CRC screening among Medicare beneficiaries and the extent to which racial differences were confounded by socioeconomic status (SES); (2) determine which features of the health care system, in addition to having a usual health care provider, were associated with higher screening rates; and (3) ascertain whether these features differed for socioeconomic and racial groups of beneficiaries.
DESIGN: | Setting: Population-based, Medicare part A and B beneficiaries with a usual physician Study design: Cross-sectional Duration (mean followup): NA Overall study size (N enrolled/N analyzed): N=9985
Sample size: | N=9985
Describe intervention: | NA
RECRUITMENT: (population-based, clinic-based, volunteer, other) | Population-based from the 2000 Medicare enrollment file
INCLUSION CRITERIA: | • Medicare part A and B beneficiaries • Having a usual physician
EXCLUSION CRITERIA: | • Racial groups other than “black” or “white” • Persons who were institutionalized • < 65 years • End-stage renal disease • Not having a usual physician • Persons with a prior diagnosis of CRC • Persons with gastrointestinal symptoms • Persons with large amounts of missing data
POPULATION CHARACTERISTICS: | Frequency (N=11,154) | | | | | Weighted % (SE)
Mean age & range (years)
65–74 | 4492 | | | | | 44.9 (0.004)
≥75 | 6662 | | | | | 55.1 (0.004)
Sex (% female): | 6518 | | | | | 58.6 (0.004)
Race/ethnicity
White | 10,133 | | | | | 91.7 (0.005)
Black | 1021 | | | | | 8.2 (0.005)
Other:
Health status
Excellent–very good | 4592 | | | | | 42.1 (0.006)
Good | 3704 | | | | | 33.3 (0.005)
Fair-poor | 2828 | | | | | 24.5 (0.005)
Education
≥High school diploma | 7423 | | | | | 68.5 (0.009)
No high school diploma | 3731 | | | | | 31.5 (0.009)
Income
>50 000 | 1205 | | | | | 10.8 (0.003)
20 001–50 000 | 4618 | | | | | 41.4 (0.004)
≤20 000 | 5320 | | | | | 47.7 (0.006)
Additional insurance
Private Medigap policy | 7257 | | | | | 67.7 (0.009)
Medicaid (dual eligible) | 993 | | | | | 8.2 (0.004)
No other insurance | 2618 | | | | | 24.1 (0.008)
Attrition/Drop-out (not available for endpoint measurement): | NA
Adherence: | NA
Contamination: | NA
Response Rates (e.g. for surveys): | 84%
STATISTICAL ANALYSES: | Describe: Univariate, bivariate, and stratified analyses were performed, including assessment for interaction. Logistic regression models were then built. First, race (with age and sex) was entered into the model. Then other beneficiary characteristics were added, followed by the health system characteristics. A hierarchical model was then constructed to assess whether there was any significant clustering of MCBS respondents among physicians. Sampling weights accounting for the multistage sample design and non-response were used to obtain national estimates with SAS callable SUDAAN
ASSESSMENT OF EXPOSURES AND POTENTIAL CONFOUNDERS: | Exposure: Self-reported receipt of recent CRC screening (a home fecal occult blood test had been performed in the past 12 months, a flexible sigmoidoscopy was received in the past 5 years, or a colonoscopy was performed in the past 5 years) Independent Variables: Beneficiary • Race • SES (income and education) Health care financing • Insurance Delivery system • Physician specialty • Perceived quality of care • Availability of specialists, • HMO status Confounders • Age • ^~^Sex • Attitudes toward health care • Health status • Rural V urban residence • Awareness of CRC • Frequency of physician out-patient visits
OUTCOME ASSESSMENT: | Outcome Measures: Factors which influence the self-reported receipt of recent CRC screening including: • Home fecal occult blood test had been performed in the past 12 months • Flexible sigmoidoscopy was received in the past 5 years • Colonoscopy was performed in the past 5 years
KQ2 – What factors influence the use of colorectal cancer screening? | Summary: Unadjusted rates of screening were 48.2% (95% CI 46.4–50.0) for white and 39.1% (95% CI 35.7–46.2) for black beneficiaries (P< 0.001). Racial differences in CRC screening receipt were eliminated after adjustment for socioeconomic status as measured by income and education. SES remained significant after adjusting for other personal and health system factors Outcomes: Adjusted odds of receiving CRC screening: OR (95% CI)
Race
• White | 1.00 (0.82–1.16)
• Black | 1.0 (Reference)
Age, y
• ≥75 | 0.86 (0.79–0.93)
• 65–74 | 1.0 (Reference)
Sex
• Female | 0.87 (0.79–0.97)
• Male | 1.0 (Reference)
Education
• College degree or higher | 1.79 (1.55–2.07)
• Some college High school/vocational | 1.51 (1.30–1.76)
• diploma 1 | 1.23 (1.12–1.36)
• No high school diploma | 1.0 (Reference
Income (annual household), $
• >50 000 | 1.53 (1.27–1.85)
• 20 001–50 000 1. | 1.30 (1.17–1.45)
• <20 000 | 1.0 (Reference)
Urban (vs rural reference group) | 1.12 (0.97–1.31)
Supplementary insurance
• Medicaid | 0.87 (0.70–1.09)
• Private supplementary policy | 1.23 (1.07–1.42)
• No supplementary insurance | 1.0 (Reference)
Aware of colorectal cancer | 2.76 (2.29–3.33)
Attitudes toward health care
• More favorable | 1.23 (1.14–1.33)
• Less favorable | 1.0 (Reference)
Health status
• Excellent–very good | 0.98 (0.87–1.12)
• Good | 1.08 (0.95–1.24)
• Fair-poor | 1.0 (Reference)
Outpatient physician visits in past year (excludes ED visits)
• ≥4 | 1.47 (1.31–1.64)
• ≤3 | 1.0 (Reference)
Information giving by usual physician
• Higher rating | 1.12 (1.00–1.25)
• Lower rating (poorer) | 1.0 (Reference)
Usual physician type
• Primary care generalist | 1.31 (1.12–1.53)
• Specialty other than primary care | 1.0 (Reference)
HMO (vs fee for service) | 1.56 (1.34–1.82)
Availability of specialists
• Higher rating | 1.32 (1.16–1.50)
• Lower rating | 1.0 (Reference)
KQ3 – Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | NA
KQ4 – What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | NA
KQ5 – What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | NA
QUALITY RATING: | Fair
Quality Assessment-Internal Validity for Observational Studies
| | Yes | | No | | Other (CD, NR, NA)
Were the groups similar at baseline regarding the most important prognostic indicators? | | | | | | NR
Were the drop-out or response rates acceptable (≤20%)? [If between 20% and 60%, check other and explain.] | | X
Were the differential drop-out or response rates acceptable (≤15%)? | | | | | | NA
Were intervention/exposure measures valid, reliable, and equally applied? | | | | | | NA
Were the outcome assessors blinded to the intervention or exposure status of subjects? | | | | | | NR
Were outcome measures valid, reliable, and equally applied? | | X
Does the analysis control for baseline differences? | | X
Were important potential confounding and modifying variables taken into account in the design and analysis (e.g., through matching, stratification, or statistical adjustment)? | | X
Were the statistical methods used to assess the abstracted outcomes appropriate? | | X
Quality Rating (Good, Fair, or Poor): Fair
STUDY: Colorectal cancer screening among men and women in the United States | Authors, ref ID: Peterson, et al.43 Year of publication: 2007 Dates of data collection: 2000 NHIS Trial name: NA
OBJECTIVE OR AIM: | To explore gender differences in use of CRC screening tests and gender-specific correlates of CRC testing
DESIGN: | Setting: United States Study design: Cross-sectional Duration (mean followup): no f/u data reported Overall study size (N enrolled/N analyzed): 32,374 survey, 11,487 met criteria for this study
Sample size: | 11,487
Describe intervention:
RECRUITMENT: (population-based, clinic-based, volunteer, other) | Population based, national household survey The 2000 supplement (e.g., Cancer Control Module) was administered to 32,374 adults >= 18 years of age; response rate was 72%
INCLUSION CRITERIA: | Men and women >= 50 years of age without a prior diagnosis of CRC were considered eligible for analysis of CRC screening
EXCLUSION CRITERIA:
POPULATION CHARACTERISTICS (stratified by sex): | | Men (n=4782) | | | Women (n=6705)
POPULATION CHARACTERISTICS (stratified by sex): | Age | % | (95% CI) | | % | (95% CI)
POPULATION CHARACTERISTICS (stratified by sex): | 50–64 | 59.6 | (57.8–61.4) | | | (52.5–55.3)
POPULATION CHARACTERISTICS (stratified by sex): | 65–74 | 24 | (22.5–25.4) | | | (23.6–25.8)
POPULATION CHARACTERISTICS (stratified by sex): | 75 + | 16.5 | (15.3–17.7) | | | (20.3–22.6)
POPULATION CHARACTERISTICS (stratified by sex): | Race
POPULATION CHARACTERISTICS (stratified by sex): | Non-Hispanic white | 81.7 | (80.4–83.0) | | 81.7 | (80.6–82.9)
POPULATION CHARACTERISTICS (stratified by sex): | Non-Hispanic black | 8.1 | (7.2–9.2) | | 9.4 | (8.6–10.3)
POPULATION CHARACTERISTICS (stratified by sex): | Hispanic | 6.8 | (6.1–7.7) | 53.9 | 6.6 | (6.0–7.3)
POPULATION CHARACTERISTICS (stratified by sex): | Non-Hispanic other | 3.3 | (2.7–4.1) | 24.7 | 2.3 | (1.8–2.8)
POPULATION CHARACTERISTICS (stratified by sex): | Education | | | 21.4
POPULATION CHARACTERISTICS (stratified by sex): | Less than high school | 23.3 | (22.0–24.7) | | 23 | (21.6–24.3)
POPULATION CHARACTERISTICS (stratified by sex): | High school diploma | 27.8 | (26.3–29.3) | | 36.9 | (35.4–38.3)
POPULATION CHARACTERISTICS (stratified by sex): | Some college, no degree | 15.7 | (14.5–16.8) | | 16 | (15.0–17.0)
POPULATION CHARACTERISTICS (stratified by sex): | College degree or higher | 33.3 | (31.6–34.9) | | 24.2 | (22.9–25.5)
POPULATION CHARACTERISTICS (stratified by sex): | Family income
POPULATION CHARACTERISTICS (stratified by sex): | <=$20,000 | 19.8 | (18.6–21.2) | | 30 | (28.7–31.3)
POPULATION CHARACTERISTICS (stratified by sex): | >$20,000 | 80.2 | (78.9–81.4) | | 70 | (68.7–71.3)
POPULATION CHARACTERISTICS (stratified by sex): | Insurance
POPULATION CHARACTERISTICS (stratified by sex): | Private | 77.9 | (76.5–79.2) | | 73.7 | (72.4–74.9)
POPULATION CHARACTERISTICS (stratified by sex): | Public | 15 | (13.9–16.2) | | 19.5 | (18.4–20.6)
POPULATION CHARACTERISTICS (stratified by sex): | None | 7.1 | (6.3–8.1) | | 6.9 | (6.2–7.6)
POPULATION CHARACTERISTICS (stratified by sex): | Reported functional limitation | 42.2 | (40.5–43.9) | | 55 | (53.5–56.4)
POPULATION CHARACTERISTICS (stratified by sex): | Reported usual source of care | 91.8 | (90.9–92.6) | | 94.8 | (94.1–95.4)
POPULATION CHARACTERISTICS (stratified by sex): | Reported family history of CRC | 7.8 | (6.9–8.7) | | 8.3 | (7.6–9.0)
Attrition/Drop-out (not available for endpoint measurement): | NA
Adherence:
Contamination:
Response Rates (e.g. for surveys): | As above, response rate 72% for NHIS
STATISTICAL ANALYSES: | • Bivariate analysis to characterize factors associated with CRC screening by gender using Wald chi-square statistics. Two-tailed P values ≤0.05 were considered statistically significant • Separate multivariable logistic regression models for each gender to explore the relationship between CRC screening testing and factors of interest • The Survey Data Analysis computer package was used to calculate variance estimations • To reflect U.S. population estimates and adjust for nonresponse, the results were weighted using SAS version 9.1
ASSESSMENT OF EXPOSURES AND POTENTIAL CONFOUNDERS: | Sociodemographic factors included age, gender, ethnicity/ race, education, annual income, and insurance type. Age was categorized as 50–64, 65–74, and >=75. Race/ethnicity categories were non-Hispanic white, Non-Hispanic black, Hispanic, and other. Educational status was categorized as less than high school, high school diploma, some college but no degree, and college degree or higher. Dichotomous group for income (<$20,000 vs. >=$20,000). Insurance type was considered private if respondents reported having a private insurance plan, military plan, CHAMPUS, or Tricare. Public insurance included Medicaid, Medicare without private supplementation, Indian Health Service, or other public assistance, such as a state-sponsored plan. Persons who reported no insurance type or single service plan were classified as having none. Considered the presence of self-reported functional limitation, having a usual place to receive medical care, reported first-degree family history of CRC, and receipt of other preventive care (influenza vaccine in the last year, pneumovax ever, and, for women, current mammography in the last 2 years, Pap smear in the last 3 years, and for men, prostate-specific antigen [PSA] testing in the last 2 years).
OUTCOME ASSESSMENT: | Participants asked if they ever had a sigmoidoscopy, colonoscopy, or proctoscopy. If they answered affirmatively, they were then asked which test they had received (sigmoidoscopy, colonoscopy, proctoscopy, or something else) and were read definitions of the tests if necessary. Subjects who responded positively that they had previously undergone a screening test were asked when they had their most recent test. Persons who reported that they had never undergone the test or who had not had the test recently (sigmoidoscopy or colonoscopy in the last 10 years or FOBT in the last year) were asked to provide the main reason (no reason, did not need it, doctor did not offer, no problems, put it off, too expensive, too painful, had another examination, no doctor, other). Subjects who had not had recent screening were also asked if a doctor or other health professional had recommended a screening test in the past year.
Results
KQ2 - What factors influence the use of colorectal cancer screening? | Adjusted Odds Ratios and 95 % CI Predicting Current CRC Testing Among Men and Women
KQ2 - What factors influence the use of colorectal cancer screening? | | All | | Men | | Women
KQ2 - What factors influence the use of colorectal cancer screening? | Gender | OR | (95% CI) | OR | (95% CI) | OR | (95% CI)
KQ2 - What factors influence the use of colorectal cancer screening? | Male | 1 | — | NA | NA | NA | NA
KQ2 - What factors influence the use of colorectal cancer screening? | Female | 0.98 | (0.88–1.08)
KQ2 - What factors influence the use of colorectal cancer screening? | Age
KQ2 - What factors influence the use of colorectal cancer screening? | 50–64 | 1 | — | 1 | — | 1 | —
KQ2 - What factors influence the use of colorectal cancer screening? | 65–74 | 1.78 | (1.58–2.01) | 1.5 | (1.25–1.79) | 1.82 | (1.55–2.14)
KQ2 - What factors influence the use of colorectal cancer screening? | 75 + | 1.4 | (1.22–1.61) | 1.28 | (1.03–1.59) | 1.53 | (1.27–1.85)
KQ2 - What factors influence the use of colorectal cancer screening? | Race
KQ2 - What factors influence the use of colorectal cancer screening? | Non-Hispanic white | 1 | — | 1 | — | 1 | —
KQ2 - What factors influence the use of colorectal cancer screening? | Non-Hispanic black | 0.92 | (0.78–1.07) | 0.98 | (0.73–1.31) | 0.79 | (0.65–0.95)
KQ2 - What factors influence the use of colorectal cancer screening? | Hispanic | 0.79 | (0.64–0.96) | 0.78 | (0.58–1.05) | 0.75 | (0.56–1.01)
KQ2 - What factors influence the use of colorectal cancer screening? | Non-Hispanic other | 0.56 | (0.39–0.80) | 0.72 | (0.45–1.14) | 0.52 | (0.31–0.86)
KQ2 - What factors influence the use of colorectal cancer screening? | Education
KQ2 - What factors influence the use of colorectal cancer screening? | Less than high school | 1 | — | 1 | — | 1 | —
KQ2 - What factors influence the use of colorectal cancer screening? | High school diploma | 1.41 | (1.23–1.62) | 1.39 | (1.12–1.74) | 1.22 | (1.01–1.47)
KQ2 - What factors influence the use of colorectal cancer screening? | Some college, no degree | 1.55 | (1.32–1.81) | 1.36 | (1.06–1.75) | 1.44 | (1.16–1.78)
KQ2 - What factors influence the use of colorectal cancer screening? | College degree or higher | 2.12 | (1.84–2.44) | 1.93 | (1.54–2.41) | 1.73 | (1.40–2.14)
KQ2 - What factors influence the use of colorectal cancer screening? | Family income
KQ2 - What factors influence the use of colorectal cancer screening? | <=$20,000 | 0.81 | (0.71–0.92) | 0.86 | (0.70–1.06) | 0.93 | (0.79–1.10)
KQ2 - What factors influence the use of colorectal cancer screening? | >$20,000 | 1 | — | 1 | — | 1 | —
KQ2 - What factors influence the use of colorectal cancer screening? | Insurance
KQ2 - What factors influence the use of colorectal cancer screening? | Private | 1 | — | 1 | — | 1 | —
KQ2 - What factors influence the use of colorectal cancer screening? | Public | 0.77 | (0.67–0.88) | 0.87 | (0.69–1.09) | 0.79 | (0.66–0.94)
KQ2 - What factors influence the use of colorectal cancer screening? | None | 0.51 | (0.40–0.64) | 0.51 | (0.35–0.74) | 0.71 | (0.51–1.00)
KQ2 - What factors influence the use of colorectal cancer screening? | Reported functional limitation
KQ2 - What factors influence the use of colorectal cancer screening? | No | 1 | — | 1 | — | 1 | —
KQ2 - What factors influence the use of colorectal cancer screening? | Yes | 1.41 | (1.27–1.55) | 1.42 | (1.21–1.67) | 1.38 | (1.21–1.57)
KQ2 - What factors influence the use of colorectal cancer screening? | Reported usual source of care
KQ2 - What factors influence the use of colorectal cancer screening? | No | 0.3 | (0.24–0.39) | 0.42 | (0.28–0.61) | 0.47 | (0.32–0.69)
KQ2 - What factors influence the use of colorectal cancer screening? | Yes | 1 | — | 1 | — | 1 | —
KQ2 - What factors influence the use of colorectal cancer screening? | Reported first-degree family history of CRC
KQ2 - What factors influence the use of colorectal cancer screening? | No | 1 | — | 1 | — | 1 | —
KQ2 - What factors influence the use of colorectal cancer screening? | Yes | 2.08 | (1.77–2.43) | 1.96 | (1.51–2.54) | 2.21 | (1.82–2.69)
KQ2 - What factors influence the use of colorectal cancer screening? | Had mammogram in the last 2 years (women only)
KQ2 - What factors influence the use of colorectal cancer screening? | No | NA | NA | NA | NA | 0.25 | (0.21–0.29)
KQ2 - What factors influence the use of colorectal cancer screening? | Yes | | | | | 1 | —
KQ2 - What factors influence the use of colorectal cancer screening? | Had PSA testing in the last 2 years (men only)
KQ2 - What factors influence the use of colorectal cancer screening? | No | NA | NA | 0.29 | (0.25–0.34) | NA | NA
KQ2 - What factors influence the use of colorectal cancer screening? | Yes | | | 1 | —
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | Outcomes: NA
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Outcomes: NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | NA
QUALITY RATING: | Good
Quality Assessment-Internal Validity for Observational Studies
| | Yes | | No | | Other (CD, NR, NA)
Were the groups similar at baseline regarding the most important prognostic indicators? | | | | | | n/a
Were the drop-out or response rates acceptable (≤ 20%)? [If between 20% and 60%, check other and explain.] | | x | | | | NHIS RR > 70%, but I don’t see mention of response rate for those aged >= 50.
Were the differential drop-out or response rates acceptable (≤ 15%)? | | | | | | n/a
Were intervention/exposure measures valid, reliable, and equally applied? | | x
Were the outcome assessors blinded to the intervention or exposure status of subjects? | | | | | | n/a
Were outcome measures valid, reliable, and equally applied? | | x | | | | Self-report, but equal across all participants
Does the analysis control for baseline differences? | | x
Were important potential confounding and modifying variables taken into account in the design and analysis (e.g., through matching, stratification, or statistical adjustment)? | | x
Were the statistical methods used to assess the abstracted outcomes appropriate? | | x
Quality Rating (Good, Fair, or Poor): Good Reviewer #1 initials: MJG Reviewer #2 initials: DJH Comments (explain poor quality ratings):
STUDY: | Authors, ref ID: Pham HH, et al.44 Year of publication: 2005 Dates of data collection: 2001 Trial name: NA (secondary analysis of CTS)
OBJECTIVE OR AIM: | To identify characteristics of physicians and their practices that are associated with the quality of preventive care their patients receive.
DESIGN: | Setting: National primary care physician survey Study design: Cross-sectional, retrospective study Duration (mean follow-up): NA Overall study size (N enrolled/N analyzed): 3,660 physicians, 24, 581 patients
Sample size: | 3,660 physicians, 24, 581 patients
Describe intervention: | NA (survey)
RECRUITMENT: (population-based, clinic-based, volunteer, other) | Population-based Data from Community Tracking Study (CTS)
INCLUSION CRITERIA: | Primary care delivered by physicians providing usual care for Medicare beneficiaries ≥ 65 yrs
EXCLUSION CRITERIA: | Cancer diagnosis, ID-9-CM or V codes: 153, 154.0, 154.1, V10.05, V10.06
POPULATION CHARACTERISTICS:
Mean age & range (years): | NR (≥ 65 yrs)
Sex (% female): | NR
Race:
Other:
Attrition/Drop-out (not available for endpoint measurement): | NA
Adherence:
Contamination:
Response Rates (e.g. for surveys):
STATISTICAL ANALYSES: | Individual beneficiaries were the unit of analysis. Each patient was assigned to a single usual-source-of-care physician, but each physician could serve as the usual source of care for multiple beneficiaries. Reported percentages are therefore weighted to represent estimates for the national population of Medicare beneficiaries aged 65 years and older, using CTS survey weights to take into account the complex physician sampling strategy. Authors used logistic regression to analyze the association between physician and practice characteristics and beneficiary delivery of each of the 6 preventive services. We used SUDAAN software to adjust estimates and variances given the complex survey sampling strategy and the clustering of beneficiaries within physicians.25 This study was approved by the institutional review contractor for Mathematica Inc. P = .05 was set as significant.
ASSESSMENT OF EXPOSURES AND POTENTIAL CONFOUNDERS: | NR
OUTCOME ASSESSMENT: | Proportion of eligible beneficiaries receiving each of 6 preventive services: diabetic monitoring with hemoglobin A_1c_ measurement or eye examinations, screening for colon (colonoscopy/FS) or breast cancer, and vaccination for influenza or pneumococcus (self-report and claims)
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | Association between CRC screening and physician specialty (patients cared for by family physicians 9.9% vs. patients cared for by general internists 7.8%, P < 0.001); board certification (board certified 9.5% vs. not board certified 6.5%, P < 0.05); and site of medical school graduation (US or Canada 9.3% vs. non-US or Canada 7.7%, P < 0.05). No statistically significant association between CRC screening among patients cared for by physicians in different practice types (e.g., medium/large group vs. solo/two-person group: AOR, 1.12 [95% CI, 0.90–1.38]). Patients cared for by physicians with access to reminders were not more likely to have been screened: 5.8% with reminders vs. 5.9% without reminders (adjusted AOR, 0.96 [95% CI, 0.84–1.09])
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and follow-up? | NA
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | NA
QUALITY RATING: | Fair
Quality Assessment-Internal Validity for Observational Studies
| | Yes | | No | | Other (CD, NR, N/A)
Were the groups similar at baseline regarding the most important prognostic indicators? | | | | | | CD
Were the drop-out or response rates acceptable (≤ 20%)? [If between 20% and 60%, check other and explain.] | | | | | | NA
Were the differential drop-out or response rates acceptable (≤ 15%)? | | | | | | NA
Were intervention/exposure measures valid, reliable, and equally applied? | | | | | | NR
Were the outcome assessors blinded to the intervention or exposure status of subjects? | | X
Were outcome measures valid, reliable, and equally applied? | | X
Does the analysis control for baseline differences? | | X
Were important potential confounding and modifying variables taken into account in the design and analysis (e.g., through matching, stratification, or statistical adjustment)?
Were the statistical methods used to assess the abstracted outcomes appropriate? | | X
Quality Rating (Good, Fair, or Poor): Fair
STUDY: | Authors, ref ID: Rosen, A.B., Schneider, E.C.45 Year of publication: 2004 Dates of data collection: 1999 Trial name: NA
OBJECTIVE OR AIM: | To evaluate whether there is an association between body mass index (BMI) and rates of colorectal cancer screening. To examine whether BMI-related disparities in colorectal cancer screening differ between men and women.
DESIGN: | Setting: National telephone survey Study design: Cross-sectional, Secondary data analysis Duration (mean follow-up): No follow-up, one-time data collection Overall study size (N enrolled/N analyzed): 52,886 respondents
| [underlined: Normal Weight] | | [underlined: Overweight] | | Obese | [underlined: Morbidly Obese]
Sample size: | Sample size: 19,826 | | Sample size: 21,285 | | Sample size: 8,315 | Sample size: 3,460
Describe intervention: | No intervention, responded to BRFFS | | No intervention, responded to BRFFS | | No intervention, responded to BRFFS | No intervention, responded to BRFFS
RECRUITMENT: (population-based, clinic-based, volunteer, other) | Population-based, BRFFS
INCLUSION CRITERIA: | Age 50 to 80
EXCLUSION CRITERIA: | Did not know, or refused, to report their CRC screening status, did not report height or weight, BMI<15.5 kg/m^2^, older than 80
POPULATION CHARACTERISTICS: | [underlined: Normal Weight] | | [underlined: Overweight] | | [underlined: Obese] | [underlined: Morbidly Obese]
Mean age & range (years): | Age range: 50–80 | | Age range: 50–80 | | Age range: 50–80 | Age range: 50–80
| Age: 53.5% 50–64, 32.1% 65–74, 14.5% 75+ | | Age: 58.4% 50–64, 30.6% 65–74, 11% 75+ | | Age: 78% 50–64, 9.9% 65‐74, 10% 75+ | Age: 75.4% 50–64, 13.9% 65–74, 8.3% 75+
Sex (% female): | Sex: 61.8% female | | Sex: 44.7% female | | Sex: 50.6% female | Sex: 62% female
Race: | Race: 83.3% White (non-Hispanic), 5.9% Black (non-Hispanic), 6.7% Hispanic, 4.2% other | | Race: 80.2% White (non- Hispanic), 8.5% Black (non-Hispanic), 8.7% Hispanic, 2.7% other | | Race: 78% White (non-Hispanic), 9.9% Black (non-Hispanic), 10% Hispanic, 2.2% other | Race: 75.4% White (non-Hispanic), 13.9% Black (non-Hispanic), 8.3% Hispanic, 2.4% other
Attrition/Drop-out (not available for endpoint measurement): | NA
Adherence:
Contamination:
Response Rates (e.g. for surveys): | Median response rate = 68.4%
STATISTICAL ANALYSES: | Describe: • Respondents were stratified based on BMI and tabulated the characteristics of each group • Association between BMI and CRC screening using multiple logistic regression to control for potential confounders was assessed • Examined the results for trends and then separately compared each overweight/obese group to the corresponding group with normal BMI
ASSESSMENT OF EXPOSURES AND POTENTIAL CONFOUNDERS: | • Examined several factors thought to be potential confounders of the relationship between obesity and screening • Sociodemographic factors included age, gender, ethnicity, education, marital status, income, and census region • Other variables examined as potential confounders included self-reported health status, smoking status, time since last check-up, and lack of insurance coverage for any part of the past year.
OUTCOME ASSESSMENT: | Outcome Measures: • Classified an individual as having had colorectal cancer screening if he or she reported undergoing either FOBT within the last year or endoscopic screening within the last 5 years • Each respondent’s BMI was calculated as weight in kilograms divided by height in meters squared
Results
KQ2 - What factors influence the use of colorectal cancer screening? | Outcomes: • The rate of screening for morbidly obese respondents was 39.5%, significantly lower than the rate for obese (45.0%), overweight (44.3%), or normal weight (43.5%) groups. • Those who were less than 65 years of age (P < 0.0001), female (P = 0.0018), Hispanic (P < 0.0001), not high school graduates (P< 0.0001), widowed, divorced, or separated (P < .0001), had low incomes (P < .0001), were uninsured for part or all of the past year (P < .0001), current smokers (P < 0.0001) and those respondents whose last checkups were over 1 year ago (P < .0001) were less likely to be screened than their counterparts. • Respondents who reported fair or poor health status were more likely to be screened than others. • Residents of the Northeast were significantly more likely and residents of the South were significantly less likely to be screened than others (data NR) • Morbidly obese females were less likely than females with a normal body mass index to receive CRC screening (AOR, −5.6; 95% CI, −2.6 to −8.5). • There were no obesity-related disparities in screening rates for males.
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | Outcomes: NA
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Outcomes: NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Outcomes: NA
QUALITY RATING: | Fair
Quality Assessment-Internal Validity for Observational Studies
| | Yes | | No | | Other (CD, NR, NA)
Were the groups similar at baseline regarding the most important prognostic indicators? | | | | X | | Some characteristics were different between the weight categories, such as age, sex, and ethnicity
Were the drop-out or response rates acceptable (≤ 20%)? [If between 20% and 60%, check other and explain.] | | | | | | 69% response rate for those reached by phone
Were the differential drop-out or response rates acceptable (≤15%)? | | | | | | NR
Were intervention/exposure measures valid, reliable, and equally applied? | | | | | | NA
Were the outcome assessors blinded to the intervention or exposure status of subjects? | | | | | | NA
Were outcome measures valid, reliable, and equally applied? | | X
Does the analysis control for baseline differences? | | X
Were important potential confounding and modifying variables taken into account in the design and analysis (e.g., through matching, stratification, or statistical adjustment)? | | X
Were the statistical methods used to assess the abstracted outcomes appropriate? | | X
Quality Rating (Good, Fair, or Poor): Fair Reviewer #1 initials: BLM Reviewer #2 initials: DJH Comments (explain poor quality ratings):
STUDY: | Authors, ref ID: Schenck AP, Klabunde CN, Davis WW46 Year of publication: 2006 Dates of data collection: 2001 Trial name: NA
OBJECTIVE OR AIM: | In an attempt to increase understanding of predictors of CRC test use and the role of race, an investigation of CRC test use among African Americans and whites enrolled in the Medicare program was initiated.
DESIGN: | Setting: Telephone survey Study design: Observational cross-sectional study Duration (mean followup): No follow-up, one-year date collection Overall study size (N enrolled/N analyzed): 1,321 White; 580 African American
| [underlined: All]
Sample size: | Sample size: 1,321 White; 580 African American
Describe intervention: | Intervention: Telephone survey designed to assess baseline consumer knowledge, awareness, and use of CRC test
RECRUITMENT: (population-based, clinic-based, volunteer, other) | Population-based, telephone survey
INCLUSION CRITERIA: | Age 50–80, no history of CRC
EXCLUSION CRITERIA: | No personal history of CRC
POPULATION CHARACTERISTICS: | [underlined: Whites] | | [underlined: African Americans]
Mean age & range (years): | Age: 8.46% age 50–64, 65.23% age 65–74, 26.31% age 75–80 | | Age: 15.02% age 50–64, 60.9% age 65–74, 24.08% age 75–80
Sex (% female): | Sex: 55.58% Female | | Sex: 60.61% Female
Race:
Other:
| [underlined: All]
Attrition/Drop-out (not available for endpoint measurement):
Adherence:
Contamination:
Response Rates (e.g. for surveys): | Cooperation rate = 69%
STATISTICAL ANALYSES: | Describe: • A series of nested multivariate logistic regression analyses were conducted to assess thea independent association of race by category of CRC test use. • Unadjusted models were constructed using a single predictor variable for African American compared with white race.
ASSESSMENT OF EXPOSURES AND POTENTIAL CONFOUNDERS: | Additional questions assessed respondents’ awareness that CRC risk increases with age, that both genders are at risk for the disease, and their perceived susceptibility to colorectal cancer. Access to medical care was assessed through two survey questions asking whether the respondent had a primary care provider, and had visited a physician for a checkup in the past 12 months. Respondents’ history of CRC and chronic health conditions also were assessed in the survey. CRC risk status was determined by three factors: physician counseling that the respondent was at high risk for colorectal cancer, a family member with colorectal cancer, or a history of having polyps removed. Additional demographic information, obtained from the Medicare Enrollment Database, included date of birth, race, gender, and eligibility for Medicaid, which was used as a proxy for low income.
OUTCOME ASSESSMENT: | Outcome Measures: • Colorectal cancer test use was determined by describing each test (FOBT, sigmoidoscopy, and colonoscopy) and asking four questions about each test. The questions were: “Before this test was described, had you ever heard of it?”; “Have you ever had (this test)?”; “When did you have your most recent (test)?”; and, “Why did you have your most recent (test)?” • CRC test use was classified into three categories: no CRC test use, some CRC test use but not current with Medicare testing intervals, and current with testing. Respondents were classified as being current with testing if they had had any of the CRC tests at Medicare covered intervals, including FOBT in the past year, sigmoidoscopy within the past 4 years, colonoscopy within the past 10 years, or barium enema within the past 10 years.
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | Outcomes: • Unadjusted analyses showed that African Americans were significantly less likely to be tested according to Medicare-covered intervals (OR=0.57, 95% CI 0.46–0.71). However, after adjustment for sociodemographic characteristics, healthcare access, and CRC risk status, racial differences were not statistically significant (OR=0.82, 95%, CI 0.63–1.06). • Among those not tested according to Medicare-covered intervals, African Americans were less likely to have been tested at all compared with whites. This difference remained significant after adjustment for sociodemographic characteristics, healthcare access, and CRC risk status (OR=0.48, 95%, CI=0.33–0.70). • African Americans were significantly more likely than whites to have been tested by an endoscopic procedure than by FOBT (OR=3.06, 95% CI=1.70 –5.51). • The strongest predictors identified with adherence to Medicare-covered testing intervals were elevated CRC risk (OR=3.82, 95% CI=2.79 –5.23), having a checkup in the past year (OR 2.80, 95%CI1.75–4.44), and having a usual source of care (OR=2.27, 95% CI=1.10–4.69) • White race and several health services use variables were strong predictors of having some CRC tests compared to having none. Medicare consumers with a usual source of care (OR=6.96, 95% CI=1.80–26.91) and those with a checkup in the last year (OR=2.16, 95% CI=1.27–3.67) were much more likely to have had some CRC tests.
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | NA
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | NA
QUALITY RATING: | Fair
Quality Assessment-Internal Validity for Observational Studies
| | Yes | | No | | Other (CD, NR, NA)
Were the groups similar at baseline regarding the most important prognostic indicators? | | | | X | | Age difference p<0.001, sex difference p<0.0001
Were the drop-out or response rates acceptable (≤ 20%)? [If between 20% and 60%, check other and explain.] | | | | X | | 69% cooperation rate
Were the differential drop-out or response rates acceptable (≤ 15%)? | | | | | | NA
Were intervention/exposure measures valid, reliable, and equally applied? | | X
Were the outcome assessors blinded to the intervention or exposure status of subjects? | | | | | | NA
Were outcome measures valid, reliable, and equally applied? | | X
Does the analysis control for baseline differences? | | X
Were important potential confounding and modifying variables taken into account in the design and analysis (e.g., through matching, stratification, or statistical adjustment)? | | X
Were the statistical methods used to assess the abstracted outcomes appropriate? | | X
Quality Rating (Good, Fair, or Poor): Fair
STUDY: | Authors, ref ID: Schneider, E.C., Rosenthal, M., Gatsonis, C.G., Zheng, J., Epstein, A.M.47 Year of publication: 2008 Dates of data collection: 2000 Trial name: NA
OBJECTIVE OR AIM: | The authors assessed whether beneficiaries in MMC plans were more likely than those in traditional FFS insurance to receive colorectal cancer (CRC) screening and whether type of insurance was associated with use of specific screening strategies.
DESIGN: | Setting: In-person survey Study design: Cross-sectional, retrospective secondary data analysis Duration (mean follow-up): No follow-up, 2000 survey data Overall study size (N enrolled/N analyzed): 10,173
| [underlined: MMC] | | [underlined: FFS Supplemental] | | | [underlined: FFS No Supplemental]
Sample size: | Sample size: 10,173 | | Sample size: 2,219 | | | Sample size: 6,167
Describe intervention: | No intervention, answered Medicare Current Beneficiary Survey | | No intervention, answered Medicare Current Beneficiary Survey | | | No intervention, answered Medicare Current Beneficiary Survey
RECRUITMENT: (population-based, clinic-based, volunteer, other) | Medicare population-based
INCLUSION CRITERIA: | Age 65+, Medicare beneficiary, non-institutionalized
EXCLUSION CRITERIA: | Institutionalized, from 11 states (and Puerto Rico) that had no MMC plan option, from 12 states that had fewer than 5 MMC enrollees, age 65 and younger, part-year enrollees in MMC, respondents who were not white, African American, or Hispanic, and respondents who reported a personal history of CRC
POPULATION CHARACTERISTICS: | [underlined: MMC] | | [underlined: FFS Supplemental] | | | [underlined: FFS No Supplemental]
Mean age & range (years): | Age: 26.1% 65–69, 27.5% 70–74, 22.4% 75–79, 24% 80+ | | Age: 21.6% 65–69, 28.3% 70–74, 24.3% 75–79, 25.7% 80+ | | | Age: 28.2% 65–69, 25.8% 70–74, 20.4% 75–79, 25.6% 80+
Sex (% female): | Sex: 58.7% female | | Sex: 58% female | | | Sex: 59.3% female
Race: | Race: 90.6% White, 9.4% Black | | Race: 95.8% White, 4.2% Black | | | Race: 79.1% White, 20.9% Black
Other:
| [underlined: Overall]
Attrition/Drop-out (not available for endpoint measurement):
Adherence:
Contamination:
Response Rates (e.g. for surveys): | Response rate was 84.3%
STATISTICAL ANALYSES: | Describe: • The authors calculated the weighted percentage of beneficiaries with each of the sociodemographic and other characteristics of interest overall and for each insurance group. • Using the definitions of CRC screening, they calculated, for each insurance group, the unadjusted percentage of beneficiaries that reported CRC screening strategies. • They compared percentages of beneficiaries who had received CRC screenings across each potential pairing of the insurance groups using a chi-square test or a t test as appropriate. • To address potential “selection biases” they used a propensity score model to adjust statistically for the nonrandom distribution of beneficiaries among insurance types. • To calculate propensity scores, they constructed a multinomial logistic regression model that included all of the patient characteristics that could plausibly predict whether or not an enrollee would choose to enroll in managed care.
ASSESSMENT OF EXPOSURES AND POTENTIAL CONFOUNDERS: | Variables examined: • Demographics (age, gender, race, Hispanic origin, education, unmarried) • Access (SES, insurance type) • Health status • Care-seeking variables (worry about health, avoid going to a MD, keep to self when sick, visit a MD as soon as feel bad, had a problem and didn’t visit a MD, same MD for >5 yr) • Area of residence (non-metro area resident)
OUTCOME ASSESSMENT: | Outcome Measures: CRC screening status and type of test received
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | Outcomes: • Beneficiaries who were age 80 or older, women, black, Hispanic, and who had lower educational attainment and lower income were less likely to receive screening (data not shown). • Beneficiaries were less likely to receive interval-appropriate screening (FOBT in past 2 yrs or invasive screening in past 5 yrs.) if they reported that they avoided going to the physician (41.1% vs. 54.9%), kept to themselves when sick (47.3% vs. 53.4%), failed to visit a physician as soon as they felt bad (55.6% vs. 48.7%), or had a problem and didn’t visit the physician (44.6% vs. 51.6%), all at (P < 0.001). • Worrying about health more than others was not associated with receiving a screening, nor was having the same physician for 5 years, except for having an invasive screening within the past 5 years (39.6% vs. 37.3%, P < 0.024). • MMC (52.9%) was more likely than supplemental insurance groups (FFS SUP) (50.7%, P = 0.15) to receive CRC screening, but time-interval appropriateness was similar between groups (no confidence intervals provided) • Beneficiaries in MMC were more likely than those In the FFS SUPP group to receive interval-appropriate FOBT (36.3% vs. 32.1%; P = 0.013), but less likely to receive an interval-appropriate invasive screening procedure (35.9% vs. 40.8%; P < 0.001)
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | Outcomes: NA
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Outcomes: NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Outcomes: NA
QUALITY RATING: | Fair
Quality Assessment-Internal Validity for Observational Studies
| | Yes | | No | | Other (CD, NR, NA)
Were the groups similar at baseline regarding the most important prognostic indicators? | | | | X | | The Managed care, FFS, and FFS no supplemental groups had several large differences in the age distribution, race, etc. of their populations.
Were the drop-out or response rates acceptable (≤ 20%)? [If between 20% and 60%, check other and explain.] | | X
Were the differential drop-out or response rates acceptable (≤ 15%)? | | | | | | NA
Were intervention/exposure measures valid, reliable, and equally applied? | | | | | | NA
Were the outcome assessors blinded to the intervention or exposure status of subjects? | | | | | | NA
Were outcome measures valid, reliable, and equally applied? | | X
Does the analysis control for baseline differences? | | X
Were important potential confounding and modifying variables taken into account in the design and analysis (e.g., through matching, stratification, or statistical adjustment)? | | X
Were the statistical methods used to assess the abstracted outcomes appropriate? | | X
Quality Rating (Good, Fair, or Poor): Fair Reviewer #1 initials: BLM Reviewer #2 initials: DJH Comments (explain poor quality ratings):
STUDY: | Authors, ref ID: Schootman, M., Jeffe, D., Baker, E., Walker, M.48 Year of publication: 2006 Dates of data collection: 2002 Trial name: NA
OBJECTIVE OR AIM: | To analyze the contextual effect of area poverty rate on never having been screened for breast, cervical, and colorectal cancer by (1) describing the extent of the variation in screening behaviors among 98 US metropolitan areas; (2) determining if the variation in lack of screening can be explained by differences in the characteristics of the persons who resided in these areas; and (3) determining if living in a metropolitan area with a higher poverty rate increased the likelihood of never having been screened for cancer over and above individual characteristics.
DESIGN: | Setting: Cities in the United States Study design: econdary data analysis Duration (mean follow-up): No follow-up, data collection for one year Overall study size (N enrolled/N analyzed): 118,000 persons residing in 98 areas
| [underlined: MMSA poverty rate 5.0–9.9] | | [underlined: MMSA poverty rate 10.0+]
Sample size: | Sample size: 59,336 | | Sample size: 59,301
Describe intervention: | Intervention: None, survey (BRFFS) | | Intervention: None, survey (BRFFS)
RECRUITMENT: (population-based, clinic-based, volunteer, other) | Population-level
INCLUSION CRITERIA: | Age 50 or older
EXCLUSION CRITERIA: | NR
POPULATION CHARACTERISTICS: | [underlined: MMSA poverty rate 5.0–9.9] | | [underlined: MMSA poverty rate 10.0+]
Mean age & range (years): | Age: 17.8% 50–59, 11% 60–69, 13% 70+ | | Age: 17.4% 50–59, 12.2% 60–69, 14.4% 70+
Sex (% female): | Sex: 58.9% | | Sex: 60.4%
Race: | Race: 80.8% White, 7.2% African American, 7.5% Other, 4.6% Hispanic | | Race: 73.1% White, 11.1% African American, 7.8% Other, 8% Hispanic
Other:
Attrition/Drop-out (not available for endpoint measurement): | NR
Adherence:
Contamination:
Response Rates (e.g. for surveys):
STATISTICAL ANALYSES: | Describe: The multilevel logistic models reported in this paper were all two level models in which persons (level 1) were nested within MMSAs (level 2). The authors used restricted iterative generalized least squares and second order penalized quasilikelihood estimation in all models.
ASSESSMENT OF EXPOSURES AND POTENTIAL CONFOUNDERS: | Multilevel logistic models to control for income, education, employment, insurance, race, age, sex, self-perceived health, having trouble getting medical care, and smoking status.
OUTCOME ASSESSMENT: | Outcome Measures: FOBT and sigmoidoscopy/colonoscopy
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | Outcomes: • The variation (ICC) between MMSAs varied by screening test: FOBT: 2.7 and colonoscopy/sigmoidoscopy: 1.2 (P<0.05). • The crude odds ratios per 5% increase in MMSA level poverty rate were attenuated by the inclusion of the individual level factors, but remained associated with never having had an FOBT (adjusted OR=1.19, 95% CI (1.12–1.27) • Adding the individual level factors to the model did not affect the crude odds ratios for a 5% increase in MMSA level poverty rate in never having had a colonoscopy. • For all screening tests, significant MMSA level variance remained after including only the individual level factors, and after adding MMSA level poverty rate (all P<0.05).
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | Outcomes: NA
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Outcomes: NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Outcomes: NA
QUALITY RATING: | Fair
Quality Assessment-Internal Validity for Observational Studies
| | Yes | | No | | Other (CD, NR, NA)
Were the groups similar at baseline regarding the most important prognostic indicators? | | | | | | NA
Were the drop-out or response rates acceptable (≤ 20%)? [If between 20% and 60%, check other and explain.] | | | | | | NR
Were the differential drop-out or response rates acceptable (≤ 15%)? | | | | | | NA
Were intervention/exposure measures valid, reliable, and equally applied? | | | | | | NA
Were the outcome assessors blinded to the intervention or exposure status of subjects? | | | | | | NA
Were outcome measures valid, reliable, and equally applied? | | X
Does the analysis control for baseline differences? | | X
Were important potential confounding and modifying variables taken into account in the design and analysis (e.g., through matching, stratification, or statistical adjustment)? | | X
Were the statistical methods used to assess the abstracted outcomes appropriate? | | X
Quality Rating (Good, Fair, or Poor): Fair Reviewer #1 initials: BLM Reviewer #2 initials: DJH Comments (explain poor quality ratings):
STUDY: | Authors, ref ID: Schumacher, M., Slattery, M., Lanier, A., Ma, K., Edwards, S., Ferucci, E., Tom-Orme, L.49 Year of publication: 2008 Dates of data collection: 2004–2007 Trial name: Education and Research Towards Health (EARTH) Study
OBJECTIVE OR AIM: | The purpose of this study was to examine the prevalence rates for cervical, breast, and colorectal cancer screening among American Indian and Alaska Native people living in Alaska and in the Southwest US, and to investigate predictive factors associated with receiving each of the cancer screening tests.
DESIGN: | Setting: Clinic Study design: Cross-sectional Duration (mean followup): One-time data collection Overall study size (N enrolled/N analyzed): 2,779 (participants 50 yrs with data available on colonoscopy/sigmoidoscopy)/2,745 for whom timing since last procedure was known)
Sample size: | Sample size: 2,745
Describe intervention: | Intervention: Participants completed several surveys: Health, Lifestyle, and Physical Activity Questionnaire; diet history questionnaire
RECRUITMENT: (population-based, clinic-based, volunteer, other) | Population-based
INCLUSION CRITERIA: | Required participants to be American Indian or Alaska Native eligible for Indian Health Services-funded health care; at least 18 years of age (colonoscopy/sigmoidoscopy analyses were restricted to those age 50+), not pregnant, not actively undergoing cancer treatment, and physically and mentally able to read and understand the consent form and to complete survey instruments and medical tests
EXCLUSION CRITERIA: | Individuals with unknown duration between colonoscopy/sigmoidoscopy
POPULATION CHARACTERISTICS:
Mean age & range (years): | NR
Sex (% female): | NR
Race: | 100% American Indian/Alaska native
Other:
Attrition/Drop-out (not available for endpoint measurement): | NA
Adherence:
Contamination:
Response Rates (e.g. for surveys):
STATISTICAL ANALYSES: | Describe: • Prevalence odds ratios and their 95% confidence intervals were calculated using unconditional logistic regression models. • Linear tests for trend were done by including the categorical variable as a continuous variable in the logistic regression analysis. • For each of the potential predictors described, they calculated odds ratios and 95% confidence limits controlling for age and location because age and location most often confounded the relationship between the predictor and the screening test. • Multivariate logistic regression was then done including all variables that were statistically significantly related to the screening test (95% confidence limits exclude 1.0) in the analysis controlling for age and location.
ASSESSMENT OF EXPOSURES AND POTENTIAL CONFOUNDERS: | • For each of the potential predictors described, they calculated odds ratios and 95% confidence limits controlling for age and location because age and location most often confounded the relationship between the predictor and the screening test.
OUTCOME ASSESSMENT: | Outcome Measures: Analyses classified individuals as having had a colonoscopy/sigmoidoscopy in the past five years, or not
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | Outcomes: • Individuals in the age group 60+ were somewhat more likely to have received colonoscopy or sigmoidoscopy in the past five years that those aged 50–59 years. • There was a significant difference in the prevalence of screening by location (Alaska 41.9% versus Southwest 11.8%). • There was an increasing trend in screening with increasing level of education (linear test for trend P<0.01). • Individuals with a family history of any cancer were more likely to be screened, as were those with a family history of colorectal cancer. Former smokers were more likely to be screened than current or never smokers; those with other medical conditions were more likely to be screened. • Individuals who spoke only English at home versus those who spoke a Native language (either alone or with English) were also more likely to be screened, as were those residing in an urban area, and those with higher incomes. Women who had received other screening tests (Pap test or mammogram) were also more likely to have received a colonoscopy or sigmoidoscopy. • Overall screening rate was 22% (n = 604) • Alaska Natives were more likely to have obtained CRC screening than Southwest American Indians (AOR, 3.86; 95% CI, 2.92–5.10)
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | Outcomes: NA
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Outcomes: NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Outcomes: NA
QUALITY RATING: | Fair
Quality Assessment-Internal Validity for Observational Studies
| | Yes | | No | | Other (CD, NR, NA)
Were the groups similar at baseline regarding the most important prognostic indicators? | | | | | | NA
Were the drop-out or response rates acceptable (≤20%)? [If between 20% and 60%, check other and explain.] | | | | | | NR
Were the differential drop-out or response rates acceptable (≤ 15%)? | | | | | | NA
Were intervention/exposure measures valid, reliable, and equally applied? | | | | | | NA
Were the outcome assessors blinded to the intervention or exposure status of subjects? | | | | | | NA
Were outcome measures valid, reliable, and equally applied? | | X
Does the analysis control for baseline differences? | | X
Were important potential confounding and modifying variables taken into account in the design and analysis (e.g., through matching, stratification, or statistical adjustment)? | | X
Were the statistical methods used to assess the abstracted outcomes appropriate? | | X
Quality Rating (Good, Fair, or Poor): Fair Reviewer #1 initials: BLM Reviewer #2 initials: DJH Comments (explain poor quality ratings):
STUDY: | Authors, ref ID: Seeff et al.50 Year of publication: 2004 Dates of data collection: 2000 Trial name: NA
OBJECTIVE OR AIM: | Estimate the most current rates of CRC test use, to evaluate factors previously described in association with CRC test use, and to describe first-time national estimates of barriers to CRC testing from the perspective of the general public.
DESIGN: | Setting: In-person interview, National Health Interview Survey (NHIS) Study design: Secondary data analysis Duration (mean follow-up): No follow-up, analyzed 2000 data Overall study size (N enrolled/N analyzed): 11,734 responded to FOBT questions, 11,816 responded to sigmoidoscopy/colonoscopy/proctoscopy questions
| [underlined: All]
Sample size: | Sample size: 11,734 responded to FOBT questions, 11,816 responded to sigmoidoscopy/colonoscopy/proctoscopy questions
Describe intervention:
RECRUITMENT: (population-based, clinic-based, volunteer, other) | National Health Interview Survey (NHIS)
INCLUSION CRITERIA: | Age 50+
EXCLUSION CRITERIA: | Inadequate responses to questions, history of CRC, or refused or did not know the answer to questions
POPULATION CHARACTERISTICS: | [underlined: All]
| NR
Mean age & range (years):
Sex (% female):
Race:
Other:
| [underlined: All]
Attrition/Drop-out (not available for endpoint measurement): | Household response rate was 88.9% for the core NHIS survey and 72.1% for the Cancer Control Module
Adherence:
Contamination:
Response Rates (e.g. for surveys):
STATISTICAL ANALYSES: | Describe: • Multivariate logistic regression was used to determine the independent variables associated with each of the three endpoints. • Additional models were designed to determine whether either mammography or Pap smear tests were associated with CRC test use among women. • Two additional models compared screening test versus no test and nonscreening test versus no test. • Variables were included in the multivariate models if they have been previously associated with CRC or CRC screening, if they appeared to be associated with test use based on descriptive tables, or if they varied according to test indication.
ASSESSMENT OF EXPOSURES AND POTENTIAL CONFOUNDERS: | Variables included: • Demographic (age, gender, race, Hispanic, education, marital status) • Access (insurance status, income, usual source of care, MD visits/year) • Personal/risk factors (general health status, obesity/BMI, history of cancer- personal and family, prior screening, physical activity, fruit/veggies, smoking, alcohol)
OUTCOME ASSESSMENT: | Outcome Measures: FOBT within the previous year, endoscopy (sigmoidoscopy/colonoscopy/proctoscopy) within the past 10 years, and either FOBT within the previous year and/or endoscopy within the past 10 years. Secondary outcome: Reasons for Never Undergoing Colorectal Examinations or for Undergoing Tests beyond the Recommended Time Interval
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | Outcomes: • With regard to FOBT, test rates increased with increasing age until ages 70–79 years and then decreased. • Persons 65+ years old were significantly more likely to report having undergone an FOBT compared with persons 50–64 years old. • White, non-Hispanic, and married persons were more likely to report having undergone a CRC test than Black, Hispanic, or unmarried persons. • Those who had private health insurance, Medicare, Medi-GAP, or a combination of private insurance and Medicare had higher rates of FOBT use than those with other public insurance or no insurance. • Having a usual source of care and the frequency with which the respondent reported seeing a physician were both associated with higher reported test rates. • Patterns of associations for endoscopy were similar to those for FOBT use, with the exception that being male was associated with higher rates of endoscopy. • Those respondents with a personal or family history of cancers other than CRC or a family history of CRC were more likely to report having undergone endoscopy than those without such a history. • Women who underwent a mammogram or Pap smear test within recommended intervals were more likely to report having undergone CRC tests compared with those who did not. • Persons who exercised regularly reported higher rates of test use for all CRC tests evaluated. • Former cigarette smokers reported higher test rates compared with never-smokers or current smokers. • Between 4–7% of respondents who did not undergo CRC testing had been advised by a physician to do so. • MD recommended FOBT (Age 50–64 yrs): 258 (5.9%); 95% CI, (5.1–6.7); MD did not recommend FOBT (Age 50–64 yrs): 4006 (94.1%); 95% CI, (93.3–94.9) • MD recommended FOBT (Age ≥ 65): 162 (4.1%); 95% CI, (3.4–4.9); MD did not recommend FOBT (Age ≥ 65): 3838 (95.9%); 95% CI, (95.1–96.6) • MD recommended Endoscopy (Age 50–64 yrs): 255 (7.2%); 95% CI, (6.3–8.1); MD did not recommend Endoscopy (Age 50–64 yrs): 3318 (92.8%); 95% CI, (91.9–93.7) • MD recommended Endoscopy (Age 50–64 yrs): 135 (4.8%); 95% CI, (3.9–5.6); MD did not recommend FOBT (Age 50–64 yrs): 2907; (95.2%); 95% CI, (94.4–96.1)
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and follow-up? | Outcomes: NA
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Outcomes: NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Outcomes: NA
QUALITY RATING: | Fair
Quality Assessment-Internal Validity for Observational Studies
| | Yes | | No | | Other (CD, NR, N/A)
Were the groups similar at baseline regarding the most important prognostic indicators? | | | | | | N/A
Were the drop-out or response rates acceptable (≤ 20%)? [If between 20% and 60%, check other and explain.] | | | | | | Household response rate was 88.9% for the core NHIS survey and 72.1% for the Cancer Control Module
Were the differential drop-out or response rates acceptable (≤ 15%)? | | | | | | N/A
Were intervention/exposure measures valid, reliable, and equally applied? | | | | | | N/A
Were the outcome assessors blinded to the intervention or exposure status of subjects? | | | | | | N/A
Were outcome measures valid, reliable, and equally applied? | | X | | | | The procedures were defined only to those who asked, so this may introduce some bias.
Does the analysis control for baseline differences? | | X
Were important potential confounding and modifying variables taken into account in the design and analysis (e.g., through matching, stratification, or statistical adjustment)? | | X
Were the statistical methods used to assess the abstracted outcomes appropriate? | | X
Quality Rating (Good, Fair, or Poor): Fair Reviewer #1 initials: BLM Reviewer #2 initials: DJH Comments (explain poor quality ratings):
STUDY: | Authors, ref ID: Shah, M, Zhu, K., Potter, J.51 Year of publication: 2006 Dates of data collection: 2000 Trial name: National Health Interview Survey
OBJECTIVE OR AIM: | This study aimed to examine whether low acculturation is a risk factor for the underutilization of colorectal cancer screening examinations in the Hispanic population.
DESIGN: | Setting: US Study design: Survey study; secondary data analysis Duration (mean followup): One-time data collection, no follow-up Overall study size (N enrolled/N analyzed): 1163
| [underlined: All]
Sample size: | Sample size: 1163
Describe intervention: | Intervention: None; National Health Interview Survey (NHIS)
RECRUITMENT: (population-based, clinic-based, volunteer, other) | Population-based
INCLUSION CRITERIA: | Hispanic men and women between the age of 50 and 80 years who identified themselves as Hispanic and never were diagnosed with colon or rectal cancer
EXCLUSION CRITERIA: | Respondents that underwent any of tests for diagnostic purposes were excluded from the study.
POPULATION CHARACTERISTICS: | [underlined: Low Acculturation] | | [underlined: Moderate Acculturation] | | | [underlined: High Acculturation]
| Sex: 58.9% female | | Sex: 54.9% female | | | Sex: 55.3% female
Mean age & range (years): | Age: 38.8% 50–59, 33.6% 60–69, 27.5% 70–80 | | Age: 47.1% 50–59, 32.1% 60–69, 20.8% 70–70 | | | Age: 50.6% 50–59, 30.8% 60–69, 18.7% 70–80
Sex (% female):
Race: | Race: Hispanic | | Race: Hispanic | | | Race: Hispanic
Other:
| [underlined: All]
Attrition/Drop-out (not available for endpoint measurement): | The total household response rate was approximately 88.9% and the final response rate for the Adult Core component was 72.1%.
Adherence: | The total household response rate was approximately 88.9% and the final response rate for the Adult Core component was 72.1%.
Contamination: | The total household response rate was approximately 88.9% and the final response rate for the Adult Core component was 72.1%.
Response Rates (e.g. for surveys): | The total household response rate was approximately 88.9% and the final response rate for the Adult Core component was 72.1%.
STATISTICAL ANALYSES: | Describe: • Chi-square tests were executed to assess differences in colorectal cancer screening across various levels of acculturation and to evaluate statistical significance among the cross-tabulations. • With the use of multiple logistic regression, odds ratios having a screening procedure were computed for each acculturation level. • The analysis was repeated for each of the outcomes: having a FOBT, or an endoscopy, or both. • Odds ratios and 95% confidence intervals were adjusted for demographic factors that included gender, age, education, marital status, family income, and ratio of family income to poverty threshold. • Other variables that were included in the logistic regression model were selected if they were related to the use of either FOBT in the past year or an endoscopy in the past 5 years and the acculturation levels. • Logistic regression analyses were also performed separately for men and women.
ASSESSMENT OF EXPOSURES AND POTENTIAL CONFOUNDERS: | Cross-tabulations were performed to assess relationships among potential confounding variables and the dependent variables.
OUTCOME ASSESSMENT: | Outcome Measures: The use of at-home FOBT in the past year, any endoscopy procedures in the past 5 years, or either procedure were the outcomes of the study.
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | Outcomes: • Higher acculturated Hispanics were significantly less likely to not have an endoscopy in the past 5 years or not have either an FOBT in the past year or endoscopy in the past 5 years. When other variables were adjusted for in addition to sociodemographic variables, the confidence intervals for the odds ratio estimates for both moderate and high acculturation included the null and no dose-effect relations appeared (Endoscopy: OR = 0.77; 95% CI (0.49–1.20); p=0.040; FOBT: p=.032) • After adjusting for sociodemographic variables and other factors, the confidence intervals of the odds ratio for males included the null for no endoscopy and no FOBT and for either procedure. Similarly, for Hispanic women, there was no association for any of the three screening variables. (Male: OR = 0.55; 95% CI (0.19–1.58) p=0.046; Female: OR = 0.54; 95% CI (0.22–1.31) p=0.189) • Adjusted rates for not being screening with low English language usage as the referent: Moderate: AOR, 0.92; 95% CI, 0.60–1.42; High: AOR, 0.75; 95% CI, 0.45–1.25
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | Outcomes: NA
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Outcomes: NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Outcomes: NA
QUALITY RATING: | Fair
Quality Assessment-Internal Validity for Observational Studies
| | Yes | | No | | Other (CD, NR, NA)
Were the groups similar at baseline regarding the most important prognostic indicators? | | | | X | | Higher acculturated individuals had different characteristics than other groups.
Were the drop-out or response rates acceptable (≤ 20%)? [If between 20% and 60%, check other and explain.] | | | | | | The total household response rate was approximately 88.9% and the final response rate for the Adult Core component was 72.1%.
Were the differential drop-out or response rates acceptable (≤ 15%)? | | | | | | NA
Were intervention/exposure measures valid, reliable, and equally applied? | | | | | | NA
Were the outcome assessors blinded to the intervention or exposure status of subjects? | | | | | | NA
Were outcome measures valid, reliable, and equally applied? | | X
Does the analysis control for baseline differences? | | X
Were important potential confounding and modifying variables taken into account in the design and analysis (e.g., through matching, stratification, or statistical adjustment)? | | X
Were the statistical methods used to assess the abstracted outcomes appropriate? | | X
Quality Rating (Good, Fair, or Poor): Fair Reviewer #1 initials: BLM Reviewer #2 initials: DR Comments (explain poor quality ratings):
STUDY: | Authors, ref ID: Shapiro et al.52 Year of publication: 2008 Dates of data collection: 2005 Trial name: NA
OBJECTIVE OR AIM: | The purpose of this analysis was to determine the prevalence of colorectal cancer test use in the United States by various factors and to examine reasons for not having a colorectal cancer test.
DESIGN: | Setting: USA Study design: Secondary data analysis Duration (mean follow-up): No follow-up Overall study size (N enrolled/N analyzed): 30,873
| [underlined: All]
Sample size: | Sample size: 13,480 people > 50
Describe intervention: | No Intervention
RECRUITMENT: (population-based, clinic-based, volunteer, other) | Population-based; National Health Interview Survey
INCLUSION CRITERIA: | Respondents ages 50+, no family history of colorectal cancer or certain other risk factors
EXCLUSION CRITERIA: | Respondents with a personal history of colorectal cancer or missing information on history of colorectal cancer
POPULATION CHARACTERISTICS: | [underlined: All]
| NR
Mean age & range (years):
Sex (% female):
Race:
Other:
| [underlined: All]
Attrition/Drop-out (not available for endpoint measurement): | NA
Adherence:
Contamination:
Response Rates (e.g. for surveys):
STATISTICAL ANALYSES: | Describe: To provide national estimates of the prevalence of colorectal cancer test use, responses were weighted to reflect the probability of selection with adjustments for nonresponse and poststratification. Adjusted percentages (predictive margins) were computed from multiple logistic regression models controlling for all of the variables in Table 2
ASSESSMENT OF EXPOSURES AND POTENTIAL CONFOUNDERS: | NR
OUTCOME ASSESSMENT: | Outcome Measures: Rates of CRC screening: FOBT within one year, or endoscopy within 10 years. Secondary Outcome: Reasons for not having a FOBT or endoscopy, by colorectal cancer testing history, NHIS 2005
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | Outcomes: • For respondents who reported an endoscopy within the past 10 years, 72.8% (95% CI, 71.3–74.3) said that their most recent endoscopy was part of a routine exam, whereas 24.3% (95% CI, 22.9–25.8) said that they had the endoscopy because of a problem. • Among respondents who reported a FOBT within the past year, 91.0% (95% CI, 89.2–92.6) said that their most recent FOBT was part of a routine exam, whereas 7.8% (95% CI, 6.3–9.5) said that they had the FOBT because of a problem. • Among those respondents who had not had a FOBT or endoscopy within the recommended time interval, the most commonly reported reason for not having a colorectal cancer test was “never thought about it”. Reasons for not having a FOBT and reasons for not having an endoscopy were similar • Significant factors to receiving any CRC screening test are: education (P < .0001), annual household income (P < .0006), marital status (P = .01), health care coverage (P < .0001), usual source of health care (P < .0001), general health status (P < .0001), personal history of noncolorectal cancer (P < .0001), physical activity (P < .0001), cigarette smoking (P < .0001), and alcohol use (P < .0001) • Large effect sizes for SES variables and for factors related to healthcare access (insurance and having regular doctor) • Yes, doctor recommended FOBT/Endoscopy to respondents that never had FOBT: 159; %, 3.7; 95% CI, (3.1–4.4); and never had Endoscopy: 435; %, 10.3; 95% CI, (9.3–11.5); No, doctor did not recommend FOBT/Endoscopy to respondents that never had FOBT: 4,347; %, 96.3; 95% CI, (95.6–96.9); and never had Endoscopy: 4,091; %, 89.7; 95% CI, (88.5–90.7); Yes, doctor recommended FOBT/Endoscopy to respondents that had FOBT but not within the recommended time: 244; %, 4.6; 95% CI, (4.0–5.3); Yes, doctor recommended FOBT/Endoscopy to respondents that had Endoscopy but not within the recommended time: 635; %, 12.1; 95% CI, (11.1–13.1); No, doctor did not recommend FOBT/Endoscopy to respondents that had FOBT but not within the recommended time: 5,362; %, 95.4; 95% CI, (94.7–96.0)
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and follow-up? | Outcomes: Black and white about same; Latino much lower
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Outcomes: NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Outcomes: NA
QUALITY RATING: | Good
Quality Assessment-Internal Validity for Observational Studies
| | Yes | | No | | Other (CD, NR, NA)
Were the groups similar at baseline regarding the most important prognostic indicators?
Were the drop-out or response rates acceptable (≤20%)? [If between 20% and 60%, check other and explain.] | | | | | | N/A
Were the differential drop-out or response rates acceptable (≤ 15%)? | | X | | | | N/A
Were intervention/exposure measures valid, reliable, and equally applied? | | | | | | N/A
Were the outcome assessors blinded to the intervention or exposure status of subjects? | | | | | | N/A
Were outcome measures valid, reliable, and equally applied? | | X
Does the analysis control for baseline differences? | | X
Were important potential confounding and modifying variables taken into account in the design and analysis (e.g., through matching, stratification, or statistical adjustment)? | | X
Were the statistical methods used to assess the abstracted outcomes appropriate? | | X
Quality Rating (Good, Fair, or Poor): Good Reviewer #1 initials: BLM Reviewer #2 initials: RPH Comments (explain poor quality ratings):
STUDY: | Authors, ref ID: Shih, YT, Zhao, L, Elting, L53 Year of publication: 2006 Dates of data collection: 2000 and 2003 NHIS data analyzed (secondary data analysis) Trial name: NA
OBJECTIVE OR AIM: | To examine differences in colonoscopy screening rates between 2000 and 2003 among racial/ethnic groups (the authors are interested in whether Medicare coverage of colonoscopy, beginning July 2001 changed the pattern of use adults 65 years and older).
DESIGN: | Setting: Population-based, nationally representative sample (Cancer Control Module 2000 and Cancer Screening Supplement 2003 of the NHIS) Study design: secondary data analysis of cross-sectional data from 2000 and 2003 (comparisons made between the two datasets) Duration (mean followup): NA Overall study size (N enrolled/N analyzed): 2000, N = 6,180; 2003, N = 5,759
| [underlined: 2000] | | [underlined: 2003]
Sample size: | N = 6,180 | | N = 5,759
Describe intervention: | NA | | NA
RECRUITMENT: (population-based, clinic-based, volunteer, other) | NHIS recruitment strategy not reported
INCLUSION CRITERIA: | Civilian, noninstitutionalized U.S. households for NHIS; current analysis restricted to participants ≥ 65 years
EXCLUSION CRITERIA: | NR
POPULATION CHARACTERISTICS: | [underlined: 2000] | | [underlined: 2003]
Mean age & range (years): | • Age (years) 65–74: 54.62% 75–85: 36.53% 85+: 8.85% | | •Age (years) 65–74: 52.83% 75–85: 36.37% 85+: 10.80%
Sex (% female): | • Female: 57.46% | | •Female: 57.67%
Race: | • Race/ethnicity Hispanic: 5.85% Non-Hispanic white: 83.85% Non-Hispanic black: 8.17% Non-Hispanic other: 2.13% | | •Race/ethnicity Hispanic: 5.89%Non- Hispanic white: 83.41% Non-Hispanic black: 8.21% Non-Hispanic other: 2.49%
Other: | •Highest education attained <HS: 31.57% HS: 34.02% Some college: 19.18% ≥ College: 15.23% | | •Highest education attained <HS: 27.66% HS: 34.54% Some college: 20.94% ≥College: 16.86%
Other: | •Income Poor: 28.03% Low income: 13.44% Middle income: 8.13% Upper income: 15.53% Unknown: 34.87% | | •Income Poor: 24.09% Low income: 14.69% Middle income: 8.27% Upper income: 16.39% Unknown: 36.57%
Attrition/Drop-out (not available for endpoint measurement): | NA (secondary data)
Adherence:
Contamination:
Response Rates (e.g. for surveys):
STATISTICAL ANALYSES: | Wald chi-squareWald chi-square statistics were used to compare the differences in CRC screening rates between the 2000 and 2003 samples for the identified racial/ethnic groups. Multivariate logistic regression used to examine differences in the likelihood of screening across racial/ethnic groups.
ASSESSMENT OF EXPOSURES AND POTENTIAL CONFOUNDERS: | Potential confounders identified in the literature were controlled for in the multivariate analysis. Variables: •Age •Income •Education •Marital status •Census region •Secondary insurance Self-perceived health status •History of cancer •Usual source of care
OUTCOME ASSESSMENT: | Outcome Measures: Ever screened by colonoscopy: NHIS survey question, “Have you EVER HAD a sigmoidoscopy, colonoscopy, or proctoscopy?” If the respondent answered yes, they considered that respondent screened.
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | •In 2000 blacks were less likely to have had endoscopic CRC screening compared with whites (OR = 0.788, 95% CI, 0.630, 0.984). However, the odds of screening increased in 2003, and the disparities between the two groups were no longer significant (OR = 0.909, 95% CI, 0.731, 1.131). • The odds of screening declined for Hispanics between the two study years (0.806 vs. 0.768), and the differences between Hispanics and non-Hispanic whites was not significant in 2000, but became significant in 2003 (95% CI, 0.592, 0.997 (P = .048). • No statistically significant differences were found between non-Hispanic whites and non-Hispanic others in either year. • Sex differences were not significant in 2000, but were in 2003 (OR =, 95% CI, 1.115, 1.440) • Having a history of cancer was not significantly associated with screening in 2000 but became significant in 2003 (OR = 1.627, 95% CI, 1.021, 2.591), (P = .041). • The positive effect of having a usual source of care was significant in 2000 and 2003, and also became more pronounced over time (OR = 4.68, 1 95% CI, 3.092, 7.085) • Unadjusted screening rates were approximately 30% among Hispanics in 2000, with only a slight increase by 2003. Screening among non-Hispanic whites was approximately 45% in 2000, increasing increase by 2003. Screening among non-Hispanic whites was approximately 45% in 2000, increasing to 50% in 2003 (findings presented only in a bar chart) • . Odds of screening declined for Hispanics between 2000 and 2003 and the differences between Hispanics and non-Hispanic whites became significant in 2003 (AOR; 0.77; 95% CI, 0.59–0.997; P = 0.048).
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | NA
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | NA
QUALITY RATING: | Fair
Quality Assessment-Internal Validity for Observational Studies
| | Yes | | No | | Other (CD, NR, NA)
Were the groups similar at baseline regarding the most important prognostic indicators? | | X
Were the drop-out or response rates acceptable (≤ 20%)? [If between 20% and 60%, check other and explain.] | | | | | | NR
Were the differential drop-out or response rates acceptable (≤ 15%)? | | | | | | NA
Were intervention/exposure measures valid, reliable, and equally applied? | | X | | | | NHIS data
Were the outcome assessors blinded to the intervention or exposure status of subjects? | | | | | | NR
Were outcome measures valid, reliable, and equally applied? | | X | | | | They used NHIS survey data; however, screening variable wasn’t divided into diagnostic and screening colonoscopy
Does the analysis control for baseline differences? | | | | | | NA
Were important potential confounding and modifying variables taken into account in the design and analysis (e.g., through matching, stratification, or statistical adjustment)? | | X
Were the statistical methods used to assess the abstracted outcomes appropriate? | | X
Quality Rating (Good, Fair, or Poor): Fair
STUDY: | Authors, ref ID: Shih, Y.T, Elting, L.S, Levin, B.54 Year of publication: 2008 Dates of data collection: 2000 Trial name: NA
OBJECTIVE OR AIM: | Examine the disparities in colorectal cancer (CRC) screening between US- and foreign-born groups and explore factors associated with such disparities
DESIGN: | Setting: data from 2000 National Health Interview Survey Cancer Control Module Study design: Cross-sectional retrospective Duration (mean follow-up): No follow-up Overall study size (N enrolled/N analyzed): 12,179
| [underlined: US-Born] | | | [underlined: Foreign-Born]
Sample size: | Sample size: 10,739 | | | Sample size: 1,440
Describe intervention: | Survey gathered information on CRC screening rates | | | Survey gathered information on CRC screening rates
RECRUITMENT: (population-based, clinic-based, volunteer, other) | Data from 2000 National Health Interview Survey Cancer Control Module
INCLUSION CRITERIA: | Men and women aged 40 years and over in 2000 were asked questions related to CRC screening
EXCLUSION CRITERIA: | NR
POPULATION CHARACTERISTICS: | [underlined: US-Born] | | | [underlined: Foreign-Born]
Mean age & range (years): | Age: 49.41% 50–64, 35.72% 65–79, 14.87% 80+ | | | Age: 52.18% 50–64, 35.13% 65–79, 12.68% 80+
Sex (% female): | Sex: 57.75% Female | | | Sex: 56.10% Female
Race: | Race/ethnicity: 2.73% Hispanic, 86.42% Non-Hispanic White, 9.63% Non-Hispanic African American/Black, 1.22% Non-Hispanic other | | | Race/ethnicity: 37.14% Hispanic, 40.03% Non-Hispanic African American/Black, 15.47% Non-Hispanic other
Other:
| [underlined: Sample]
Attrition/Drop-out (not available for endpoint measurement): | A cancer control module in the 2000 NHIS received a household response rate of 72.1%.
Adherence:
Contamination:
Response Rates (e.g. for surveys):
STATISTICAL ANALYSES: | Describe: • Descriptive statistics were first presented to depict the differences in demographic and socioeconomic characteristics between the US- and foreign-born groups. Differences were compared using chi-square statistics for categorical variables and t tests for continuous variables. The authors employed appropriate weighting procedures to account for the complex sample design of the NHIS using survey-related commands in STATA® 7.0 statistical software. • Controlling for factors associated with CRC screening in the literature, they modeled differences in the likelihood of CRC screening between the US-born and foreign- born groups using multivariate logistic regression. • The authors then added terms that interact the binary variable indicating foreign-born status with demographic, socioeconomic, or access barrier variables that were shown to differ significantly between the US- and foreign-born groups in their univariate analysis and conducted additional multivariate regression analyses.
ASSESSMENT OF EXPOSURES AND POTENTIAL CONFOUNDERS: | NR--- multivariate logistic models
OUTCOME ASSESSMENT: | Outcome Measures: • The module included the following 7 sections: Hispanic acculturation, diet and nutrition, physical activity, tobacco use, cancer screening, genetic testing, and family history. • The cancer screening section for adults included skin examinations, Pap smears, mammography, clinical breast examinations, prostate specific antigen tests, and CRC screening using endoscopic procedures and/or FOBT.
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | Outcomes: • The foreign-born group had a significantly lower rate of CRC screening than US-born group (39.3% vs 54.9%, P < 0.001). • Long-time, foreign-born residents of the United States were significantly less likely to be screened than US-born non-Hispanic whites (OR, 0.58; 95% CI, 0.51–0.67). • Among the foreign-born group, the recent immigrants (defined as people who migrated to the United States within the last 10 years) (OR= 0.46, 95% CI, 0.29–0.71, P = 0.0001) were significantly less likely to receive CRC screening than those who had a long residency (15 years or more) (OR = 0.58, 95% CI, 0.51–1.37, P < 0.0001) in the United States. • Among the US-born individuals, lower rates of CRC screening were found in non-Hispanic African Americans/Blacks (OR=.77, 95% CI, 0.68–0.88, p<.0001) and Hispanics (OR=.65, 95% CI, 0.51–0.82, P < 0.0001). • Men were significantly less likely to be screened as were poorer respondents (OR= 0.89, 95% CI, 0.81–0.97, P = 0.01). • Factors found to be positively associated with CRC screening were older age; higher educational attainment; being insured; married; living in the West census region (vs Northeast); being in good, fair, or poor health condition (vs in excellent health); and having a usual source of care. • Comparisons of ORs indicated that every foreign-born racial/ethnic subgroup had a lower OR than its US-born counterpart
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | Outcomes: NA
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Outcomes: NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Outcomes: NA
QUALITY RATING: | Good
Quality Assessment-Internal Validity for Observational Studies
| | Yes | | No | | Other (CD, NR, NA)
Were the groups similar at baseline regarding the most important prognostic indicators? | | | | | | N/A The US-born and Foreign-born groups were similar except for Race/ethnicity.
Were the drop-out or response rates acceptable (≤ 20%)? [If between 20% and60%, check other and explain.] | | X | | | | A cancer control module in the 2000 NHIS received a household response rate of 72.1%.
Were the differential drop-out or response rates acceptable (≤ 15%)? | | | | | | NR
Were intervention/exposure measures valid, reliable, and equally applied? | | | | | | NA
Were the outcome assessors blinded to the intervention or exposure status of subjects? | | | | | | NA
Were outcome measures valid, reliable, and equally applied? | | X
Does the analysis control for baseline differences? | | X
Were important potential confounding and modifying variables taken into account in the design and analysis (e.g., through matching, stratification, or statistical adjustment)? | | X
Were the statistical methods used to assess the abstracted outcomes appropriate? | | X
Quality Rating (Good, Fair, or Poor): Good Reviewer #1 initials: BLM) Reviewer #2 initials: DR Comments (explain poor quality ratings):
STUDY: | Authors, ref ID: Sun, W., Basch, C., Wolf, R., Li, X.55 Year of publication: 2004 Dates of data collection: December 1, 1999 to March 15, 2000 Trial name: NA
OBJECTIVE OR AIM: | To investigate factors associated with receipt of colorectal cancer (CRC) screening among urban senior Chinese-Americans
DESIGN: | Setting: Senior centers Study design: Cross-sectional Duration (mean follow-up): No follow-up Overall study size (N enrolled/N analyzed): 203
| [underlined: All]
Sample size: | Sample size: 203
Describe intervention: | Intervention: None, survey
RECRUITMENT: (population-based, clinic-based, volunteer, other) | Population-based; community centers
INCLUSION CRITERIA: | Age 50+, current New York City resident, free from symptoms of bowel disease
EXCLUSION CRITERIA: | NR
POPULATION CHARACTERISTICS: | [underlined: All]
Mean age & range (years): | Age: 22.2% 50–59, 39.4% 60–69, 37.4% 70+
Sex (% female): | Sex: 43.8% female
Race: | Race: 100% Asian
Other:
| [underlined: All]
Attrition/Drop-out (not available for endpoint measurement):
Adherence:
Contamination:
Response Rates (e.g. for surveys): | 89.4% agreed to participate
STATISTICAL ANALYSES: | Describe: Chi-squared tests were used to analyze categorical data. Stepwise logistic regression was used to determine possible predictors that included age, gender, marital status, ownership of dwelling, citizenship, years of residency, education, household income, health insurance, employment, family history of CRC, salience and coherence, self-efficacy, social influence, efficacy of screening, worries or fears, perceived susceptibility, and intention. One-way analysis of variance (ANOVA) was used to compare means for measured variables among subjects who had an FOBT, FOBT plus sigmoidoscopy, or neither.
ASSESSMENT OF EXPOSURES AND POTENTIAL CONFOUNDERS: | After excluding confounding factors, senior Chinese who had fewer years of residency, lower levels of worries or fears, and higher levels of perceived susceptibility to CRC tended to have higher rates of FOBT.
OUTCOME ASSESSMENT: | Outcome Measures: CRC screening with FOBT or FOBT plus sigmoidoscopy
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | Outcomes: •In multivariate analysis, years of residency in the US (AOR = 0.64, 95% CI, 0.41–0.99; P < 0.05), worries or fears of positive results (OR = 0.82, P < 0.05), and perceived susceptibility (OR = 1.14, P < 0.05) were significant predictors of participation in FOBT alone. •In addition, years of residency in the US (OR = 0.55, P < 0.01), worries or fears of positive results (OR = 0.66, P < 0.01), and perceived susceptibility participation in FOBT or FOBT plus sigmoidoscopy. •Family history, social influence, efficacy of screening, and intention to screen were no longer independent predictors once the other variables were in the model. •For subjects who received both FOBT and sigmoidoscopy, level of education (OR = 1.58, P = 0.04), worriers or fears of positive results (OR = 0.72, P < 0.01), and perceived susceptibility (OR = 1.26, P < 0.01) were significant predictors in multivariate analysis. Family history, self-efficacy, social influence, and intention to screen were no longer independent predictors once the other variables were in the model.
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | Outcomes: NA
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Outcomes: NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Outcomes: NA
QUALITY RATING: | Fair
Quality Assessment-Internal Validity for Observational Studies
| | Yes | | No | | Other (CD, NR, NA)
Were the groups similar at baseline regarding the most important prognostic indicators? | | | | | | NA
Were the drop-out or response rates acceptable (≤ 20%)? [If between 20% and 60%, check other and explain.] | | X
Were the differential drop-out or response rates acceptable (≤ 15%)?
Were intervention/exposure measures valid, reliable, and equally applied? | | | | | | NA
Were the outcome assessors blinded to the intervention or exposure status of subjects? | | | | | | NA
Were outcome measures valid, reliable, and equally applied? | | X
Does the analysis control for baseline differences? | | X
Were important potential confounding and modifying variables taken into account in the design and analysis (e.g., through matching, stratification, or statistical adjustment)? | | NA X
Were the statistical methods used to assess the abstracted outcomes appropriate? | | X
Quality Rating (Good, Fair, or Poor): Fair Reviewer #1 initials: BLM Reviewer #2 initials: DJH Comments (explain poor quality ratings):
STUDY: | Authors, ref ID: Thompson et al.56–58 Year of publication: 2002, 2004, 2006 Dates of data collection: baseline: 1998–1999; “final” survey: 2003 Trial name: NR
OBJECTIVE OR AIM: | 2002{#2275): socioeconomic status is explored as a predictor of differences between Hispanics and non-Hispanic whites in cancer prevention behavior 2004{#1219): to compare CRC screening prevalence and the association between reported barriers and screening participation between Hispanics and non-Hispanic whites 2006{#1188): to examine whether a comprehensive intervention influenced cancer screening behaviors and lifestyle practices in rural communities in Eastern WA state
DESIGN: | Setting: 20 communities in Lower Yakima Valley, Washington State Study design: randomization of communities; cross sectional community based surveys at baseline{#1219) and post-intervention Also, cohort of 823 individuals aged 50 and older who were non-compliant with CRC screening at baseline and who agreed to be re-interviewed at final surveying Duration (followup): 30 months of intervention, > 3 years for follow-up survey Overall study size (N enrolled/N analyzed):
INTERVENTIONS: | [underlined: No intervention] | | [underlined: Intervention] | | | [underlined: At baseline all 20 communities sampled in study #1219]
Sample size: | 10 communities | | 10 communities
Describe intervention: | | | Community Advisory Board; Focus groups to develop and test interventions; Activities directed at the community, organizational, small group, and individual levels: Health fairs, block parties, festivals and other events where educational presentations were made Multiple interventions through churches, clinical (free colorectal cancer screening), worksites Home health parties Promotoras
RECRUITMENT: (population-based, clinic-based, volunteer, other) | Recruitment of communities not described
INCLUSION CRITERIA: | Presumed convenience sample of 20 communities that range in size from very small (300) to medium (7,000) in the Lower Yakima Valley. For 2004 study, subset of the population-based survey (n = 1795) based on eligibility to answer questions about CRC screening (age > =50)
EXCLUSION CRITERIA:
POPULATION CHARACTERISTICS: | 2004 | 2004 | | 2004 CRC study | 2004 CRC study | Demographics for intervention vs. control are not presented Total sample for final survey
Age (%) | Baseline: Non-Hispanic White | Baseline: Hispanic | | Baseline Non-Hispanic White | Baseline Hispanic
18–39 | 29 | 63 | | | | 43.4%
40–49 | 20 | 1 | 50–59 | 34.2 | 37.2 | 20.0%
50–64 | 24 | 11 | 60–69 | 25.1 | 31.4 | 19.9%
65+ | 27 | 8 | ≥70 | 40.7 | 31.4 | 16.7%
| | | | 58.0 | 62.0
Sex (% female): | 57 | 58 | | | | 55.2%
Race: | | | | | | Breakdown not presented
Other population qualities:
Education | | | | 12.7 | 76.6
8^th^ grade or less | 7 | 54 | | 52.6 | 16.8 | 26.1%
9^th^–12^th^, no diploma | 18 | 23 | | 19.4 | 5.8 | 23.1%
High school or GED | 32 | 13 | | 15.3 | <1.0 | 22.3%
At least some college | 43 | 11 | | | | 28.5%
Insurance | | | Have Insurance: 93.9% | | Have Insurance: 73.0%
Private | 66 | 24 | | | | 45.6%
Medicare | 11 | 7 | | | | 8.4%
Public | 10 | 26 | | | | 24.3%
None | 1 | 43 | | | | 21.7%
Attrition/Drop-out (not available for endpoint measurement): | NR
Adherence in control group:
Contamination in control group:
OUTCOME ASSESSMENT: | Outcome Measures: For persons > 50 years: FOBT screening within the past 2 years Flex sig/colonoscopy within the past 5 years Categorized as “ever screened, but noncompliant”; “never screened”; “compliant”. For the 2005{#1219) report, when examining the intervention effect, the community pairing and community level effects were controlled for as random effects. To examine whether the interaction effect differed for Hispanic and non-Hispanic whites, the authors included an interaction between treatment arm status and ethnicity. Respondents{#1219) who reported having had an FOBT within the past 2 years were classified as being “in compliance.” Similarly, if residents ≥50 years reported having received a sigmoidoscopy within the previous 5 years, they were compliant, but they were not compliant if the sigmoidoscopy was received > 5 years, or if they had never received a sigmoidoscopy. In piloting the instrument, they found that their respondents could not differentiate a sigmoidoscopy from a colonoscopy even when they used a visual of the procedure and described the differences. For that reason, they report sigmoidoscopy/colonoscopy together.
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | Outcomes: 2002{#2275): Non significant differences between Non-Hispanic white and Hispanics in rates of FOBT and FS/colonoscopy, when adjusted for age, education, and insurance coverage
KQ2 - What factors influence the use of colorectal cancer screening? | | | | Non Hispanic | White Hispanic | p
KQ2 - What factors influence the use of colorectal cancer screening? | FOBT ever screened, but noncompliant | | | 54.1 | 44.1 | 0.315
KQ2 - What factors influence the use of colorectal cancer screening? | FOBT never screened | | | 47.5 | 47.4 | 0.986
KQ2 - What factors influence the use of colorectal cancer screening? | FS/Colon screened, but noncompliant | | | 35.1 | 27.3 | 0.453
KQ2 - What factors influence the use of colorectal cancer screening? | FS/Colon never screened | | | 58.6 | 63.1 | 0.458
KQ2 - What factors influence the use of colorectal cancer screening? | 2004{#1219): Table 2 Participation in FOBT and FS/colon screening, by ethnicity (age unadjusted numbers)
KQ2 - What factors influence the use of colorectal cancer screening? | | | Non-Hispanic | White Hispanic | P
KQ2 - What factors influence the use of colorectal cancer screening? | FOBT ever | | 55.7 | 40.6 | 0.003
KQ2 - What factors influence the use of colorectal cancer screening? | In last 2years | | 34.8 | 25.8 | 0.32
KQ2 - What factors influence the use of colorectal cancer screening? | >2 years ago | | 20.9 | 9.9 | 0.005
KQ2 - What factors influence the use of colorectal cancer screening? | FS/colon ever | | 44.4 | 26.9 | <0.001
KQ2 - What factors influence the use of colorectal cancer screening? | In last 5 years | | 33.7 | 24.1 | <0.05
KQ2 - What factors influence the use of colorectal cancer screening? | >5 years ago | | 10 | 3.0 | 0.013
KQ2 - What factors influence the use of colorectal cancer screening? | Table 3 Associations of demographic characteristics with compliance with FOBT and sig/colon
KQ2 - What factors influence the use of colorectal cancer screening? | | | Relative OR (95% CI) of FOBT | | | Relative OR (95% CI) of FS/Colon
KQ2 - What factors influence the use of colorectal cancer screening? | | | Raw | | Adjusted | Raw | Adjusted
KQ2 - What factors influence the use of colorectal cancer screening? | Race/ethnicity
KQ2 - What factors influence the use of colorectal cancer screening? | Non-Hispanic white | | | | 1.0 | 1.0
KQ2 - What factors influence the use of colorectal cancer screening? | Hispanic | | 0.44 (0.27–0.74) 1.0 | | 0.63 (0.33–1.24) | 0.63 (0.39–1.01) | 0.52 (0.28–0.98) 1.0
KQ2 - What factors influence the use of colorectal cancer screening? | • adjusted for all other demographic and lifestyle variables In 2004{#1219): For being current with FOBT, the OR for Hispanic was lower in raw data (0.44). This difference was attenuated (OR 0.63) when adjusting for age, education, gender and insurance, and became not statistically significant (but with a wide CI, raising question of power to detect difference). For FS/colonoscopy, OR significant in raw (borderline) and actually increased slightly after adjustment for above factors. In 2002{#2275):
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | Outcomes: Final cancer screening practices and cancer prevention lifestyle behaviors of intervention and control, adjusted for community pair and community and ethnic-specific baseline proportions of screening service use A. Community Survey results
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | | Hispanic | | | Non-Hispanic White
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | | Intervention | Control | p | Intervention | Control | p
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | FOBT ever screened | 48.1 | 54.2 | 0.50 | 57.9 | 62.9 | 0.43
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | FOBT compliant | 70.4 | 52.8 | 0.09 | 48.2 | 48.6 | 0.94
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | FS/Colon ever screened | 29.1 | 37.5 | 0.30 | 44.6 | 48.7 | 0.47
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | FS/Colon compliant with screening | 83.9 | 69.7 | 0.24 | 77.4 | 79.8 | 0.66
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | B. Cohort results Final use of screening services for CRC among cohort of respondents ages 50 and older who were non-compliant at baseline survey
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | | Hispanic | | | Non-Hispanic White
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | | Intervention | Control | p | Intervention | Control | p
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | FOBT ever screened, noncompl | 78.5 | 64.0 | 0.53 | 62.2 | 47.8 | 0.23
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | FOBT never screened | 57.1 | 48.3 | 0.59 | 47.4 | 29.0 | 0.03
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | FS/Colon ever screened, but noncompl | * | * | * | * | * | *
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | FS/Colon never screened | 92.6 | 86.1 | 0.55 | 64.8 | 54.3 | 0.21
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Outcomes: NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Outcomes: NA
QUALITY RATING: | KQ2 fair KQ3 poor
Quality Assessment-Internal Validity for Controlled Trials; note this is for the RCT study
| | Yes | | No | | Other (CD, NR, NA)
Was the study described as randomized? | | x
Was the method of randomization adequate? | | | | | | X possibly, not described
Was the treatment allocation concealed?
Were the groups similar at baseline regarding the most important prognostic indicators? | | | | | | X not described!
Was the outcome assessor blinded?
Was the care provider blinded?
Was the patient blinded?
Was the drop-out rate acceptable (≤ 20%)? [If between 20% and 60%, check other and explain.]
Was the differential drop-out rate acceptable (≤ 15%)?
Were co-interventions avoided or similar? | | | | | | unknown
Were outcome measures valid, reliable, and equally applied? | | x
Were all randomized participants analyzed in the group to which they were originally assigned?
Quality Rating (Good, Fair, or Poor): KQ 3 poor; KQ 2 fair Reviewer #1 initials: DSP Reviewer #2 initials: DR Comments:
STUDY: | Authors, ref ID: Thorpe, L.E., et al.59 Year of publication: 2005 Dates of data collection: 2003 Trial name: NA
OBJECTIVE OR AIM: | This detailed analysis of individual- and neighborhood-level factors associated with colon cancer screening practices will guide the NYC campaign to increase colonoscopy screening and will provide baseline measures with which the campaign can be evaluated.
DESIGN: | Setting: New York City, NY Study design: Secondary data analysis; cross-sectional telephone survey Duration (mean followup): No followup, data collection over 3 months Overall study size (N enrolled/N analyzed): 9,802 (≥50 yrs = 3,606)
| [underlined: All]
Sample size: | Sample size: 3,606 adults
Describe intervention: | Intervention: No intervention; New York City Community Health Survey (CHS)
RECRUITMENT: (population-based, clinic-based, volunteer, other) | Population-based; New York City Community Health Survey (CHS)
INCLUSION CRITERIA: | To be surveyed: age 18+ In analysis: age 50+
EXCLUSION CRITERIA: | NR
POPULATION CHARACTERISTICS: | NR
Mean age & range (years):
Sex (% female):
Race:
Other:
Attrition/Drop-out (not available for endpoint measurement):
Adherence:
Contamination:
Response Rates (e.g. for surveys): | Cooperation rate of 59%, response rate of 26%l
STATISTICAL ANALYSES: | Describe: • Descriptive statistics were used to determine prevalence of screening patterns, and 95% confidence intervals for both prevalence and affected population estimates were calculated with the exact binomial distribution. • Univariate associations were tested at the 0.05 significance level with the chi-square statistic, and stratified analyses were used to examine nonhomogeneity of associations across other covariates. • Multiple logistic regression was used to identify independent predictors of colorectal cancer screening and to adjust for confounding.
ASSESSMENT OF EXPOSURES AND POTENTIAL CONFOUNDERS: | Multiple logistic regression was used to identify independent predictors of colorectal cancer screening and to adjust for confounding. Variables included: Demographic (age, race, ethnicity, gender) Personal risk behaviors (smoking, physical activity) SES/Access (house income, insurance, regular doctor) Neighborhood/contextual variable (Neighborhood income)
OUTCOME ASSESSMENT: | Outcome Measures: Two models were constructed with different dependent outcomes: having undergone any CRC screening test in a recommended time frame (every 10 years for colonoscopy, every year for FOBT, and every 5 years for flexible sigmoidoscopy) and having undergone a colonoscopy within the past 10 years.
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | Outcomes: • Adults born outside of the U.S. reported significantly lower levels of any colorectal cancer screening than adults born in the U.S. • Reports of FOBT screening during the preceding year were particularly high among non-Hispanic black women (40%, 95% CI, 35%–45%). • Colonoscopy was the most frequently reported screening test in all race and ethnic groups, although non-Hispanic white adults had a significantly higher rate of colonoscopy (and overall colorectal screening) than other groups. Non-Hispanic black adults reported higher levels of FOBT screening than other racial and ethnic groups. • CRC screening was significantly higher among men aged 65+ years compared with men aged 50–64 years (63% vs. 52%, OR = 1.3; 95%CI, 1.0 –1.6), whereas differences in overall CRC screening frequency among older women compared with younger women were more modest (57% vs. 52%; OR= 1.6; 95%CI 1.2–2.0). • Gender differences in colorectal screening were most evident among Asians, with Asian men being twice as likely as Asian women to have received any timely colorectal cancer screening test (50% vs. 23%; OR= 2.9; 95%CI, 1.4–6.3). • Current smokers were less likely to have received a timely screening than nonsmokers (44% vs. 57%; OR= 0.62; 95% CI, 0.50–0.78), and physically inactive adults were less likely to be screened than those reporting some physical activity (50% vs. 59%; OR= 0.75; 95% CI, 0.63– 0.89). • Adults who did not receive an influenza vaccination in the past 12 months were less likely to have been screened than those who did obtain the vaccination (46% vs. 66%, OR= 0.44; 95% CI, 0.37– 0.53). • Simultaneous adjustment for multiple covariates tended to reduce the magnitude of observed differences in recent colorectal cancer screening by any modality across racial and ethnic groups and among foreign-born persons. • Factors significantly associated with not having a colonoscopy within the past 10 years included age < 65 years (AOR= 0.68; 95%CI, 0.54–0.86), black or Asian ethnicity (black AOR = 0.72, 95%CI, 0.58–0.91; Asian AOR= 0.36, 95%CI, 0.22– 0.58), and female gender (AOR= 0.74, 95% CI, 0.62– 0.89).
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | Outcomes: NA
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Outcomes: NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Outcomes: NA
QUALITY RATING: | Fair
Quality Assessment-Internal Validity for Observational Studies
| | Yes | | No | | Other (CD, NR, NA)
Were the groups similar at baseline regarding the most important prognostic indicators? | | | | | | NA
Were the drop-out or response rates acceptable (≤ 20%)? [If between 20% and 60%, check other and explain.] | | | | | | Cooperation rate=58%, response rate=26%
Were the differential drop-out or response rates acceptable (≤ 15%)? | | | | | | NA
Were intervention/exposure measures valid, reliable, and equally applied? | | | | | | NA
Were the outcome assessors blinded to the intervention or exposure status of subjects? | | | | | | NA
Were outcome measures valid, reliable, and equally applied? | | X
Does the analysis control for baseline differences? | | X
Were important potential confounding and modifying variables taken into account in the design and analysis (e.g., through matching, stratification, or statistical adjustment)? | | X
Were the statistical methods used to assess the abstracted outcomes appropriate? | | X
Quality Rating (Good, Fair, or Poor): Fair Reviewer #1 initials: BLM Reviewer #2 initials: DJH Comments (explain poor quality ratings):
STUDY: | Authors, ref ID: Trivers, K.F., Shaw, K.M., Sabatino, S.A., Shapiro, J.A., Coates, R.J.60 Year of publication: 2008 Dates of data collection: 2000 and 2005 Trial name: NA
OBJECTIVE OR AIM: | This study aimed to determine whether progress was made between 2000 and 2005 in reducing CRC screening disparities by race, ethnicity, income, and insurance status.
DESIGN: | Setting: Household survey Study design: Longitudinal, cross-sectional study Duration (mean followup): 5-year follow-up Overall study size (N enrolled/N analyzed): n=6020 in 2000, n=6706 in 2005
| [underlined: 2000] | | [underlined: 2005]
Sample size: | Sample size = 6,020 | | Sample size = 6,706
Describe intervention: | Intervention: NHIS cancer control supplement | | Intervention: NHIS cancer control supplement
RECRUITMENT: (population-based, clinic-based, volunteer, other) | Population-based
INCLUSION CRITERIA: | Respondents to the 2000 and 2005 NHIS cancer control supplements, age 50–64, civilian, non-institutionalized
EXCLUSION CRITERIA: | History of CRC
POPULATION CHARACTERISTICS: | [underlined: 2000] | | [underlined: 2005]
Mean age & range (years): | Age: 41.9% 50–54, 32% 55–59, 26.1% 60–64 | | Age: 39.9% 50–54, 33.6% 55–59, 26.5% 60–64
Sex (% female): | Sex: 51.9% | | Sex: 51.8% female
Race: | Race: 84.8% White, 9.8% Black, 2.9% Asian, .7% AI/AN, 1.7% Other | | Race: 85% White, 10.7% Black, 3.2% Asian, .8% AI/AN, .2% Other
Other:
| [underlined: 2000] | | [underlined: 2005]
Attrition/Drop-out (not available for endpoint measurement): | 72.1% response rate for cancer control supplements | | 69.0% response rate for cancer control supplements
Adherence:
Contamination:
Response Rates (e.g. for surveys):
STATISTICAL ANALYSES: | Describe: • For each group of interest, the percentages of respondents reporting screening within the defined time frame and 95% CIs were calculated, stratified by gender, and age-adjusted within the survey year. • Changes in disparities over time (from 2000 to 2005) were present if CIs for the differences in percentages did not overlap or exhibited only minimal overlap. • Multivariate logistic regression analysis, stratified by gender, was used to estimate screening disparities adjusted for age, race, ethnicity, poverty ratio, insurance status, education, region, and duration of U.S. residence
ASSESSMENT OF EXPOSURES AND POTENTIAL CONFOUNDERS: | NR
OUTCOME ASSESSMENT: | Outcome Measures: Up-to-date with CRC screening
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | Outcomes: • Among men, the percentages screened in 2005 were higher than those in 2000 for white men, non-Hispanic men, those with middle or high incomes, and those with private insurance. The largest significant increase in screening over time was among middle-income men (7.4 percentage points, CI=1.8, 12.9). The uninsured made the least progress over time and had the lowest screening rates in both years (e.g., 19.1%, CI=14.6, 24.5 in 2005). • In 2005, Asian men continued to report the lowest screening of any racial group examined, with 33.2% reporting screening, a 12.0 percentage-point difference compared to white men. In both years, Hispanic men reported less screening than non-Hispanic men, as did men with lower compared to higher incomes. • The largest disparity was associated with being uninsured, and no reduction in the disparity occurred over time. • Screening did not increase among Hispanic women or uninsured women (27.1%, CI=22.0, 32.8; and 19.3%, CI=15.7, 23.4 in 2005, respectively). Asian women had the largest gain in screening (in 2005, 38.5%, CI=27.6, 50.7); however, they had the lowest observed screening rate of any racial group examined among women. • In 2005, uninsured women were least likely to be screened. • Disparities associated with Hispanic ethnicity, low income, and being uninsured were larger in 2005 versus 2000. The difference between Hispanic and non-Hispanic women in 2000 was 8.8 percentage points (CI=3.0, 14.6). This gap rose to 19.3 percentage points (CI=13.6, 25.0) in 2005.
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | Outcomes: NA
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Outcomes: NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Outcomes: NA
QUALITY RATING: | Fair
Quality Assessment-Internal Validity for Observational Studies
| | Yes | | No | | Other (CD, NR, NA)
Were the groups similar at baseline regarding the most important prognostic indicators? | | X
Were the drop-out or response rates acceptable (≤ 20%)? [If between 20% and 60%, check other and explain.] | | | | | | 72.1% response rate for cancer control supplements in 2000, 69% in 2005
Were the differential drop-out or response rates acceptable (≤ 15%)? | | X
Were intervention/exposure measures valid, reliable, and equally applied? | | | | | | NA
Were the outcome assessors blinded to the intervention or exposure status of subjects? | | | | | | NA
Were outcome measures valid, reliable, and equally applied? | | X
Does the analysis control for baseline differences? | | X
Were important potential confounding and modifying variables taken into account in the design and analysis (e.g., through matching, stratification, or statistical adjustment)? | | X
Were the statistical methods used to assess the abstracted outcomes appropriate? | | X
Quality Rating (Good, Fair, or Poor): Fair Reviewer #1 initials: BLM Reviewer #2 initials: DJH Comments (explain poor quality ratings):
STUDY: | Authors, ref ID: Walsh JME et al.61 Year of publication: 2004 Dates of data collection: November 2001 to June 2002 Trial name: NA
OBJECTIVE OR AIM: | To identify current colorectal cancer screening practices and barriers and facilitators to colorectal cancer screening in Latino, Vietnamese, and non-Latino white populations in San Jose, California
DESIGN: | Setting: Telephone survey amongst Latino, Vietnamese, and non-Latino whites aged 50 to 79 years residing in San Jose (Santa Clara County), California Study design: Cross-sectional Duration (mean followup): NA Overall study size (N enrolled/N analyzed): 1,559 contacted, 775 enrolled (50%)
| [underlined: White] | | [underlined: Latino] | | | [underlined: Vietnamese]
Sample size: | N=310 | | N=226 | | | N=239
Describe intervention: | NA | | NA | | | NA
RECRUITMENT: (population-based, clinic-based, volunteer, other) | Community-based
INCLUSION CRITERIA: | • 50 to 79 years old • Self identified as white, Latino, or Vietnamese. • Able to communicate in either English, Spanish, or Vietnamese
EXCLUSION CRITERIA: | • Those not within the target age group and population
POPULATION CHARACTERISTICS: | Total: Educational level, insurance status, median income, employment status, marital status, having a regular physician, and having been to the doctor in past 12 months were significantly different (P < 0.05) between ethnic groups
Mean age & range (years): | • 61 (±8)
Sex (% female): | • 50.5%F
Race: | • 40% white • 29.2% Latino • 30.8% Vietnamese
Other:
• Education • Insurance (%) • Income (median) • Acculturation (%) • Marital status • Having a regular physician | • 42.4% ≤ High School education • 6.7% Uninsured • $50,000 • 48% low • 69.9% married • 87.1%
| Overall
Attrition/Drop-out (not available for endpoint measurement): | 50% of those contacted and eligible refused to participate
Adherence:
Contamination:
Response Rates (e.g. for surveys): | • 40% white • 29.2% Latino • 30.8% Vietnamese
STATISTICAL ANALYSES: | • Descriptive statistics for demographic and dependent variables • Univariate analysis (Student’s t test and logistic regression) to determine association between predictor variables (age, gender, ethnicity, acculturation, education, income and insurance) and dependent variables (bring up-to-date for screening and intention to be screened) • Multivariate analysis: Multivariate regression analysis to determine which predictors remained significant when correcting for other variables
ASSESSMENT OF EXPOSURES AND POTENTIAL CONFOUNDERS: | Multivariate regression analysis to account for age, gender, ethnicity, acculturation, education, insurance, and income
OUTCOME ASSESSMENT: | Outcome Measures: • Unadjusted Screening rates for FOBT in the past year or sigmoidoscopy in the past 5 years or colonoscopy in the past 10 years or receipt of any of the tests in the recommended time interval • Predictors of being up-to-date with colon screening: FOBT in the past year or sigmoidoscopy in the past 5 years or colonoscopy in the past 10 years or receipt of any of the tests in the recommended time interval • Predictors of intention to be screened: Plan to have FOBT in next year or sigmoidoscopy in the next 5 years or colonoscopy in the next 10 years or planning to have any of the tests in the recommended time interval
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | The biggest predictor of having had a sigmoidoscopy or colonoscopy was physician recommendation (OR, 6.50; 95 CI, 2.34–18.08). Because this was such a strong factor, excluding it from the analysis allowed other important variables to be explored.
KQ2 - What factors influence the use of colorectal cancer screening? | Outcomes: | | FOBT in past yr | SIG in past 5 yrs | COL in past 10 yrs | Any
KQ2 - What factors influence the use of colorectal cancer screening? | Unadjusted screening rates:
KQ2 - What factors influence the use of colorectal cancer screening? | • White | | 19% | 35.5% | 30.6% | 41.9%
KQ2 - What factors influence the use of colorectal cancer screening? | • Latino | | 18.1% | 29.2% | 27% | 37.2%
KQ2 - What factors influence the use of colorectal cancer screening? | •Vietnamese | | 31.4% | 18.4% | 21.8% | 45.2%
KQ2 - What factors influence the use of colorectal cancer screening? | Adjusted predictors of being up-to-date (OR, 95% CI) | | (OR, 95% CI) | (OR, 95% CI) | (OR, 95% CI) | (OR, 95% CI)
KQ2 - What factors influence the use of colorectal cancer screening? | •Age (per 5 yrs) | | 1.22 (1.04–1.44) | 1.22 (1.05–1.43) | 1.19 (1.02–1.39) | 1.24 (1.03–1.50)
KQ2 - What factors influence the use of colorectal cancer screening? | •Gender (male) | | 0.89 (0.60–1.31) | 1.44 (0.96–2.16) | 1.36 (0.91–2.03) | 1.50 (1.00–2.25)
KQ2 - What factors influence the use of colorectal cancer screening? | Ethnicity (compared with white)
KQ2 - What factors influence the use of colorectal cancer screening? | •Latino | | 1.01 (0.52–1.94) | 0.90 (0.52–1.56) | 1.27 (0.73–2.22) | 0.55 (0.30–1.02)
KQ2 - What factors influence the use of colorectal cancer screening? | •Vietnamese | | 1.37 (0.49–3.86) | 0.26 (0.09 –0.72) | 0.65 (0.30–1.44) | 0.37 (0.12–1.08)
KQ2 - What factors influence the use of colorectal cancer screening? | •Acculturation(low) | | 0.87 (0.38–1.99) | 1.71 (0.84–3.48) | 0.96 (0.49–1.88) | 2.10 (0.84–5.26)
KQ2 - What factors influence the use of colorectal cancer screening? | •Education | | 0.89 (0.73–1.09) | 1.51 (0.86–1.27) | 1.01 (0.83–.23) | 1.04 (0.84–1.28)
KQ2 - What factors influence the use of colorectal cancer screening? | •Income | | 1.05 (0.90 –1.23) | 0.99 (0.87–1.14) | 1.02 (0.90–1.17) | 1.01 (0.89 –1.15)
KQ2 - What factors influence the use of colorectal cancer screening? | •No Insurance (compared with medicare) | | 0.97 (0.38– 2.50) | 0.44 (0.15–1.34) | 0.31 (0.10–0.94) | 0.57 (0.22 –1.50)
KQ2 - What factors influence the use of colorectal cancer screening? | Adjusted Predictors of intention to be screened
KQ2 - What factors influence the use of colorectal cancer screening? | •Age (per 5 yrs) | | 1.12 (0.95–1.32) | 0.97 (0.84–1.14) | 0.92 (0.78–1.08) | 1.28 (1.07–1.52
KQ2 - What factors influence the use of colorectal cancer screening? | •Gender | | 1.09 (0.76–1.56) | 1.29 (0.91–1.83) | 1.05 (0.71–1.54) | 1.20 (0.79–1.84)
KQ2 - What factors influence the use of colorectal cancer screening? | Ethnicity (compared with white)
KQ2 - What factors influence the use of colorectal cancer screening? | •Latino | | 1.18 (0.66–2.12) | 1.41 (0.79–2.52) | 2.04 (1.07–3.88) | 1.31 (0.70–2.44)
KQ2 - What factors influence the use of colorectal cancer screening? | •Vietnamese | | 1.70 (0.71–4.05) | 1.52 (0.70–3.29) | 1.19 (0.50–2.84) | 0.73 (0.31–1.74)
KQ2 - What factors influence the use of colorectal cancer screening? | •Acculturation (low) | | 1.81 (0.91–3.58) | 2.19 (1.12–4.28 | 1.86 (0.90–3.83) | 2.07 (1.00–4.30)
KQ2 - What factors influence the use of colorectal cancer screening? | •Education | | 0.96 (0.79–1.16) | 1.07 (0.89–1.29) | 1.06 (0.87–1.29) | 0.98 (0.78–1.22)
KQ2 - What factors influence the use of colorectal cancer screening? | •Income | | 0.96 (0.84–1.08) | 1.03 (0.87–1.23) | 1.01 (0.88–1.16) | 1.06 (0.88–1.27)
KQ2 - What factors influence the use of colorectal cancer screening? | •No Insurance(compared with Medicare) | | 0.56 (0.23–1.34) | 0.43 (0.18–1.01) | 0.95 (0.38–2.37) | 1.18 (0.44–3.14)
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | NA
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | NA
QUALITY RATING: | Fair
Quality Assessment-Internal Validity for Observational Studies
| | Yes | | No | | Other (CD, NR, NA)
Were the groups similar at baseline regarding the most important prognostic indicators? | | | | X
Were the drop-out or response rates acceptable (≤ 20%)? [If between 20% and 60%, check other and explain.]
Were the differential drop-out or response rates acceptable (≤15%)? | | X | | | | NR
Were intervention/exposure measures valid, reliable, and equally applied? | | X
Were the outcome assessors blinded to the intervention or exposure status of subjects? | | | | | | NR
Were outcome measures valid, reliable, and equally applied? | | X
Does the analysis control for baseline differences? | | X
Were important potential confounding and modifying variables taken into account in the design and analysis (e.g., through matching, stratification, or statistical adjustment)? | | X
Were the statistical methods used to assess the abstracted outcomes appropriate? | | X
Quality Rating (Good, Fair, or Poor): Fair
STUDY: | Authors, ref ID: Wee, C.C., McCarthy, E.P., Philips, R.S.62 Year of publication: 2004 Dates of data collection: 2000 Trial name: NA
OBJECTIVE OR AIM: | Understand the relative contribution of patient factors and physician counseling patterns to the low prevalence of screening.
DESIGN: | Setting: Home; telephone survey: 2000 National Health Interview Survey with the Cancer Control Module Study design: Secondary data analysis Duration (mean followup): One-time survey collection during 2000 Overall study size (N enrolled/N analyzed): 11,427
| [underlined: All]
Sample size: | Sample Size: 11,427
Describe intervention: | No intervention, telephone survey
RECRUITMENT: (population-based, clinic-based, volunteer, other) | Population-based
INCLUSION CRITERIA: | Age 50–75, completed the national Health Interview Survey
EXCLUSION CRITERIA: | NR
| [underlined: All]
POPULATION CHARACTERISTICS:
Mean age & range (years): | Age range: 50–75 Mean age: 64
Sex (% female):
Race:
Other:
| [underlined: All]
Attrition/Drop-out (not available for endpoint measurement): | Combined response of 72% to the supplement and core surveys
Adherence:
Contamination:
Response Rates (e.g. for surveys):
STATISTICAL ANALYSES: | Describe: • Used descriptive statistics and bivariate analyses to characterize the sample. • Used multivariable logistic regression to examine the correlates of the colon cancer screening outcomes
ASSESSMENT OF EXPOSURES AND POTENTIAL CONFOUNDERS: | • Exposures, i.e. factors of interest were cited reasons for not having screening, with specific inquiry about physician counseling. Participants asked what was the most important reason for not having FOBT. • Other demographic factors were age, race/ethnicity, education, region of US, BMI. • Potential confounders included family history of CRC, healthcare access, smoking status, and illness burden.
OUTCOME ASSESSMENT: | Outcome Measures: Respondents were asked if and when they ever have had FOBT, sigmoidoscopy, or colonoscopy. Secondary Outcome: Reasons respondents did not have FOBT or sigmoidoscopy or colonoscopy
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | Outcomes: • Sex, race/ethnicity, region, and health status were significant at the level of P<.001 for FOBT screening. • BMI was significant at the level of P<.001 for simoidoscopy/colonoscopy. • Education, insurance coverage, and usual source of care were significant at the level of P<.0001 for FOBT and sigmoidoscopy/colonoscopy. • Nonwhites less likely to have FOBT in unadjusted analysis. After adjustment, race/ethnicity, access, and education were associated with screening. Hispanics and low SES were less likely to be screened than their counterparts. • Hispanics and “other” (non-black, non white) less likely to report physician counseling. This was true even when adjusted for other factors in the table (e.g. USOC). • Reasons that respondents did not have an FOBT (of 9017): 22% reported their physician not recommending it. Among respondents who gave a reason other than lack of physician recommendation for not completing FOBT, 5793 respondents had a provider visit in the previous year; of these, 94% reported that their doctor had not discussed FOBT with them. • Reasons that respondents did not have a sigmoidoscopy or colonoscopy (of 7863): 21% reported their physician not recommending it. Among the subset of respondents who gave a reason other than lack of physician advice, 5096 had a provider visit in the previous year; of these, 92% reported that their doctor did not recommend sigmoidoscopy or colonoscopy
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | Outcomes: NA
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Outcomes: NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Outcomes: NA
QUALITY RATING: | Fair
Quality Assessment-Internal Validity for Observational Studies
| | Yes | | No | | Other (CD, NR, NA)
Were the groups similar at baseline regarding the most important prognostic indicators? | | | | | | NA
Were the drop-out or response rates acceptable (≤20%)? [If between 20% and 60%, check other and explain.] | | | | X | | combined response of 72% to the supplement and core surveys
Were the differential drop-out or response rates acceptable (≤15%)? | | | | | | NA
Were intervention/exposure measures valid, reliable, and equally applied? | | | | | | NA
Were the outcome assessors blinded to the intervention or exposure status of subjects? | | | | | | NA
Were outcome measures valid, reliable, and equally applied? | | X
Does the analysis control for baseline differences? | | X
Were important potential confounding and modifying variables taken into account in the design and analysis (e.g., through matching, stratification, or statistical adjustment)? | | X
Were the statistical methods used to assess the abstracted outcomes appropriate? | | X
Quality Rating (Good, Fair, or Poor): Fair Reviewer #1 initials: BLM Reviewer #2 initials: DR Comments (explain poor quality ratings):.
STUDY: | Authors, ref ID: Wong et al.63 Year of publication: 2005 Dates of data collection: 2001 Trial name: NA
OBJECTIVE OR AIM: | To examine CRC screening rates among different Asian-American groups compared with non-Latino whites, and factors related to CRC screening
DESIGN: | Setting: California Study design: population-based telephone survey Duration (mean follow-up): NA Overall study size (N enrolled/N analyzed): 19,489
| [underlined: Asian Americans] | | [underlined: Non-Latino whites]
Sample size: | 1, 771 | | 17,718
Describe intervention: | NA | | NA
RECRUITMENT:(population-based, clinic-based, volunteer, other) | random digit dialing, list samples
INCLUSION CRITERIA: | Asian-Americans, non-Latino whites, 50 years and older
EXCLUSION CRITERIA: | Individuals who had CRC (n = 162); Cambodians were excluded from analysis because of small number who met age criteria
POPULATION CHARACTERISTICS: | Chinese | Fillipino | South Asian | Japanese | Korean | Vietnamese | Non-Latino whites
Mean age & range (years): | 62.56 | 61.58 | 56.77 | 65.97 | 62.21 | 61.27 | 64.97
Sex (% female): | 54 | 56 | 42 | 58 | 56 | 51 | 54
Education (%)
Grade lt 12 | 22 | 9 | 2 | 2 | 21 | 39 | 6
HS grad, some college | 39 | 43 | 22 | 59 | 35 | 43 | 55
College graduate or more | 39 | 48 | 76 | 39 | 44 | 18 | 39
Married | 78 | 71 | 83 | 70 | 79 | 73 | 62
Born in US (%) | 14 | 6 | 2 | 82 | 2 | 0 | 83
Uninsured (%) | 9 | 10 | 10 | 1 | 32 | 14 | 4
0–99% FPL | 24 | 80 | 7 | 4 | 19 | 55 | 6
100–199% FPL | 20 | 26 | 4 | 18 | 30 | 24 | 17
≥ 300% FPL | 44 | 48 | 77 | 63 | 36 | 15 | 62
Attrition/Drop-out (not available for endpoint measurement): | NA
Adherence:
Contamination:
Response Rates (e.g. for surveys):
STATISTICAL ANALYSES: | Describe: Descriptive statistics were computed for all sociodemographic and dependent variables, including means and standard errors for continuous data and frequency distributions for each categorical variable. In the bivariate analyses, chi-square tests and t tests were used to determine any significant ethnic differences in sociodemographics and CRC screening outcomes. Six multivariate logistic regression models were used to assess the extent to which ethnic group differences in CRC screening were explained by predisposing, enabling, and need factors. All reported ORs were considered statistically significant at the P < 0.05 level.
ASSESSMENT OF EXPOSURES AND POTENTIAL CONFOUNDERS: | Predisposing variables that were controlled for included ethnic group (Chinese, Filipino, South Asian, Japanese, Korean, Vietnamese, and non-Latino white), age, gender, educational attainment (≤ Grade 12, some college, undergraduate degree or greater), marital status, household size (1, 2, or ≥ 3 individuals), years in the United States(< 15 yrs, ≥ 15 yrs), English-language proficiency, income (0%–99% of the FPL, 100%–199% of the FPL, 200%–299% of the FPL, and ≥ 300% of the FPL), comorbid conditions (diabetes or cardiovascular disease), and a family history of CRC. Enabling variables that were controlled for included insurance status (public, private, or uninsured), a usual source of care (yes or no), and the number of physician visits in the last year. Need variables that were controlled for included both physical and mental health, which were scored from 0 to 100(higher score = better health), general health status, and limitation of activities. They also included a variable that accounted for the data collection method (RDD sample or list sample).
OUTCOME ASSESSMENT: | Outcome Measures: Whether individuals ever had CRC screening; whether individuals were up to date for CRC screening. A respondent was considered up to date if she/he had undergone either FOBT in past yr or endoscopy in past 10 yrs or both
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | Outcomes: [underlined: Bivariate] • Receipt of CRC screening low for all groups • Asian Americans had lower rates compared with non-Latino whites (P < 0.001) • Non-Latino whites had highest rate of undergoing FOBT (58%), endoscopy (57%), and any CRC screening (75%) •Asian American rates were 38% for FOBT, 42% for endoscopy and 58% for any screening • Koreans had lowest rate of undergoing FOBT (23%) and any screening (49%) • Vietnamese had lowest rate of undergoing endoscopy (36%) • Japanese rates for all three CRC screening outcomes similar to non-Latino white rates [underlined: Multivariate] • After controlling for predisposing, enabling and need variables, the only ethnic group less likely than non-Latino whites to have undergone FOBT was Koreans (OR 0.40; 95% CI: 0.25, 0.62) • Other predisposing factors associated with significantly lower receipt of FOBT included male gender (OR 0.90; 95% CI: 0.83, 0.97), those who lived in households with ≥ 3 individuals (OR 0.80; 95% CI: 0.74, 0.87), those who lived in US for < 15 yrs (OR 0.56; 95% CI: 0.38, 0.83), and those with family income < 300% of FPL • Individuals more likely to have undergone FOBT included those who were older (OR 1.02; 95% CI: 1.01, 1.03), college graduates (OR 1.70; 95% CI: 1.42, 2.03), and those with family history of colon cancer (OR 1.77; 95% CI: 1.43, 2.19) • Significant enabling factors for FOBT receipt were having either public insurance (OR 2.00; 95% CI: 1.53, 2.61), or private insurance (OR 1.59; 95% CI: 1.30, 1.95), having a usual source of care (OR 2.49; 95% CI: 1.97, 3.14) • Need factors associated with undergoing FOBT included more physician visits (OR 1.04; 95% CI: 1.02, 1.05) • All Asian-American ethnic groups had similar rates of being up to date with FOBT compared with non- Latino whites • One predisposing factor was associated with individuals who were significantly less likely to be up to date with FOBT: living in households with ≥ 3 individuals (OR 0.68; 95% CI: 0.58, 0.79) • Individuals more likely to be up to date with FOBT screening if they were married (OR 1.41; 95% CI: 1.24, 1.62), if they had a family history of colon cancer (OR 1.77; 95% CI: 1.43, 2.19), if they had either public health insurance (OR 2.00; 95% CI: 1.53, 2.61), or private health insurance (OR 1.59; 95% CI: 1.30, 1.95), if they had more physician visits (OR 1.04; 95% CI: 1.02, 1.05), if they had a usual source of care (OR 2.49; 95% CI: 1.97, 3.14), and if they had better physical health (OR 1.00; 95% CI: 1.00, 1.01) or better mental health (OR 1.00; 95% CI: 1.00, 1.01) • Filipinos were less likely to be up to date with endoscopy (OR 0.68; 95% CI: 0.48, 0.97) • Individuals significantly less likely to be up to date with endoscopy if they lived in a household of ≥ 3 individuals (OR 0.79; 95% CI: 0.69, 0.90), if they had lived in US for < 15 yrs (OR 0.50; 95% CI: 0.37, 0.69), or if they had a family income < 200% of FPL • Additional predisposing factors associated significantly with being up to date with endoscopy included male gender (OR 1.54; 95% CI: 1.44, 1.65), and having a greater educational attainment (high school graduate: OR 1.34; 95% CI: 1.13, 1.57; college graduate: OR 1.85; 95% CI: 1.57, 2.18)
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | Outcomes: NA
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Outcomes: NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Outcomes: NA
QUALITY RATING: | Fair
Quality Assessment-Internal Validity for Observational Studies
| | Yes | | No | | Other (CD, NR, N/A)
Were the groups similar at baseline regarding the most important prognostic indicators? | | | | X | | Significant differences in sociodemographics by ethnic group
Were the drop-out or response rates acceptable (≤ 20%)? [If between 20% and 60%, check other and explain.] | | | | | | N/A
Were the differential drop-out or response rates acceptable (≤ 15%)? | | | | | | N/A
Were intervention/exposure measures valid, reliable, and equally applied? | | X
Were the outcome assessors blinded to the intervention or exposure status of subjects?
Were outcome measures valid, reliable, and equally applied? | | X
Does the analysis control for baseline differences? | | X
Were important potential confounding and modifying variables taken into account in the design and analysis (e.g., through matching, stratification, or statistical adjustment)? | | X
Were the statistical methods used to assess the abstracted outcomes appropriate? | | X
Quality Rating (Good, Fair, or Poor): Fair Reviewer #1 initials: LCM Reviewer #2 initials: DJH Comments (explain poor quality ratings):
STUDY: | Authors, ref ID: Yano, E., Soban, L., Parkerton, P., Etzioni, D.64 Year of publication: 2006 Dates of data collection: 1999–2001 Trial name: NA
OBJECTIVE OR AIM: | To identify primary care practice characteristics associated with colorectal cancer (CRC) screening performance, controlling for patient-level factors.
DESIGN: | Setting: VA Primary care clinics Study design: Cross-sectional Duration (mean followup): No follow-up, data duration of 2 years Overall study size (N enrolled/N analyzed): 155 facilities; 38.818 patients
| [underlined: Patients] | | [underlined: Group 2]
Sample size: | Sample Size: 38,818
Describe intervention: | Intervention: none, data collected on CRC screening
RECRUITMENT: (population-based, clinic-based, volunteer, other) | Clinic-based; VA Survey of Primary Care Practices
INCLUSION CRITERIA: | Physician chiefs at all VA facilities serving 4,000 or more outpatients and providing 20,000 or more outpatient visits in FY98
EXCLUSION CRITERIA: | Patients over age 86; patients with a prior history of CRC, inflammatory bowel disease, or colorectal polyps
POPULATION CHARACTERISTICS: | [underlined: Patients]
Mean age & range (years): | Age: 31.3% 52–64, 36.3% 65–74, 32.4% 75–85
Sex (% female): | Sex: 10.8% female
Race: | Race: 86.2% White, 11.1% Black, 2.8% Other
Other:
| [underlined: All]
Attrition/Drop-out (not available for endpoint measurement): | VA Survey of Primary Care Practices 93% response rate
Adherence:
Contamination:
Response Rates (e.g. for surveys):
STATISTICAL ANALYSES: | Describe: • Linked organizational data (n=155 primary care clinics) with the patient-level data (n=38,818) using station identifiers from which each patient was sampled, confirmed through evaluation of each patient’s visit patterns. • Evaluated relationships between hypothesized organizational predictors and facility-level CRC screening rates using correlation coefficients for continuous variables and ANOVA for categorical variables, applying a cutpoint of P <= .10 as inclusion criterion. • Included these organizational measures in logistic regression to estimate the influence of specific organizational characteristics on a patient’s probability of receipt of CRC screening, adjusting for cluster effects and patient-level covariates associated with screening.
ASSESSMENT OF EXPOSURES AND POTENTIAL CONFOUNDERS: | NR
OUTCOME ASSESSMENT: | Outcome Measures: CRC screening is documented as evidence of (1) three returned FOBT cards in the prior 12 months, (2) performance of a flexible sigmoidoscopy in the last 5 years, or (3) performance of a colonoscopy in the last 10 years, among patients 52 years and older.
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | Outcomes: • Authority over the internal structure and operations of the practice was significantly correlated with CRC screening (r=0.18; P<.01) (centralization), as was the sufficiency of clinical support arrangements (r=0.22; P<.001) (resources). • Facility size was significantly, negatively correlated with CRC screening (r= −0.16; P<.05) (complexity). • After adjusting for region and individual patient characteristics, patients who received their care from a primary care practice characterized by higher centralization (as measured by primary care practice autonomy) (P<.04) and resources (as measured by sufficiency of clinical support arrangements) (P<.03) were significantly more likely to receive CRC screening. • Overall screening rate 62.2%. No other absolute screening rates reported
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | Outcomes: NA
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Outcomes: NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Outcomes: NA
QUALITY RATING: | Fair
Quality Assessment-Internal Validity for Observational Studies
| | Yes | | No | | Other (CD, NR, NA)
Were the groups similar at baseline regarding the most important prognostic indicators? | | X
Were the drop-out or response rates acceptable (≤ 20%)? [If between 20% and 60%, check other and explain.] | | X | | | | VA Survey of Primary Care Practices 93% response rate
Were the differential drop-out or response rates acceptable (≤ 15%)? | | X
Were exposure measures valid, reliable, and equally applied? | | X
Were the outcome assessors blinded to the intervention or exposure status of subjects? | | X
Were outcome measures valid, reliable, and equally applied? | | X
Does the analysis control for baseline differences? | | X | | | | Probably others not adjusted for
Were important potential confounding and modifying variables taken into account in the design and analysis (e.g., through matching, stratification, or statistical adjustment)? | | | | | | uncertain
Were the statistical methods used to assess the abstracted outcomes appropriate? | | X
Quality Rating (Good, Fair, or Poor): Fair Reviewer #1 initials: BLM Reviewer #2 initials: RPH Comments (explain poor quality ratings):
STUDY: | Authors, ref ID: Yip et al.65 Year of publication: 2006 Dates of data collection: July 2003–Sept 2004 Trial name: Part of a Randomized trial (Tu et al., 2006- included under KQ3)
OBJECTIVE OR AIM: | To describe CRC screening among less acculturated Chinese Americans and to identify factors associated with CRC screening
DESIGN: | Setting: Primary care clinic Study design: retrospective chart review Duration (mean follow-up): NA Overall study size (N enrolled/N analyzed): 383
| [underlined: Group 1] | | [underlined: Group 2]
Sample size: | 383
Describe intervention: | NA
RECRUITMENT: (population-based, clinic-based, volunteer, other) | Chinese patients seen at a community clinic providing primary medical services to Asian and Pacific Islanders in Seattle
INCLUSION CRITERIA: | none were given other than they had to be of Chinese decent and patients of the clinic
EXCLUSION CRITERIA: | greater acculturation (fluent in English, n = 3)
POPULATION CHARACTERISTICS: | [underlined: Group 1] | | [underlined: Group 2]
Mean age & range (years): | 50–64, n=193 (50%) 65+, n=191 (50%)
Sex (% female): | 63.2% female
Race: | 100% Asian/Chinese 5.2% uninsured
Other: | 100% used an Asian language as their primary language
| [underlined: Group 1] | | [underlined: Group 2] | | | Overall
Attrition/Drop-out (not available for endpoint measurement): | NA
Adherence:
Contamination:
Response Rates (e.g. for surveys):
STATISTICAL ANALYSES: | Describe: descriptive statistics and then Chi-square
ASSESSMENT OF EXPOSURES AND POTENTIAL CONFOUNDERS: | Age, gender, insurance status, language
OUTCOME ASSESSMENT: | Outcome Measures: Whether patients had received screening per USPSTF guidelines
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | Outcomes: Overall, 39.7% were assessed as being screened for CRC according to guidelines. Of these, 18.9% had completed FOBT in past year, 2.9% completed FS in past 5 years, and 21.3% completed colonoscopy in past 10 years. There was no significant differences for users and non-users of any of the CRC tests (FOBT, sig, colonoscopy) based on age, gender, insurance status, or language were found.
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and follow-up? | Outcomes: NA
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Outcomes: NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Outcomes: NA
QUALITY RATING: | Fair
Quality Assessment-Internal Validity for Observational Studies
| | Yes | | No | | Other (CD, NR, NA)
Were the groups similar at baseline regarding the most important prognostic indicators? | | | | | | NR
Were the drop-out or response rates acceptable (≤ 20%)? [If between 20% and 60%, check other and explain.] | | | | | | N/A
Were the differential drop-out or response rates acceptable (≤ 15%)? | | | | | | N/A
Were intervention/exposure measures valid, reliable, and equally applied? | | | | | | NR
Were the outcome assessors blinded to the intervention or exposure status of subjects? | | | | X | | health educator, who is the same person providing the intervention in the Tu paper is the one who reviewed the charts
Were outcome measures valid, reliable, and equally applied? | | X
Does the analysis control for baseline differences? | | | | | | N/A
Were important potential confounding and modifying variables taken into account in the design and analysis (e.g., through matching, stratification, or statistical adjustment)? | | | | X | | as an example, they wanted to see about language differences but then only included patients who use an Asian language as their primary language (i.e., no comparison group)
Were the statistical methods used to assess the abstracted outcomes appropriate? | | X
Quality Rating (Good, Fair, or Poor): Fair Reviewer #1 initials: DJH Reviewer #2 initials: LCM Comments (explain poor quality ratings):
STUDY: | Authors, ref ID: Young, W.F., McGloin, J., Zittleman, L., West, D.R., Westfall, J.M.66 Year of publication: 2007 Dates of data collection: Spring 2005, for 2 weeks Trial name: Testing to Prevent Colon Cancer in Rural Colorado
OBJECTIVE OR AIM: | To establish baseline attitudinal, knowledge, belief, and behavior measures on colorectal cancer screening and to identify barriers to or predictors of colorectal cancer screening.
DESIGN: | Setting: High Plains Research Network (HPRN), a practice-based research network in 9 rural and frontier counties in northeast Colorado Study design: Baseline telephone survey Duration (mean followup): NA, no follow-up Overall study size (N enrolled/N analyzed): 1,050 respondents
| [underlined: Sample]
Sample size: | Sample size: 1,050 respondents
Describe intervention: | The authors conducted a baseline random-digit dialing telephone survey to assess colon cancer knowledge and screening behaviors among people 50 years old and older.
RECRUITMENT: (population-based, clinic-based, volunteer, other) | Random-digit dialing telephone survey
INCLUSION CRITERIA: | Age 50+
EXCLUSION CRITERIA: | NR
POPULATION CHARACTERISTICS: | [underlined: Sample]
Mean age & range (years): | Mean age: 65.3
Sex (% female): | 67.1% female
Race: | 88.4% Caucasia, .2% African American, .4% Asian, .5% Native Hawaiian/Pacific Islander, 1.5% American Indian/Alaskan Native, 7.6% Other 9.6% Hispanic
Attrition/Drop-out (not available for endpoint measurement): | 51.6% response rate
Adherence:
Contamination:
Response Rates (e.g. for surveys):
STATISTICAL ANALYSES: | Describe: • Used t tests for continuous variables and chi-square tests for categorical variables. • Performed logistic regression modeling • To test the hypothesis that the geographic distance to colorectal cancer screening services might be related to screening rates, the authors conducted 2 geographical information system (GIS) analyses.
ASSESSMENT OF EXPOSURES AND POTENTIAL CONFOUNDERS: | Logistic regression modeling. Covariates included: age, gender, race/ethnicity, marital status, educational level, employment status, and household income, when the respondent had last seen a doctor or other health care practitioner for a checkup, requesting a colorectal cancer test at last visit, whether they thought colorectal cancer ranked as a cause of death, level of agreement with the statement “Testing can identify problems in the colon before colorectal cancer can start,” family and personal history of colorectal cancer, personal history of polyp removal, perceived chances of getting colorectal cancer, the likelihood of preventing and curing colorectal cancer, and residence in a ZIP code with a hospital.
OUTCOME ASSESSMENT: | Outcome Measures: • Compared colorectal cancer knowledge and screening behavior between major demographic variables. • Used the standard American Cancer Society guidelines to define up-to-date on colorectal cancer screening (yearly FOBT, flexible sigmoidoscopy every 5 years, barium enema every 5 years, or colonoscopy every 10 years).
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | Outcomes: • Sixty-three percent reported they ever had an FOBT, but only 50% of those (32%) were up-to-date. • Participants who were of 65 years or older, married, Hispanic, or had an income more than $35,000 were more likely to be up-to-date. • Being up-to-date on this test was also associated with seeing a doctor or other health care practitioner in the past year (O.R. = 1.2, 95% C.I.1.16–1.27) or having asked for a screening test (O.R. = 2.44, 95% C.I. 2.08–2.86). • Thirty-four percent had ever had sigmoidoscopy, with 28% up-to-date. • Persons 50–64 years old were more than twice as likely as those 65 years old or older to report “financial reasons” (23.0% vs 10.3%, P < .001) as a reason for not having this test. • Nearly half (48.3%) of the Hispanic study participants reported that they “never heard of the test” compared to 35.7% of non-Hispanics (P < .05). • Hispanics were also more likely to report “financial reasons” for not having had a flexible sigmoidoscopy (24.1% vs 17.2%, P < .05). • Forty-three percent reported they ever had a colonoscopy and 38% were up-to-date. • Being up-to-date on colonoscopy was associated with having seen a doctor or health care practitioner in the past year, asking for a colon cancer test from their doctor, believing that their chances of getting colorectal cancer were greater than average and having a family history of colon cancer. • Participants who were Hispanic, unemployed, low income or were 50–64 years old were more likely to cite financial reasons for not having this test (P < .001 for all). Hispanics were also more likely to report that they never heard of this test (28.0% vs 14.8% all others, P = .02). • Only 29% had ever had a barium enema and only 13% were up-to-date. • Thirteen percent reported they ever had a virtual colonoscopy and only 2% of participants who never had this test planned to have it in the next year. • Up-to-date screening rates for participants residing in ZIP codes with a health facility were no different than those without a health facility: clinic (59.6% with clinic vs 58.2% without clinic, P = .78), hospital (59.4% with hospital vs 57.3% without hospital, P = .49), hospital or clinic (59.5% with facility vs 56.7% without a facility, P = 0.38). • Demographic predictors of being up-to-date on at least 1 colorectal cancer test were being 65 years or older (OR = 1.40; 95% CI = 1.22–1.61) or married (OR = 1.14; 95% CI = 1.02–1.27)
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | Outcomes: NA
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Outcomes: NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Outcomes: NA
QUALITY RATING: | Fair
Quality Assessment-Internal Validity for Observational Studies
| | Yes | | No | | Other (CD, NR, NA)
Were the groups similar at baseline regarding the most important prognostic indicators? | | | | | | NA
Were the drop-out or response rates acceptable (≤ 20%)? [If between 20% and 60%, check other and explain.]
Were the differential drop-out or response rates acceptable (≤ 15%)? | | | | | | NA
Were intervention/exposure measures valid, reliable, and equally applied? | | | | | | NA
Were the outcome assessors blinded to the intervention or exposure status of subjects? | | | | | | NA
Were outcome measures valid, reliable, and equally applied? | | X
Does the analysis control for baseline differences? | | X
Were important potential confounding and modifying variables taken into account in the design and analysis (e.g., through matching, stratification, or statistical adjustment)? | | X
Were the statistical methods used to assess the abstracted outcomes appropriate? | | X
Quality Rating (Good, Fair, or Poor): Fair Reviewer #1 initials: BLM Reviewer #2 initials: DR; LCM Comments (explain poor quality ratings):
STUDY: | Authors, ref ID: Zapka et al.67 Year of publication: Dates of data collection: 2002 Trial name: NA
OBJECTIVE OR AIM: | Assess the role of insurance status, type of plan, frequency of preventive health visits, and provider recommendation on utilization of CRC screening tests.
DESIGN: | Setting: Telephone survey Study design: Cross-sectional, random-digit-dial survey Duration (mean followup): June to August 1998 Overall study size (N enrolled/N analyzed): 1,002
| [underlined: Population]
Sample size: | Sample Size = 1,002
Describe intervention:
RECRUITMENT: (population-based, clinic-based, volunteer, other) | Population-based; A random-digit-dial telephone survey; Three samples—a basic random sample, a male oversample, and a racial/ethnic minority oversample targeting African Americans and Hispanics—were drawn using the Kish sampling method
INCLUSION CRITERIA: | Participants were Massachusetts residents, aged 50, who had a working residential telephone number and had never been diagnosed with CRC.
EXCLUSION CRITERIA:
POPULATION CHARACTERISTICS: | [underlined: Population]
Mean age & range (years): | Age 50+
Sex (% female): | Sex: 57%
Race: | Race: 90.1% White, 4% African American/other; 4.9% Hispanic
Other:
| [underlined: Population]
Attrition/Drop-out (not available for endpoint measurement): | Response rate = 64%
Adherence:
Contamination:
Response Rates (e.g. for surveys):
STATISTICAL ANALYSES: | Describe: • Data were standardized for gender, race, and education level to represent the overall Massachusetts population. Analyses were performed separately by age group because of inherent differences in insurance coverage based on Medicare eligibility. Statistical significance was set at < 0.05. • Contingency tables and single-predictor, logistic regression models assessed the bivariate association between the dependent variable, current CRC screening status, and each potential independent variable. • For each age group, a multiple logistic regression model was fit using independent variables that demonstrated a bivariate association of P < 0.10.
ASSESSMENT OF EXPOSURES AND POTENTIAL CONFOUNDERS: | Variables included: • Demographic (gender, race, education, ethnicity – Hispanic only, employment status, marital status) • Health factors (family history of CRC, health status) • Access (income, insurance, regular MD, gets regular checkups, frequency of checkups, ever given FOBT card, MD recommendation)
OUTCOME ASSESSMENT: | Outcome Measures: • Items asked about testing for FSIG, colonoscopy, BE, and FOBT, including those done at home and returned (FOBT) and those done in a physician’s office (FOBT/MD). • A broad definition of CRC screening status included colonoscopy or BE (screening or diagnostic) within 10 years, FSIG within 5 years, and FOBT in the past year as options Secondary Outcomes: Insurance and health service characteristics by age and CRC screening.
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | Outcomes: Significant predictors of CRC screening for younger group (age 50–64): marital status (P = 0.02), family history of CRC (P = 0.032), perceived health status (P = 0.015); for older group (age 65+): income (P = 0.03) Among the younger group, those in plans that subjects believed did not cover CRC screening had the lowest rates and those with Medicare or Medicaid had the highest (P < 0.0001). Among participants with private insurance, those with HMO coverage had a slightly higher rate (59.1%) than non-HMO respondents (55.3%). Screening status in the older group also varied substantially by insurance coverage, but did not reach statistical significance. Medicare HMO members were most likely to be currently tested. Respondents who reported that their plans covered FOBT, FSIG, and/or colonoscopy were significantly related to being currently tested (P < 0.0001). Having a regular physician and receiving a regular checkup were significantly related to current testing (P = 0.0001) Provider recommendations (P < 0.0001) and getting a regular checkup (P < 0.0001) were significantly related to screening status. M.D. ever rec. Sigmoidoscopy, Age 50–64 from total sample: NO: N, 175; %, 33.8; YES: N, 342; %, 66.2; Age 50–64 from *currently tested sample: NO: N, 151; %, 86.3; YES: N, 118; %, 34.5 P <0.0001 Age ≥ 65from total sample: NO: N, 203; %, 42.5; YES: N, 274; %, 57.5; Age ≥ 65from currently tested sample: NO: N, 181; %, 89.5; YES: N, 111; %, 40.5 P <0.0001 *Currently tested: up to date
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | Outcomes: NA
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Outcomes: NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Outcomes: NA
QUALITY RATING: | Fair
Quality Assessment-Internal Validity for Observational Studies
| | Yes | | No | | Other (CD, NR, NA)
Were the groups similar at baseline regarding the most important prognostic indicators? | | | | X (Different age groups had different characteristics)
Were the drop-out or response rates acceptable (≤ 20%)? [If between 20% and 60%, check other and explain.] | | | | | | 64%, this was a telephone survey, so seems reasonable
Were the differential drop-out or response rates acceptable (≤ 15%)? | | | | | | N/A
Were intervention/exposure measures valid, reliable, and equally applied? | | | | | | N/A
Were the outcome assessors blinded to the intervention or exposure status of subjects? | | | | | | N/A
Were outcome measures valid, reliable, and equally applied? | | X
Does the analysis control for baseline differences? | | X
Were important potential confounding and modifying variables taken into account in the design and analysis (e.g., through matching, stratification, or statistical adjustment)? | | X
Were the statistical methods used to assess the abstracted outcomes appropriate? | | X
Quality Rating (Good, Fair, or Poor): Fair Reviewer #1 initials: BLM Reviewer #2 initials: Comments (explain poor quality ratings):

Evidence Table 2 KQ 3: Which strategies are effective in increasing the appropriate use of colorectal cancer screening and surveillance?

STUDY: | Authors, ref ID: Ayanian, J.Z., Sequist, T.D., Zaslavsky, A.M., Johannes R.S.68 Year of publication: 2008 Dates of data collection: May 1 – October 31, 2006 Trial name:
OBJECTIVE OR AIM: | To determine whether surveillance colonoscopy can be increased among overdue patients by reminders to primary physicians.
DESIGN: | Setting: Clinics in Massachusetts primary care networks Study design: Randomized controlled trial Duration (mean followup): 6 months Overall study size (N enrolled/N analyzed):
INTERVENTIONS: | [underlined: Intervention] | | [underlined: Control]
Sample size: | Sample size = 358 | | Sample size = 359
Describe intervention: | Intervention: Sent letter to physicians to notify them about potential need for colonoscopy among their patients in intervention group. Included a personally addressed letter to each patient recommending colonoscopy and encouraging them to call their physician’s office to schedule procedure. If physicians felt colonoscopy was clinically indicated they could send these letters. Physicians who did not respond to initial letter within 1 month were sent a second cover letter, response form, and reminder letters addressed to their patients. | | Intervention: After 6-month observation period, an identical mailing was sent to physicians of patients in control group to ensure their physicians were aware of potential need for colonoscopy if clinically appropriate.
RECRUITMENT: (population-based, clinic-based, volunteer, other) | • Clinic-based; Physicians from 2 Massachusetts primary care networks were informed that their participation in study was voluntary and confidential. • Patients who had colorectal polyps removed via flexible sigmoidoscopy or colonoscopy during 1995 through 2000 were ascertained from electronic endoscopy database maintained by hospital’s gastroenterology division.
INCLUSION CRITERIA: | Patients had 1 or more adenomas detected by colonoscopy at Brigham and Women’s Hospital from 1995 through 2000, did not have a follow-up colonoscopy documented in electronic clinical data during 2001 through March 2006, and had an active attending physician in a primary care practice affiliated with Brigham and Women’s Hospital or Harvard Vanguard Medical Associates.
EXCLUSION CRITERIA: | Did not have an adenoma on pathology report from initial colonoscopy, had subsequent colonoscopy noted in electronic records of integrated practice, patient who did not have an active primary physician listed in electronic records.
POPULATION CHARACTERISTICS: | [underlined: Group 1] | [underlined: Group 2]
Mean age & range (years): | Mean age: 69.2 | Mean age: 69.2
Sex (% female): | 62.3% 65 years or older | 63% 65 years or older
Race: | 45% female | 47.6% female
Other population qualities: | Mean years since colonoscopy: 6.7 | Mean years since colonoscopy: 6.6
| [underlined: Group 1] | [underlined: Group 2] | | [underlined: Overall]
Attrition/Drop-out (not available for endpoint measurement): | NA
Adherence in control group:
Contamination in control group:
OUTCOME ASSESSMENT: | Outcome Measures: The primary study outcome was proportion of patients receiving colonoscopy during 6-month observation period in intervention and control groups A response form was included in mailings to physicians, asking them to report whether they intended to send a reminder letter or call each of their patients in intervention group to recommend colonoscopy. They were also asked for reasons a patient should not have this procedure (deceased, severe comorbid illness, advanced age, had follow-up colonoscopy since 2000, or no longer active in physician’s practice).
RESULTS:
KQ2 - What factors influence use of colorectal cancer screening? | Outcomes: NA
KQ3 - Which strategies are effective in increasing appropriate use of colorectal cancer screening and followup? | Outcomes: Patients whose physicians received reminders 9.2% patients underwent colonoscopy within 6 months, compared with 4.5% of patients whose physicians did not receive reminders (P = 0.009). In prespecified subgroups, this effect did not differ statistically between 2 primary care networks, elderly and nonelderly patients, or women and men (all P > 0.60 by Breslow–Day test).
KQ4 - What are current and projected capacities to deliver colorectal cancer screening and surveillance at population level? | Outcomes: NA
KQ5 - What are effective approaches for monitoring use and quality of colorectal cancer screening? | Outcomes: NA
QUALITY RATING: | Good
Quality Assessment-Internal Validity for Controlled Trials
| | Yes | No | Other (CD, NR, NA)
Was study described as randomized? | | X
Was method of randomization adequate? | | X
Was treatment allocation concealed?
Were groups similar at baseline regarding most important prognostic indicators? | | X
Was outcome assessor blinded? | | X
Was care provider blinded? | | X
Was patient blinded? | | X X | | The patient did not know they were in a study, so I consider that blinded.
Was drop-out rate acceptable (≤ 20%)? [If between 20% and 60%, check other and explain.] | | | | NA
Was differential drop-out rate acceptable (≤ 15%)? | | | | NA
Were co-interventions avoided or similar? | | X
Were outcome measures valid, reliable, and equally applied? | | X
Were all randomized participants analyzed in group to which they were originally assigned? | | X
Quality Rating (Good, Fair, or Poor): Good
STUDY: | Authors, ref ID: Basch, CE, Wolf, RL, Brouse, CH, Shmukier, C, Neugut, A, DeCarlo, LT, & Shea, S {#1175) Year of publication: 2006 Dates of data collection: 2000 – 2003 Trial name: NA
OBJECTIVE OR AIM: | • Authors compared effectiveness of a telephone outreach approach versus a direct mail approach in improving rates of colorectal cancer (CRC) screening in a predominantly Black population
DESIGN: | Setting: New York City. Sampling frame from membership lists of a health benefit fund compromising approximately 250,000 members. Through this benefit fund, all individuals had health insurance coverage that included coverage for CRC screening. Study design: RCT Duration (mean followup): Medical records reviewed 6 months after randomization Overall study size (N enrolled/N analyzed): 456/456
INTERVENTIONS: | [underlined: Intervention (telephone)] | | [underlined: Control (mailing)]
Sample size: | N=226 | | [underlined: N=230]
Describe intervention: | Tailored telephone outreach by a health educator to include establishing a positive and trusting rapport with recipient; reinforcing accurate knowledge and healthful beliefs, correcting misconceptions, and bolstering self-efficacy to obtain a CRC screening on basis of participant’s readiness and individual cognitive factors; addressing identified barriers (e.g., fear, transportation) and skill deficits that could impede CRC screening; providing social and emotional support for obtaining CRC screening; and eliciting a verbal commitment to obtain CRC screening. Median number of intervention calls was 5, and median number of total telephone minutes spent per participant was 23.5. | | Printed materials of cover letter welcoming participants into study and educational brochure.
RECRUITMENT: (population-based, clinic-based, volunteer, or) | Telephone recruitment among those in health plan, eligibility assessed by telephone.
INCLUSION CRITERIA: | Inclusion criteria were age greater than 52 years, no self-report of a recent CRC screening (defined as a home stool test within past 2 years, a flexible sigmoidoscopy within past 5 years, or colonoscopy or barium enema within past 10 years), no scheduled appointment for a CRC screening test, accessibility by telephone, ability to identify a current primary care physician (PCP), and consent to participate
EXCLUSION CRITERIA: | Exclusion criteria included self-report of prior diagnosis of colorectal polyps, inflammatory bowel disease, CRC, or other cancer that had been treated within past 5 years; stated intention to travel or to move away from region within subsequent 6 months; unemployed, retired, or unable to work due to disability; enrollment of someone else in household into study; or another medical condition that precluded meaningful participation in study
POPULATION CHARACTERISTICS: | [underlined: Intervention (n=226)] | [underlined: Control (n=230)] | Screened (n=61) | Not screened (n=61)
Mean Age | | | 57.5y (sd 3.4) | 57.5y (s.d. 3.1)
Age 52–54 | 19.5% (n=44) | 25.7% (n=59)
55–59 | 47.8% (n=108) | 43.5% (n=100)
>=60 | 32.7% (n=74) | 30.9% (n=71)
Sex (% female): | 69.9% (n=158) | 72.2% (n=166) | 67.2% (n=41) | 65.6% (n=40)
Race: Black | 67.7% (n=153) | 58.7% (n=135) | 72.1% (n=44) | 62.7% (n=37)
White | 13.7% (n=31) | 18.7% (n=43) | 11.5% (n=7) | 20.3% (n=12)
Or | 17.7% (n=40) | 21.7% (n=50) | 15.4% (n=10) | 17.0% (n=10)
Refused | 0.9% (n=2) | 0.9% (n=2)
Education: < H.S. | 11.9% (n=27) | 7.8% (n=18) | 11.5% (n=7) | 18.3% (n=11)
H.S. grad | 46.0% (n=104) | 40.4% (n=93) | 42.6% (n=26) | 46.7% (n=28)
Some college/tech school | 31.9% (n=72) | 38.7% (n=89) | 34.4% (n=21) | 26.7% (n=16)
College or beyond | 10.2% (n=23) | 12.6% (n=29) | 11.5% (n=7) | 8.3% (n=5)
| [underlined: Intervention] | [underlined: Group 2] | [underlined: Overall]
Attrition/Drop-out (not available for endpoint measurement): | Telephone intervention was implemented (1 or more calls completed) in 216 of 226 (95.6%) of those assigned to intervention. 10 intervention participants refused participation after randomization
Adherence in control group: | Telephone intervention was implemented (1 or more calls completed) in 216 of 226 (95.6%) of those assigned to intervention. 10 intervention participants refused participation after randomization
Contamination in control group: | Telephone intervention was implemented (1 or more calls completed) in 216 of 226 (95.6%) of those assigned to intervention. 10 intervention participants refused participation after randomization
OUTCOME ASSESSMENT: | Primary outcome was receipt of CRC screening within 6 months of randomization. Outcome criteria were met by receipt of a 3-day fecal occult blood test (defined as 2 samples from each of 3 consecutive bowel movements), sigmoidoscopy, colonoscopy, or a barium enema. A single stool test (defined as a single sample of stool obtained and tested for occult blood during a medical examination) was not considered an acceptable CRC screening outcome.
Results
KQ2 - What factors influence use of colorectal cancer screening? | NA
KQ3 - Which strategies are effective in increasing appropriate use of colorectal cancer screening and followup? | CRC screening was documented in 61 of 226 (27%) in G1 and 14 of 230 (6.1%) in G2 (20.9 percentage point difference). Compared with G2, those in G1 were 4.4 times more likely to receive CRC screening within 6 months of randomization (AOR, 6.38; 95% CI: 3.44–11.85).
QUALITY RATING: | Good
Quality Assessment-Internal Validity (for RCT)
| | Yes | No | Or (CD, NR, NA)
Was study described as randomized? | | x
Was method of randomization adequate? | | x
Was treatment allocation concealed? | | x
Were groups similar at baseline regarding most important prognostic indicators? | | x
Was outcome assessor blinded? | | x
Was care provider blinded? | | x
Was patient blinded?
Was drop-out rate acceptable? | | x
Was differential drop-out rate acceptable? | | x
Were co-interventions avoided or similar? | | x
Were outcome measures valid, reliable, and equally applied? | | x
Were all randomized participants analyzed in group to which y were originally assigned? | | x
Quality Rating: Good
STUDY: | Authors, ref ID: Braun, K.L., Fong, M., Kaanoi, M.E., Kamaka, M.L., Gotay, C.C.69 Year of publication: 2005 Dates of data collection: January 2003 to May 2003 Trial name: NA
OBJECTIVE OR AIM: | Test CRC screening interventions for Native Hawaiians.
DESIGN: | Setting: Hawaiian civic clubs Study design: Randomized trial Duration (mean followup): No results were collected after 16 weeks post-intervention. Overall study size (N enrolled/N analyzed): 121 people
INTERVENTIONS: | [underlined: Experimental] | | [underlined: Control]
Sample size: | Sample size: 69 | | Sample size: 52
Describe intervention: | Intervention: Native Hawaiian physician delivered the targeted educational Presentation; Native Hawaiian CRC survivor told his personal story, addressing myths and feelings of embarrassment related to CRC screening and communicating positive feelings associated with self-care and survivorship; free FOBT kits, Native Hawaiian physician provided instructions on testing and demonstrated how to use the FOBT kit to collect stool samples. Multiple telephone calls were placed to those who did not complete their FOBT 4 to 16 weeks post intervention | | Intervention: Targeted educational workshop by non-Hawaiian nurse; brochure on CRC that featured Native Hawaiian nurse; FOBT kit; nurse gave basic instructions about completing FOBT kit; telephone reminder if FOBT kit not returned within a month.
RECRUITMENT: (population-based, clinic-based, volunteer, other) | Civic centers; 16 of the 39 Hawaii based clubs volunteered to participate
INCLUSION CRITERIA: | Age 50+
EXCLUSION CRITERIA: | NR
POPULATION CHARACTERISTICS: | [underlined: Experimental] | | [underlined: Control]
Mean age & range (years): | Mean age: 65.68 | | Mean age: 65.77
Sex (% female): | Sex: 70% female | | Sex: 75% female
Race: | Ethnicity: 90% Hawaiian, 10% Non-Hawaiian | | Ethnicity: 90% Hawaiian, 10% Non-Hawaiian
Other population qualities:
| [underlined: Experimental] | | [underlined: Control]
Attrition/Drop-out (not available for endpoint measurement): | 95% data-completion rate | | 95% data-completion rate
Adherence in control group:
Contamination in control group:
OUTCOME ASSESSMENT: | Outcome Measures: FOBTs returned
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | NA
KQ3 - Which strategies are effective in Outcomes: increasing the appropriate use of colorectal cancer screening and followup? | Outcomes: • 33% of the experimental group (n=23) completed the free FOBT, compared to 40% (n=21) of the control group (no p-value given). • 13 were screened for 1^st^ time (5 in experimental and 8 in control) • People in the intervention group were less likely to be screened than people in the control group (AOR, 20.9 percentage points; 95% CI, 14.34–27.46 percentage points); RR 4.4 (2.6–7.7)
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | NA
QUALITY RATING: | Fair
Quality Assessment-Internal Validity for Controlled Trials
| | Yes | No | Other (CD, NR, NA)
Was the study described as randomized? | | X
Was the method of randomization adequate? | | X
Was the treatment allocation concealed? | | | X
Were the groups similar at baseline regarding the most important prognostic indicators? | | X
Was the outcome assessor blinded? | | | | NR
Was the care provider blinded? | | | | NA
Was the patient blinded?
Was the drop-out rate acceptable (≤ 20%)? [If between 20% and 60%, check other and explain.] | | X | | Actually, only a 50% response rate to final questionnaire
Was the differential drop-out rate acceptable (≤ 15%)? | | X
Were co-interventions avoided or similar? | | X
Were outcome measures valid, reliable, and equally applied? | | | X | Only the experimental group was measured on whether they took an FOBT kit for family members.
Were all randomized participants analyzed in the group to which they were originally assigned? | | X
Quality Rating (Good, Fair, or Poor): Fair
STUDY: | Authors, ref ID: Campbell, MK, James, A, Hudson, MA, Carr, C, Jackson, E, Oates, V, Demissie, S, & Farrell, D 70 Year of publication: 2004 Dates of data collection: 1999–2000? Trial name: WATCH
OBJECTIVE OR AIM: | To compare the effectiveness of 2 strategies to promote multiple health behaviors including colorectal cancer preventive behaviors among African American members of 12 rural North Carolina churches.
DESIGN: | Setting: Churches in rural NC Study design: RCT Duration (mean followup): 1 year Overall study size (N enrolled/N analyzed): 587 individuals, 12 churches
INTERVENTIONS: | [underlined: G1: TPV] | [underlined: G2: LHA] | [underlined: G3: Combined] | [underlined: G4: Control]
Sample size: | Sample size: 76 (50 years or older) | Sample size: 51 (50 years or older) | Sample size: 87 (50 years or older) | Sample size: 69 (50 years or older)
Describe intervention: | Intervention: included four personalized computer-tailored newsletters and four targeted videotapes corresponding to the same behaviors mailed to participants’ homes bimonthly for the first 6 months after baseline data collection (Months 2, 4, and 6); the fourth mailing occurred 9 months postbaseline. | Intervention: Church members who volunteered were invited to a reception and orientation to participate in the LHA training program. A total of seven monthly or bimonthly group training sessions (approximately 16 hr of training) were scheduled at respective churches at times chosen by the LHAs. Each trained LHA was required to identify up to 3 specific church-wide activities where they could spread the word about the intervention. | Intervention: Both TPV and LHA interventions | Intervention: Control churches were offered health education sessions and materials and speakers on topics of their choice not directly related to study objectives.
RECRUITMENT: (population-based, clinic-based, volunteer, other) | Population-based; members of 12 African American churches in five rural eastern North Carolina counties
INCLUSION CRITERIA: | Medically incapable of participation, less than 18 years old
EXCLUSION CRITERIA: | NR
POPULATION CHARACTERISTICS: (NOTE: Of total sample, not just those50 years or older) | [underlined: Control] | [underlined: LHA] | [underlined: TPV] | [underlined: Combined]
Mean age & range (years):
Sex (% female): | Sex: 77.3% female | Sex: 72.4% female | Sex: 73.6% female | Sex: 74.0% female
Race: | Age: 21.1% <40, 26.6% 40–49, 52.3% 50+ | Age: 21.1% <40, 37.5% 40–49, 41.4% 50+ | Age: 30.1% <40, 22.7% 40–49, 47.2% 50+ | Age: 27.8% <40, 23.1% 40–49, 49.1% 50+
Other population qualities:
| [underlined: All]
Attrition/Drop-out (not available for endpoint measurement): | 10 of 26 eligible churches participated (38%)
Adherence in control group: | 58% of eligible people completed baseline survey
Contamination in control group: | CASRO response rate = 66%
OUTCOME ASSESSMENT: | Outcome Measures: • Baseline telephone interviews were conducted before randomization. • Participants were asked whether they had ever had any CRC screening tests and, if so, how long ago (< 1 year, 1–2 years, 2–5 years, or > 5 years). • From these items, authors computed two variables indicating compliance with recommendations: FOBT in the past year and any combination of tests indicating up-to-date adherence with recommendations (FOBT in the past year plus or minus sigmoidoscopy in the past 5 years, double contrast barium enema in the past 5 years, or colonoscopy in the past 5 years).
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | NA
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | Outcomes: G1: 36.8% received FOBT test; 21.1% received another CRC test G2: 33.3% received FOBT test; 25.5% received another CRC test G3: 31.0% received FOBT test; 14.9% received another CRC test G4: 21.7% received FOBT test; 27.5% received another CRC test • Differences in group are not statistically significant (p=0.08 for FOBT, NR for ‘other’ tests; only ‘ns’ noted). Rates of other screening tests did not differ among study groups at baseline or follow-up.
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | NA
QUALITY RATING: | Fair
Quality Assessment-Internal Validity for Controlled Trials
| | Yes | No | Other (CD, NR, NA)
Was the study described as randomized? | | X
Was the method of randomization adequate? | | | X
Was the treatment allocation concealed? | | | X
Were the groups similar at baseline regarding the most important prognostic indicators?
Was the outcome assessor blinded? | | | X
Was the care provider blinded? | | | X
Was the patient blinded? | | X | X
Was the drop-out rate acceptable (≤ 20%)? [If between 20% and 60%, check other and explain.] | | | | CD
Was the differential drop-out rate acceptable (≤ 15%)? | | | | CD
Were co-interventions avoided or similar? | | X
Were outcome measures valid, reliable, and equally applied? | | | X
Were all randomized participants analyzed in the group to which they were originally assigned? | | X
Quality Rating (Good, Fair, or Poor): Fair
STUDY: | Authors, ref ID: Church, T.R., Yeazel, M.W., Jones, R.M, Kochevar, L.K, Watt, G.D., Mongin, S.J., Cordes, J.E., Engelhard, D. 71 Year of publication: 2004 Dates of data collection: February 2000 to March 2001 Trial name:
OBJECTIVE OR AIM: | Test whether direct mailing of FOBT kits with and without reminders to a general population could increase colorectal cancer screening.
DESIGN: | Setting: Mailed questionnaires and FOBT kits to study participants’home Study design: Randomized trial Duration (mean followup): 1 year Overall study size (N enrolled/N analyzed): 1255 baseline, 1144 1 year follow-p
INTERVENTIONS: | [underlined: Reminders] | [underlined: No Reminders] | | [underlined: Control]
Sample size: | Sample Size: 404 baseline, 351 1 year | Sample Size: 434 baseline, 390 1 year | | Sample Size: 417 baseline, 403 1 year
Describe intervention: | Intervention: questionnaire, FOBT kits with mailed reminders | Intervention: questionnaire, FOBT kits with no reminders | | Intervention: questionnaire
RECRUITMENT: (population-based, clinic-based, volunteer, other) | Minnesota State Driver’s License and Identification Card database
INCLUSION CRITERIA: | at least 50 years old and had a mailing address with a ZIP code that included some part of the county as of January 1, 2000
EXCLUSION CRITERIA:
POPULATION CHARACTERISTICS: | [underlined: Reminders] | [underlined: No Reminders] | | [underlined: Control]
Mean age & range (years): | Mean age: 63.4 baseline, 63.1 year 1 | Mean age: 63.1 baseline, 62.6 year 1 | | Mean age: 63.3 baseline; 63.4 year 1
Sex (% female): | Sex: 55.9% female baseline; 56.4% | Sex: 52.5% female baseline, 53.6% | | Sex: 51.8% female baseline, 53.3%
Race: | 1 year | 1 year | | 1 year
Other population qualities:
| [underlined: Reminders] | [underlined: No Reminders] | | [underlined: Control]
Attrition/Drop-out (not available for endpoint measurement): | 84.1% response rate baseline, 76.5% year 1 | 89% response rate baseline, 83.3% year 1 | | 86.4% response rate baseline, 86.1% year 1
Adherence in control group:
Contamination in control group:
OUTCOME ASSESSMENT: | Outcome Measures: The primary outcome of the study was the change in overall self-reported adherence to screening guidelines.
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | Outcomes: NA
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | Outcomes: • The 1-year rate changes for self-reported adherence to FOBT use were 1.5% (95% CI: −2.9% to 5.9%) for the control group, 16.9% (95% CI: 11.5% to 22.3%) for the group receiving direct mail FOBT with no reminders, and 23.2% (95% CI:17.2% to 29.3%) for the group receiving direct mail FOBT with reminders. • The 1-year rate changes for self-reported adherence to any colorectal cancer screening test were 7.8% (95% CI: 3.2% to 12.0%) for the control group, 13.2% (95% CI: 8.4% to 18.2%) for the group receiving direct mail FOBT with no reminders, and 14.1% (95% CI: 9.1% to 19.1%) for the group receiving direct mail FOBT with reminders. • Self-reported adherence to guidelines for FOBT increased 18.4% more (95% CI: 12.5% to 24.3%) in the direct mail group than in the control group; overall self-reported adherence to guidelines for any of the colorectal cancer screening tests increased 5.9% more (95% CI: 0.5% to 11.5%) in the direct mail group than in the control group. • By contrast, the differences in the 1-year rate change between the FOBT-with-reminders group versus the FOBT-with-noreminders group were smaller and not statistically significant.
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Outcomes: NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Outcomes: NA
QUALITY RATING: | Fair
Quality Assessment-Internal Validity for Controlled Trials
| | Yes | No | Other (CD, NR, NA)
Was the study described as randomized? | | X
Was the method of randomization adequate?
Was the treatment allocation concealed?
Were the groups similar at baseline regarding the most important prognostic indicators? | | X
Was the outcome assessor blinded? | | | NR | NA
Was the care provider blinded? | | X | | NA
Was the patient blinded? | | X
Was the drop-out rate acceptable (≤ 20%)? [If between 20% and 60%, check other and explain.] | | X
Was the differential drop-out rate acceptable (≤ 15%)? | | X
Were co-interventions avoided or similar? | | X
Were outcome measures valid, reliable, and equally applied? | | | | ?
Were all randomized participants analyzed in the group to which they were originally assigned? | | X
Quality Rating (Good, Fair, or Poor): Fair
STUDY: | Authors, ref ID: Costanza, M.E., Luckmann, R., Stoddard, A.M., White, M.J., Stark, J.R., Avrunin, J.S., Rosal, M.C., Clemow, L.72 Year of publication: 2007 Dates of data collection: 2001–2004 Trial name:
OBJECTIVE OR AIM: | This study’s purpose was to implement and evaluate stage-based computer-assisted tailored telephone counseling to promote colorectal cancer screening in a primary care population.
DESIGN: | Setting: Practices of community-based PCPs in the UMass Health Care system (UMHC) Study design: Randomized controlled trial Duration (mean followup): 3 months Overall study size (N enrolled/N analyzed): 51 active office-based PCPs; 2,448 patients
INTERVENTIONS: | [underlined: Intervention] | [underlined: Control]
Sample size: | Sample Size: 1187 records audited | Sample size: 1261 records audited
Describe intervention: | Intervention: mailed booklet on colorectal cancer screening followed by computer-assisted telephone counseling that was based on the Precaution Adoption Process Model three months later | Regular care
RECRUITMENT: (population-based, clinic-based, volunteer, other) | Clinic-based; patients of PCPs in the UMass Health Care system
INCLUSION CRITERIA: | Patients were between 50 and 75 years old, had documentation of a visit to a study practice within the prior two years and no record of a colonoscopy within the prior 10 years
EXCLUSION CRITERIA: | Patients with a limited life expectancy, cognitive impairment, a history of CRC or adenomatous polyps, other colon disease requiring frequent screening or non-English speakers
POPULATION CHARACTERISTICS: | [underlined: All]
Mean age & range (years): | Mean age: 61.4 years, between 50–75 years
Sex (% female): | 57% female
Race: | 92% non-Hispanic white
Other population qualities:
| [underlined: Group 1] | [underlined: Group 2] | | [underlined: Overall]
Attrition/Drop-out (not available for endpoint measurement): | NA
Adherence in control group:
Contamination in control group:
OUTCOME ASSESSMENT: | Outcome Measures: • Chart audit was used to document completion of colonoscopy, sigmoidoscopy or fecal occult blood testing; completed between 17 and 22 months after a subject’s baseline survey mailing. • Patients were coded as having a test in the post-TCC period if the test date was more than 3 months after the mailing of the brochure. Patients were coded as having a test in the post-brochure period if the test date was within three months following the mailing of the brochure • For each test authors coded patients as up-to-date with the test if the medical record indicated a test within the recommended period. If there was no indication of a test in the record, patients were coded as not up-to-date.
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | Outcomes: NA
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | G1: 25% completed any CRC test G2: 24% completed any CRC test (P = 0.68)
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Outcomes: NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Outcomes: NA
QUALITY RATING: | Fair
Quality Assessment-Internal Validity for Controlled Trials
| | Yes | No | Other (CD, NR, NA)
Was the study described as randomized? | | X
Was the method of randomization adequate? | | | | NR
Was the treatment allocation concealed? | | | | NR
Were the groups similar at baseline regarding the most important prognostic indicators? | | X | | However, statistics on each group were not reported. Author just said they were similar.
Was the outcome assessor blinded? | | | | NR
Was the care provider blinded? | | | | NR
Was the patient blinded? | | | | NR
Was the drop-out rate acceptable (≤ 20%)? [If between 20% and 60%, check other and explain.] | | | | NA
Was the differential drop-out rate acceptable (≤ 15%)? | | | | NA
Were co-interventions avoided or similar? | | X
Were outcome measures valid, reliable, and equally applied? | | X
Were all randomized participants analyzed in the group to which they were originally assigned? | | X
Quality Rating (Good, Fair, or Poor): Fair
STUDY: | Authors, ref ID: Denberg, TD, Coombes, JM, Byers, TE, Marcus, AC, Feinberg, LE, Steiner, JF, & Ahnen, DJ73 Year of publication: 2006 Dates of data collection: pt enrollment in 2005 Trial name: NA
OBJECTIVE OR AIM: | Test whether a mailed brochure after referral for screening colonoscopy will lead to a 10% increase in colonoscopy completion compared to those receiving usual care
DESIGN: | Setting: 2 general internal medicine practices affiliated with University of Colorado Health Sciences Center. Study design: randomized controlled trial Duration (mean followup): hospital claims record reviewed 4 months after referral to determine if c-scope had been completed Overall study size (N enrolled/N analyzed): 781 consecutive patients enrolled. 25 duplicates removed for patients who had received more than 1 c-scope referral.
INTERVENTIONS: | [underlined: No Mailer (control)] | [underlined: Mailer (intervention)]
Sample size: | 395 | 386
Describe intervention: | “usual care” | Brochure was mailed within 10 days of referral for screening colonoscopy; it mentioned name of patient’s primary care physician and encouraged patients to schedule a procedure. Also described colorectal cancer and polyps and similar lifetime risks for colorectal cancer for men and women, colonoscopy and risk for perforation, nature of bowel preparation for procedure, and alternative screening tests.
RECRUITMENT: (population-based, clinic-based, volunteer, other) | 2 General Internal Medicine practices associated with University of Colorado Health Science System. Consecutive patients recruited
INCLUSION CRITERIA: | Authors included asymptomatic men and women 50 years of age and older who received referrals for screening colonoscopy.
EXCLUSION CRITERIA: | Patients referred because of gastrointestinal symptoms, iron-deficiency anemia, positive fecal occult blood test results, or any other diagnostic purpose were excluded.
POPULATION CHARACTERISTICS: | [underlined: No mailer (control)] | [underlined: Mailer (intervention)]
Mean age & range (years):
50–64y | 75.7% (n=299) | 78.5% (n=303)
>=65y | 24.3% (n=96) | 21.5% (n=83)
Sex (% female): | 62.5% (n=148) | 61.1% (n=236)
Race:
White, non-Latino | 53.7% (n=212) | 59.6% (n=230)
Black, non-Latino | 10.1% (n=40) | 7.0% (n=27)
Latino | 3.8% (n=15) | 4.2% (n=16)
Other or unknown | 32.4% (n=128) | 29.3% (n=113)
Marital status
Not married | 29.4% (n=116) | 29.5% (n=114)
Married | 58.0% (n=229) | 58.0% (n=224)
Unknown | 12.7% (n=50) | 12.4% (n=48)
| [underlined: Group 1] | [underlined: Intervention] | | [underlined: Overall]
Attrition/Drop-out (not available for endpoint measurement): | | 2 mailers returned as undeliverable
Adherence in control group: | | No attrition, since medical record claims were reviewed after mailing
Contamination in control group: | | No attrition, since medical record claims were reviewed after mailing
OUTCOME ASSESSMENT: | Outcome Measures: Medical claims examined at 4 months to see if a record had been generated. If yes, c-scope completed. If no claims record, recorded as not completed. Pt demographics obtained from medical record, cross-referenced with medical record number Blinded manual review of claims data was unnecessary because the primary outcome was based on the presence and tabulation of electronic claims generated within 4 months of patient enrollment.
Results
KQ2 - What factors influence the use of colorectal cancer screening? | NA
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | Receiving a mailer was associated with a rate of colonoscopy completion that was 11.7 percentage points (95% CI, 5.1 to 18.4 percentage points) greater than that seen with usual care (70.7% vs. 59.0%, respectively; P = 0.001).
QUALITY RATING: | Fair
Quality Assessment-Internal Validity
| | Yes | No | Other (CD, NR, NA)
Was the study described as randomized? | | x
Was the method of randomization adequate? | | x | | (random # generator)
Was the treatment allocation concealed?
Were the groups similar at baseline regarding the most important prognostic indicators? | | x
Was the outcome assessor blinded?
Was the care provider blinded? | | x | | NA
Was the patient blinded?
Was the drop-out rate acceptable? | | x
Was the differential drop-out rate acceptable? | | x
Were co-interventions avoided or similar? | | x
Were outcome measures valid, reliable, and equally applied? | | x | | Medical records claim will underestimate utilization, but this should blunt the intervention’s effect
Were all randomized participants analyzed in the group to which they were originally assigned? | | x
Quality Rating: Fair
STUDY: | Authors, ref ID: Dietrich AJ, Tobin JN, Cassells A, Robinson CM, Greene MA, Sox CH, Beach ML, DuHamel KN, Younge RG74 Year of publication: 2006 Dates of data collection: November 2001 to April 2004 Trial name: NA
OBJECTIVE OR AIM: | To evaluate the effect of a telephone support intervention to increase rates of breast, cervical, and colorectal cancer screening among minority and low-income women.
DESIGN: | Setting: 11 community and migrant health centers in New York City Study design: Randomized controlled trial Duration (mean followup): 18 months Overall study size (N enrolled/N analyzed): 707 in control, 706 in intervention
INTERVENTIONS: | [underlined: Control] | [underlined: Intervention]
Sample size: | Sample size: 707 | Sample size: 706
Describe intervention: | Intervention: Usual care | Intervention: Over 18 months, women assigned to the intervention group received an average of 4 calls from prevention care managers (PCM). PCM worked with patients to address barriers, including providing motivational intervention. Physician recommendations were provided to all patients via letter or in the office. Mailing of FOBT was done but data NR.
RECRUITMENT: (population-based, clinic-based, volunteer, other) | Clinic-based
INCLUSION CRITERIA: | Women were 50 to 69 years of age, were overdue for at least 1 cancer screening according to their medical records, were patients of the center for at least 6 months, and had no plans to move or change health centers within 15 months
EXCLUSION CRITERIA: | Language barriers, up-to-date on all screenings, unresolved abnormal screening, declined to participate
POPULATION CHARACTERISTICS: | [underlined: Intervention] | [underlined: Control]
Mean age & range (years): | Mena age: 58.1 | Mean age: 58.1
Sex (% female):
Race:
Other population qualities:
| [underlined: All]
Attrition/Drop-out (not available for endpoint measurement): | 64% consented to participate
Adherence in control group:
Contamination in control group:
OUTCOME ASSESSMENT: | Outcome Measures: • Medical record documentation of mammography, Papanicolaou testing, and colorectal cancer screening according to U.S. Preventive Services Task Force recommendations. • A woman was also considered up to date for colorectal cancer screening if she had received a colonoscopy within the past 10 years or a barium enema or sigmoidoscopy within the past 5 years.
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | NA
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | G1: 63% obtained any CRC test in follow-up period (0.24 point change from baseline) G2: 50% obtained any CRC test (0.11 point change from baseline) 0.13 point difference between G1 and G2 (95% CI, 0.07–0.19)
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | NA
QUALITY RATING: | Fair
Quality Assessment-Internal Validity for Controlled Trials
| | Yes | No | Other (CD, NR, NA)
Was the study described as randomized? | | X
Was the method of randomization adequate? | | X
Was the treatment allocation concealed? | | | X
Were the groups similar at baseline regarding the most important prognostic indicators?
Was the outcome assessor blinded? | | X
Was the care provider blinded?
Was the patient blinded?
Was the drop-out rate acceptable (≤ 20%)? [If between 20% and 60%, check other and explain.] | | X | X | 64% consented to participate
Was the differential drop-out rate acceptable (≤ 15%)? | | X | | NA
Were co-interventions avoided or similar? | | X
Were outcome measures valid, reliable, and equally applied? | | X
Were all randomized participants analyzed in the group to which they were originally assigned? | | X
Quality Rating (Good, Fair, or Poor): Fair
STUDY: | Authors, ref ID: Dietrich, A.J., Tobin, J.N., Cassells, A., Robinson, C.M., Reh, M., Romero, K.A., Flood, A.B., Beach, M.L.75 Year of publication: 2007 Dates of data collection: May 2005–March 2006 Trial name:
OBJECTIVE OR AIM: | This study evaluated the impact of a streamlined prevention care management (PCM) delivered through a Medicaid managed care organization (MMCO), an infrastructure with the potential to sustain this program for the long term.
DESIGN: | Setting: Medicaid managed care organization (MMCO); New York City Study design: Randomized trial Duration (mean followup): Overall study size (N enrolled/N analyzed): 1,316 (626 women 50 years or older)
INTERVENTIONS: | [underlined: PCM intervention] | | [underlined: Affinity’s Mammography Outreach Program (AMOP) Comparison Group]
Sample size: | Sample size: 317 | | Sample size: 309
Describe intervention: | Intervention: received up to 3 scripted telephone calls to identify and overcome barriers and provide support to obtain needed breast, cervical, and colorectal cancer-screening tests and provided scheduling assistance and appointment reminders for CRC screening; educational material on breast, cervical, and CRC screening, | | Intervention: received up to 3 scripted telephone calls to encourage participation and schedule mammography appointment, remind patient of upcoming mammography appointment, and verify that patient received mammography; $25 gift certificate on confirmation of mammogram; brochure providing educational information on breast, cervical, and CRC screening; and a brief recommendation during the first telephone call to discuss CRC screening with healthcare professional.
RECRUITMENT: (population-based, clinic-based, volunteer, other) | Women were identified through Affinity’s (the MMCO) administrative database
INCLUSION CRITERIA: | Age 40–68; received care at 1 of 6 participating Community Health Centers, had been enrolled with Affinity for at least 12 months, and were overdue for at least 1 of the targeted cancer-screening tests.
EXCLUSION CRITERIA:
POPULATION CHARACTERISTICS: | [underlined: PCM intervention] | | [underlined: Affinity’s Mammography Outreach Program (AMOP) Comparison Group]
Mean age & range (years):
Sex (% female):
Race:
Other population qualities:
| [underlined: PCM intervention] | | [underlined: Affinity’s Mammography Outreach Program (AMOP) Comparison Group]
Attrition/Drop-out (not available for endpoint measurement):
Adherence in control group:
Contamination in control group:
OUTCOME ASSESSMENT: | Outcome Measures: • Screening status was assessed through MMCO administrative data • Definitions of up-to-date status were derived from US Preventive Services Task Force guidelines and matched Health Plan Employer Data and Information Set (HEDIS) breast and cervical cancer-screening guidelines used to assess the quality of MMCOs. • Up-to-date screening status for colorectal cancer (limited to women aged 50 years and older), home fecal occult blood testing within the past year, sigmoidoscopy or double-contrast barium enema within 5 years, or colonoscopy within 10 years
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | Outcomes: NA
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | Outcomes: In an intent-to-treat comparison adjusted for baseline screening status, PCM women were 1.69 times more likely to be up-to-date for colorectal cancer screening tests at follow-up than women in the comparison group (95% confidence interval, 1.03–2.77). Comparison of Up-to-Date Status between Study Groups at Baseline and Follow up (CRC results only) Colorectal Cancer Screening (smaller N reflects that this analysis was done on a subset of participants who were aged 50 years and older) PCM group N = 317 AMOP group N = 309 Adjusted Comparison (only adjusted for baseline screening status): Baseline Up to Date N = 56 (18%) in PCM group, N = 48 (16%) in AMOP group Baseline OR – none reported Follow up Up-to Date N= 103 (32%) in PCM group, N = 78 (25%) in AMOP group Follow up OR – 1.69 (95% CI 1.03–2.77), p = .04
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | NA
QUALITY RATING: | Fair
Quality Assessment-Internal Validity for Controlled Trials
| | Yes | No | Other (CD, NR, NA)
Was the study described as randomized? | | X
Was the method of randomization adequate? | | | | NR
Was the treatment allocation concealed? | | | | NR
Were the groups similar at baseline regarding the most important prognostic indicators? | | X
Was the outcome assessor blinded? | | X
Was the care provider blinded? | | | | NR
Was the patient blinded? | | | X
Was the drop-out rate acceptable (≤ 20%)? [If between 20% and 60%, check other and explain.] | | | X
Was the differential drop-out rate acceptable (≤ 15%)? | | | X
Were co-interventions avoided or similar? | | | X
Were outcome measures valid, reliable, and equally applied? | | X
Were all randomized participants analyzed in the group to which they were originally assigned? | | X
Quality Rating (Good, Fair, or Poor): Fair
STUDY: | Authors, ref ID: Dolan, J.G., Frisina, S.76 Year of publication: 2002 Dates of data collection: NR Trial name: NA
OBJECTIVE OR AIM: | To conduct a pilot test of a decision aid designed to help patients choose among currently recommended colorectal cancer screening tests.
DESIGN: | Setting: Clinic; Rochester, New York Study design: Randomized controlled trial Duration (mean followup): 2–3 months post-visit Overall study size (N enrolled/N analyzed): 95
INTERVENTIONS: | [underlined: Experimental] | | [underlined: Control]
Sample size: | • Sample size: 49 | | • Sample size: 46
Describe intervention: | • Intervention: description of colorectal cancer and the 5 screening tests, patients were urged to discuss colorectal cancer screening with their physician at their upcoming visit. | | • Intervention: standardized interview consisting of a preliminary phase and an educational phase. The preliminary phase consisted of a brief description of colorectal cancer and the purpose of the study, and a demographic survey, questions regarding past colorectal cancer screening and whether patients had a preference for a particular screening method, a question regarding how colorectal cancer screening decisions should be made, and a 10-question test of patient knowledge about colorectal cancer and its prevention
RECRUITMENT: (population-based, clinic-based, volunteer, other) | Clinic-based; patients at average risk for colon cancer being seen for routine appointments at 2 internal medicine practices in Rochester, New York. Most patients were recruited from a suburban practice with 5 general internists; 4 additional patients were obtained from an inner city faculty-resident teaching practice
INCLUSION CRITERIA: | At average risk for colorectal cancer (defined as ≥ 50 years old, a negative family history, and no personal history of inflammatory bowel disease, colorectal cancer, or polyps), spoke English fluently, had normal mental status, were not too physically ill to participate, were able to hear conversational level speech, had a life expectancy of at least 3 years, were eligible for a colorectal cancer screening test according to the guideline recommendations (i.e., no history of fecal occult blood testing within the past 11 months, flexible sigmoidoscopy or double contrast barium enema within the past 5 years, or colonoscopy within the past 10 years), and were willing to participate
EXCLUSION CRITERIA: | Recent screening, history of polyp, positive family history, too ill, abnormal mental status, history of “colitis”, history of colorectal cancer, non-compliant or refuses all screening, not fluent enough in English, “no” per physician
POPULATION CHARACTERISTICS: | [underlined: Experimental] | | [underlined: Control]
Mean age & range (years): | Mean age: 65 Age range: 50 to 81 | | Mean age: 67.3 Age range: 50 to 83
Sex (% female): | Sex: 53% female | | Sex: 52% female
Race: | Race: 98% white | | Race: 98% white
Other population qualities:
| [underlined: Experimental] | | [underlined: Control]
Attrition/Drop-out (not available for endpoint measurement): | 2% (1 patient) withdrew | | NA
Adherence in control group:
Contamination in control group:
OUTCOME ASSESSMENT: | Outcome Measures: • Decision process and decision outcomes • Note that they gave the patients numerous surveys that don’t seem to have validated or piloted questions. Materials given to those in experimental group don’t seem to be culturally tested or tested for literacy levels. There seems to be differences at baseline in the control and intervention group on some scales like decisional conflict (Table 2) but no data are provided.
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | Outcomes: NA
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | Outcomes: • Substantially fewer patients in the experimental group chose the no screening “wait & see” option before the physician visit: 18% versus 37% (P = 0.06). However, there was no difference between the groups in the number of patients who completed planned screening tests: 14 (52%) of 27 in the control group and 18 (49%) of 37 in the experimental group, P = 1.0.
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Outcomes: NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Outcomes: NA
QUALITY RATING: | Fair
Quality Assessment-Internal Validity for Controlled Trials
| | Yes | No | Other (CD, NR, NA)
Was the study described as randomized? | | X
Was the method of randomization adequate? | | X
Was the treatment allocation concealed? | | | X
Were the groups similar at baseline regarding the most important prognostic indicators? | | X | | Some measures were not assess for the control
Was the outcome assessor blinded? | | X
Was the care provider blinded?
Was the patient blinded? | | X
Was the drop-out rate acceptable (≤ 20%)? [If between 20% and 60%, check other and explain.] | | X
Was the differential drop-out rate acceptable (≤ 15%)? | | X
Were co-interventions avoided or similar? | | X
Were outcome measures valid, reliable, and equally applied? | | X
Were all randomized participants analyzed in the group to which they were originally assigned? | | NR
Quality Rating (Good, Fair, or Poor): Fair
STUDY: | Authors, ref ID: Jandorf, L., Gutierrez, Y., Lopez, J., Christie, J., Itzkowitz, S.H. 77 Year of publication: 2005 Dates of data collection: January to May 2002 Trial name:
OBJECTIVE OR AIM: | Test the effectiveness of a patient navigator (PN) in increasing compliance with screening colonoscopy in a minority community health setting.
DESIGN: | Setting: Clinic; primary care practice in East Harlem, New York City Study design: Prospective clinical trial Duration (mean followup): 6 months Overall study size (N enrolled/N analyzed): 78 total
INTERVENTIONS: | [underlined: Intervention] | [underlined: Control]
Sample size: | Sample size: 38 | Sample size: 40
Describe intervention: | Intervention: Patient Navigator: provided written reminders, telephone calls, and/or scheduling assistance; FOBT card placed in chart; physicians were asked to recommend screening to patients (but did not assess whether all participants received a recommendation for endoscopic screening from their physician) | FOBT card placed in chart to ensure clinician was blinded; physicians were asked to recommend screening to patients (but did not assess whether all participants received a recommendation for endoscopic screening from their physician)
RECRUITMENT: (population-based, clinic-based, volunteer, other) | Patients that attended the clinic; reviewed charts of patients to find eligibility and approached patients.
INCLUSION CRITERIA: | Men and women; aged 50 or older
EXCLUSION CRITERIA: | Had an FOBT within the past year; had an FS or barium enema within the past 3–5 years; had a colonoscopy within the past 10 years
POPULATION CHARACTERISTICS: | [underlined: Intervention] | [underlined: Control]
Mean age & range (years): | Mean age: 61.1 | Mean age: 61.3
Sex (% female): | 76.3% female | 72.5% female
Race: | 78.9% Hispanic | 85% Hispanic
Other population qualities: | 68.5% have public health insurance 36.8% had family history of cancer | 70% have public health insurance 38.5% had family history of cancer
| [underlined: Total]
Attrition/Drop-out (not available for endpoint measurement): | 70% agreed to participate
Adherence in control group:
Contamination in control group:
OUTCOME ASSESSMENT: | Outcome Measures: • CRC screening; Completion of CRC screening tests was determined by a series of sequential chart reviews conducted in a nonblinded fashion by the PN/RA • A second chart review took place 2–3 weeks after the initial interview and medical visit. FOBT completion as well as referral for FS or colonoscopy was recorded. • The third chart review was performed 3 months after the initial contact. During this time, FOBT completion as well as FS or colonoscopy completion was noted. After 6 months, the charts of all participants were reviewed for a fourth and final time to assess FOBT, FS, and/or colonoscopy completion.
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | Outcomes: NA
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | G1: 23.7% completion rate for endoscopy; 42.1% for FOBT G2: 5% completion rate for endoscopy (P = 0.019); 25.0% for FOBT (P = 0.086)
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Outcomes: NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Outcomes: NA
QUALITY RATING: | Fair
Quality Assessment-Internal Validity for Controlled Trials
| | Yes | No | Other (CD, NR, NA)
Was the study described as randomized? | | X
Was the method of randomization adequate? | | | | NR
Was the treatment allocation concealed? | | | | NR
Were the groups similar at baseline regarding the most important prognostic indicators? | | X
Was the outcome assessor blinded?
Was the care provider blinded? | | X
Was the patient blinded? | | | X
Was the drop-out rate acceptable (≤ 20%)? [If between 20% and 60%, check other and explain.] | | X
Was the differential drop-out rate acceptable (≤ 15%)? | | X
Were co-interventions avoided or similar? | | X
Were outcome measures valid, reliable, and equally applied? | | X
Were all randomized participants analyzed in the group to which they were originally assigned? | | X
Quality Rating (Good, Fair, or Poor): Fair
Applicability Assessment
Population | Mean age 61.2, primarily Hispanic women
Intervention | Patient Navigator: provided written reminders, telephone calls, and/or scheduling assistance
Comparison | Control group that received an FOBT card and recommendation from physician for screening
Outcomes | CRC screening rates
Timing of follow-up | 3 and 6 months
Setting | Clinic
STUDY: | Authors, ref ID: Ling BS, Schoen RE, Trauth JM, Wahed AS, Eury T, Simak DM, Solano FX, Weissfeld JL78 Year of publication: 2009 Dates of data collection: June 1, 2002, through April 30, 2004 Trial name: NA
OBJECTIVE OR AIM: | In a controlled study of primary care patients eligible for colorectal cancer screening, authors sought to compare 2 PPIP-based physician office and patient management interventions for their effect on completion of endoscopic screening.
DESIGN: | Setting: 10 Primary care practices participating in the Physician Research in Office Network (PRONET) Study design: Randomized controlled trial. 2×2 factorial design. Duration (mean followup): 1 year Overall study size (N enrolled/N analyzed): 599 patients
Methods: | Practices were paired according to the number of physicians, specialty, location, and clientele, and then randomized one member of each pair to enhanced office and patient management and the second to a nonehnanced office and patients management. Within each physician group practice, eligible patients were randomized individually to receive a personalize (tailored) or nonpersonalized letter that recommended endoscopic screening. Flips of a coin witnessed by a person not involved in the research was used to allocate practices and computer generated random numbers to allocate individuals. Patients were recruited via a mailed packet (see Recruitment). Following recruitment and randomization, patients received letters recommending endoscopic CRC screening and asking recipients to telephone for an appointment. The non tailored letter lacked a personalized salutation or patient specific content. The tailored letter included a personalized salutation, named the personal physician, commented on the patients age, family history, history of CRC testing.
INTERVENTIONS: Sample size: | [underlined: Enhanced Office and Patient Management Practices (with and without tailored letters to patients)] | | [underlined: Nonenhanced Office and Patient Management Practices (with and without tailored letters to patients)]
Describe intervention: | Intervention: The enhanced office and patient management intervention used research staff to help office staff (1) adapt office-based protocols for endoscopic screening referral, (2) track patient outcomes, and (3) resolve patient-specific barriers to screening. They also worked with the office staff to develop protocols for CRC screening and implement them within their practice. This was combined with: Tailored letter mailed to patients (n=152) No tailored letter sent (n=190) | | Intervention: In the nonenhanced office and patient management intervention, authors educated physicians and office staff members about colorectal cancer screening guidelines and common barriers and misperceptions related to colorectal cancer screening. Working with office managers, authors also helped offices write protocols to guide patient referrals for endoscopic screening of the lower gastrointestinal tract. The nonenhanced intervention represented a current standard of care in which providers use published tools (e.g., PPIP10) and existing resources to initiate and sustain office procedures for promoting preventive clinical services. This was combined with: Tailored letter mailed to patients (n=133) No tailored letter sent (control group) (n=124)
RECRUITMENT: (population-based, clinic-based, volunteer, other) | Clinic-based (primary care physician-based practices). 10 practices from among unknown number of PRONET practices were identified and recruited. Patients within these practices were recruited via: electronic billing records identified age-=eligible patients who had an office visit in the preceding fiscal year. Patients were mailed a packet with an invitation letter requesting participation in the project. The packet also included a survey with included questions about exclusion criteria.
INCLUSION CRITERIA: | Patients aged 50 to 79 years, no personal history of colorectal cancer or polyp and no recent lower gastrointestinal tract procedures (FS or BE in 5 years or colonoscopy in 10 years)
EXCLUSION CRITERIA: | Patients with a personal history of colorectal cancer or polyp, recent lower gastrointestinal tract procedure
POPULATION CHARACTERISTICS: | [underlined: Enhanced Office and Patient Management] | | [underlined: Nonenhanced Office and Patient Management]
Mean age & range (years): | Sex: 56.7% women | | Sex: 52.9% women
Sex (% female): | Age: 36.3% age 50–54, 24.6% age 55–59, 14.3% age 60–64, 10.8% age 65–69, 7.9% age 70–74, 6.1% age 75+ | | Age: 31.1% age 50–54, 22.2% age 55–59, 12.8% age 60–64, 13.6% age 65–69, 12.5% age 70–74, 7.8% age 75+ Race: 84.4% White, 15.6% Other
Race: | Race: 90% White, 10% Other
Other population qualities:
| [underlined: Tailored/enhanced] | [underlined: Nontailored/enhanced] | [underlined: Tailored/nonenhanced] | [underlined: Nontailored/nonenhanced]
Attrition/Drop-out (not available for endpoint measurement): | 92.1% completed follow-up | 86.8% completed follow-up | 96.2% completed follow-up | 96.0% completed follow-up
Adherence in control group:
Contamination in control group:
OUTCOME ASSESSMENT: | Outcome Measures: • The primary end point was medical-record-verified flexible sigmoidoscopy or colonoscopy. • To ascertain procedures missed by medical record reviews, authors telephoned patients in the enhanced and nonenhanced management intervention to ask about completed or planned procedures. The enhanced office intervention included periodic telephone contacts. Authors attempted to contact patients in the non enhanced management intervention after the anniversary of the letter if preliminary medical record reviews failed to document occurrence of the end point. • Statistical end-point analysis (according to randomization intent) used generalized estimating equations to account for correlated outcomes according to physician group. • Because authors realized that the outcome from 2 individuals belonging to the same matched pair of physician practices will be correlated, statistical analysis of the clinical trial end point (analyzed according to randomization intent) used generalized estimating equation (GEE) methods to model the association of interventions with the outcome. This approach consists of 2 models fitted simultaneously. The main model specifies the logistic regression of the outcome on the independent variables and the other model accounts for the correlations between patients arising from their belonging to the same physician group practice (within practice) and to the same matched pair (between practice). • Authors used alternate logistic regression models to specify within- and between-practice associations in terms of pair-wise odds ratios.
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | NA
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | Outcomes: • During a one year period, endoscopy occurred in 48.2%. This included: 53.3% of patients in the group with tailored letter and enhanced management, 54.2% in the group with nontailored letter and enhanced management; 43.6% in the group with tailored letter and nonenhanced management; and 37.9% in the group with nontailored letter and nonenhanced management. • Enhanced management increased the odds of completing a colonoscopy or FS by 1.63 fold (95% CI 1.11–2.41). However, the tailored letter increased the odds of completion by only 1.08 fold (0.72–1.62).
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | NA
QUALITY RATING: | Fair
Quality Assessment-Internal Validity for Controlled Trials
| | Yes | No | Other (CD, NR, NA)
Was the study described as randomized? | | X
Was the method of randomization adequate? | | X
Was the treatment allocation concealed?
Were the groups similar at baseline regarding the most important prognostic indicators? | | X
Was the outcome assessor blinded? | | | X
Was the care provider blinded? | | | X
Was the patient blinded? | | | X
Was the drop-out rate acceptable (≤ 20%)? [If between 20% and 60%, check other and explain.] | | X
Was the differential drop-out rate acceptable (≤ 15%)? | | X
Were co-interventions avoided or similar? | | X
Were outcome measures valid, reliable, and equally applied? | | | x | Phone contact with enhanced group was greater, introducing possible measurement bias
Were all randomized participants analyzed in the group to which they were originally assigned? | | X
Quality Rating (Good, Fair, or Poor): Fair
Applicability Assessment:
Population | Patients age 50–79
Intervention | Enhanced office and patient-based management training
Comparison | Compared those with enhanced and non-enhanced management training
Outcomes | Flexible sigmoidoscopy or colonoscopy
Timing of follow-up | 1 year
/
Setting | Primary care practices
STUDY: | Authors, ref ID: Myers, RE, Sifri, R, Hyslop, T, Rosenthal, M, Vernon, SW, Cocroft, J, Wolf, T, Andrel, J, & Wender, R 79 Year of publication: 2007 Dates of data collection: 2002–2004 Trial name: NR
OBJECTIVE OR AIM: | To determine whether targeted and tailored interventions can increase screening use.
DESIGN: | Setting: Jefferson Family Medicine Associates (JFMA), a large urban practice located at Thomas Jefferson University in Philadelphia (1 central practice site) Study design: RCT Duration (mean followup): 24 months Overall study size (N enrolled/N analyzed): 1546/1546
INTERVENTIONS: | [underlined: SI] | [underlined: TI] | [underlined: TIP] | [underlined: Control]
Sample size: | 387 | 386 | 386 | 387
Describe intervention: | Targeted intervention by mail (i.e., personalized screening invitation letter, informational booklet, FOBT fit, and reminder letter) | SI intervention plus Targeted intervention with tailored “message pages.” | (SI and TI combined) Targeted intervention, tailored message pages, and a telephone reminder. | Usual care
RECRUITMENT: (population-based, clinic-based, volunteer, other) | Clinic-based; practice billing database was used to identify potential study participants. In February and March of 2002, JFMA sent a letter to potential participants introducing the research study. The letter informed recipients of the purpose of the study, provided details regarding participation, and explained opt-out procedures
INCLUSION CRITERIA: | Adult male and female patients of JFMA, between 50–74 years old, no prior diagnosis with colorectal neoplasia or inflammatory bowel disease, had had at least one visit to JFMA within the previous 2 years, had complete contact information (i.e., address and telephone number) available, and had not undergone recent CRC screening. The latter criterion related to having an SBT within the previous year, FS within the previous 5 years, a DCBE X-ray within the previous 5 years, or a colonoscopy within the previous 10 years.
EXCLUSION CRITERIA: | See above
POPULATION CHARACTERISTICS: | Overall
Mean age & range (years): | NR
Sex (% female): | 67%
Race: | 58% African American
Other population qualities:
Family history of CRC | 5%
> high school education | 51%
Prior cancer screening test | 41%
| [underlined: SI] | [underlined: TI] | [underlined: TIP] | [underlined: Control]
Attrition/Drop-out (not available for endpoint measurement): | 19% | 19% | 20% | 21%
Adherence in intervention group:
Contamination in control group:
OUTCOME ASSESSMENT: | Outcome Measures: Screening use
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | NA
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | Outcomes: • Univariate analyses showed screening rates in study groups were 33% in the control group, 46% in the SI group, 44% in the TI group, and 48% in the TIP group. Screening was found to be significantly higher in all 3 intervention groups compared with the control group (OR 1.7 [95% CI 1.3–2.5], OR 1.6 [95% CI, 1.2–2.1], and OR 1.9 [95% CI, 1.4–2.6], respectively), but did not vary significantly across intervention groups.
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Outcomes: NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Outcomes: NA
QUALITY RATING: | Fair
Quality Assessment-Internal Validity for Controlled Trials
| | Yes | No | Other (CD, NR, NA)
Was the study described as randomized? | | X
Was the method of randomization adequate? | | X
Was the treatment allocation concealed?
Were the groups similar at baseline regarding the most important prognostic indicators? | | | | CD
Was the outcome assessor blinded?
Was the care provider blinded? | | X
Was the patient blinded?
Was the drop-out rate acceptable (≤ 20%)? [If between 20% and 60%, check other and explain.] | | X
Was the differential drop-out rate acceptable (≤ 15%)? | | X
Were co-interventions avoided or similar? | | X
Were outcome measures valid, reliable, and equally applied? | | X
Were all randomized participants analyzed in the group to which they were originally assigned? | | X
Quality Rating (Good, Fair, or Poor): Fair
Applicability Assessment
Population | Patients (50–74) of a large urban primary care practice
Intervention | Standard and tailored interventions to increase CRC screening
Comparison | Usual care
Outcomes | CRC screening
Timing of follow-up | 24 months after intervention
Setting | Primary care practice center
STUDY: | Authors, ref ID: Pignone, M., Harris, R., Kisinger, L.80 Year of publication: 2000 Dates of data collection: May to November 1998 Trial name: NA
OBJECTIVE OR AIM: | To test whether a decision aid consisting of an educational video, targeted brochure, and chart marker increased performance of colon cancer screening in primary care practices.
DESIGN: | Setting: Community primary care practices Study design: Randomized controlled trial Duration (mean followup): 3-month chart review Overall study size (N enrolled/N analyzed): 249
INTERVENTIONS: | [underlined: Intervention] | | [underlined: Control]
Sample size: | Sample size: 125 | | Sample size: 124
Describe intervention: | Intervention: Questionnaire about intentions for CRC screening, watched video about CRC screening options, received brochure about CRC screening, then another questionnaire about CRC screening intentions | | Intervention: Questionnaire about intentions for CRC screening, watched video about traffic safety, then another questionnaire about CRC screening intentions
RECRUITMENT: (population-based, clinic-based, volunteer, other) | Clinic-based; Patients were contacted by telephone before their scheduled visits and asked to participate in a study of preventive care.
INCLUSION CRITERIA: | Adults 50 to 75 years of age who were scheduled to be seen for a new or ongoing health problem by one of the participating providers from the three practices
EXCLUSION CRITERIA: | Reported a personal or family history of colon cancer, had home fecal occult blood testing (FOBT) in the past year or flexible sigmoidoscopy, colonoscopy, or barium enema in the past 5 years, were judged by the research assistant to be too ill to participate, or appointments were only for laboratory blood work.
POPULATION CHARACTERISTICS: | [underlined: Intervention] | | [underlined: Control]
Mean age & range (years): | Mean age: 63.1 | | Mean age: 62.7
Sex (% female): | Sex: 59% female | | Sex: 61% female
Race: | Race: 84% white | | Race: 90% white
Other population qualities:
Attrition/Drop-out (not available for endpoint measurement): | All None
Adherence in control group:
Contamination in control group:
OUTCOME ASSESSMENT: | Outcome Measures: Intervention group participants were less likely than controls to have graduated from high school (73% vs. 84%) and were more likely to have Medicare as their main form of insurance (56% vs. 45%).
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | Outcomes: N
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | Outcomes: • At baseline, the mean score for intent to ask for screening (measured on a 4-point Likert scale) was 2.2 in both groups. • After the participants watched the video, the mean 6 SD score for intent to ask for screening was significantly higher in the intervention group (3.1 6 1.0) than the control group (2.5 6 1.1) (P, 0.001, Wilcoxon rank-sum test). In the intervention group, 50.0% of participants moved from low (1 or 2) to high (3 or 4) intent to be screened after watching the video compared with 26.5% of controls. • When asked after their visits whether they had had any conversation about colon cancer screening, 68.5% of intervention group participants and 43.4% of controls reported some conversation (difference, 25.1 percentage points [95% CI, 12.7 to 37.6 percentage points]). • For the main outcome of any test completed, the absolute difference between the intervention (36.8%) and control (22.6%) groups was 14.2 percentage points (CI, 3.0 to 25.4 percentage points).
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Outcomes: NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Outcomes: NA
QUALITY RATING: | Fair
Quality Assessment-Internal Validity for Controlled Trials
| | Yes | No | Other (CD, NR, NA)
Was the study described as randomized? | | X
Was the method of randomization adequate? | | X
Was the treatment allocation concealed?
Were the groups similar at baseline regarding the most important prognostic indicators? | | X | X | Intervention group participants were less likely than controls to have graduated from high school (73% vs. 84%) and were more likely to have Medicare as their main form of insurance (56% vs. 45%).
Was the outcome assessor blinded? | | X
Was the care provider blinded? | | | X
Was the patient blinded? | | | X
Was the drop-out rate acceptable (≤ 20%)? [If between 20% and 60%, check other and explain.] | | X
Was the differential drop-out rate acceptable (≤ 15%)? | | X
Were co-interventions avoided or similar? | | X
Were outcome measures valid, reliable, and equally applied? | | X
Were all randomized participants analyzed in the group to which they were originally assigned? | | X
Quality Rating (Good, Fair, or Poor): Fair
Applicability Assessment
Population | North Carolina adults age 50–75
Intervention | Questionnaire about intentions for CRC screening, watched video about CRC screening options, received brochure about CRC screening, then another questionnaire about CRC screening intentions
Comparison | Compared to patients who received a video about traffic safety
Outcomes | CRC screening rates
Timing of follow-up | 3 month chart review
Setting | Primary care clinics
STUDY: | Authors, ref ID: Potter MB, Phengrasamy L, Hudes ES, McPhee SJ, Walsh JME81 Year of publication: 2009 Dates of data collection: September 2006–March 31, 2007 Trial name: NA
OBJECTIVE OR AIM: | Authors wanted to determine whether providing home fecal occult blood test (FOBT) kits to eligible patients during influenza inoculation (flu shot) clinics can contribute to higher colorectal cancer screening (CRCS) rates.
DESIGN: | Setting: Family Health Center, a residency-based clinic at San Francisco General Hospital Study design: Time-randomized trial Duration (mean followup): Overall study size (N enrolled/N analyzed): 514
INTERVENTIONS: | [underlined: Control] | [underlined: Intervention]
Sample size: | Sample size: 8 flu shot sessions, n= 247 | Sample size: 9 flu shot session, 264 flu shots given
Describe intervention: | Intervention: Flu shot given | Intervention: Flu shot and FOBT kit given
RECRUITMENT: (population-based, clinic-based, volunteer, other) | Clinic-based; patients aged 50 to 79 years were mailed multilingual flu shot campaign announcements in English, Chinese, Russian, Spanish, and Vietnamese
INCLUSION CRITERIA: | Age 50–79 years, had not had a FOBT since the end of the prior influenza season, a colonoscopy in the past 10 years, any previously unevaluated abnormal FOBT results, a history of recent unevaluated rectal bleeding. Persons with FS in the last 5 years alone were eligible.
EXCLUSION CRITERIA: | NR
POPULATION CHARACTERISTICS: | [underlined: Control] | [underlined: Intervention]
Mean age & range (years): | Mean age: 65.6 | Mean age: 63.7
Sex (% female): | Sex: 65.9% female | Sex: 61.2% female
Race: | Ethnicity: 6.1% African American, 56.1% Asian/Pacific Islander, 25.2% Latino, 9.8% Non-Latino White, 2.8% Other/Unknown | Ethnicity: 5.6% African American, 48.1% Asian/Pacific Islander, 35.8% Latino, 7.8% Non-Latino White, 2.6% Other/Unknown
Other population qualities:
| [underlined: Overall] | [underlined: Group 2] | | [underlined: Overall]
Attrition/Drop-out (not available for endpoint measurement): | 264 flu shots given 153 eligible for FOBT
Adherence in control group: | 149 offered FOBT and 4 missed
Contamination in control group: | 143 given FOBT and 6 refused
OUTCOME ASSESSMENT: | Outcome Measures: • The primary study outcome was change in CRCS up-to-date status from being due for a screening test, defined as not having a FOBT in the last year, a flexible sigmoidoscopy or double-contrast barium enema in the past 5 years, a colonoscopy in the past 10 years, or having any previously unevaluated abnormal FOBT results or recent unevaluated rectal bleeding, to having completed the FOBT. • Authors compared baseline characteristics of the intervention and control groups using the 2-sample t test for continuous variables and the Pearson χ^2^ test for categorical variables. • To compare the changes in CRCS status between the 2 study arms, a −1, 0, +1 score was created for the preintervention to postintervention change for each patient. In this scoring system, +1 indicates being due for screening at preintervention and up-to-date at postintervention; −1 indicates being up-to‐date at preintervention and due for screening at postintervention; and 0 indicates no preintervention to postintervention change in CRCS status. • A 2-sample Wilcoxon test was used to compare these change scores for the 2 groups. Within each arm, the McNemar test was used to compare preintervention to postintervention percentage point change in CRCS status. • Using available preselected predictor variables that have been associated with variations in screening completion, authors next explored predictors of CRCS with multivariate logistic regression models.
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | NA
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | G1: 83 (68.0%) became up-to-date with any CRC screening at follow-up (29.8 percentage point change from baseline; 95% CI, 23.7–36.0) G2: 24 (20.7%) became up-to-date with any CRC test (4.4 percentage point change; 95% CI, −0.7–9.7) P < 0.001
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | NA
QUALITY RATING: | Good
Quality Assessment-Internal Validity for Controlled Trials
| | Yes | No | Other (CD, NR, NA)
Was the study described as randomized? | | X
Was the method of randomization adequate? | | X | | Not well described
Was the treatment allocation concealed? | | | X
Were the groups similar at baseline regarding the most important prognostic indicators? | | X | | Except for age, p=.004
Was the outcome assessor blinded? | | | | Not stated
Was the care provider blinded? | | | x | The clinic staff was not told in advance on what dates they would perform the intervention. However, contamination possible as the same staff were conducting flu shots on all days
Was the patient blinded? | | | x
Was the drop-out rate acceptable (≤ 20%)? [If between 20% and 60%, check other and explain.] | | x
Was the differential drop-out rate acceptable (≤ 15%)? | | | | NA
Were co-interventions avoided or similar? | | X
Were outcome measures valid, reliable, and equally applied? | | X
Were all randomized participants analyzed in the group to which they were originally assigned? | | X
Quality Rating (Good, Fair, or Poor): Good
Applicability Assessment:
Population | Patients age 50–79 in a San Francisco clinic
Intervention | FOBT kits handed out during flu shots
Comparison | Compared FOBT screening rates of patients who had flu shot with no FOBT kit and those who received an FOBT kit
Outcomes | FOBT screening
Timing of follow-up | FOBT returned within 7 months
Setting | Clinic in San Francisco
STUDY: | Authors, ref ID: Roetzheim RG, Christman LK, Jacobsen PB, Cantor AB, Schroeder J, Abdulla R, Hunter S, Chirikos TN, Krischer JP 82^) AND {#3521^ Year of publication: 2004, 2005 Dates of data collection: Trial name:
OBJECTIVE OR AIM: | Authors developed a low-cost office systems intervention, Cancer Screening Office Systems (Cancer SOS), for primary care clinics serving disadvantaged populations. Authors tested the efficacy of the system among patients attending community health centers, a representative setting of care for the target population.
DESIGN: | Setting: Community health centers Study design: Randomized controlled trial Duration (mean followup): Follow-up at 12 and 24 months Overall study size (N enrolled/N analyzed): 8 clinics—each time period, a different set of random medical charts were selected for data collection—1196 at baseline; 1237 at 12 months; 1296 at 24 months
INTERVENTIONS: | [underlined: Intervention Group] | | [underlined: Control Group]
Sample size: | Sample size: 600 | | Sample size: 596
Describe intervention: | Intervention: Key components of the intervention included a cancer-screening checklist completed by patients and indicating whether patients were due for screening, and a series of red, yellow, and green stickers that indicated whether recommended screening tests had been ordered and completed. | | Intervention: Control
RECRUITMENT: (population-based, clinic-based, volunteer, other) | Clinic-based; To target an underserved population, clinics were recruited from among 16 clinics participating in a county-funded health insurance plan in Hillsborough County, Fla.
INCLUSION CRITERIA: | • Clinics were eligible for the randomized trial if (1) they provided primary medical care 5 days a week, (2) a majority of the physician and nonphysician providers agreed to participate, and (3) the clinic was expected to continue operating in the same fashion for the following 24 months. • Patient’s records were eligible to be abstracted if both the following criteria were met: (1) the patient was 50 to 75 years of age, and (2) the patient was established in the clinic (defined as having had at least 1 visit 12 months or more before the sampled visit).
EXCLUSION CRITERIA: | Patients with a personal history of colon cancer and those who had received a colonoscopy or double-contrast barium enema in the previous 10 years were excluded from the analysis of FOBT.
POPULATION CHARACTERISTICS: | [underlined: Intervention Group] | | [underlined: Control Group]
Mean age & range (years): | Age: 38.7% 50–56, 33.1% 57–63, 28.3% 64–75 | | Age: 35.6% 50–56, 32.9% 57–63, 31.5% 64–75
Sex (% female): | Sex: 78% female | | Sex: 78% female
Race: | Race: 34% African American, 45.3% White, 20.7% Hispanic | | Race: 24.2% African American, 51.5% White, 24.3% Hispanic
Other population qualities:
| [underlined: Intervention Group] | | [underlined: Control Group]
Attrition/Drop-out (not available for endpoint measurement): | NA | | NA
Adherence in control group:
Contamination in control group:
OUTCOME ASSESSMENT: | Outcome Measures: • Authors defined being up-to-date as having completed FOBT within either the 12 months before the audited visit or within the 3 months after the audited visit. • Chart abstracters used a standardized method and instrument to abstract chart information and were trained by the project manager. Relevant clinical data were abstracted from all sections of the chart, including progress notes, laboratory reports, radiology reports, consultation letters, and hospital records. • Interrater reliability was calculated (0.91)
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | NA
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | Outcomes: At the 12 month follow-up • FOBT screening rates in intervention group was 40.1% vs. 11.9% in control • Multivariate analysis results: FOBT – Odds ratio=2.56, 95% CI 1.65–4.01, p<.0001 At 24 months, the intervention had no significant effect on FOBT screening • OR =1.17 (95% CI, 0.92–1.48) • When results were repeated comparing patients having a Cancer SOS screening checklist with those who did not, presence of a checklist was associated with increased odds of FOBT screening (OR = 3.28; 95% CI, 2.05–5.23; P <.0001). •Compliance with the Cancer SOS intervention decreased during the course of the intervention, with 334 of 615 (54.3%) showing evidence of the checklist at 24 months, compared to 74% at 6 month f/u.
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | NA
QUALITY RATING: | Fair
Quality Assessment-Internal Validity for Controlled Trials
| | Yes | No | Other (CD, NR, NA)
Was the study described as randomized? | | X
Was the method of randomization adequate? | | | | Not described
Was the treatment allocation concealed? | | | | NR
Were the groups similar at baseline regarding the most important prognostic indicators? | | X | | Except for race: Intervention-34% African American, 45.3% White, 20.7% Hispanic; Control- 24.2% African American, 51.5% White, 24.3% Hispanic
Was the outcome assessor blinded? | | | X
Was the care provider blinded? | | | X
Was the patient blinded? | | | X
Was the drop-out rate acceptable (≤ 20%)? [If between 20% and 60%, check other and explain.] | | | | NA
Was the differential drop-out rate acceptable (≤ 15%)? | | | | NA
Were co-interventions avoided or similar? | | X
Were outcome measures valid, reliable, and equally applied? | | X
Were all randomized participants analyzed in the group to which they were originally assigned? | | X
Quality Rating (Good, Fair, or Poor): Fair
Applicability Assessment:
Population | Patients 50 to 75 years of age who went to a community health clinic in Hillsborough County, FL.
Intervention | Cancer-screening checklist completed by patients and indicating whether patients were due for screening, and a series of red, yellow, and green stickers that indicated whether recommended screening tests had been ordered and completed.
Comparison | Compared patients who received intervention to those who did not.
Outcomes | FOBT screening
Timing of follow-up | 12 and 24 months
Setting | Community health centers
STUDY: | Authors, ref ID: Ruffin, MT, Fetters, MD, & Jimbo, M 83 Year of publication: 2007 Dates of data collection: 2002–2003 Trial name:
OBJECTIVE OR AIM: | Compare Colorectal Web and an existing stand-alone Web site in a RCT
DESIGN: | Setting: 5 urban, suburban, rural communities in MI Study design: RCT Duration (mean followup): 24 weeks Overall study size (N enrolled/N analyzed): 174/174
INTERVENTIONS: | [underlined: Intervention] | [underlined: Control]
Sample size: | • 87 | • 87
Describe intervention: | • At study sites that were community locations (hotels, meeting rooms in malls, other public meeting areas) participants were provided a laptop and they viewed either the Colorectal web or alternative website
RECRUITMENT: (population-based, clinic-based, volunteer, other) | • Population based • 5 communities selected based on 1) CRC burden and 2) presence of minority populations • List of 3000 residential telephone numbers likely to meet the age and geographical eligibility requirements purchased by a marketing company (1000 each urban, suburban, rural) • Up to 5 calls per number to recruit
INCLUSION CRITERIA: | • Between ages of 50–70 • Resident in one of the urban, suburban, or rural communities selected in MI • Not previously screened for CRC • Comfortable using a computer to find information on the Internet • Self-reported health status better than poor
EXCLUSION CRITERIA: | ‘Screened for CRC’, Age, ability to use computer (no explanation of how that’s assessed), and poor health
POPULATION CHARACTERISTICS: | [underlined: Intervention] | | [underlined: Control]
Mean age & range (years): | 56.9 | | 57.4
Sex (% female): | 52 | | 57
Race:
Caucasian | 54 | | 52
African-American | 46 | | 48
Other population qualities:
| [underlined: Intervention] | [underlined: Control] | | [underlined: Overall]
Attrition/Drop-out (not available for endpoint measurement): | 0 | 0
Adherence in control group:
Contamination in control group:
OUTCOME ASSESSMENT: | Outcome Measures: Follow up phone calls at 2, 8, 24 weeks to ascertain whether participant had been screened for CRC
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | Outcomes:
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | Outcomes: • Main result: At 24 weeks, 89 persons had been screened. In intervention group, 56% completed any CRC test compared to 33% in control group (23 percentage point difference; AOR, 3.23; 95% CI, 2.73–3.50; P = 0.035) • In a logistic regression model, with exposure to Colorectal Web, age, gender, ethnicity, preference for CRC screening, and interaction term between preference and exposure to Colorectal Web, and screening as the outcome, exposure to the intervention was associated with the outcome (OR = 3.23, CI, 2.73–3.50)
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Outcomes:
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Outcomes:
QUALITY RATING: | Good
Quality Assessment-Internal Validity for Controlled Trials
| | Yes | No | Other (CD, NR, NA)
Was the study described as randomized? | | X
Was the method of randomization adequate? | | X
Was the treatment allocation concealed? | | X
Were the groups similar at baseline regarding the most important prognostic indicators? | | X
Was the outcome assessor blinded? | | X
Was the care provider blinded? | | X
Was the patient blinded? | | X
Was the drop-out rate acceptable (≤ 20%)? [If between 20% and 60%, check other and explain.] | | X
Was the differential drop-out rate acceptable (≤ 15%)? | | X
Were co-interventions avoided or similar? | | X
Were outcome measures valid, reliable, and equally applied? | | X
Were all randomized participants analyzed in the group to which they were originally assigned? | | X
Quality Rating (Good, Fair, or Poor): Good
Applicability Assessment
Population | Urban, suburban, rural residents of one state
Intervention | Supervised viewing of a website, results may not translate to spontaneous viewing at home
Comparison | Viewing of a control website (standard site on CRC)
Outcomes | Self-reported CRC screening
Timing of follow-up | 24 weeks, appropriate
Setting | Viewing websites under a research setting, in public spaces, likely is not the same as viewing websites at home.
STUDY: | Authors, ref ID: Sequist TD, Zaslavsky AM, Marshall R, Fletcher RH, Ayanian JZ 84 Year of publication: 2009 Dates of data collection: April 2006 to June 2007 Trial name: NA
OBJECTIVE OR AIM: | Authors conducted a randomized controlled trial to compare the individual and joint impact of personalized mailings to patients and electronic reminders to primary care physicians to promote colorectal cancer screening within a multisite group practice.
DESIGN: | Setting: Harvard Vanguard Medical Associates (HVMA), a multispecialty group practice composed of 14 ambulatory health care centers in eastern Massachusetts Study design: Randomized controlled trial Duration (mean followup): Screening within 15-month study period Overall study size (N enrolled/N analyzed): 21,860 patients and 110 primary care physicians
INTERVENTIONS: | [underlined: Patient Mailing] | [underlined: Patient Control Group] | [underlined: Physician Reminder] | [underlined: Physician Control Group]
Sample size: | Sample size: 10,930 Patients | Sample size: 10,930 Patients | Sample size: 55 Physicians | Sample size: 55 Physicians
Describe intervention: | Intervention: Patients overdue for colorectal cancer screening received a mailing with the following 4 components: (1) a cover letter from the HVMA chief medical officer identifying the patient as overdue for screening and indicating the dates of their most recent screening examinations, (2) an educational pamphlet detailing screening options, (3) an FOBT kit with 3 Coloscreen stool cards from Helena Laboratories Corporation, Beaumont, Texas, instructions, and a stamped return envelope, and (4) a dedicated telephone number to schedule flexible sigmoidoscopy or colonoscopy. | Intervention: control | Intervention: Throughout the 15-month intervention period, physicians received electronic reminders during office visits with their patients overdue for colorectal cancer screening. | Intervention: Control
RECRUITMENT: (population-based, clinic-based, volunteer, other) | Clinic-based
INCLUSION CRITERIA: | Patients aged 50 to 80 years who had a visit with 1 of the 110 primary care physicians at 11 centers during the prior 18 months
EXCLUSION CRITERIA: | Patients who had been screened for colorectal cancer in accordance with the HVMA clinical guideline, having received either flexible sigmoidoscopy within 5 years along with FOBT in the prior year or colonoscopy within 10 years.
POPULATION CHARACTERISTICS: | [underlined: Patient Mailing Intervention] | [underlined: Patient Control] | [underlined: Physician Reminder] | [underlined: Physician Control]
Mean age & range (years): | Mean age: 60.5 | Mean age: 60.4 | Mean age: 60.3 | Mean age: 60.5
Sex (% female): | Sex: 56.8% female | Sex: 57% female | Sex: 54% female | Sex: 59.8% female
Race: | Race: 58% White, 8% Black, 2% Hispanic, 2% Asian, 3% Other, 27% Unknown | Race: 57% White, 8% Black, 2% Hispanic, 3% Asian, 3% Other, 27% Unknown | Race: 57% White, 9% Black, 2% Hispanic, 2% Asian, 3% Other, 28% Unknown | Race: 58% White, 8% Black, 2% Hispanic, 3% Asian, 3% Other, 27% Unknown
Other population qualities:
| [underlined: Patient Mailing Intervention] | [underlined: Patient Control] | [underlined: Physician Reminder] | [underlined: Physician Control]
Attrition/Drop-out (not available for endpoint measurement): | 0% drop-out | 0% drop-out | 0% drop-out | 0% drop-out
Adherence in control group:
Contamination in control group:
OUTCOME ASSESSMENT: | Outcome Measures: • All data were collected from the electronic record, and study outcomes were assessed 15 months following the start of the intervention for all randomized patients. • The primary study outcome was completion of 1 of the following 3 options during the 15-month study period: FOBT, flexible sigmoidoscopy, or colonoscopy. • Because the detection and removal of precancerous adenomas is a major objective of colorectal cancer screening, 29 the secondary study outcome was detection of adenomas based on diagnostic codes.
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | NA
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | Outcomes: • Among this group of patients who were overdue for screening with usual care, patients who received the mailing were significantly more likely to complete colorectal cancer screening than those who did not (44.0% vs. 38.1%; P_.001). • The mailing primarily increased the performance of FOBT among the intervention group compared with the control group (25.4% vs. 20.4%; P<.001). • Patients whose physicians received electronic reminders during the study period were not more likely than patients whose physicians did not receive reminders to complete colorectal screening (41.9% vs. 40.2%; P=.47), but among patients with 3 or more primary care visits, reminders tended to increase screening rates (59.5% vs. 52.7%; P=.07) • The interaction between the patient intervention and the physician intervention was small, negative, and not statistically significant (−0.6%; 95% CI, −1.2% to 0.1%) (P=.08), indicating that the observed effect of the combined patient and physician reminders was 0.6% less than the sum of their effects when applied individually.
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | NA
QUALITY RATING: | Good
Quality Assessment-Internal Validity for Controlled Trials
| | Yes | No | Other (CD, NR, NA)
Was the study described as randomized? | | X
Was the method of randomization adequate? | | X | | Within each physician panel, authors paired patients overdue for screening with similar values of this propensity and randomly assigned 1 patient in each pair to receive the intervention mailing, thus closely balancing treatment groups on characteristics related to their baseline screening propensity. The physician intervention was randomized at the physician level. Within each health care center, authors paired physicians with similar colorectal cancer screening rates and numbers of patients overdue for screening and then randomly assigned 1 physician in each pair to receive electronic reminders.
Was the treatment allocation concealed? | | | X
Were the groups similar at baseline regarding the most important prognostic indicators? | | X
Was the outcome assessor blinded? | | | | NR
Was the care provider blinded? | | | | NR
Was the patient blinded? | | | X
Was the drop-out rate acceptable (≤ 20%)? [If between 20% and 60%, check other and explain.] | | | | NA
Was the differential drop-out rate acceptable (≤ 15%)? | | | | NA
Were co-interventions avoided or similar? | | X | | The interaction between the patient intervention and the physician intervention was small, negative, and not statistically significant (−0.6%; 95% CI, −1.2% to 0.1%) (P=.08), indicating that the observed effect of the combined patient and physician reminders was 0.6% less than the sum of their effects when applied individually
Were outcome measures valid, reliable, and equally applied? | | X
Were all randomized participants analyzed in the group to which they were originally assigned? | | X
Quality Rating (Good, Fair, or Poor): Good
Applicability Assessment:
Population | Patients aged 50 to 80 years who had a visit with 1 of the 110 primary care physicians
Intervention | Patient mailings and physician reminders
Comparison | Compared Patients who received mailings and those who did not and patients of physicians who received reminder and those who did not.
Outcomes | Screening during the 15-month study period
Timing of follow-up | None
Setting | Clinic
STUDY: | Authors, ref ID: Stokamer, CL, Tenner, CT, Chaudhuri, J, Vazquez, E, & Bini, EJ 85 Year of publication: 2004 Dates of data collection: 2002–2003 Trial name:
OBJECTIVE OR AIM: | To determine whether intensive patient education increases FOBT card return rates.
DESIGN: | Setting: primary care clinics at the VA New York Harbor Healthcare System in NYC, NY Study design: RCT Duration (mean followup): 6 months Overall study size (N enrolled/N analyzed): 794 referred/788 randomized/788 analyzed
INTERVENTIONS: | [underlined: Intensive education] | | [underlined: Standard education]
Sample size: | 396 | | 392
Describe intervention: | 10–15 minutes educational session from 1 of 12 nurses: how to perform FOBT; meaning of test results; what would happen if test positive or negative; 2 page informational handout Nurses answered questions Instructed to return FOBT in 2 weeks and call with questions | | Written instructions on how to perform FOBT Same instructions to return cards within 2 weeks and to call with questions
RECRUITMENT: (population-based, clinic-based, volunteer, other) | Health-system based All patients referred to primary care nursing for patient education and distribution of FPBT kits (standard practice for this medical center)
INCLUSION CRITERIA: | Age >=50 years old; outpatients in the primary care clinic; had an FOBT ordered by their health care provider, and referred to primary care nursing for patient education and distribution for FOBT kits
EXCLUSION CRITERIA: | Refused participation
POPULATION CHARACTERISTICS: | [underlined: Intensive] | [underlined: Standard]
Mean age & range (years): | 67.0 (58.0–75.0) | 67.0 (58.0–74.0)
Sex (% male): | 95.2% | 96.2%
Race: | 46.7 | 48.5
Non-Hispanic white | 37.1 | 32.9
Non-Hispanic black | 14.9 | 16.8
Hispanic | 1.3 | 1.8
Other | 7.1 | 6.1
Other population qualities: • Family history of CRC
| [underlined: Intensive] | [underlined: Standard] | | Note: Outcome measured % returning FOBT. If a pt. did not return the FOBT in 6 months, they were censored and considered not returned.
Attrition/Drop-out (not available for endpoint measurement): | [underlined: 0] | [underlined: 0] | | Note: Outcome measured % returning FOBT. If a pt. did not return the FOBT in 6 months, they were censored and considered not returned.
Adherence in control group: | Not reported | | | Note: Outcome measured % returning FOBT. If a pt. did not return the FOBT in 6 months, they were censored and considered not returned.
Contamination in control group: | | | | Note: Outcome measured % returning FOBT. If a pt. did not return the FOBT in 6 months, they were censored and considered not returned.
OUTCOME ASSESSMENT: | Outcome Measures: Proportion of patients that returned FOBT cards within 6 months
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | NA
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | Outcomes: • Overall 462 of 788 participants returned FOBT cards in 6 months (58.6%): • A greater proportion of those with intensive education vs. standard returned the FOBT cards (65.9% vs. 51.3%; P < .001)
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | NA
QUALITY RATING: | Fair
Quality Assessment-Internal Validity for Controlled Trials
| | Yes | No | Other (CD, NR, NA)
Was the study described as randomized? | | x
Was the method of randomization adequate? | | | | Can’t assess how the randomization was done
Was the treatment allocation concealed?
Were the groups similar at baseline regarding the most important prognostic indicators? | | x
Was the outcome assessor blinded? | | x x | | Nurses were all trained on both groups and then administered all education so knew from materials which patients were in which groups
Was the care provider blinded? | | | X
Was the patient blinded? | | x | | Pt. unaware of what other patients receiving
Was the drop-out rate acceptable (≤ 20%)? [If between 20% and 60%, check other and explain.] | | | X (58.6 %) | Limited response rate and no responses at all from standard group and they don’t know enough about possible differences in groups to assess the non-response
Was the differential drop-out rate acceptable (≤ 15%)? | | x | | 65.9% vs. 51.3% which is their outcome
Were co-interventions avoided or similar? | | x
Were outcome measures valid, reliable, and equally applied? | | X
Were all randomized participants analyzed in the group to which they were originally assigned? | | X
Quality Rating (Good, Fair, or Poor): Fair
Applicability Assessment
Population | Men in a NYC healthcare system; may not apply to women or to patients outside large city or in a different type of healthcare setting
Intervention | Intensive education on CRC screening and FOBT provided by a nurse; this might not be feasible for all healthcare systems
Comparison | At baseline, nurses provide FOBT kits to patients. Effect size would be even larger if standard practice of physicians handing kits to patients had been comparison.
Outcomes | FOBT return rate is appropriate
Timing of follow-up | 6 month follow up appropriate for this study
Setting | Primary care setting is appropriate, however, the nature of the health care system and being in NYC make results potentially less generalizable
STUDY: | Authors, ref ID: Tu SP, Taylor V, Yasui Y, Chun A, Yip MP, Acorda E, Li L, Bastani R. 86 Year of publication: 2006 Dates of data collection: July 2003 – September 2004 Trial name:
OBJECTIVE OR AIM: | Evaluate a clinic-based, culturally and linguistically appropriate intervention promoting FOBT screening.
DESIGN: | Setting: International Community Health Services (ICHS), a community clinic serving predominately Asians in the metropolitan area of Seattle, Washington. Study design: Randomized Controlled Trial Duration (mean followup): 6 months Overall study size (N enrolled/N analyzed): 210
INTERVENTIONS: | [underlined: Intervention] | [underlined: Control]
Sample size: | Sample Size: 105 | Sample Size: 105
Describe intervention: | Intervention: Motivational video on CRC screening produced in Cantonese and dubbed into Mandarin, bilingual motivational pamphlet, an FOBT instruction sheet, bilingual CRC informational pamphlet, CRC screening education from a health educator, and an FOBT kit with instructions in Chinese and English. | Standard Care
RECRUITMENT: (population-based, clinic-based, volunteer, other) | Clinic-based; randomized those that agreed to participate using a randomization table to assign eligible patients in chronological order to intervention or control status using a random number generator of R software.
INCLUSION CRITERIA: | Age 50–78, spoke Cantonese, Mandarin and/or Chinese; patient for at least a year at ICHS
EXCLUSION CRITERIA: | Less than 12 months of medical care at ICHS; history of CRC; en-stage disease (e.g., congestive heart failure and chronic obstructive pulmonary disease requiring oxygen), gastrointestinal symptoms requiring diagnostic work-up; adherence to CRC screening (defined as FOBT in the past year or colonoscopy in the past 10 years); and participation in qualitative interviews to discuss CRC screening.
POPULATION CHARACTERISTICS: | [underlined: Group 1] | [underlined: Group 2]
| Intervention | Control
Mean age & range (years): | Age (50–78): 59.1% 50–64, 40.9% 65+ | Age (50–78): 49.5% 50–64, 50.5% 65+
Sex (% female): | Sex: 63.8% Female | Sex: 61.9% female
Race: | Race: Asian (Chinese) | Race: Asian (Chinese)
Other population qualities: | Language: 78.1% Cantonese, 21.0% Mandarin, 0.9% English Insurance: 81.9% Public, 12.4% Private, 5.7% None | Language: 79.1% Cantonese, 20.0% Mandarin, 0.9% English Insurance: 83.8% Public, 11.4% Private, 4.8% None
| [underlined: Group 1] | [underlined: Group 2] | | [underlined: Overall]
Attrition/Drop-out (not available for endpoint measurement):
Adherence in control group:
Contamination in control group:
OUTCOME ASSESSMENT: | Outcome Measures: FOBT screening within 6 months of randomization, based on chart audit by a study personnel who was blinded to the patients’ trial arm assignments. Only patients with 3 FOBT cards documented in their medical records were considered as having completed FOBT screening.
Results
KQ2 - What factors influence the use of colorectal cancer screening? | Outcomes: NA
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | Outcomes: • 69.5% of the intervention patients received FOBT screening, compared with 27.6% of control patients. Crude odds ratio for FOBT screening within 6 months of randomization by the intervention arm was 5.98. • In logistic regression models adjusting for covariates, the odds of FOBT increased to over 6-fold greater in the intervention arm than in the control arm (AOR, 6.38; 95% CI, 3.44–11.85). No effect modification by age, gender, language, insurance, or prior FOBT was found.
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Outcomes: NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Outcomes: NA
QUALITY RATING: | Good
Quality Assessment-Internal Validity for Controlled Trials
| | Yes | No | Other (CD, NR, NA)
Was the study described as randomized? | | X
Was the method of randomization adequate? | | X
Was the treatment allocation concealed?
Were the groups similar at baseline regarding the most important prognostic indicators? | | X
Was the outcome assessor blinded? | | X
Was the care provider blinded?
Was the patient blinded? | | | X
Was the drop-out rate acceptable (≤20%)? [If between 20% and 60%, check other and explain.] | | | | NA
Was the differential drop-out rate acceptable (≤15%)? | | | NR
Were co-interventions avoided or similar? | | CD | | NA
Were outcome measures valid, reliable, and equally applied? | | X
Were all randomized participants analyzed in the group to which they were originally assigned? | | X | NA
Quality Rating (Good, Fair, or Poor): Good
Applicability Assessment:
Population | Age (50–78), male/female, Chinese only
Intervention | Motivational video, bilingual motivational pamphlet, FOBT instruction sheet, bilingual CRC informational pamphlet, CRC screening education from a health educator, and an FOBT kit
Comparison | Same pop with no intervention
Outcomes | FOBT screening rates
Timing of follow-up | Screening within 6 months of randomization
Setting | Clinic
STUDY: | Authors, ref ID: Zapka JG, Lemon SC, Puleo E, Estabrook B, Luckmann R, Erban S.87 Year of publication: 2004 Dates of data collection: February 1999 – December 2000 Trial name:
OBJECTIVE OR AIM: | To test the effect of an educational video, mailed to patients’ homes before a physical examination, on performance of colorectal cancer screening, particularly sigmoidoscopy.
DESIGN: | Setting: 5 primary care practices in central Massachusetts Study design: randomized, controlled trial Duration (mean followup): 6 months Overall study size (N enrolled/N analyzed): 938 scheduled for physical exam
INTERVENTIONS: | [underlined: Intervention Group] | | [underlined: Control Group]
Sample size: | Sample size: 450 | | Sample size: 488
Describe intervention: | Treatment: Video about CRC, importance of early detection, and screening options | | Treatment: Usual care
RECRUITMENT: (population-based, clinic-based, volunteer, other) | Clinic-based; participants were recruited from 5 sites in central Massachusetts. Most were patients in internal medicine and family medicine clinics of an academic medical center. Computerized appointment system identified potentially eligible participants
INCLUSION CRITERIA: | Age 50 to 74; had an upcoming periodic health assessment; eligible for sigmoidoscopy according to screening guidelines
EXCLUSION CRITERIA: | No sigmoidoscopy within 5 years or colonoscopy within 10 years; recent or planned tests; did not undergo scheduled sigmoidoscopy in the past 10 years; reported colorectal cancer diagnosis or related symptoms, canceled periodic examination appointment; could not participate because or illness, death, disability, or dementia or because they were institutionalized; do not speak English; had a spouse enrolled in the study; moved out of the area; older than 74
POPULATION CHARACTERISTICS: | [underlined: Intervention Group] | | [underlined: Group 2]
Mean age & range (years): | Age: 290 age 50–64; 160 age over 65 | | Age: 322 age 50–64; 166 age over 65
Sex (% female): | Sex: 56.7% female | | Sex: 56.4% female
Race: | Insurance: 8.2% private, non-HMO; 52.8% private, HMO; 12.5% Medicare, non-HMO; 20.3% Medicare, HMO; 6.2% Medicaid or other | | Insurance: 5.5% private, non-HMO; 56.4% private, HMO; 10.5% Medicare, non-HMO; 19.5% Medicare, HMO; 8.2% Medicaid or other
Other population qualities: | Ever had FOB: 60.4% No | | Ever had FOB: 62.7% No
| [underlined: Group 1] | [underlined: Group 2] | | [underlined: Overall]
Attrition/Drop-out (not available for endpoint measurement): | | | | 20 were classified as not screened due to loss to follow-up.
Adherence in control group:
Contamination in control group:
OUTCOME ASSESSMENT: | Outcome Measures: Baseline and 4 to 6-month follow-up telephone assessments were conducted. Dependent variable classified screening since baseline as 1) sigmoidoscopy with or without other tests, 2) another test or test combination, or 3) no tests
Results
KQ2 - What factors influence the use of colorectal cancer screening? | Outcomes: NA
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | G1: 55% overall screening rate G2: 55% screening rate
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Outcomes: NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Outcomes: NA
QUALITY RATING: | Good
Quality Assessment-Internal Validity for Controlled Trials
| | Yes | No | Other (CD, NR, NA)
Was the study described as randomized? | | X
Was the method of randomization adequate? | | X
Was the treatment allocation concealed? | | X
Were the groups similar at baseline regarding the most important prognostic indicators? | | X
Was the outcome assessor blinded? | | X
Was the care provider blinded? | | X
Was the patient blinded? | | X
Was the drop-out rate acceptable (≤20%)? [If between 20% and 60%, check other and explain.] | | X
Was the differential drop-out rate acceptable (≤15%)? | | X
Were co-interventions avoided or similar? | | | NA
Were outcome measures valid, reliable, and equally applied? | | X
Were all randomized participants analyzed in the group to which they were originally assigned? | | X
Quality Rating (Good, Fair, or Poor): Good
Applicability Assessment
Population | Age 50+, both sexes
Intervention | Video about CRC, importance of early detection, and screening options
Comparison | Usual care
Outcomes | CRC screening
Timing of follow-up | Baseline and 4 to 6-month follow-up telephone assessments were conducted.
Setting | Clinic

Evidence Table 3 KQ 4: Current and projected capacity to deliver colorectal cancer screening and surveillance

STUDY: | Authors, ref ID: Ballew et al.88 Year of publication: 2009 Dates of data collection: March May 2008 Trial name: NA
OBJECTIVE OR AIM: | Montana Department of Public Health and Human Services wanted to assess the colonoscopy capacity in Montana before embarking on a campaign to increase colorectal screening participation statewide.
DESIGN: | Setting: Montana Study design: Hospital survey Duration (mean follow-up): No follow-up Overall study size (N enrolled/N analyzed): 41 hospitals, 3 ambulatory surgical centers
| [underlined: Group]
Sample size: | Sample size: 41 hospitals, 3 ambulatory surgical centers
Describe intervention: | Intervention: None, 8-question survey about current and projected screening capacity
RECRUITMENT: (population-based, clinic-based, volunteer, other) | All hospitals and ambulatory surgical centers in Montana
INCLUSION CRITERIA: | Perform colonoscopy
EXCLUSION CRITERIA: | NA
POPULATION CHARACTERISTICS: | NA
Mean age & range (years):
Sex (% female):
Race:
Other:
| 1 hospital did not respond
Attrition/Drop-out (not available for endpoint measurement):
Adherence:
Contamination:
Response Rates (e.g. for surveys):
STATISTICAL ANALYSES: | Collected data on CRC screening capacity and ran comparative statistics
ASSESSMENT OF EXPOSURES AND POTENTIAL CONFOUNDERS: | NR
OUTCOME ASSESSMENT: | Outcome Measures: CRC screening capacity
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | NA
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and follow- up? | NA
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Outcomes: • In the aggregate, hospitals performed 36,636 colonoscopies per year, including 19,444 screening procedures (54% of total procedures, range 11% to 100%). Hospitals estimated that they could perform 23,096 more screening colonoscopies per year. • The number of Montana adults who need screening colonoscopy was estimated to be 142,627 in 2008, increasing to 159,863 in 2020. Assuming that all unscreened individuals demanded colonoscopy every 10 years, and utilizing 100% of hospitals’ estimated screening capacity, full screening coverage by colonoscopy could be achieved by 2013. There was an uneven distribution of current volume and additional available capacity in Montana, a large and primarily rural state. Urban hospitals had more resources but also less additional available capacity. 35% of the population lived in urban areas where 49% of the total capacity was located but where only 24% of the unused capacity was located. 65% of the population lived in rural areas where 51% of the total capacity exists but where 76% of unused capacity was located.
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Outcomes: NA
QUALITY RATING: | Fair
Quality Assessment-Internal Validity for Observational Studies
| | | | | Yes | | | | No | | | | Other (CD, NR, NA)
Were the groups similar at baseline regarding the most important prognostic indicators? | | | | | | | | | | | | | NA
Were the drop-out or response rates acceptable (≤20%)? [If between 20% and 60%, check other and explain.] | | | | | X
Were the differential drop-out or response rates acceptable (≤15%)? | | | | | | | | | | | | | NA
Were intervention/exposure measures valid, reliable, and equally applied? | | | | | | | | | | | | | NA
Were the outcome assessors blinded to the intervention or exposure status of subjects? | | | | | | | | | | | | | NA
Were outcome measures valid, reliable, and equally applied? | | | | | X
Does the analysis control for baseline differences? | | | | | | | | | | | | | NA
Were important potential confounding and modifying variables taken into account in the design and analysis (e.g., through matching, stratification, or statistical adjustment)?
Were the statistical methods used to assess the abstracted outcomes appropriate? | | | | | X
Quality Rating (Good, Fair, or Poor): Fair
STUDY: | Authors, ref ID: Benuzillo JG, Jacobs ET, Hoffman RM, Heigh RI, Lance P, Martinez ME89 Year of publication: 2009 Dates of data collection: 2004 Trial name: Rural urban differences in colorectal cancer screening capacity in Arizona
OBJECTIVE OR AIM: | The aims of this work were to evaluate current colorectal cancer endoscopy screening capacity and to estimate potential volume for rural and urban regions in Arizona.
DESIGN: | Setting: Arizona clinics Study design: Observational cohort study Duration (mean followup): No follow-up, one-time survey Overall study size (N enrolled/N analyzed): 105 gastroenterologists and colorectal surgeons
| [underlined: All]
Sample size: | Sample size: 105 gastroenterologists and colorectal surgeons
Describe intervention: | Intervention: Survey that assessed current colonoscopy and sigmoidoscopy screening and estimated future capacity.
RECRUITMENT: (population-based, clinic-based, volunteer, other) | Population-based (population of gastroenterologists and colorectal surgeons; membership directories of three specialist professional societies to identify gastroenterologists and colorectal surgeons practicing in Arizona). The names of the societies were not given.
INCLUSION CRITERIA: | Physicians who indicated that they performed lower gastrointestinal endoscopies for colorectal cancer screening. How this was determined was not specified.
EXCLUSION CRITERIA: | Other health care professionals, such as hepatologists, pathologists, and nurses with a shared interest in the care of patients with digestive diseases but who typically do not perform lower endoscopic screening procedures were excluded. Not clear whether they were not sampled or were excluded from the sample.
POPULATION CHARACTERISTICS: | [underlined: All]
Mean age & range (years): | Age range: 30–67
Sex (% female): | Sex: 26.7% female
Race: | Specialty: 90% gastroenterology
Other:
| [underlined: All] | | | | | | | | [underlined: Group 2] | | | | Overall
Attrition/Drop-out (not available for endpoint measurement): | 338 identified to receive the survey; 104 not performing endoscopy or not practicing in AZ Therefore, 234 eligible physicians received the mailed surveys and of these, 105 were returned, resulting in a response rate of 44.9%
Adherence:
Contamination:
Response Rates (e.g. for surveys):
STATISTICAL ANALYSES: | Describe: Standard descriptive statistics, including means and medians, were used to analyze these data. All data were stratified according to rural/urban areas.
ASSESSMENT OF EXPOSURES AND POTENTIAL CONFOUNDERS: | Authors compared survey responses by rural and urban regions in Arizona using the 2003 U.S. Department of Agriculture Rural–Urban Continuum Codes. For the present analyses, authors categorized the three counties corresponding to the metropolitan codes as urban and the remaining non-core counties as rural.
OUTCOME ASSESSMENT: | Outcome Measures: The Colon Cancer Screening Capacity Survey was modified from an instrument used to survey New Mexico gastroenterologists. The ten questions included in the original survey were created based on literature review, the Behavioral Risk Factor Surveillance System’s (BRFSS) survey, and the experience of researchers and clinicians from New Mexico. Survey respondents were asked to report their average number of endoscopic procedures performed during a week and to estimate the number of additional procedures that could be performed.
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | NA
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | NA
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Outcomes: •The average number of weekly colonoscopies and sigmoidoscopies per endoscopist were 21 and 2, respectively. When data were stratified by physician type, the median number of weekly colonoscopies was 20 (interquartile range, 15–25) for gastroenterologists and 14 (interquartile range, 10–20) for colorectal surgeons. Colorectal surgeons performed a median of 5 flexible sigmoidoscopies a week (interquartile range, 2–10) compared to a median of 1 (interquartile range, 0–2) procedure performed by gastroenterologists. •Overall, physicians reported performing 8,717 weekly endoscopic procedures (8,312 in urban and 405 in rural areas). The vast majority of the procedures were colonoscopies in both regions (91% in urban and 97% in rural areas). Responders estimated being able to increase their capacity by an additional 3,183 (36.5%) procedures per week (2,347 colonoscopies and 836 flexible sigmoidoscopies). While only 5% of all procedures were performed in rural areas, the data suggest that the potential increase in volume is greater for rural than urban areas (53.1% and 35.7%, respectively). This is an important finding given that rates of endoscopic screening are lower in rural (49.5%; 95% confidence interval [CI] 46.8–52.2) compared to urban areas (54.5%; 95% CI 51.4– 57.5). •Among all respondents, more physicians was most commonly cited as the resource that would be needed to increase capacity (49.5%); although this was the most common response for urban physicians (52.1%), rural doctors noted appropriate compensation as the top response (54.6%). Further, urban physicians more frequently cited the need for additional resources, such as space and staff, to meet capacity than their rural counterparts. A total of 27.3% of rural physicians reported that they needed no additional resources to increase their endoscopic capacity whereas only 14.9% of urban practitioners did so.
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | NA
QUALITY RATING: | Fair
Quality Assessment-Internal Validity for Observational Studies
| | | | | Yes | | | | No | | | | Other (CD, NR, NA)
Were the groups similar at baseline regarding the most important prognostic indicators? | | | | | | | | | | | | | NA
Were the drop-out or response rates acceptable (≤ 20%)? [If between 20% and 60%, check other and explain.] | | | | | | | | | X | | | | Response rate 44.9%
Were the differential drop-out or response rates acceptable (≤ 15%)? | | | | | | | | | | | | | NA
Were intervention/exposure measures valid, reliable, and equally applied? | | | | | | | | | | | | | NA
Were the outcome assessors blinded to the intervention or exposure status of subjects? | | | | | | | | | | | | | NA
Were outcome measures valid, reliable, and equally applied? | | | | | X
Does the analysis control for baseline differences? | | | | | X
Were important potential confounding and modifying variables taken into account in the design and analysis (e.g., through matching, stratification, or statistical adjustment)? | | | | | | | | | | | | | NA
Were the statistical methods used to assess the abstracted outcomes appropriate? | | | | | X
Quality Rating (Good, Fair, or Poor): Fair
STUDY: Current capacity for endoscopic colorectal cancer screening in the United States: data from the National Cancer Institute survey of colorectal cancer screening practices | Authors, ref ID: Brown et al.90 Year of publication: 2003 Dates of data collection: November 1999 – April 2000 Trial name: Data from Survey of Colorectal Cancer Screening Practices
OBJECTIVE OR AIM: | The purpose of this study was to provide nationally representative data on endoscopic resources at the provider level.
DESIGN: | Setting: United States Study design: cross-sectional mailed survey + modeling study Duration (mean follow-up): NA Overall study size (N enrolled/N analyzed): 1235 primary care physicians, 349 gastroenterologists, 316 general surgeons (see response rates below)
Sample size: | 1630 primary care physicians, 467GI, 467 general surgeons
Describe intervention: | NA
RECRUITMENT: (population-based, clinic-based, volunteer, other) | Used survey data collected in 1999 – 2000. Physicians approached for this survey were identified through the American Medical Association’s Physician Masterfile.
INCLUSION CRITERIA: | Little detail given. For more information, reader is referred to: http://healthservices.cancer.gov/surveys/colorectal/
EXCLUSION CRITERIA: | NR
POPULATION CHARACTERISTICS: | Characteristics of respondents and their practice setting, Survey of Colorectal Cancer Screening Practices, 1999 –2000
Mean age & range (years):
Sex (% female):
Race: Other: | Characteristic | | | | Primary care (n = 1235) | | | | Gastroenterolgists (n = 349) | | | | General surgeons (n = 316)
Race: Other: | | | | | Number (%)
Race: Other: | Male sex | | | | 960 (77.7) | | | | 324 (92.8) | | | | 294 (93.0)
Race: Other: | White, non-Hispanic | | | | 894 (72.4) | | | | 279 (79.8) | | | | 256 (81.1)
Race: Other: | Board certified | | | | 921 (74.6) | | | | 325 (93.1) | | | | 249 (78.8)
Race: Other: | IMG | | | | 277 (22.4) | | | | 72 (20.6) | | | | 74 (23.4)
Race: Other: | Age ≥ 50 years | | | | 589 (47.7) | | | | 109 (31.2) | | | | 164 (51.9)
Race: Other: | Metropolitan location | | | | 751 (60.8) | | | | 252 (72.2) | | | | 181 (57.3)
Race: Other: | Practice type
Race: Other: | Solo | | | | 316 (25.6) | | | | 78 (22.0) | | | | 126 (39.8)
Race: Other: | Single-specialty | | | | 508 (41.1) | | | | 168 (48.2) | | | | 106 (33.7)
Race: Other: | Multispecialty | | | | 411 (33.3) | | | | 103 (29.5) | | | | 84 (27.0)
Race: Other: | Practice volume (per week)
Race: Other: | > 50 patients | | | | 548 (44.4) | | | | 102 (29.2) | | | | 40 (13.0)
Race: Other: | > 100 patients | | | | 441 (35.7) | | | | 39 (11.0) | | | | 10 (3.0)
Race: Other: | > 50% of patients covered by managed care | | | | 760 (61.5) | | | | 141 (40.5) | | | | 131 (41.6)
Attrition/Drop-out (not available for endpoint measurement): | The authors obtained 1235responses to the primary care survey, a response rate of 72%, and 665 to the specialty survey (349 gastroenterologists, 316 general surgeons), a response rate of 83%.
Adherence: | The authors obtained 1235responses to the primary care survey, a response rate of 72%, and 665 to the specialty survey (349 gastroenterologists, 316 general surgeons), a response rate of 83%.
Contamination: | The authors obtained 1235responses to the primary care survey, a response rate of 72%, and 665 to the specialty survey (349 gastroenterologists, 316 general surgeons), a response rate of 83%.
Response Rates (e.g. for surveys): | The authors obtained 1235responses to the primary care survey, a response rate of 72%, and 665 to the specialty survey (349 gastroenterologists, 316 general surgeons), a response rate of 83%.
STATISTICAL ANALYSES: | The authors calculated means, proportions, and 95% confidence intervals based on weights that reflect the probability of selection into the sample, and adjusted for known sources of respondent bias. (Because of the high response rates, weighted and unweighted results were very similar.) In addition, the authors used MISCAN-COLON to obtain estimates of national endoscopy requirements implied by various programmatic approaches to colorectal cancer screening. MISCAN-COLON is a microsimulation model that takes into account national population estimates and assumptions about screening test performance characteristics and screening program policy parameters, including the frequency of screening, diagnostic, and surveillance procedures. The authors assumed that screening of average risk persons would occur from ages 50 to 80 years; that 70% of the population would comply with the first screening; and that if someone attended a screening, he or she had a 90% probability of attending the next screening, whereas if someone did not attend a screening, he or she had a 20% probability of attending the next screening. The authors further assumed a test positivity rate of 2% for fecal occult blood testing; that after discovery of a polyp _5 mm, a person was returned to routine screening; and that after discovery of a polyp _5 mm, a person received surveillance colonoscopy once every 5 years until no lesions were found.
ASSESSMENT OF EXPOSURES AND POTENTIAL CONFOUNDERS: | NA
OUTCOME ASSESSMENT: | The authors used items from the primary care and GI/general surgeon questionnaires that asked about the volume of FS and colonoscopy procedures performed in a typical month during the survey period. Screening endoscopy was defined as the use of a procedure to detect cancer or neoplasia in an asymptomatic patient; diagnostic endoscopy was defined as use in patients with symptoms or previously abnormal test results. Readers are referred to further details at: http://healthservices.cancer.gov/surveys/colorectal/. Surveys themselves are downloadable here, but no further detail on methods is given.
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | NA
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and follow-up? | NA
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Reported volume of endoscopy procedures by physician specialty
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | | | | | Physician Specialty
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | | | | | Primary care (n = 1235) | | | | Gastroenterology (n = 346) | | | | General surgery (n = 251)
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Physicians in the United States | | | | 156,605 | | | | 7,835 | | | | 15,181
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | | | | | Number (%) or Mean ± SD
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Sigmoidoscopy procedures/month | | | | 1.9 ± 4.3 | | | | 14.2 ± 39.3 | | | | 3.1 ± 32.6
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | 0 | | | | 871 (71) | | | | 14 (4) | | | | 86 (34)
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | 1 – 5 | | | | 203 (17) | | | | 47 (14) | | | | 93 (37)
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | 6 – 10 | | | | 95 (7) | | | | 76 (22) | | | | 43 (17)
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | 11 – 20 | | | | 38 (3) | | | | 88 (25) | | | | 7 (3)
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | > 20 | | | | 17 (1) | | | | 107 (31) | | | | 4 (2)
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Other | | | | 11 (1) | | | | 14 (4) | | | | 18 (7)
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Estimated total procedures in the U.S. | | | | 3,205,000 (64.8) | | | | 1,224,000 (24.7) | | | | 518,000 (10.5)
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Screening colonoscopy procedures/month | | | | 0.1 ± 1.1 | | | | 12.4 ± 40.2 | | | | 3.2 ± 35.0
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | 0 | | | | 1182 (96) | | | | 19 (5) | | | | 110 (44)
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | 1 – 5 | | | | 30 (2) | | | | 71 (21) | | | | 74 (30)
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | 6 – 10 | | | | | | | | 83 (24) | | | | 39 (16)
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | 11 – 20 | | | | | | | | 74 (21) | | | | 11 (4)
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | > 20 | | | | | | | | 89 (26) | | | | 4 (2)
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Other | | | | 23 (2) | | | | 10 (3) | | | | 13 (5)
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Total procedures in the U.S. | | | | 9100 (0.6) | | | | 1,071,000 (66.3) | | | | 535,000 (33.1)
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Diagnostic colonoscopy procedures/month | | | | | | | | 19.5 ± 33.0 | | | | 4.4 ± 42.7
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | 0 | | | | | | | | 8 (2) | | | | 103 (41)
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | 1 – 5 | | | | | | | | 11 (3) | | | | 65 (26)
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | 6 – 10 | | | | | | | | 29 (8) | | | | 43 (17)
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | 11 – 20 | | | | | | | | 97 (28) | | | | 26 (10)
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | > 20 | | | | | | | | 193 (56) | | | | 6 (2)
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Other | | | | | | | | 8 (2) | | | | 8 (3)
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Total procedures in the U.S. | | | | | | | | 1,678,000 (69.6) | | | | 731,000 (30.4)
| Approximately 4.9 million sigmoidoscopies in 2000, 1.6 million screening colonoscopies, and 4 million (screening plus diagnostic) colonoscopies were performed. On averaqe, general surgeons performed about 8 colonoscopies per month, compared with about 32 for gastroenterologists11 of 11 group practices 9 or 12 solo practitioners Current capacity compared to projected national requirements The authors estimated national requirements for endoscopy associated with programs of colorectal cancer screening based on fecal occult blood testing, with or without sigmoidoscopy or colonoscopy, as the primary screening method under the counterfactual assumption that population usage levels of colorectal cancer screening were similar to current rates for screening mammography of 70% of eligible women. Under this assumption, screening based on sigmoidoscopy once every 5 years would require the delivery of almost 10 million flexible sigmoidoscopy procedures in 2000, about twice the number of sigmoidoscopy procedures currently performed. Screening with colonoscopy performed once every 10 years would require, under very conservative assumptions, the delivery of 4.8 million screening and surveillance colonoscopy procedures in 2000, about 20% more than the estimated 4 million procedures that were performed for all purposes in 2000. From discussion: the authors estimated that a national program of colorectal cancer screening based on colonoscopy would have required about 4.8 million procedures in 2000, about 20% more than the estimated 4 million procedures that were performed for all purposes in 2000. Alternatively, a screening program operating at the same level of population use based on annual fecal occult blood testing would have required the delivery of 1.2 million diagnostic and surveillance colonoscopies; sigmoidoscopy once ever y 5 years would have required 1.6 million colonoscopy procedures and a program of combined fecal occult blood testing and sigmoidoscopy would have required about 2.6 million procedures in 2000.
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | NA
QUALITY RATING: | Good
Quality Assessment-Internal Validity for Observational Studies
| | | | | Yes | | | | No | | | | Other (CD, NR, NA)
Were the groups similar at baseline regarding the most important prognostic indicators? | | | | | | | | | | | | | NA
Were the drop-out or response rates acceptable (≤20%)? [If between 20% and 60%, check other and explain.] | | | | | X | | | | | | | | Yes, report response rate of greater than 70%
Were the differential drop-out or response rates acceptable (≤15%)? | | | | | X | | | | | | | | 72% response rate for generalists vs. 83% for GI and surgery
Were intervention/exposure measures valid, reliable, and equally applied? | | | | | | | | | X | | | | Measurement of outcome # of procedures capped at 20
Were the outcome assessors blinded to the intervention or exposure status of subjects? | | | | | | | | | | | | | NA
Were outcome measures valid, reliable, and equally applied? | | | | | X | | | | | | | | Self reported capacity
Does the analysis control for baseline differences? | | | | | | | | | | | | | NA
Were important potential confounding and modifying variables taken into account in the design and analysis (e.g., through matching, stratification, or statistical adjustment)?
Were the statistical methods used to assess the abstracted outcomes appropriate?
Were data inputs valid? | | | | | | | | | | | | | Limited inputs described without references. Loeve F, Boer R, van Oortmarssen GJ, et al. The MISCAN-COLON simulation model for the evaluation of colorectal cancer screening. Comput Biomed Res. 1999;32:13B33. 13. Loeve F, Brown ML, Boer R, et al. Endoscopic colorectal cancer screening: a cost-saving analysis. J Natl Cancer Inst. 2000;92:557–563. This article describes the model but not data inputs.
Was an appropriate search strategy used to find data inputs?
Were the calculations and statistical analyses adequate? | | | | | | | | | | | | | Not clear how screening strategies applied take into account risk groups.
Were appropriate sensitivity analyses conducted (especially for any variables that were not based on data from literature)?
Other considerations: [These might include the following for various types of models: was the cost effectiveness analysis conducted from the societal perspective? Was an appropriate comparison used (standard of care or next most effective alternative)? Were the appropriate health benefits, harms, and costs described and included?] | | | | | X
Quality Rating (Good, Fair, or Poor): Fair
STUDY: Colonoscopy Demand and Capacity in New Hampshire | Authors, ref ID: Butterly et al.91 Year of publication: 2007 Dates of data collection: 2003–2004 Trial name: NA
OBJECTIVE OR AIM: | Evaluate the demand and capacity for colonoscopy in the state of New Hampshire.
DESIGN: | Setting: All endoscopy sites in NH contacted in 2003–2004 Study design: Observational Duration (mean follow-up):
Sample size: | Overall study size (N enrolled/N analyzed): 114 endoscopists at 36 centers [underlined: Endoscopists] 62 (54.4%) gastroenterologists 45 (39.5%) general or colorectal surgeons 3 (2.6% FP) or GIM docs 4 other
Describe intervention: | NA
RECRUITMENT: (population-based, clinic-based, volunteer, other) | All endoscopy sites in NH contacted. Two-phase telephone interview: The 1^st^ phase had questions regarding capacity and limitations to performing colonoscopies, # of colonoscopies done/week, description of scheduling processes, and barriers to increasing capacity. In the 2^nd^ phase, sites were recontacted to obtain calculated number of colonoscopies for 2002.
INCLUSION CRITERIA: | All endoscopy sites in the state of New Hampshire
EXCLUSION CRITERIA: | All others
POPULATION CHARACTERISTICS: | NA
Response Rates (e.g. for surveys): | Phase 1: not described Phase 2: all sites but one
DATA INPUTS/Outcome assessment | Total # of colonoscopies reported per week (currently), including an estimate of the number performed for screening vs. diagnostic or therapeutic Number of colonoscopies conducted in 2002: calculated from procedure logs for the year or through billing codes for all forms of colonoscopy For colonoscopies done in hospital settings (with the exception of the VA), #s were compared to results of New Hampshire Hospital Association (NHHA) Of the 36 sites, nine sites were free-standing ambulatory surgical centers not associated with hospitals; no means of validating results from these sites was available To estimate demand, Census 2000 data obtained from the NH Office of State Planning. Estimates were included for individuals at increased risk as well as those at average risk. Demand equals all individuals needing screening or surveillance according to current guidelines. Estimated 30% increased risk and 65% at average risk. The increased risk population was assumed to require surveillance intervals of 5 years.
STATISTICAL ANALYSES: | Analysis of demand was modeled according to three compliance rates of 100%, 70% and 60%. Each of these rates was applied to population statistics for the years 2002, 2005, and 2010. Two proposed methods of improving capacity are to increase the percentage of current colonoscopy devoted to screening and to increase capacity itself. Capacity was therefore calculated for 40%, 50%, or 60% (the NH finding) of colonoscopy being devoted to screening, and the potential increase in capacity if known 2002 capacity increased by 10% and 20%. For the latter estimates, it was assumed that all of the 10% and 20% increase in capacity was devoted to screening.
RESULTS:
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | 114 endoscopists at 36 centers performed 49,352 colonoscopies in 2002, an average of 39–43/month/endoscopist. 60% of these estimated to have been done for CRC screening. To confirm the accuracy of the colonoscopy numbers, results were compared to the NHAA records, which show that 32,802 colonoscopies were performed in NH between 7/1/01 and 6/30/02. To adjust for the appropriate comparison, the total for centers that would be included in the NHAA database was calculated: 32,987. Estimated demand was approximately twice the available capacity for screening and surveillance. The primary factor reported to limit capacity was # of endoscopists (72% of centers), # of procedure rooms (65.6% of centers), and # of available endoscopy nurses and support staff (50% of centers). Demand for screening and surveillance colonoscopies per year by population
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | | | | | 2002 | | | | 2005 | | | | 2010
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Population aged >50 y | | | | 364,108 | | | | 425,539 | | | | 523,498
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | 65% avg. risk | | | | 23,667 | | | | 27,660 | | | | 34,027
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | 35% increased risk | | | | 25,487 | | | | 29,788 | | | | 36,645
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Total | | | | 49,154 | | | | 57,448 | | | | 70,672
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Potential increase in colonoscopy screening capacity varied by % of colonoscopies conducted for screening
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Total # of colonoscopes | | | | 40% screening | | | | 50% screening | | | | 60% screening
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Total in 2002 (49,352) | | | | 19,741 | | | | 24,676 | | | | 29,611
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | If increase capacity by 10% (54,287) | | | | 24,676 | | | | 29,611 | | | | 34,546
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | If increase capacity by 20% (59,222) | | | | 29,611 | | | | 34,546 | | | | 39,481
| 49,325 colonoscopies performed in 2002. If the capacity was increased by 10%, this would increase total # of colonoscopies/year to 54,287. If this capacity were increased by 20%, this would increase total # of colonoscopies/year to 59,222 Annual demand for screening and surveillance c-scope adjusted for varying compliance rates
| | | | | 2002 | | | | 2005 | | | | 2010
| 100% compliance | | | | 49,154 | | | | 57,448 | | | | 70,672
| 70% compliance | | | | 34,408 | | | | 40,214 | | | | 49,470
| 60% compliance | | | | 29,493 | | | | 34,469 | | | | 42,203
| Note top line of this table is the same as the totals in the 1^st^ table above
| If capacity increases by 20%, at the current rate of 60% of procedures for screening, and estimated 70% compliance rate, capacity would almost meet demand. Monthly figure of 39–43 colonoscopies per months is similar to the results from NCI study. New Mexico reported 16‐20/week.
QUALITY RATING: | Fair
Quality Assessment-Internal Validity
| | | | | Yes | | | | No | | | | Other (CD, NR, NA)
Did the authors report conducting a power analysis or some other basis for determining the adequacy of study group sizes for the outcome(s) being abstracted? | | | | | | | | | | | | | NA
Were the groups similar at baseline regarding the most important prognostic indicators? | | | | | | | | | | | | | NA
Were the drop-out or response rates acceptable? | | | | | | | | | | | | | NA
Were the differential drop-out or response rates acceptable? | | | | | | | | | | | | | NA
Were co-interventions avoided or similar? | | | | | | | | | | | | | NA
Were intervention/exposure measures valid, reliable, and equally applied? | | | | | | | | | | | | | NA
Were the outcome assessors blinded to the intervention or exposure status of subjects? | | | | | | | | | | | | | NA
Were outcome measures valid, reliable, and equally applied? | | | | | X | | | | | | | | Capacity was self-reported, but validated with NHAA records
Were all participants analyzed in the group to which they were originally assigned? | | | | | | | | | | | | | NA
Does the analysis control for baseline differences? | | | | | | | | | | | | | NA
Were important potential confounding and modifying variables taken into account in the design and analysis (e.g., through matching, stratification, or statistical adjustment)? | | | | | | | | | | | | | NA
Were the statistical methods used to assess the abstracted outcomes appropriate? | | | | | | | | | | | | | NA
Were data inputs valid? | | | | | X
Was an appropriate search strategy used to find data inputs? | | | | | | | | | X | | | | Data inputs relatively simple, however: Ratio of average to above average risk was estimated, no reference given
Were the calculations and statistical analyses adequate? | | | | | X
Were appropriate sensitivity analyses conducted (especially for any variables that were not based on data from literature)? | | | | | | | | | | | | | none
Other considerations: [These might include the following for various types of models: was the cost effectiveness analysis conducted from the societal perspective? Was an appropriate comparison used (standard of care or next most effective alternative)? Were the appropriate health benefits, harms, and costs described and included?] | | | | | X
Quality Rating: Fair
STUDY: New Mexico’s capacity for increasing the prevalence of colorectal cancer screening with screening Colonoscopies | Authors, ref ID: Hoffman et al.92 Year of publication: 2005 Dates of data collection: October – December 2001 Trial name: Colorectal Cancer Working Group of the Clinical Prevention Initiative (CPI)
OBJECTIVE OR AIM: | The authors evaluate New Mexico’s capacity to increase the prevalence of colorectal cancer screening using colonoscopy.
DESIGN: | Setting: New Mexico endoscopists Study design: Descriptive, cross-sectional and modeling Duration (mean follow-up): One-time survey Overall study size (N enrolled/N analyzed): Survey information collected from 9/12 solo practitioners and all 11 group practices representing 40 endoscopists (2–8 practitioner/group)
Sample size: | 9 solo practitioners and 11 group practices representing 40 endoscopists NA
Describe intervention:
RECRUITMENT: (population-based, clinic-based, volunteer, other) | The authors The authors identified endoscopists in New Mexico by using data from the Board of Medical Examiners, contacting manufacturers of endoscopic equipment, and obtaining the membership lists of a statewide gastroenterology journal club, the New Mexico Medical Society, and the American Medical Association. Eligible subjects for this analysis were gastroenterologists actively practicing in New Mexico, which included 40 gastroenterologists practicing in one of the 11 group practices and 12 solo practitioners.
INCLUSION CRITERIA: | Gastroenterologists actively practicing in New Mexico
EXCLUSION CRITERIA:
POPULATION CHARACTERISTICS: | Physicians and practices were based in 12 different counties 10/11 group practices and 6/12 solo practitioners were in urban areas
Mean age & range (years):
Sex (% female):
Race:
Other:
Attrition/Drop-out (not available for endpoint measurement): | 11 of 11 group practices 9 or 12 solo practitioners
Adherence:
Contamination:
Response Rates (e.g. for surveys):
STATISTICAL ANALYSES: | The authors used descriptive nonparametric statistics to estimate the weekly median number of procedures performed by endoscopists in group practice and solo practice and the estimated weekly potential increase in capacity. Endoscopic capacity. The authors determined the number of additional screening colonoscopies that could be performed using survey responses. Responses were averaged when multiple members of a group practice completed the survey and provided different estimates for the weekly number of baseline and additional procedures performed by the practice. The weekly number of base-line and additional colonoscopies for the solo-practitioner nonrespondents was imputed using data from the responding solo practitioners. For the annual number of colonoscopies, it was assumed that endoscopists performed procedures for 40 weeks. Similar estimates were performed for the number of flexible sigmoidoscopies. Volume of colonoscopies. The authors modeled the number of procedures required for a statewide screening colonoscopy strategy. To identify the number of subjects potentially eligible for colonoscopic screening, they used data from the 2000 United States Census for New Mexico that reported 468,000 resident adults aged 50 to 85. Based on the census data, they evaluated the additional number of screening colonoscopies required to increase the prevalence of current screening by 5% (23,400 additional people being screened), 10% (46,800), 15% (70,200), 20% (93,600), and 25% (117,000) during a five-year period. The authors assumed that the additional screening procedures would be performed in equal numbers during the five-year period. The authors then modeled the number of surveillance procedures that would be required following the initial screening colonoscopy, and used clinical data on the yield of colorectal cancers and adenomatous polyps from a recent, large Department of Veterans Affairs (VA) colonoscopic screening trial and consensus guidelines for the timing of surveillance procedures. A sensitivity analysis was performed by reducing the expected rates of detected colorectal cancers and adenomatous polyps by approximately 50%.
ASSESSMENT OF EXPOSURES AND POTENTIAL CONFOUNDERS: | NA
OUTCOME ASSESSMENT: | The CPI colorectal cancer group developed a brief survey to obtain information about endoscopic capacity, including colonoscopies and flexible sigmoidoscopies. Questions were based on literature review, the BRFSS, and the clinical experience of the CPI colorectal cancer group, which included two gastroenterologists and two internists who performed sigmoidoscopy. Revisions were based on pilot testing the survey with clinical colleagues and other members of the CPI.
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | NA
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and follow- up? | NA
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | # of procedures currently being performed weekly and the weekly capacity for additional procedures, stratified by type of practice
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Practice type | | Total # endoscopists | | Current c- scopes/endoscopist* | | | | Total current c- scopes | | Weekly capacity for additional procedures | | | | Weekly capacity for total additional c- scopes
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Group | | 40 | | 16.3 (12.9, 26.50 | | | | 652 | | 6.3 (1.8, 10) | | | | 252
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Solo | | 9 | | 20 (15, 21) | | | | 180 | | 10 (5, 15) | | | | 90
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Combined | | 49 | | NA | | | | 832 | | NA | | | | 342
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | *values are median (interquartile range) Overall, gastroenterologists reported performing 832 colonoscopies a week. They estimated being able to increase their capacity by an additional 342 (41%) procedures each week. Statewide, endoscopists could perform an estimated 13,680 additional colonoscopic procedures each year. If the nonresponding solo practitioners performed similarly to those completing the survey, the estimated annual additional capacity for colonoscopy would be 14,880 procedures. Number of c-scopes required to increase the prevalence of current screening during a 5-year period for NM adults aged 50 – 85 years
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Screening increase over 5 years (%) | | | | Annual # of c-scopes (based on detection rates from VA study)^a^ | | | | | | Annual # of c-scopes (based on detection rates from sensitivity analysis) ^b^
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | 5 | | | | 5568 (5983)* | | | | | | 5137 (5360)
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | 10 | | | | 11,136 (11,966) | | | | | | 10,274 (10,721)
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | 15 | | | | 16,704 (17,949) | | | | | | 15,411 (16,082)
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | 20 | | | | 22,272 (23,932) | | | | | | 20,548 (21,442)
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | 25 | | | | 27,840 (29,915) | | | | | | 25,568 (26,800)
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | ^a^ Includes numbers of screening tests based on 2000 New Mexico census data and numbers of surveillance tests based on applying cancer (1.0%) and adenomatous polyp (37%) detection rates from a Department of Veterans Affairs (VA) study. ^b^ Includes numbers of screening tests based on 2000 New Mexico census data and numbers of surveillance tests based on applying cancer (0.5%) and adenomatous polyp (20%) detection rates from sensitivity analysis. *Numbers in parentheses reflect the strategy of performing a three-year surveillance colonoscopy on all patients with adenomatous polyps compared to five- year surveillance interval. All but one of the group practices performed flexible sigmoidoscopies, but only five of the solo practitioners performed them. Overall, however, only 165 procedures were performed weekly; respondents estimated that they could perform an additional 188 procedures. New Mexico gastroenterologists responding to the survey estimated having the capacity to increase their weekly number of colonoscopies by about 41%, from 832 to 1174. This substantial increase could raise the prevalence of current endoscopic screening by approximately 15% within five years.
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | NA
QUALITY RATING: | Fair
Quality Assessment-Internal Validity for Observational Studies
| | | | | Yes | | | | No | | | | Other (CD, NR, NA)
Were data inputs valid? | | | | | X
Was an appropriate search strategy used to find data inputs? | | | | | X | | | | | | | | Few modifications to population estimates were made.
Were the calculations and statistical analyses adequate? | | | | | X | | | | | | | | Static model.
Were appropriate sensitivity analyses conducted (especially for any variables that were not based on data from literature)? | | | | | X
Other considerations: [These might include the following for various types of models: was the cost effectiveness analysis conducted from the societal perspective? Was an appropriate comparison used (standard of care or next most effective alternative)? Were the appropriate health benefits, harms, and costs described and included?] | | | | | X
Quality Rating (Good, Fair or Poor): Fair
STUDY: | Authors: Hur et al.93 Year: 2004 Trial name (if applicable):
DESIGN: | Study design: Mathematical model Number of subjects: NA Time period covered: 5 years
QUESTIONAIM/OBJECTIVE: | To analyze the impact of CTC on colonoscopy demand
DATA INPUTS: | • Colonoscopy practice patterns data from 1998 to 2002 were used as the foundation to estimate current (2003) colonoscopy practice. • The number of screening colonoscopies was observed to increase after July 2001 in published and presented reports as well as in the endoscopy unit experience at Massachusetts General Hospital (the percentages of colonoscopies for average-risk screening were 14.2%, 3 20%, and 47% from other reports and 33.5% for Massachusetts General Hospital). These trends were applied to the 2001 data to provide current (2003) national estimates for the total number of screening colonoscopies. • Parameters: Population estimate; CTC and polyp characteristics: sensitivity, specificity, prevalence, % CTC studies (positive findings), Number of patients (positive CTC findings); follow-up interval for second CTC after first study; surveillance colonoscopy for subsequent colonoscopies after colonic adenoma detected; • Because positivity thresholds are so pivotal to the analysis and no consensus exists regarding the optimal value, the authors chose to perform all analyses using both 6-mm and 10-mm values (lower and upper boundaries).
ANALYSIS AND CALCULATIONS: | • With a range between 40% (current or lower limit) and approximately 70% (mammography or upper limit), the authors estimated a CRC screening compliance of 55% (or a 15% increase) with implementation of CTC. • Applying this estimate eliminated 45% (noncompliant, 100%-55%) of the eligible cohort from the screening pool. • The authors reasoned that, within the 5 years following implementation of CTC (time horizon of first period), all of the patients who underwent any of these screening modalities would be due for another CRC screening; therefore, all of these patients were included in the screening pool. However, because screening colonoscopies are recommended every 10 years, the authors the authors estimated that 8.75% (one half of the 17.5% of patients who had undergone colonoscopy within the past 5 years) would need CRC screening in the following 5 years. The remaining cohort was divided by 5 to reflect the time horizon of the first period of the model for reasons described previously, resulting in 7.21 million patients. • In the 323 subjects studied, when given information about both procedures, 60.2% chose CTC, 25.7% chose colonoscopy, and 14.2% were undecided. Based on these results, the base-case estimate used for CTC penetrance was 67.3% (60.2% + one half of the undecided group) • The percentages of CTC examinations with positive findings using the base-case CTC sensitivity, specificity, and prevalence values were 24.9% (6 mm) and 7.0% (10 mm). These percentages multiplied by the number of patients undergoing a CTC per year (4.85 million) yielded 1.21 million (6 mm) and .34 million (10 mm) patients who would require a follow-up colonoscopy in the base cases. • Patients who had negative findings on CTC examination were modeled to undergo a follow-up CTC screening every 5 years, with colonoscopy reserved for those patients who had positive findings. Using published polyp data from the Veterans Affairs Cooperative Study and definitions of higher- and lower-risk groups from published polyp surveillance recommendations, the model assumed that 41% of patients with previous adenomatous polyps would undergo surveillance colonoscopy every 3 years and 59% every 5 years.
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | NA
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and follow-up? | NA
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Outcomes: Current volume: 6.47 million COLON 1.98 COLON for screening (29%) • If CTC used as primary modality for CRC screening, assuming 55% adherence and 67% CTC penetrance, in the initial 5 year period after implementation of CTC, demand for COLON could decrease by 1.78 million. This would be partially offset by 0.34 million follow up COLON for CTC with positive findings (10 mm polyp) • The total additional colonoscopies for the second period (years 6–10) after implementation of CTC would yield 1.67 million (6 mm) or .49 million (10 mm) procedures. These figures partially offset the 1.78 million reduction associated with implementation of CTC, resulting in a net reduction of .11 million (1.7%) (6 mm) or 1.29 million (19.9%) (10 mm) of the current total number of colonoscopies performed. • To summarize the numerous sensitivity analyses performed, the model was sensitive to CTC specificity and polyp prevalence and also sensitive to the percentage of screening colonoscopies and the improvement in population compliance but only if the 6-mm polyp size cutoff was used.
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | NA
QUALITY RATING: | Fair
Quality Assessment for Modeling Studies
| | | | | Yes | | | | No | | | | Other (CD, NR, NA)
Were data inputs valid? | | | | | | | | | X | | | | Based on non-representative database
Was an appropriate search strategy used to find data inputs? | | | | | X
Were the calculations and statistical analyses adequate? | | | | | X
Were appropriate sensitivity analyses conducted (especially for any variables that were not based on data from literature)? | | | | | X
Other considerations: [These might include the following for various types of models: was the cost effectiveness analysis conducted from the societal perspective? Was an appropriate comparison used (standard of care or next most effective alternative)? Were the appropriate health benefits, harms, and costs described and included?] | | | | | X | | | | | | | | This focused analysis did not incorporate costs or other adjustments (e.g., discounting) commonly performed in cost- effectiveness analyses in an effort to keep the model simple and easily comprehendible.
Quality Rating (Good, Fair or Poor): Fair
STUDY: | Authors: Ladabaum et al.94 Year: 2005 Trial name (if applicable): NA
DESIGN: | Study design: Modeling study Number of subjects: Time period covered:
QUESTIONAIM/OBJECTIVE: | To use a model and national census data to produce integrated, comprehensive estimates of the impact of widespread screening on national clinical and economic outcomes and health services demand. The authors explored the potential demand for colonoscopy in detail, including the relative contribution of surveillance.
DATA INPUTS: | 2000 Census data. Authors make reference to a previous publication for details about the model (model estimates clinical effectiveness and cost-effectiveness of CRC screening with established and emerging strategies).
ANALYSIS AND CALCULATIONS: | Decision analytic Markov model. The natural history model was calibrated to reproduce the age-specific prevalence at autopsy of small and large adenomatous polyps and age and stage-specific CRC incidence rates. The authors superimposed screening on the natural history model. The model was used to calculate conditions under various screening proportions. The proportion of different screening tests was varied. Cost was used as an input for various screening tests. Costs were determined in a prior publication in 2003 dollars, and were updated using the medical component of the CPI. For each strategy, the model yielded the number of CRC cases by stage, deaths by cause, discounted (3% annually) and undiscounted average life-years and costs per person, and number and type of tests performed The authors include results for each strategy’s average life-years and costs per person as well as cost-effectiveness compared with natural history (no screening) from the perspective of a third-party payer. The authors assumed a 75% screening uptake rate for the national projections. The authors assumed a steady state for the population size and age distribution, as represented by year 2000 US census data. The authors determined age-specific clinical model outputs per person and economic outputs and adjusted these to reflect the fraction of persons still alive at a given age out of the original hypothetical cohort. The authors then multiplied these corrected, age-specific model outputs per person by the number of people of that age in the US population based on year 2000 census data. Next, the authors corrected our estimates to represent a 75% screening uptake rate for each strategy. Adding the results for all ages under each strategy yielded the annualized national estimates.
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | NA
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and follow-up? | NA
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Numbers of tests, including colonoscopies by indication and intervention (assuming 75% uptake) | | | | FOBT | | FS | | FS/FOBT | | Colonoscopy | | | | CT colonography
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | FS | | | | | | 10.0 million | | 6.9 million
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Colonoscopy | | | | 3.8 million | | 2.7 million | | 4.7 million | | 8.1 million | | | | 3.3 million
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | CT colonography | | | | | | | | | | | | | | 6.2 million
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Table: National demand for health services under current and potential future scenarios
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Scenario Description | | | | Current screening uptake and rates by strategy | | Uptake increases to 75%: all established strategies grow in same proportion | | Uptake increases to 75%: FOBT, FS, FS/FOBT remain stable; only COLO increases | | Uptake increases to 75%; FOBT, FS, FS/FOBT remain stable; remainder of screening with COLO or VC‐ Pickhardt (ratio 1:1) | | | | Uptake increases to 75%; FOBT, FS, FS/FOBT remain stable; remainder of screening with COLO or VC- Pickhardt (ratio 1:3)
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Associated assumptions
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Total fraction of population screened (%) | | | | 40 | | 75 | | 75 | | 75 | | | | 75
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | FOBT | | | | 10 | | 19 | | 10 | | 10 | | | | 10
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | FS | | | | 8 | | 15 | | 8 | | 8 | | | | 8
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | FOBT/FS | | | | 8 | | 15 | | 8 | | 8 | | | | 8
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | COLO | | | | 14 | | 26 | | 49 | | 25 | | | | 12
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | VC-Pickhardt Demand for health services (test #’s in millions/year) | | | | 0 | | 0 | | 0 | | 25 | | | | 37
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | FOBT | | | | 7.1 | | 13.3 | | 7.1 | | 7.1 | | | | 7.1
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | FS | | | | 1.8 | | 3.4 | | 1.8 | | 1.8 | | | | 1.8
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | VC | | | | 0 | | 0 | | 0 | | 2.0 | | | | 3.0
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | COLO | | | | 3.0 | | 5.3 | | 6.6 | | 5.2 | | | | 4.5
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Screening | | | | 1.9 | | 3.5 | | 4.7 | | 3.3 | | | | 2.7
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Postpolypectomy surveillance | | | | 0.88 | | 1.6 | | 1.7 | | 1.7 | | | | 1.7
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | To diagnose symptomatic CRC on surveillance after CRC treat | | | | 0.23 | | 0.16 | | 0.15 | | 0.16 | | | | 0.16
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Assuming current screening patterns and 40% uptake, 3.0 million total colonoscopies were required annually, with 1.9 million related to screening (primary screening with COLO or to follow up on positive screening test results with the other strategies) and 0.88 million for postpolypectomy surveillance. With increased screening uptake to 75%, colonoscopy demand increased even under the scenario assuming substantial utilization of VC. Under all 4 scenarios examined, the number of postpolypectomy surveillance colonoscopies was similar (1.6–1.7 million per year), as was the number of colonoscopies for diagnosing symptomatic CRC or surveillance after CRC treatment (0.15–0.16 million per year). In contrast, the number of colonoscopies related to screening varied from 2.7 to 4.7 million per year and was a function of the rate of utilization of COLO. Focusing on colonoscopy, the authors estimated annual colonoscopy demand of 8.1 million with COLO and 1.4–4.7 million with the other strategies.
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | NA
QUALITY RATING: | Good
Quality Assessment for Modeling Studies
| | | | | Yes | | | | No | | | | Other (CD, NR, NA)
Were data inputs valid? | | | | | X | | | | | | | | Steady state population Other reports reviewed: Song K, Fendrick AM, Ladabaum U. Fecal DNA testing compared to conventional colorectal cancer screening methods: a decision analysis. Gastroenterology 2004; 126:1270–1279. Ladabaum U, Song K, Fendrick AM. Colorectal neoplasia screening with virtual colonoscopy: when, at what cost, and with what national impact? Clin Gastroenterol Hepatol 2004; 2:554–563. Ladabaum U, Chopra CL, Huang G, Scheiman JM, Chernew ME, Fendrick AM. Aspirin as an adjunct to screening for prevention of sporadic colorectal cancer. A cost-effectiveness analysis. Ann Intern Med 2001; 135:769–781. Ladabaum U, Scheiman JM, Fendrick AM. Potential effect of cyclooxygenase-2-specific inhibitors on the prevention of colorectal cancer: a cost-effectiveness analysis. Am J Med 2003;114: 546–554.
Was an appropriate search strategy used to find data inputs? | | | | | X
Were the calculations and statistical analyses adequate? | | | | | X
Were appropriate sensitivity analyses conducted (especially for any variables that were not based on data from literature)? | | | | | | | | | | | | | NR
Other considerations: [These might include the following for various types of models: was the cost effectiveness analysis conducted from the societal perspective? Was an appropriate comparison used (standard of care or next most effective alternative)? Were the appropriate health benefits, harms, and costs described and included?] | | | | | | | | | | | | | 3^rd^ party payer perspective Not clear time horizon (costs for CRC are projected, but no discounting was used)
Quality Rating (Good, Fair or Poor): Good
STUDY: Is there sufficient MDCT capacity to provide colorectal cancer screening with CT colonography for the U.S. population? | Authors: Pickhardt et al.95 Year: 2008 Trial name (if applicable): NA
DESIGN: | Study design: modeling study Number of subjects NA Time period covered: # of existing scanners based on 2006 data, population data from U.S. census. Results projected over 10 year period.
QUESTIONAIM/OBJECTIVE: | The aim was to assess the ability of the available MDCT capacity in the United States to provide population screening with CTC.
DATA INPUTS: | Model construction: To address the first issue regarding the startup phase, the authors constructed a simple mathematic model for predicting CTC demand by simulating progressive uptake of CTC on the compliant population. The primary measured outcome was the total number of CTC examinations needed per year, assuming a 10-year span as a realistic time frame for catching up with all the millions of unscreened 50- to 75-year-old individuals in the United States. Because the authors assumed the routine screening interval for CTC would initially be set at 5 years, repeat screenings in the second half of the 10-year startup period were added to the new screenings in the startup phase. To deal with the second issue of steady-state demand, the authors used a previously validated Markov model to estimate the total number of CTC examinations needed to be performed each year once the screening program reaches this steady state. The CTC totals from the two phases were then divided among all operational MDCT units available in the United States for the standard number of working days per year to establish the number of CTC procedures per day that each MDCT unit should perform to meet the simulated demand (expressed as CTC/MDCT/day). Inputs: The baseline values for the main parameters used in the startup and steady-state phase models, and the ranges applied for the sensitivity analysis, are reported in Table 1. 2007 census data and literature is cited as references. Population variables: U.S. adults 40 – 75 years old, all cause mortality per year (%), too frail for colonoscopy (%), population at increased CRC risk (%), overall screening compliance (%), CTC penetrance (%), compliance to repeat CTC (%), duration of startup period (y), routine CTC screening interval (y), CT capacity variables: total CT units in United States, MDCT units from total (%), MDCT units performing CTC (%). The initial population consisted of the entire average-risk 40 to 75-year-old population available from U.S. census data. This population figure was adjusted to account for mortality from all causes and was further reduced by those considered to be too frail to undergo colonoscopy. The authors assumed that CTC implementation and patient acceptance for a noninvasive screening option would result in a gradual increase in the overall CTC compliance rate during the 10-year startup period. For this reason, overall CRC screening compliance (by any means) was assumed to grow in a linear fashion from 40% in year 1 to 60% at the end of the 10-year startup period. The authors assumed that only a certain fraction of the compliant screening population will favor CTC over other available screening options, which progressively increased from an initial penetration of 10% in year 1 to 67% in year 10 of the startup phase. Assuming third-party reimbursement for screening CTC, balanced by the need for appropriate training and investment in CTC-specific equipment (i.e., CTC software and carbon dioxide insufflator), the authors estimated that this rate would only gradually rise to 90% by the end of the 10-year startup period. Furthermore, the authors simulated a progressive annual increase of 3.5% in the total number of CT scanners over the 10-year period and an increase of the relative percentage of MDCT scanners from the current 71% to 85% by year 10.
ANALYSIS AND CALCULATIONS: | To evaluate the number of CTC examinations performed in the steady-state phase of population screening, the authors used a Markov model on a hypothetical cohort of 100,000 average-risk subjects ranging from 50 to 100 years old, as previously modeled in articles focusing on colonoscopic screening capacity. Briefly, the natural history of colorectal neoplasia was calibrated to reproduce the age- and sex-specific adenoma prevalence at autopsy and screening studies as well as the incidence and mortality rate of CRC. The health intervention superimposed on the natural history model was CTC repeated every 5 years between 50 and 80 years old (inclusive). For this analysis, the authors assumed that those found to have an adenoma > 5 mm required endoscopic follow-up, which prevented further CTC screening. All others were eligible for repeat screening CTC in 5 years. Although all endoscopic and radiologic CRC screening tests are advised to be repeated every 5 or 10 years, compliance for repeated examinations over a lifetime period is largely unknown. Although some postpolypectomy trials have shown short-term compliance for repeated colonoscopy of 80%, the authors thought that a 50% compliance for 5‐ year CTC repetition over a lifetime to be a more realistic baseline assumption. To project the outcomes of our simulation on the entire U.S. population, the authors assumed a steady state for population size and age distribution, represented by the 2000 census data.
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | NA
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and follow-up? | NA
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Year | | Overall compliance (%) | | CTC penetrance (%) | | No. to be screened with CTC | | Total CT units | | MDCT fraction (%) | | MDCT Units performing CTC (%) | | CTC exams per MDCT unit per day
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | 1 | | 40 | | 10 | | 295,750 | | 10,110 | | 71 | | 718 (10) | | 1.6
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | 2 | | 42 | | 16 | | 506,664 | | 10,500 | | 73 | | 1,437 (19) | | 1.4
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | 3 | | 45 | | 22 | | 738,665 | | 10,890 | | 74 | | 2,237 (28) | | 1.3
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | 4 | | 47 | | 29 | | 991,754 | | 11,280 | | 76 | | 3,120 (37) | | 1.3
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | 5 | | 49 | | 35 | | 1,265,929 | | 11,670 | | 77 | | 4,090 (46) | | 1.2
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | 6 | | 52 | | 41 | | 1,709,066 | | 12,060 | | 79 | | 5,150 (54) | | 1.3
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | 7 | | 54 | | 47 | | 2,130,872 | | 12,450 | | 80 | | 6,303 (63) | | 1.4
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | 8 | | 56 | | 53 | | 2,584,309 | | 12,840 | | 82 | | 7,551 (72) | | 1.4
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | 9 | | 58 | | 60 | | 3,069,376 | | 13,230 | | 83 | | 8,899 (81) | | 1.4
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | 10 | | 60 | | 67 | | 3,586,073 | | 13,620 | | 85 | | 10,349 (90) | | 1.4
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Note—Overall compliance indicates total participation in screening, by any technique. CTC penetrance indicates the percentage of compliant adults who favor CTC over other available screening options. MDCT fraction indicates the percentage of all CT scanners that are multidetector and therefore CTC capable. MDCT units performing CTC indicates the number (and fraction) of MDCT scanners actually performing CTC. Start up phase: “At the simulated compliance and eligibility rate, 37,227,541 U.S. adults would need to be screened for CRC in the 10‐ year startup phase.” At sensitivity analysis, compliance to initial screening, CTC penetrance, MDCT capacity, the duration of the program, and the population size appeared to be key variables. Steady-state phase: Screening in the steady-state was simulated with 5-year repetition of CTC between the ages of 50 and 80 years. Initial compliance and penetrance were set at 60% and 67%, corresponding to the values reached in the final year of the startup period. Compliance for repeated CTC thereafter was set at 50%. The overall number of CTC procedures needed to be performed per year in the steady-state period for the average-risk U.S population was 3,064,151. Dividing this value by the estimated MDCT capacity at the end of the startup period corresponds to 296 CTC procedures per MDCT per year and 1.2 CTC/MDCT/day. The authors conclude that available MDCT capacity in the US is large enough to satisfy the potential demand of population screening with primary CTC evaluation, for both start up and steady state periods.
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | NA
QUALITY RATING: | Fair
Quality Assessment for Modeling Studies
| | | | | Yes | | | | No | | | | Other (CD, NR, NA)
Were data inputs valid? | | | | | X | | | | | | | | Pickhardt PJ, Hassan C, Laghi A, Zullo A, Kim DH, Morini S. Cost-effectiveness of colorectal cancer screening with computed tomography colonography: the impact of not reporting diminutive lesions. Cancer 2007; 109:2213–2221
Was an appropriate search strategy used to find data inputs? | | | | | X
Were the calculations and statistical analyses adequate? | | | | | | | | | X | | | | Steady state population Very optimistic assumptions
Were appropriate sensitivity analyses conducted (especially for any variables that were not based on data from literature)? | | | | | X
Other considerations: [These might include the following for various types of models: was the cost effectiveness analysis conducted from the societal perspective? Was an appropriate comparison used (standard of care or next most effective alternative)? Were the appropriate health benefits, harms, and costs described and included?]
Quality Rating (Good, Fair or Poor): Fair
STUDY: | Authors, ref ID: Robertson et al.96 Year of publication: 2006 Dates of data collection: 1999 – 2001 Trial name:
OBJECTIVE OR AIM: | Examine trends in the utilization of flex sig, DCBE, and colonoscopy and trends in the choices of colorectal cancer screening service providers within Tricare and Medicare from 1999 – 2001
DESIGN: | Setting: United States Study design: review of Tricare and Medicare claims data Duration (mean follow-up): Overall study size (N enrolled/N analyzed): (see tables below)
RECRUITMENT: (population-based, clinic-based, volunteer, other) | Two sources of data were used in this study: the Medicare Physician/Supplier Summary (PSPS) File and the Military Health System’s Management Analysis and Reporting Tool (M2).
INCLUSION CRITERIA: | Only those Medicare beneficiaries over age 65 and in fee-for-service plans were analyzed. The M2 file, which represents the military’s commercial network (Tricare) claims, included beneficiaries age 50 through 64
EXCLUSION CRITERIA: | NR
POPULATION CHARACTERISTICS: | NA
Mean age & range (years):
Sex (% female):
Race:
Other:
Attrition/Drop-out (not available for endpoint measurement):
Adherence:
Contamination:
Response Rates (e.g. for surveys):
STATISTICAL ANALYSES: | Since the data comprised the populations of Tricare and Medicare claims, descriptive rather than inferential statistics were used. The data were examined for changes in procedure volume for the three procedures over time and for changes in colonoscopy provider volume. For the analysis of colonoscopy provider data, six provider groups with low procedure volumes (i.e., colorectal surgeons, family practitioners, general practitioners, nurse practitioners, physician assistants, multi-specialty clinic) were combined into one provider category, “other”.
ASSESSMENT OF EXPOSURES AND POTENTIAL CONFOUNDERS:
OUTCOME ASSESSMENT: | What type of provider performed screening test. Volume of screening tests performed. No distinction made between screening and diagnostic exams. These were evaluated in 1999, 2000, and 2001 for both Medicare and Tricare.
Results
KQ2 - What factors influence the use of colorectal cancer screening? | NA
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and follow-up? | NA
RESULTS: | Colonoscopy by medical discipline, 1999 – 2001
| Discipline | 1999 | | | | 2000 | | | | 2001 | | | | % change 1999–2001
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | | TC | | MC | | TC | | MC | | TC | | MC | | TC | MC
| | N | % of total | N | % of total | N | % of total | N | % of total | N | % of total | N | % of total
| GI | 18,208 | 59 | 1,047,044 | 66 | 26,455 | 72 | 1,202,192 | 66 | 32,344 | 73 | 1,404,713 | 66 | 78 | 34
| GS | 2,706 | 9 | 209,195 | 13 | 3,974 | 11 | 243,571 | 13 | 4,989 | 11 | 276,165 | 13 | 84 | 32
| IM | 3,197 | 10 | 187,954 | 12 | 3,939 | 11 | 201,079 | 11 | 4,675 | 10 | 219,602 | 10 | 46 | 17
| Other | 6,576 | 21 | 146,662 | 9 | 2,216 | 6 | 173,378 | 10 | 2,519 | 6 | 225,081 | 11 | −62 | 53
| Total | 30,687 | 100 | 1,590,855 | 100 | 36,584 | 100 | 1,820,220 | 100 | 44,527 | 100 | 2,125,561 | 100 | 45 | 34
| Procedure volume by year 1999-2001
| B.E. | 6,457 | 12 | 394,949 | 15 | 5,572 | 10 | 340,277 | 12 | 4,367 | 7 | 266,329 | 10 | −32 | −33
| Colo | 30,687 | 58 | 1,590,855 | 59 | 36,584 | 64 | 1,820,220 | 66 | 44,527 | 74 | 2,125,561 | 76 | 45 | 34
| F.S. | 15,668 | 30 | 690,056 | 26 | 15,052 | 26 | 603,420 | 22 | 11,316 | 19 | 409,845 | 15 | −28 | −41
| Total | 52,812 | 100 | 2,675,860 | 100 | 57,208 | 100 | 2,763,917 | 100 | 60,210 | 100 | 2,801,735 | 100 | 14 | 5
| TC = Tricare MC = Medicare GI = Gastroenterologist GS = general surgeon IM = Internal Medicine B.E. = barium enema Colo = colonoscopy F.S. = flexible sigmoidoscopy Summary: “The total volume of procedures increased 5% and 14%, respectively, in Tricare and Medicare. Tricare and Medicare, respectively, saw 32% and 33% reductions in barium enemas and 28% and 41% reductions in flexible sigmoidoscopies. Colonoscopies increased by 45% and 34% in Tricare and Medicare, respectively. Gastroenterologists provided the majority of colonoscopies for both groups each year.”
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | NA
QUALITY RATING:
Quality Assessment-Internal Validity for Observational Studies
| | | | | Yes | | | | No | | | | Other (CD, NR, NA)
Were the groups similar at baseline regarding the most important prognostic indicators? | | | | | | | | | | | | | NA
Were the drop-out or response rates acceptable (≤ 20%)? [If between 20% and 60%, check other and explain.] | | | | | | | | | | | | | NA
Were the differential drop-out or response rates acceptable (≤ 15%)? | | | | | | | | | | | | | NA
Were intervention/exposure measures valid, reliable, and equally applied? | | | | | X
Were the outcome assessors blinded to the intervention or exposure status of subjects? | | | | | | | | | | | | | NA
Were outcome measures valid, reliable, and equally applied? | | | | | X | | | | | | | | No distinction between screening and diagnostic procedures
Does the analysis control for baseline differences? | | | | | | | | | | | | | NA
Were important potential confounding and modifying variables taken into account in the design and analysis (e.g., through matching, stratification, or statistical adjustment)? | | | | | | | | | | | | | NA
Were the statistical methods used to assess the abstracted outcomes appropriate? | | | | | X
Quality Rating (Good, Fair, or Poor): Fair
STUDY: “Is there endoscopic capacity to provide colorectal cancer screening to the unscreened population in the United States?” | Authors, ref ID: Seeff et al.97 Year of publication: 2004 Dates of data collection: 2000 & 2001 Trial name:
OBJECTIVE OR AIM: | The authors designed a forecasting model to (1) estimate the number of average-risk people aged 50 years or older who have not been screened for colorectal cancer, (2) describe the sociodemographic characteristics of this population, and (3) estimate the annual number of procedures required to provide screening and follow-up examinations for this population. This report compares available capacity calculated in a companion publication {#3269) with the number of tests needed for the currently unscreened population, assuming that all or one half of the available capacity is used for colorectal cancer screening. The authors focused on the average-risk population in this analysis because consensus exists about when to begin and how to screen the average-risk population for colorectal cancer.
DESIGN: | Setting: United States Study design: Modeling study Duration (mean follow-up): NA Overall study size (N enrolled/N analyzed): NA
Data sources: | To estimate the size of the US population currently unscreened for colorectal cancer, the authors first estimated the size of the total US population aged 50 years or older in 2001, stratified by sex, race, ethnicity, income, region, and age, using US Census Bureau 2000 Public Use Microdata Sample data. Insurance status by sex, race, ethnicity, income, region, and age was estimated using data from the March Current Population Surveys for 2000 and 2001. The authors then identified and removed persons at increased risk for colorectal cancer, including those with a personal or family history of colorectal cancer and those with inflammatory bowel disease, because the model estimated the need for average-risk persons only. Colorectal cancer prevalence rates by age, race, ethnicity, and sex were obtained from the Surveillance, Epidemiology and End Results program. The size of the population with a family history of colorectal cancer was obtained from the 2000 NHIS. Persons were considered to have a family history of colorectal cancer if they had a parent, sibling, or child who had been diagnosed with colorectal cancer at any age. The number of individuals with inflammatory bowel disease was obtained from the National Institute of Diabetes and Digestive and Kidney Diseases. Although the prevalence of inflammatory bowel disease varies by age, race/ethnicity, and sex, the authors assumed an equal prevalence across age, race/ethnicity, and sex and assumed a mortality rate for inflammatory bowel disease equal to that of the general population. Approximately 1.0 million persons (1.3% of the population aged 50 years or older) with a personal history of colorectal cancer, 5.2 million persons (6.8% of the population aged 50 years or older) with a family history of colorectal cancer, and .17 million persons (.2% of the population aged 50 years or older) with inflammatory bowel disease, all considered at increased risk for colorectal cancer, were excluded from the total population in need of screening.
STATISTICAL ANALYSES: | The authors used a 2-step modeling method to determine the size of the screened population. In step 1, the authors used data from the 2000 NHIS15 to construct a multivariate multinomial logistic regression model to determine the relationship between sociodemographic characteristics (e.g., age, sex, race, income level, health insurance status, region of the United States) and the probability that an individual has been screened for colorectal cancer according to current guidelines: FOBT in the past year, endoscopy (flexible sigmoidoscopy, colonoscopy, or proctoscopy) in the past 10 years, both FOBT in the past year and endoscopy in the past 10 years, or none of the above. NHIS respondents were asked about their use of any lower endoscopic procedure (sigmoidoscopy, colonoscopy, or proctoscopy) but were only asked to identify which of the 3 endoscopic procedures they had received most recently. The authors therefore measured the use of all endoscopies combined and used10 years as a measure of screening according to recommended guidelines to fully capture colonoscopy use. NHIS respondents were not asked about their use of double-contrast barium enema (DCBE). Stata 6.0 was used to account for the sampling weights and survey design and to calculate 95% confidence intervals. In step 2, the coefficients from the logistic regression model described previously were used to estimate the proportion of persons who have been screened. These proportions were applied to the average-risk US population aged 50 years or older to generate counts of the population already screened for colorectal cancer. Finally, the authors subtracted the number of individuals who have already been screened from the total average-risk population to produce an estimate of the number of average-risk persons in the US population currently in need of colorectal cancer screening. To determine the number of procedures needed to screen this unscreened average-risk population, the authors modeled 5 program options under which screening could occur. The first program assumed that screening would occur with a combination of screening tests in proportions consistent with the current test used based on the 2000 NHIS. To determine the number and type of tests needed in this scenario, the coefficients of the logistic regression analysis were applied to the unscreened average-risk population to predict the numbers of required screening tests (FOBT only, sigmoidoscopy only, sigmoidoscopy plus FOBT, and colonoscopy) based on sociodemographic characteristics of the unscreened average-risk population. To determine endoscopies by type, the authors assumed that the most recent test reported in the NHIS was the only test performed. The other 4 programs were selected because they each represent screening options recommended by national guidelines. These programs assumed that the unscreened population would be screened with (1) annual FOBT with diagnostic colonoscopy for positive tests, (2) FOBT plus sigmoidoscopy, (3) sigmoidoscopy with diagnostic colonoscopy for positive tests, or (4) colonoscopy. For the program using FOBT and sigmoidoscopy, the authors assumed that all persons would first be screened with FOBT, with positive FOBTs followed by a diagnostic colonoscopy. Persons with a negative FOBT would be offered screening sigmoidoscopy with positive sigmoidoscopies followed by a diagnostic colonoscopy. For any of the proposed screening programs, positive FOBTs and flexible sigmoidoscopies would be followed by a diagnostic colonoscopy. To estimate the number of diagnostic colonoscopies that would be generated by screening the unscreened population, the authors applied a positivity rate of 2.5% for unrehydrated FOBT and 5% sigmoidoscopy. For individuals undergoing both FOBT and sigmoidoscopy during 1 year, a 6.25% positivity rate was applied, which assumes that FOBT is performed annually but only one fifth of the people receive sigmoidoscopy each year and one half of the positive cases identified through sigmoidoscopy are not identified by FOBT.
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | NA
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and follow-up? | NA
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Assuming all available sigmoidoscopic capacity is used for colorectal cancer screening, the capacity would exist to screen the unscreened population with a program based on current screening patterns if tests were offered over 3 or more years, but 6 years would be required to screen the unscreened population using 100% sigmoidoscopy or FOBT plus sigmoidoscopy. If only one half of the available capacity were used for screening, it would take 5 years to screen the unscreened population based on current screening patterns and 10 years using screening sigmoidoscopy or FOBT plus sigmoidoscopy. This would not take into account repeat screening tests needed within that time period or tests needed to keep the screened population current with their screening tests. Table 2. Number of Colorectal Cancer Screening and Follow-up Examinations Needed for Unscreened Population in Different Screening Programs (in Millions)
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | | | | | | | | | Colonoscopy
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Screening programs^a^ | | | | FOBT | | Flexible sigmoidoscopy | | Screening colonoscopy | | Follow-up colonoscopy | | | | Total colonoscopy
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | US average-risk population, 50 years or older
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Current screening practices^b^ | | | | 18.5 | | 16.1 | | 15.2 | | 1.2 | | | | 16.3
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | 100% FOBT | | | | 41.8 | | NA | | NA | | 1.0 | | | | 1.0
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | FOBT plus sigmoidoscopy^c^ | | | | 41.8 | | 40.8 | | NA | | 3.0 | | | | 3.0
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | 100% sigmoidoscopy | | | | NA | | 41.8 | | NA | | 2.1 | | | | 2.1
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | 100% colonoscopy | | | | NA | | NA | | 41.8 | | NA | | | | 41.8
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | US population, 50–54 years old, <250% of poverty level, no health insurance
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Mixed tests^d^ | | | | 1.7 | | 0.6 | | 0.6 | | 0.07 | | | | 0.65
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | 100% FOBT | | | | 2.3 | | NA | | NA | | 0.06 | | | | 0.06
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | FOBT plus sigmoidoscopy | | | | 2.3 | | 2.3 | | NA | | 0.17 | | | | 0.17
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | 100% sigmoidoscopy | | | | NA | | 2.3 | | NA | | 0.12 | | | | 0.12
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | 100% colonoscopy | | | | NA | | NA | | 2.3 | | NA | | | | 2.3
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | NA. not applicable. ^a^All positive screening FOBTs and sigmoidoscopies would be followed by a diagnostic colonoscopy. ^b^Current patterns of screening. ^c^FOBT performed first: sigmoidoscopy performed only if FOBT negative. ^d^50% FOBT. 25% FOBT plus flexible sigmoidoscopy, and 25% colonoscopy. Comparing the need for colonoscopy with available capacity, if all available capacity were used for screening, it would take 5 years to screen the unscreened population using 100% screening colonoscopy and 2 years using a program based on current screening patterns. Two of the programs that have available colonoscopy capacity would require sigmoidoscopy as well; sigmoidoscopy is in a shortage until the sixth year. For a program using screening FOBTs with diagnostic colonoscopies for positive tests, there would be enough capa[city to provide the necessary follow-up colonoscopies within 1 year. If only one half of the available colonoscopy capacity were used for screening, it would take 4 years to screen the unscreened population using a program based on current screening patterns and 10 years using 100% colonoscopy. For a program designed to screen only an uninsured, low-income population between 50 and 64 years of age, there is enough sigmoidoscopic and colonoscopic capacity to screen the unscreened population within 1 year using any of the proposed programs. Table 3. Capacity by US Census Region to Perform Lower Endoscopic Procedures According to Current Screening Practices for Average-Risk Persons Aged 50 Years or Older^a^ (in Millions), 2000
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | | | | | Current volume^b^ (95% confidence interval) | | Potential volume^b^ (95% confidence interval) | | Available capacity^c^ | | Test need^d^ | | | | Available capacity minus test need
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Flexible sigmoidoscopy
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Total | | | | 2.8 (2.4–3.1) | | 9.5 (8.4–10.5) | | 6.7 | | 16.1 | | | | −9.4
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Northeast | | | | 0.7 (0.4–1.0) | | 2.5 (1.7–3.2) | | 1.8 | | 3.3 | | | | −1.5
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Midwest | | | | 0.7 (0.6–0.9) | | 2.2 (1.8–2.7) | | 1.5 | | 3.7 | | | | −2.2
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | South | | | | 0.8 (0.6–0.9) | | 3.2 (2.8–3.6) | | 2.4 | | 5.7 | | | | −3.3
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | West | | | | 0.6 (0.4–0.7) | | 1.6 (1.3–1.9) | | 1.0 | | 3.4 | | | | −2.4
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Colonoscopy^e^
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Total | | | | 14.2 (12.1–16.3) | | 22.4 (20.1–24.8) | | 8.2 | | 16.3 | | | | −8.1
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Northeast | | | | 4.2 (2.2–6.1) | | 5.9(3.9–7.8) | | 1.7 | | 3.4 | | | | −1.7
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Midwest | | | | 3.1 (2.6–3.7) | | 5.1 (4.4–5.9) | | 2.0 | | 3.6 | | | | −1.6
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | South | | | | 4.8 (4.3–5.4) | | 8.0 (7.1–8.9) | | 3.2 | | 6.3 | | | | −3.1
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | West | | | | 2.1 (1.8–2.5) | | 3.5 (2.9–4.0) | | 1.4 | | 3.1 | | | | −1.7
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | ^a^According to 2000 NHIS. ^b^Based on results of SECAP: 100% FOBT, follow-up with colonoscopy. ^c^Difference between current and potential volume. ^d^Based on results of forecasting model. ^e^Includes screening plus follow-up.
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | NA
QUALITY RATING: | Good
Quality Assessment for modeling studies:
| | | | | Yes | | | | No | | | | Other (CD, NR, NA)
Were data inputs valid? | | | | | X
Was an appropriate search strategy used to find data inputs? | | | | | X
Were the calculations and statistical analyses adequate? | | | | | X
Were appropriate sensitivity analyses conducted (especially for any variables that were not based on data from literature)? | | | | | X
Other considerations: [These might include the following for various types of models: was the cost effectiveness analysis conducted from the societal perspective? Was an appropriate comparison used (standard of care or next most effective alternative)? Were the appropriate health benefits, harms, and costs described and included?]
Quality Rating (Good, Fair or Poor): Good
STUDY: “How many endoscopies are performed for colorectal cancer screening? Results from CDC’s survey of endoscopic capacity” | Authors, ref ID: Seeff et al.98 Year of publication: 2004 Dates of data collection: April to September 2002 Trial name: Data from Survey of Endoscopic Capacity (SECAP) used for this study
OBJECTIVE OR AIM: | The purpose of this survey was to provide an estimate of the current capacity for endoscopic screening and follow-up examinations in the United States.
DESIGN: | Setting: United States, medical practices that were known to have purchased or leased lower endoscopic equipment between 1996 and 2000 were surveyed. Study design: Telephone & mailed survey Duration (mean follow-up): Overall study size (N enrolled/N analyzed): Surveys were mailed to 1809 practices and 1346 (74.4%) completed surveys were returned. Of the returned surveys, 78 were ineligible; 1268 surveys were analyzed.
Sample size: Describe intervention: | Sample of 1809 practices The sampling frame included all US medical facilities known to have purchased or leased lower endoscopic (sigmoidoscopy and colonoscopy) equipment between January 1, 1996, and December 31, 2000. The authors obtained lists of these customers from the 4 leading US endoscopic equipment manufacturers: Fujinon Inc, Olympus America, Pentax Precision Instruments Inc, and Welch-Allyn. The authors also obtained a list of all single-specialty and multispecialty ambulatory endoscopy/surgery centers (AECs) in the United States from AmSurg Corp, a company that owns and manages AECs. The 4 manufacturer lists were merged and sorted by ZIP code, city, and purchaser name. Duplicate addresses were removed to create a sampling frame that represented a single record for each practice. The AEC list was sorted by ZIP code, city, and purchaser name and maintained in a separate file to allow for oversampling. Urban/rural practice locations were classified using a ZIP code version of the rural-urban commuting area coding scheme. To yield a rural-urban dichotomy, rural-urban commuting area codes 1 (urban core census tract) through 3 (census tract weakly tied to urban core) were considered urban, and codes 4 (large town census tract) through 10 (isolated small rural census tract) were considered rural. Stratified sample US census region and by urban/rural location. AECs and rural practices were oversampled.
RECRUITMENT: (population-based, clinic-based, volunteer, other) | Sample of practices known to provide colonoscopy, as described above. $40 reimbursement for survey response
INCLUSION CRITERIA: | US medical facilities know to have purchased or leased lower endoscopic equipment during study period?
EXCLUSION CRITERIA: | Not currently performing lower GI procedures in adults, or address/phone number that could not be identified.
POPULATION CHARACTERISTICS: | Survey respondents identified themselves as physicians (81.6%), nurses (5.7%), and “other” (12.7%), which included administrators. Responding physicians identified their practice specialties as gastroenterology (49.0%), internal medicine (21.5%), surgery (16.9%), and family or general practice (12.0%).
Mean age & range (years):
Sex (% female):
Race:
Other:
Response Rates (e.g. for surveys): | Surveys were mailed to 1809 practices and 1346 (74.4%) completed surveys were returned. Of the returned surveys, 78 were ineligible; 1268 surveys were analyzed.
STATISTICAL ANALYSES: | Once data collection was completed, the eligibility rate for the sampled facilities was applied to each stratum to produce a total number of possible practices in each stratum. Sampling weights were computed by dividing the total number of practices in each stratum by the total number of completed surveys in those strata. The sampling weights adjusted for differences in the probability of being selected and response rates across cells. The authors then multiplied each survey response by the corresponding survey weight to obtain an estimate of the total number of facilities in the United States that perform flexible sigmoidoscopy and colonoscopy, the total number of procedures that are currently being performed, and the maximum number of procedures that could be performed given current resources. These estimates are generalizable to the population of all US health care practices that use lower gastrointestinal flexible endoscopic equipment for the detection of colorectal cancer in adults. The weighted national weekly estimates were then multiplied by the number of workweeks per year to obtain national annual estimates. The authors assumed a 46-week working year across all practice specialties and facility types to account for vacations, professional travel, and nonprocedural time. The survey data were analyzed and 95% confidence intervals (CIs) were calculated using Stata to adjust for sampling design effects. For the estimation of endoscopic capacity, 2 survey questions were critical to the analysis: the number of procedures currently performed and the maximum number of procedures that could be performed. These data items were imputed when missing (40 surveys were missing current endoscopic volume data and 290 were missing potential endoscopic volume data) using a variation of the hot-deck method. For surveys with missing current volume data, a current volume estimate was randomly selected from all surveys with known current volume estimates and used as a replacement for the missing current volume value. For surveys with missing potential maximum volume data, a ratio of current volume to potential volume was randomly selected from among all surveys with known current and potential volume estimates, multiplied by the current volume estimate, and used as a replacement for the missing potential volume value.
ASSESSMENT OF EXPOSURES AND POTENTIAL CONFOUNDERS: | NA
OUTCOME ASSESSMENT: | Respondents were asked to Identify their practice as private practice, an AEC, or a hospital. Responses were inconsistent, making it difficult to classify facilities by facility type. For this analysis, facilities were classified according to the practice specialty based on types of physicians that perform the majority of procedures. If ≥75% of procedures were performed by GI, the facility is classified as a GI practice. Same for primary care and for surgical. If no dominant physician specialty, the facility was classified as a mixed practice. Survey respondents were asked to estimate the weekly number of flexible sigmoidoscopies performed by the practice (“During a typical week, how many flexible sigmoidoscopies are performed by all physician and non-physician endoscopists in this practice site?”) and the weekly potential maximum number the practice could perform (“If the demand for colorectal cancer screening were to increase substantially, what is the maximum number of flexible sigmoidoscopies that could be provided at this practice site per week with no other investment of resources?”). The same questions were asked about colonoscopy volume. Available capacity was then determined by taking the difference between the current and the potential volume.
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | NA
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and follow-up? | NA
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Number and Specialty of US Practice Sites that perform flexible sigmoidoscopy and colonoscopy, by region, 2002
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Procedure | | Total (95% CI) | | Gastroenterology practices (95% CI) | | | | Primary care practices (95% CI) | | Surgical practices (95% CI) | | Mixed practices (95% CI)
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Any lower endoscopy
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Total | | 8207 | | 3800 (3582 – 4017) | | | | 1644 (1456 – 1832) | | 988 (838 – 1138) | | 1775 (1585 – 1965)
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | N.E. | | 1611 (1604 – 1618) | | 970 (874 – 1066) | | | | 195 (128 – 262) | | 154 (95 – 213) | | 292 (215 – 369)
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | South | | 2890 (2878 – 2901) | | 1417 (1287 – 1547) | | | | 542 (435 – 649) | | 429 (332 – 526) | | 502 (398 – 606)
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | M.W. | | 2082 (2074 – 2090) | | 678 (574 – 782) | | | | 463 (363 – 563) | | 257 (180 – 334) | | 684 (574 – 794)
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | West | | 1624 (1615 – 1634) | | 734 (633 – 835) | | | | 444 (345 – 543) | | 149 (87 – 211) | | 297 (211 – 383)
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Flex Sig
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Total | | 6732 (6557 – 6907) | | 2851 (2644 – 3058) | | | | 1563 (1397 – 1769) | | 708 (577 – 839) | | 1590 (1408 – 1772)
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | N.E. | | 1363 (1292 – 1434) | | 756 (658 – 854) | | | | 195 (128 – 262) | | 147 (89 – 205) | | 265 (190 – 340 )
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | South | | 2292 (2184 – 2400) | | 1046 (922 – 1170) | | | | 513 (409 – 617) | | 329 (242 – 416) | | 404 (309 – 499)
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | M.W. | | 1752 (1667 – 1837) | | 508 (414 – 602) | | | | 456 (357 – 555) | | 141 (82 – 200) | | 647 (539 – 755)
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | West | | 1325 (1243 – 1407) | | 541 (445 – 637) | | | | 420 (323 – 517) | | 91 (40 – 142) | | 273 (190 – 356)
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Colonoscopy
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Total | | 6214 (6016 – 6412) | | 3373 (3158 – 3588) | | | | 300 (211 – 389) | | 822 (684 – 960) | | 1719 (1532 – 1906)
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | N.E. | | 1217 (1130 – 1304) | | 825 (727 – 923) | | | | 13 (0 – 32) | | 94 (47 – 235) | | 285 (209 – 361)
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | South | | 2230 (2118 – 2342) | | 1266 (1138 – 1394) | | | | 128 (71 – 185) | | 360 (270 – 450) | | 475 (373 – 577)
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | M.W. | | 1602 (1505 – 1699) | | 596 (495 – 697) | | | | 109 (56 – 162) | | 228 (156 – 300) | | 669 (561 – 777)
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | West | | 1165 (1065 – 1265) | | 686 (586 – 786) | | | | 49 (12 – 86) | | 140 (80 – 200) | | 289 (204 – 374)
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Number of flex sigs and colonoscopies performed by week by practices that own or lease lower endoscopic equipment, per practice, by practice specialty, 2002
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Procedure | | GI practices (95% CI) | | Primary Care practices (95% CI) | | | | Surgical practices (95% CI) | | | | Mixed practices (95% CI)
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Flex sig
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | % of practices that perform | | 76.0 (72.5 – 79.5) | | 96.3 (93.8 – 98.8) | | | | 72.7 (65.2 – 80.2) | | | | 89.6 (85.8 – 93.4)
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Current # (mean) | | 9.0 (7.0 – 11.0) | | 5.0 (4.1 – 5.9) | | | | 14.4 (8.9 – 19.9) | | | | 10.1 (7.8 – 12.4)
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Performed for screening (%) | | 38.0 (34.5 – 41.5) | | 78.6 (75.1 – 82.1) | | | | 43.9 (36.4 – 51.4) | | | | 61.9 (57.3 – 66.5)
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Potential maximum # (mean) | | 37.7 (31.0 – 44.4) | | 14.3 (12.6 – 16) | | | | 34.6 (26.2 – 43) | | | | 11.0 (9.0 – 13.0)
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Colonoscopy
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | % of practices that perform | | 88.8 (86.2 – 91.4) | | 18.6 (13.6 – 23.6) | | | | 83.2 (77.1 – 89.3) | | | | 97.6 (95.7 – 99.5)
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Current # (mean) | | 65.5 (52.8 – 78.2) | | 8.3 (6.5 – 10.1) | | | | 15.8 (13.1 – 18.5) | | | | 42.6 (36.4 – 48.8)
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Performed for screening (%) | | 45.6 (43.5 – 47.7) | | 52.3 (44.6 – 60) | | | | 48.3 (42.5 – 54.1) | | | | 46.9 (43.7 – 50.1)
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Potential maximum # (mean) | | 100.0 (86.3 – 113.7) | | 19.7 (15.7 – 23.7) | | | | 32.9 (26.9 – 38.9) | | | | 68.6 (59.5 – 77.7)
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Percentage of all FS and Colonoscopies performed by physician specialty, 2002 Specialty
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Flex sig % (95% CI) | | Colonscopy % ((%% CI)
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | GI | | 43.7 (37.2–50.2) | | | | | | 82.5 (80.3–84.7)
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | PCP | | 24.9 (20.3–29.5) | | | | | | 2.0 (1.4–2.6)
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Surgeon | | 20.5 (14.2–26.8) | | | | | | 10.8 (9.l2–12.4)
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Resident with supervising MD | | 1.4 (0.2–2.6) | | | | | | 0.2 (0.1–0.3)
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Fellow with supervising MD | | 2.5 (1.3–3.7) | | | | | | 4.3 (2.1–6.7)
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Non MD | | 6.1 (2.1–10.1) | | | | | | 0.0 (0–0.1)
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Other | | 0.7 (0–1.9) | | | | | | 0.1 (0–0.2)
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Current Volume, potential volume and available capacity for annual ^a^ flex sigs and colonoscopies by region (in millions), 2002
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | | | Current volume (95% CI) | | | | | | Potential volume (95% CI) | | | | Available capacity ^b^
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Flex sig
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | All regions | | 2.8 (2.4 – 3.1) | | | | | | 9.5 (8.4 – 10.5) | | | | 6.7
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | N.E. | | 0.7 (0.6 – 0.9) | | | | | | 2.5 (1.7 – 3.2) | | | | 1.8
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | M.W. | | 0.7 (0.6 – 0.9) | | | | | | 2.2 (1.8 – 2.7) | | | | 1.5
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | South | | 0.8 (0.6 – 0.9) | | | | | | 3.2 (2.8 – 3.6) | | | | 2.4
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | West | | 0.6 (0.4 – 0.7) | | | | | | 1.6 (1.3 – 1.9) | | | | 1.0
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Colonoscopy
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | All regions | | 14.2 (12.1 – 16.4) | | | | | | 22.4 (20.1 – 24.8) | | | | 8.2
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | N.E. | | 4.2 (2.2 – 6.1) | | | | | | 5.9 (3.9 – 7.8) | | | | 1.7
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | M.W. | | 3.1 (2.6 – 3.7) | | | | | | 5.1 (4.4 – 5.9) | | | | 2.0
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | South | | 4.8 (4.3 – 5.4) | | | | | | 8.0 (7.1 – 8.9) | | | | 3.2
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | West | | 2.1 (1.8 – 2.5) | | | | | | 3.5 (2.9 – 4.0) | | | | 1.4
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | ^a^ Assuming 46 workweeks/year ^b^ Difference between current and potential volumes A total of 8207 practice sites across the county performed flexible sigmoidscopy or colonoscopy for CRC screening and follow up. Approximately 2.8 million flexible sigmoidoscopies and 14.2 million colonoscopies were estimated to have been performed in 2002, approximately one half of them for screening. Across all practice specialties, 53.8% of FS and 64.7% of colonoscopies were performed for screening. Survey respondents reported that they could increase their flexible sigmoidoscopy volume to 9.5 (95% CI, 8.4 –10.5) million procedures annually, an increase of 29%, and could increase their colonoscopy volume to 22.4 (95% CI, 20.1–24.8) million annually, an increase of 63%. Additional available capacity for FS and colonoscopy greatest in the South in terms of absolute number as well as percentage of potential volume that is additional available capacity; lowest additional available capacity in terms of absolute number is the West; in terms of percentage it is the Northeast.
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | NA
QUALITY RATING:
Quality Assessment-Internal Validity for Observational Studies
| | | | | Yes | | | | No | | | | Other (CD, NR, NA)
Were the groups similar at baseline regarding the most important prognostic indicators? | | | | | | | | | | | | | NA
Were the drop-out or response rates acceptable (≤ 20%)? [If between 20% and 60%, check other and explain.] | | | | | X
Were the differential drop-out or response rates acceptable (≤ 15%)? | | | | | | | | | | | | | Not measured
Were intervention/exposure measures valid, reliable, and equally applied? | | | | | | | | | | | | | NA
Were the outcome assessors blinded to the intervention or exposure status of subjects? | | | | | | | | | | | | | NA
Were outcome measures valid, reliable, and equally applied? | | | | | X
Does the analysis control for baseline differences? | | | | | | | | | | | | | NA
Were important potential confounding and modifying variables taken into account in the design and analysis (e.g., through matching, stratification, or statistical adjustment)? | | | | | | | | | | | | | NA
Were the statistical methods used to assess the abstracted outcomes appropriate? | | | | | X
Quality Rating (Good, Fair, or Poor): Good
STUDY: | Authors: Vijan et al.99 Year: 2004 Trial name (if applicable): NA
DESIGN: | Study design: Use of previous Markov model Number of subjects: The authors used the current population of the United States, ages 50–79 Time period covered: October 2002 to October 2003
QUESTIONAIM/OBJECTIVE: | To quantify the demand for colonoscopy with different screening tests, and to estimate the ability of the United States health care system to meet demand.
DATA INPUTS: | • For this analysis, the authors used the decision model to estimate the number of colonoscopies and flexible sigmoidoscopies undergone using several screening strategies: flexible sigmoidoscopy combined with fecal occult-blood testing (FS/FOBT), a single colonoscopy at ages 50, 60, or 65 twice lifetime colonoscopy undergone at ages 50 and 60, or colonoscopy every 10 years. Positive results with screening FS/FOBT resulted in performance of colonoscopy. Patients in whom high risk adenomatous polyps were diagnosed (polyps 1 cm or greater, three or more polyps, or polyps with advanced histology) underwent an initial surveillance colonoscopy at 3-years; if this endoscopy was negative, further surveillance was carried out at 5-year intervals. • The average rate of colonoscopy performance was then extrapolated to all USA gastroenterologists. The authors then increased this number by 33%, based on the assumption that some screening-related colonoscopies that are performed by providers other than gastroenterologists
ANALYSIS AND CALCULATIONS: | • The cohort was divided into 5 year clusters and the model was run to assess the total number of colonoscopies and flexible sigmoidoscopies that would be necessary for each of these age clusters over the remaining lifetime of the cohort. • The authors ran these calculations using two main scenarios. In the first, the authors assumed a fixed adherence level of 70%; i.e. 70% in the age-range were eligible for and followed recommendations for initial screening. In the second, as an upper bound of demand estimates, the authors assumed that all patients were eligible, but that the total proportion of eligible and willing patients declined with age (a proxy measure for comorbidity). • The authors used the CORI data to calculate the average number of colonoscopies performed per month by USA gastroenterologists from October 2002 through September 2003. • The average rate of colonoscopy performance was then extrapolated to all USA gastroenterologists (11,044). The authors then increased this number by 33%, based on the assumption that some screening-related colonoscopies that are performed by providers other than gastroenterologists • The authors then calculated the incremental number of colonoscopies that would be performed under various screening scenarios by subtracting the number of screening-related colonoscopies that are done at present from the total number of colonoscopies predicted by the decision model. • The authors also conducted sensitivity analyses varying the proportion of endoscopies undergone by specialties other than gastroenterology. • In the base case, approximately 46% of colonoscopies are related to screening and/or surveillance of average risk individuals; the authors ranged this from 46 (e.g. no shift) to 66% (a 20% shift) in sensitivity analyses.
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | NA
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and follow-up? | NA
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Outcomes: Current volume: • Estimated 1.27 million screening colonoscopies per year conducted by gastroenterologists; estimated 1.69 m screening colonoscopies per year by all types of providers Average of 21 colonoscopies (range 0–102) per month Even under the most favorable sensitivity analysis assumptions, a single colonoscopic screening at age 65, which requires the fewest number of colonoscopies, would require between 1360 and 4160 more gastroenterologists. • The more effective but also more resource intensive strategies would require a three to four times increase from the current number (11 044) of gastroenterologists in order to meet demand. However, even the FOBT/FS-based strategy would require a substantial increase in the number of gastroenterologists, ranging from a 30 to 110% increase, depending on assumptions about eligibility and the number of colonoscopies that could be performed. • If a group of dedicated endoscopists were trained a much smaller number of new endoscopists would be required to meet the projected demand. For example, if colonoscopy every 10 years is the predominant strategy, and a dedicated endoscopist can perform 200 colonoscopies per month (about 10 per day), then between 2100 and 2600 endoscopists could theoretically meet demand.
| 70% of age-eligible subjects
| | | | | Incr. # of screen-related colonoscopies
| FOBT/FS | | | | 1.20
| COLON every 10 years | | | | 5.03
| 100% of age-eligible subjects
| | | | | Incr. # of screen-related colonoscopies
| FOBT/FS | | | | 2.39 | | | | 1
| COLON every 10 years | | | | 6.27
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | NA
QUALITY RATING: | Fair for capacity estimates; Good for demand estimates
Quality Assessment for Modeling Studies
| | | | | Yes | | | | No | | | | Other (CD, NR, NA)
Were data inputs valid? | | | | | | | | | X | | | | Inputs based on CORI database which is not representative
Was an appropriate search strategy used to find data inputs? | | | | | X
Were the calculations and statistical analyses adequate? | | | | | X
Were appropriate sensitivity analyses conducted (especially for any variables that were not based on data from literature)? | | | | | X
Other considerations: [These might include the following for various types of models: was the cost effectiveness analysis conducted from the societal perspective? Was an appropriate comparison used (standard of care or next most effective alternative)? Were the appropriate health benefits, harms, and costs described and included?] | | | | | | | | | | | | | NA
Quality Rating (Good, Fair or Poor): Fair for capacity estimates; Good for demand estimates

Evidence Table 4 KQ5: Effective approaches for monitoring use and quality of colorectal cancer screening

STUDY: The use of screening colonoscopy for patients cared for by the Department of Veterans Affairs | Authors, ref ID: El-Serag, Peterson, Hampel, Richardson, Cooper 100 Year of publication: 2006 Dates of data collection: 1998 – 2003 Trial name: NA
OBJECTIVE OR AIM: | To investigate whether colonoscopy use increased disproportionately in the VA system and changes in rates of FS, DCBE, and FOBT use between October 1, 1998, and September 30, 2003.
DESIGN: | Setting: United States, VA medical centers Study design: cross-sectional Duration (mean followup): NA Overall study size (N enrolled/N analyzed):
Sample size: | NA
Describe intervention: NA
RECRUITMENT: (population-based, clinic-based, volunteer, other) | Population based- from VA databases
INCLUSION CRITERIA: | Procedures for VA users aged 49 to 75 years.
EXCLUSION CRITERIA: | NR
POPULATION CHARACTERISTICS: | Feature | | | Screening c-scope (n=178,853) | | FOBT (n=1,635,364) | | | | DCBE (n=78,830) | | | | FS (n=217,327)
Mean age & range (years):
Colonoscopy: 62.3 (7.6) years | Race
FOBT: 63.9 (7.8) | White | | | 105,746 (59.1) | | 815,582 (49.9) | | | | 45,894 (58.2) | | | | 118,789 (54.7)
DCBE: 62.6 (7.8) | Black | | | 17,934 (10.0) | | 133,822 (8.2) | | | | 10,458 (13.3) | | | | 20,358 (9.4)
FS: 61/8 (7.7) | Other | | | 55,173 (30.8) | | 685,960 (41.9) | | | | 22,478 (28.5) | | | | 78,180 (36.0)
Sex (% female): | Sex
| Male | | | 174,356 (97.5( | | 1,583,775 (96.8) | | | | 76,427 (97.0) | | | | 211,824 (97.5)
| Female | | | 4,497 (2.5) | | 51,589 (3.2) | | | | 2,403 (3.0) | | | | 5,503 (2.5)
Race:
Other: | The mean (SD) age of those undergoing screening colonoscopy was 62.3 (7.6) years; FOBT, 63.9 (7.8) years; DCBE, 62.6 (7.8) years; and FS, 61.8 (7.7) years.
Attrition/Drop-out (not available for endpoint measurement): | NR
Adherence:
Contamination:
Response Rates (e.g. for surveys):
STATISTICAL ANALYSES: | The frequencies and proportions of the 4 types of CRC screening procedures, and of unique individuals undergoing these procedures, were calculated for each fiscal year. The temporal changes and potential determinants (age, sex, and race) of screening colonoscopy (vs other CRC screening tests) were examined in unadjusted and adjusted logistic regression analyses. Similar calculations were performed for screening colonoscopy (vs other colonoscopy). Statistical comparisons of these proportions were not performed because of overlapping groups. The authors used the predictive values to perform a sensitivity analysis of the calculated proportions for screening colonoscopy.
ASSESSMENT OF EXPOSURES AND POTENTIAL CONFOUNDERS: | National inpatient and outpatient VA databases used to assess potential confounders/covariates
OUTCOME ASSESSMENT: | National inpatient and outpatient VA databases were searched for codes indicative of colonoscopy, FS, FOBT, and DCBE recorded during fiscal years 1998 to 2003. The authors also used the VA Patient Treatment File, which contains hospital discharge records and up to 10 diagnostic codes, 5 operating room procedures, and 32 nonoperating room procedures coded according to the International Classification of Diseases, Ninth Revision, Clinical Modification. The indications for CRC screening tests were classified as screening, diagnosis, or surveillance based on the predefined Algorithm. All FOBT procedures were designated as screening procedures. Flexible sigmoidoscopy and DCBE were considered diagnostic in the presence of specific conditions recorded within the year before the date of the procedure. They were considered to be surveillance procedures in the presence of a second set of prespecified conditions (coded as 17–28). The remaining procedures were considered to be screening procedures Colonoscopy was considered for CRC screening in the absence of conditions associated with diagnostic or surveillance indications and if no colonoscopy had been performed within the past 4 years. Because of concerns of the accuracy of diagnosis and procedure codes for specifying procedural indications, the authors also conducted a medical record review study in a subset of colonoscopic procedures nested within the main study cohort to validate and refine the algorithm that was used. A review of procedure, pathology, and progress notes was performed by 2 boardcertified gastroenterologist investigators who were blinded to the designated status based on the VA administrative data sets. They categorized indications for procedures as screening, surveillance, or diagnostic. A total of 303 medical records of unique patients with colonoscopy performed at the Michael E. DeBakey VA Medical Center, between October 6, 1999, and September 30, 2003, were identified at random using a computer generated algorithm, and reviewed from the national databases (ie, a subset from the main study cohort). Agreement between the 2 reviewers was achieved in 92.0% of cases, and differences were resolved by discussion. The predictive values of the database algorithm for identifying screening colonoscopy (compared with the medical record as a gold standard) were calculated.
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | NA
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | NA
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | The authors calculated that the algorithm has approximately 70.1% sensitivity and 71.6% specificity to define screening colonoscopy. The findings of medical record review were then applied in a sensitivity analysis to recalculate the estimated annual frequency of screening colonoscopy. Apart from reducing the total number of screening colonoscopies by up to 25%, changing the definition of screening colonoscopy had little effect on the observed trends. Concordance or kappa not calculated
QUALITY RATING: | Fair
Quality Assessment-Internal Validity for Observational Studies
| | | | | | Yes | | | | No | | | | Other (CD, NR, NA)
Were the groups similar at baseline regarding the most important prognostic indicators? | | | | | | | | | | | | | | NA
Were the drop-out or response rates acceptable (≤ 20%)? [If between 20% and 60%, check other and explain.] | | | | | | X
Were the differential drop-out or response rates acceptable (≤ 15%)? | | | | | | X
Were intervention/exposure measures valid, reliable, and equally applied? | | | | | | X
Were the outcome assessors blinded to the intervention or exposure status of subjects? | | | | | | | | | | | | | | NA
Were outcome measures valid, reliable, and equally applied? | | | | | | x | | | | | | | | Algorithm used to differentiate screening from diagnostic procedures, verified through dual review (see statistical methods section of abstraction) Concordance/kappa not calculated
Does the analysis control for baseline differences? | | | | | | x | | | | | | | | Logistic regression models used
Were important potential confounding and modifying variables taken into account in the design and analysis (e.g., through matching, stratification, or statistical adjustment)? | | | | | | x
Were the statistical methods used to assess the abstracted outcomes appropriate? | | | | | | x
Quality Rating (Good, Fair, or Poor): Fair
STUDY: | Authors, ref ID: Fiscella101 Year of publication: 2006 Dates of data collection: 1998–2002 Trial name: NR
OBJECTIVE OR AIM: | To determine whether estimates of racial and racial disparities in receipt of six different types of largely preventive procedures differ between self-report and Medicare claims data
DESIGN: | Setting: Medicare claims data Study design: observational Duration (mean followup): 2 to 4 years Overall study size (N enrolled/N analyzed): 88509 # observations (n = 1474 for colorectal testing)
Sample size: | 1474
Describe intervention: | Includes fecal occult blood testing, sigmoidoscopy, or colonoscopy
RECRUITMENT: (population-based, clinic-based, volunteer, other) | Population
INCLUSION CRITERIA: | Medicare Beneficiaries 65 and older who participated in the Medicare Current Beneficiary Survey, 1999–2002.
EXCLUSION CRITERIA: | Participated in facility interviews (i.e., resided in long-term care facilities), were less than 65 years of age (i.e., were Medicare recipients due to having a qualifying disability), reported race/ethnicity other than Hispanic, non- Hispanic African American, or non-Hispanic White, i.e. majority, were enrolled in a Medicare HMO, or were not eligible for Medicare B (or Medicare A and B) coverage dropped due to incomplete claims.
POPULATION CHARACTERISTICS: | [underlined: Overall]
Mean age & range (years): | 65–69 16.7% 70–74 35.1% 75–79 26.7% 80–84 14.3% 85+ 7.2%
Sex (% female): | 56% female
Race: | Hispanic, African American 8.8% Majority 91.2%
Other:
Attrition/Drop-out (not available for endpoint measurement): | NA
Adherence:
Contamination:
Response Rates (e.g. for surveys):
STATISTICAL ANALYSES: | Describe: used SAS Survey and logistic regression to assess the relationship, adjusted, between minority status and self report
ASSESSMENT OF EXPOSURES AND POTENTIAL CONFOUNDERS: | Predictors of self report
OUTCOME ASSESSMENT: | Outcome Measures: • Prevalence of receipt of FOBT, FS, or colonoscopy as measured by: • Self-report in the MCBS of having any of the tests in the last year (MCBS) (indication was not specified) • Medicare claims, including both screening and diagnostic codes (administrative data)
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | NA
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | NA
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Outcomes: Unadjusted prevalence of CRC screening White: Survey 38.0 Administrative 30.1 Minority: Survey 34.8 Administrative 20.4 Concordance between self-report and administrative data (measured by kappa score) for CRC screening White 0.37 Minority 0.19 The authors also calculated an odds ratios for reporting a procedure in the absence of a claim, or vice versa. Minorities were more likely to report receipt of CRC screening in the absence of a claim (OR=1.92, 95% CI, 1.32‐ 2.79), with little change after adjustment for age, gender, income, educational level, health status, proxy response, and supplemental insurance. Having a claim for CRC testing in the absence of self-report did not differ by race or ethnicity.
QUALITY RATING: | Good
Quality Assessment-Internal Validity for Observational Studies
| | | | | | Yes | | | | No | | | | Other (CD, NR, NA)
Were the groups similar at baseline regarding the most important prognostic indicators? | | | | | | | | | | | | | | NA
Were the drop-out or response rates acceptable (≤ 20%)? [If between 20% and 60%, check other and explain.] | | | | | | | | | | | | | | Response rate for MCBS not reported. Possible that non-respondents differ from respondents in terms of associations between self report and administrative claims.
Were the differential drop-out or response rates acceptable (≤ 15%)?
Were intervention/exposure measures valid, reliable, and equally applied? | | | | | | | | | | | | | | NA
Were the outcome assessors blinded to the intervention or exposure status of subjects? | | | | | | | | | | | | | | NA
Were outcome measures valid, reliable, and equally applied? | | | | | | x
Does the analysis control for baseline differences? | | | | | | x
Were important potential confounding and modifying variables taken into account in the design and analysis (e.g., through matching, stratification, or statistical adjustment)? | | | | | | x
Were the statistical methods used to assess the abstracted outcomes appropriate? | | | | | | x
Quality Rating (Good, Fair, or Poor): Good
STUDY: | Authors, ref ID: Hall et al.102 Year of publication: 2004 Dates of data collection: December 1999 – June 2001 Trial name: NA
OBJECTIVE OR AIM: | To examine the accuracy of self-reports of prostate and colorectal cancer testing and reasons for testing using questions included in national surveys, the authors conducted a survey and reviewed the medical records for procedures performed among members of three health maintenance organizations (HMOs)
DESIGN: | Setting: member lists of Kaiser Permanente-Northern California (NC), Kaiser Permanente- Georgia (GA), and HealthPartners (HP), Minnesota Study design: cross-sectional Duration (mean follow-up): NA Overall study size (N enrolled/N analyzed): 3546
| Black men | | | | | | | White and other men | | | | | | Women
Sample size: | 363 | | | | | | | 847 | | | | | | 920
Describe intervention
RECRUITMENT: (population-based, clinic-based, volunteer, other) | H.M.O. population based
INCLUSION CRITERIA: | Men aged 45 years and older and women aged 55 years and older as of September 1, 1999 who had been enrolled in the plan for at least 5 years were eligible for selection. Simple random sample for women. For men, an SRS for men at one site. At 2 sites, separate sample of black and white men recruited until all strata were filled. Also at one site, sample was drawn from members who had participated in a past survey.
EXCLUSION CRITERIA: | Screened out (statrum filled); language barrier, dead, out of network, phone disconnected, other
POPULATION CHARACTERISTICS: | Characteristics of study sample from 3 HMO’s
Mean age & range (years): Sex (% female): | | | Black men (n=363) | | | | | White and other men (n = 847) | | | | Women (n = 920)
Mean age & range (years): Sex (% female): | Age (y) | | % | | | (n) | | % | | (n) | | % | | (n)
Mean age & range (years): Sex (% female): | 45 – 49 | | 19.8 | | | (72) | | 14.3 | | (121) | | 0.0 | | 0
Mean age & range (years): Sex (% female): | 50 – 59 | | 41.0 | | | 149 | | 38.6 | | 327 | | 23.3 | | (214)
Mean age & range (years): Sex (% female): | 60 – 69 | | 19.3 | | | (70) | | 23.4 | | (198) | | 33.8 | | (311)
Mean age & range (years): Sex (% female): | 70+ | | 19.8 | | | (72) | | 23.7 | | (201) | | 42.9 | | (394)
Race: | Ethnicity
Race: | Hispanic | | 0.6 | | | (2) | | 3.5 | | (30) | | 3.2 | | (29)
Race: | Non-Hispanic | | 99.4 | | | (361) | | 96.5 | | (816) | | 96.8 | | (888)
Other: | Education
Other: | < HS | | 10.2 | | | (37) | | 6.3 | | (53) | | 9.9 | | (91)
Other: | HS/GED | | 22.6 | | | (82) | | 17.9 | | (152) | | 27.1 | | (249)
Other: | Some college/tech school | | 38.8 | | | (141) | | 31.6 | | (268) | | 35.7 | | (328)
Other: | College grad | | 28.4 | | | (103) | | 44.2 | | (374) | | 27.2 | | (250)
Other: | Marital status
Other: | Married | | 78.0 | | | (283) | | 82.4 | | (698) | | 55.8 | | (512)
Other: | Unmarried | | 22.0 | | | (80) | | 17.6 | | (149) | | 44.2 | | (406)
Other: | Employment
Other: | Employed | | 62.9 | | | (227) | | 59.2 | | (499) | | 31.5 | | (288)
Other: | Unemployed | | 33.8 | | | (122) | | 39.3 | | (331) | | 62.0 | | (566)
Other: | Retired/other | | 3.3 | | | (12) | | 1.5 | | (13) | | 6.5 | | (59)
Other: | Income
Other: | <= $20,000 | | 13.6 | | | (46) | | 9.4 | | (72) | | 29.5 | | (236)
Other: | $20,000 – $40,000 | | 24.2 | | | (82) | | 16.9 | | (130) | | 30.0 | | (240)
Other: | $40,001 – $60,000 | | 23.9 | | | (81) | | 25.8 | | (199) | | 21.4 | | (171)
Other: | > $60,000 | | 38.3 | | | (130) | | 47.9 | | (369) | | 19.0 | | (152)
Other: | Health status
Other: | Excellent/good | | 82.3 | | | (298) | | 87.6 | | (741) | | 82.1 | | (754)
Other: | Fair/poor | | 17.7 | | | (64) | | 12.4 | | (105) | | 17.9 | | (164)
Other: | Smoking status
Other: | Current | | 17.9 | | | (65) | | 10.0 | | (85) | | 7.5 | | (69)
Other: | Former | | 46.6 | | | (169) | | 49.9 | | (423) | | 36.2 | | (333)
Other: | Never | | 35.5 | | | (129) | | 40.0 | | (339) | | 56.3 | | (518)
Attrition/Drop-out (not available for Endpoint Measurement): | Response Rates (for survey): 4,833 members contacted 3,546 eligible 1,248 refused 2,298 completed
Adherence: | Response rate = 64.8% among those contacted and eligible
Contamination: | 1181 not contacted (no answer, busy, answering service, exceeded call limit)
STATISTICAL ANALYSES: | The authors analyzed the data according to our sampling frame, that is, for all women, black men, and white and other men separately. Few participants were of races other than white or black (67 [3.1%] were of other races and 83 [3.9%] were multiracial). Therefore, non- Black men of other races and multiracial men were grouped together with white men. At HP, few men were black, and no statistics are presented for them. Participants with a history of prostate or colorectal cancer were excluded from the analyses. The final sample sizes were 363 black men, 847 white and other men, and 920 women. Respondent characteristics were summarized as frequencies and percentages. The authors calculated the percentages of respondents who reported having had their most recent DRE, PSA, or FOBT within 2 years before interview and sigmoidoscopy or colonoscopy within 5 years before interview. The percentages of respondents who had tests as determined by the medical record audit were similarly calculated; for FOBT, the authors counted only home kits to match with the survey question. On the basis of these time frames, the authors calculated the concordance (agreement) between the self-report and medical record audit for the tests. The authors also calculated agreement for endoscopy by combining sigmoidoscopy and colonoscopy. The authors calculated the kappa statistic by the method of Landis and Koch, which accounts for agreement expected by chance. Excellent agreement is defined as a kappa statistic greater than 0.75, fair to good agreement as 0.40 to 0.75, and poor agreement as less than 0.40. The authors also calculated the sensitivity and specificity of self-reports using the information from the medical records as the standard. Differences in sensitivity and specificity between health plans were determined with a pairwise test of proportions. The authors assessed the relationships between agreement and demographic characteristics (age, sex-race groups, and education) with polytomous regression models. The reference was agreement between self-reports and medical records and was compared to over- and underreporting. The authors also assessed the relationship with income, but because of the relatively large number of missing observations and no significant associations in any of the models, it was not included in the final models. All analyses were adjusted for study site. Further, the authors determined the reasons for testing and the concordance between the reasons reported by participants and the reasons recorded in the medical records. Tests were defined as screening tests when the reason for testing was screening, family history, or “part of exam/ doctor just did it.” Tests were defined as being performed for “other reasons” when the reasons were symptoms, problems, follow-up of an abnormal test, or other reasons. Finally, the authors evaluated whether and how frequently participants confused sigmoidoscopy and colonoscopy.
ASSESSMENT OF EXPOSURES AND POTENTIAL CONFOUNDERS: | Computer assited telephone interviews (CATI): The survey instrument elicited information on demographic and health characteristics, including a personal or family history of prostate or colorectal cancer, whether they had ever been tested for prostate or colorectal cancer and, if so, when they had the most recent tests (see Appendix for the questions asked). In addition, participants were asked the reasons for testing and the test results. The initial questions on prostate and colorectal cancer testing were based on the questions proposed for the Year 2000 National Health Interview Survey Cancer Control Supplement and Behavioral Risk Factor Surveillance System. The questionnaire is available from the authors upon request. Medical record reviews: Medical records were reviewed to determine whether any of the cancer tests included in the survey had been recorded within 5 years before the interview date. In addition, the dates and results of the tests were obtained. For each test recorded in the medical records, the authors ascertained the reason for or symptoms associated with the test by reviewing the records for up to 6 months before the test date but no more than 5 years before the survey (index) date. At each site, each page of all relevant medical records in the study time period was physically reviewed by a trained medical record analyst. Each provider note, all laboratory, radiology, endoscopy, and pharmacy information were abstracted using a standardized medical record abstraction form. Quality control procedures included a review of all abstraction forms for missing data and ambiguous responses and duplicate abstraction for 10% of the records. Data entry for all forms was conducted at Kaiser Permanente- NC with double key entry. Programs for internal consistency and validity were used to identify and correct errors of coding and data entry.
OUTCOME ASSESSMENT: | (see above)
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | NA
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and follow-up? | NA
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Percentage of respondents who received prostate or colorectal cancer tests according to self- report and medical record audits, 1999 - 2001
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | | Black men (n=363) | | | | | White + other men (n=847) | | | | Women (n = 920)
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | | % | | | (n) | | % | | (n) | | % | | (n)
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | FOBT*
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Survey | 22.2 | | | (79) | | 20.3 | | (169) | | 25.9 | | (234)
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Med recs | 11.6 | | | (42) | | 9.5 | | (80) | | 14.1 | | (129)
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Sig’oscpy**
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Survey | 38.4 | | | (138) | | 42.0 | | (352) | | 50.0 | | (447)
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Med rec | 29.6 | | | (107) | | 30.6 | | (258) | | 34.1 | | (313)
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | C-scope**
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Survey | 13.7 | | | (49) | | 14.6 | | (121) | | 15.7 | | (140)
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Med rec | 8.1 | | | (29) | | 11.1 | | (94) | | 9.6 | | (88)
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | End’scopy**
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Survey | 44.4 | | | (159) | | 49.9 | | (415) | | 58.6 | | (523)
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Med rec | 34.4 | | | (124) | | 37.8 | | (319) | | 39.8 | | (365)
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Note: endoscopy indicates sigmoidoscopy OR colonoscopy * test within past 2 years ** test within past 5 years CRC screening information: agreement between self-reports and medical record audits, 1999 - 2001
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | procedure | Black men | | | | | | White and other men | | | | | Women
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | | | sens | | spec | conc | K | n | sens | spec | conc | K | n | sens | spec | conc | K
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Kaiser Permanente-Georgia
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Fobt | 187 | 0.89 | | 0.86 | 0.86 | 0.57 | 293 | 0.90 | 0.85 | 0.86 | 0.56 | 310 | 0.89 | 0.82 | 0.84 | 0.62
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Sig | 188 | 0.84 | | 0.81 | 0.82 | 0.56 | 294 | 0.95 | 0.86 | 0.89 | 0.77 | 310 | 0.87 | 0.77 | 0.81 | 0.61
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Col | 185 | 0.56 | | 0.93 | 0.90 | 0.43 | 292 | 0.73 | 0.95 | 0.91 | 0.69 | 309 | 0.81 | 0.93 | 0.91 | 0.68
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | End | 186 | 0.87 | | 0.83 | 0.84 | 0.64 | 294 | 0.96 | 0.88 | 0.92 | 0.83 | 311 | 0.95 | 0.73 | 0.83 | 0.67
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Kaiser Permanente – northern California
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Fobt | 165 | 0.73 | | 0.86 | 0.85 | 0.29 | 271 | 0.72 | 0.86 | 0.85 | 0.32 | 304 | 0.79 | 0.86 | 0.86 | 0.35
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Sig | 166 | 0.83 | | 0.77 | 0.80 | 0.58 | 271 | 0.80 | 0.77 | 0.78 | 0.53 | 301 | 0.83 | 0.76 | 0.78 | 0.55
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Col | 165 | 0.67 | | 0.88 | 0.87 | 0.36 | 270 | 0.80 | 0.93 | 0.92 | 0.60 | 300 | 0.95 | 0.94 | 0.94 | 0.65
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | end | 165 | 0.93 | | 0.76 | 0.82 | 0.65 | 269 | 0.91 | 0.75 | 0.81 | 0.62 | 299 | 0.91 | 0.76 | 0.82 | 0.63
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | HealthPartners, Minnesota
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Fobt | 4 | NA | | NA | NA | NA | 269 | 0.59 | 0.87 | 0.84 | 0.31 | 287 | 0.55 | 0.81 | 0.78 | 0.23
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Sig | 4 | NA | | NA | NA | NA | 270 | 0.77 | 0.67 | 0.70 | 0.38 | 280 | 0.86 | 0.53 | 0.63 | 0.31
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Col | 4 | NA | | NA | NA | NA | 267 | 0.69 | 0.90 | 0.89 | 0.38 | 280 | 0.73 | 0.87 | 0.86 | 0/30
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | end | 4 | NA | | NA | NA | NA | 267 | 0.85 | 0.64 | 0.71 | 0.43 | 279 | 0.93 | 0.45 | 0.61 | 0.30
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Fobt = fecal occult blood test Sig = flexible sigmoidoscopy Col = colonoscopy End = endoscopy Predictors of agreement between self-reports and medical record audits of crc screening tests, generalized logits models, 1999 – 2001
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Predictor | | Outcome | | | FOBT | | | | Sig | | | | Col
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | | | | | | OR | | 95% CI | | OR | | 95% CI | | OR | | 95% CI
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Age (y)
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | 50 – 59 | | Over | | | 1.69 | | 0.91, 3.13 | | 2.13 | | 1.20, 3.80 | | 6.81 | | 1.62, 28.58
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | 50 – 59 | | Under | | | 1.22 | | 0.34, 4.41 | | 3.98 | | 1.20, 13.19 | | 6.86 | | 0.90, 52.15
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | 60 – 69 | | Over | | | 2.8 | | 1.50, 5.25 | | 3.07 | | 1.70, 5.54 | | 9.29 | | 2.19, 39.42
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | 60 – 69 | | Under | | | 1.9 | | 0.51, 7.05 | | 3.41 | | 0.99, 11.72 | | 9.95 | | 1.27, 77.94
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | 70+ | | Over | | | 2.78 | | 1.46, 5.29 | | 2.85 | | 1.56, 5.19 | | 14.36 | | 3.38, 61.06
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | 70+ | | Under | | | 2.47 | | 0.66, 9.31 | | 4.06 | | 1.18, 13.93 | | 13.91 | | 1.72, 111.45
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Sex/race
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | White/other men | | Over | | | 0.92 | | 0.62, 1.37 | | 0.75 | | 0.52, 1.10 | | 0.51 | | 0.31, 0.83
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | White/other men | | Under | | | 0.74 | | 0.29, 1.90 | | 0.82 | | 0.45, 1.5 | | 0.86 | | 0.40, 1.85
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | women | | Over | | | 0.9 | | 0.60, 1.34 | | 0.91 | | 0.62, 1.32 | | 0.44 | | 0.27, 0.73
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | women | | Under | | | 0.88 | | 0.34, 2.24 | | 0.79 | | 0.43, 1.45 | | 0.34 | | 0.14, 0.81
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Education
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | HS/GED | | Over | | | 0.87 | | 0.54, 1.4 | | 1.48 | | 0.91, 2.39 | | 1.17 | | 0.64, 2.16
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | HS/GED | | Under | | | 1.74 | | 0.49, 6.19 | | 1.42 | | 0.63, 3.24 | | 0.93 | | 0.32, 2.73
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Some college / tech school | | Over | | | 0.73 | | 0.46, 1.16 | | 1.15 | | 0.72, 1.84 | | 0.84 | | 0.46, 1.55
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Some college / tech school | | Under | | | 1.55 | | 0.45, 5.40 | | 1.07 | | 0.48, 2.40 | | 0.92 | | 0.33, 2.56
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | College grad | | Over | | | 0.85 | | 0.54, 1.36 | | 1.24 | | 0.77, 2.00 | | 0.77 | | 0.41, 1.45
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | College grad | | Under | | | 1.6 | | 0.45, 5.70 | | 1.09 | | 0.48, 2.48 | | 0.73 | | 0.25, 2.10
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | ^a^Reference levels for predictors are: age = 40– 49; sex/race group = black men; education = < high school; all analyses are adjusted for site. ^b^Reference level for outcome variable is “agreement” between the survey and medical record. Over = overreport Under = underreport
QUALITY RATING: | Good
Quality Assessment-Internal Validity for Observational Studies
| | | | | | Yes | | | | No | | | | Other (CD, NR, NA)
Were the groups similar at baseline regarding the most important prognostic indicators? | | | | | | | | | | | | | | NA
Were the drop-out or response rates acceptable (≤ 20%)? [If between 20% and 60%, check other and explain.] | | | | | | X | | | | | | | | Cooperation rate 68% Some concern about exclusion criteria (language barrier)
Were the differential drop-out or response rates acceptable (≤ 15%)? | | | | | | | | | | | | | | NA
Were intervention/exposure measures valid, reliable, and equally applied? | | | | | | X
Were the outcome assessors blinded to the intervention or exposure status of subjects? | | | | | | X
Were outcome measures valid, reliable, and equally applied? | | | | | | X
Does the analysis control for baseline differences? | | | | | | X
Were important potential confounding and modifying variables taken into account in the design and analysis (e.g., through matching, stratification, or statistical adjustment)? | | | | | | X
Were the statistical methods used to assess the abstracted outcomes appropriate? | | | | | | X
Quality Rating (Good, Fair, or Poor): Good
STUDY: | Authors, ref ID: Haque et al.103 Year of publication: 2005 Dates of data collection: Trial name: NA
OBJECTIVE OR AIM: | The goal of this study was to develop an automated data algorithm designed to distinguish screening and diagnostic endoscopy (sigmoidoscopy and colonoscopy) exams. The authors assessed the algorithm’s ability to correctly classify the exams using paper medical records as the “gold standard.”
DESIGN: | Setting: Kaiser Permanente Southern California (KPSC) cares for approximately 3 million members, of whom 13% are older than 50 years and targeted for colorectal cancer screening. Automated data tracks outpatient and inpatient care received. Study design: cross-sectional Duration (mean follow-up): Overall study size (N enrolled/N analyzed): Stratified random sample of 220 medical records reviewed.
| [underlined: Had] Colonoscopies | | | | | | | | | Had Sigmoidoscopies_110
Sample size: | 110
Describe intervention:
RECRUITMENT: (population-based, clinic-based, volunteer, other) | HMO based (Kaiser Permanente)
INCLUSION CRITERIA: | Participants included all health plan members between the ages 50 and 70 years, who were continuously enrolled from 1998 to 2002, and completed an endoscopy during those years. Stratified random sample based on the algorithm’s classification. 110 FS, 30 classified as diagnostic and 80 as screening, and 110 COLON, 30 diagnostic and 80 screening.
EXCLUSION CRITERIA: | Participants with a history of colorectal cancer were excluded (N = 1972). Of the 220, 32 excluded due to mismatches in participants endoscopy dates.
POPULATION CHARACTERISTICS: | NA
Mean age & range (years):
Sex (% female):
Race:
Other:
Attrition/Drop-out (not available for endpoint measurement): | NA
Adherence:
Contamination:
Response Rates (e.g. for surveys):
STATISTICAL ANALYSES: | The authors conducted cross-tabulations between the algorithm and medical review classification to examine the sensitivity, specificity, and κ. The classification after medical record review was considered the gold standard. Sensitivity indicates the probability that a diagnostic endoscopy was classified as such by medical records review. Specificity indicates the probability that a nondiagnostic endoscopy was classified as screening. The κ indicates the overall agreement between the two sources.
ASSESSMENT OF EXPOSURES AND POTENTIAL CONFOUNDERS: | NA
OUTCOME ASSESSMENT: | Endoscopies were identified using International Classification of Disease (ICD 9 CM) and Current Procedural Technology-4 codes. In instances in which a participant completed multiple endoscopies in the 5-year period, the authors retrieved data for the first endoscopy. FOBT (due to poor sensitivity) and BE (due to infrequent use) were not included in the study. The algorithm used automated data to presumptively classify the endoscopies as diagnostic or screening. Endoscopies were classified as diagnostic if automated data included certain gastrointestinal conditions in the year prior to the exam, or signs or symptoms or a FOBT in the 45 days prior. The study gastroenterologist (KRM) identified the conditions and signs and symptoms likely to result in diagnostic endoscopies. All other endoscopies were classified into the screening group. Two trained abstractors reviewed medical records from 1997 to 2002 to confirm endoscopy use. The abstractors also assessed screening or diagnostic indications for the endoscopies, including the presence of gastrointestinal conditions or signs and symptoms. To minimize interrater variability, one abstractor reviewed all participants’ medical records classified as a diagnostic exam while the second reviewed all participants’ medical records classified as a screening exam. Abstractors classified the endoscopies as diagnostic if the exam was a follow-up to a previous abnormality or when clear-cut conditions or signs and symptoms were present, using the same list and time frames as the algorithm. All other endoscopies were classified as screening.
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | NA
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and follow- up? | NA
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | The sensitivities for identifying diagnostic sigmoidoscopy and colonoscopy were 48.1% and 23.8%, respectively. The algorithm missed most of the diagnostic endoscopies. Conversely, the sensitivities for identifying screening sigmoidoscopy and colonoscopy were high (87.9% and 84.4%, respectively) but were associated with low specificities. Comparison of classification by automated algorithm versus medical record review
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | | | Classification by medical record review
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Classification by automated algorithm | | Diagnostic (n = 90) | | | Screening (n=98) | | % sensitivity | | % specificity | | | | kappa
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Sigmoidoscopy
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Diagnostic | | 13 | | | 8 | | 48.1 (13/27) | | 12.1 (8/66) | | | | 76.3
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Screening | | 14 | | | 58 | | 87.9 (58/66) | | 51.9 (14/27)
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Total | | 27 | | | 66
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Colonoscopy
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Diagnostic | | 15 | | | 5 | | 23.8 (15/63) | | 15.6 (5/32) | | | | 44.2
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Screening | | 48 | | | 27 | | 84.4 (27/32) | | 76.2 (48/63)
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Total | | 63 | | | 32
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | The authors conclude that studies relying solely on automated data overestimate screening rates if indication is not considered. They also conclude that the automated algorithm needs further improvements to better differentiate screening from diagnostic exams.
QUALITY RATING: | Fair
Quality Assessment-Internal Validity for Observational Studies
| | | | | | Yes | | | | No | | | | Other (CD, NR, NA)
Were the groups similar at baseline regarding the most important prognostic indicators?
Were the drop-out or response rates acceptable (≤ 20%)? [If between 20% and 60%, check other and explain.]
Were the differential drop-out or response rates acceptable (≤ 15%)?
Were intervention/exposure measures valid, reliable, and equally applied? | | | | | | X | | | | | | | | Algorithm developed by investigator
Were the outcome assessors blinded to the intervention or exposure status of subjects? | | | | | | | | | | X
Were outcome measures valid, reliable, and equally applied? | | | | | | | | | | X | | | | Medical chart review—single person review. Little detail on training provided, no IRR assessment done
Does the analysis control for baseline differences?
Were important potential confounding and modifying variables taken into account in the design and analysis (e.g., through matching, stratification, or statistical adjustment)?
Were the statistical methods used to assess the abstracted outcomes appropriate?
Were data inputs valid? | | | | | | X
Was an appropriate search strategy used to find data inputs? | | | | | | | | | | X | | | | Does not say how charts used were randomly selected
Were the calculations and statistical analyses adequate? | | | | | | X
Were appropriate sensitivity analyses conducted (especially for any variables that were not based on data from literature)?
Other considerations: | | | | | | X
Quality Rating (Good, Fair, or Poor): Fair
STUDY: Yield of claims data and surveys for determining cancer screening among health plan members | Authors, ref ID: Pignone et al 104 Year of publication: 2009 Dates of data collection: Trial name: CHOICE
OBJECTIVE OR AIM: | To evaluate the independent and combined yield of claims and direct survey for identifying colorectal cancer screening among average risk health plan beneficiaries.
DESIGN: | Setting: 32 Primary care practices in Georgia, Florida taking part in a randomized trial of a CRC decision aid and practice-level academic detailing Study design: Observational Duration (mean followup): 2005-2007 Overall study size (N enrolled/N analyzed): 2558/1595 (responded to survey)
| [underlined: Group 1]
Sample size: | 1595
Describe intervention: | none
RECRUITMENT: (population-based, clinic-based, volunteer, other) | Claims data from Aetna
INCLUSION CRITERIA: | Members with ages between 52 and 80 years whose primary care physicians had agreed to participate in the CHOICE study
EXCLUSION CRITERIA: | Individuals at increased risk for colorectal cancer (because the intervention was designed for average-risk patients) or with medical conditions that would limit their ability to participate in the study or who might not be considered reasonable candidates for screening. Above average-risk persons were defined as adults with a personal history of colorectal cancer or polyps, a known history of colorectal cancer or polyps in a first-degree relative, or a known history of inflammatory bowel disease also, dementia, chronic obstructive pulmonary disease, heart failure, coronary artery disease, current treatment for cancer or history of metastatic cancer, cirrhosis, upper or lower gastrointestinal bleeding, unintentional weight loss of >10% within 6 months, blindness, or uncorrectable hearing impairment. To be excluded, the individual had to have at least two claims with either a diagnosis or procedure code indicating that they had one of these additional conditions.
POPULATION CHARACTERISTICS: | [underlined: Group 1]
Mean age & range (years): | Age group 52-59 887 (69.90) 60-64 283 (22.30) 65-69 81 (6.38) 70-82 18 (1.42)
Sex (% female): | % female 60%
Race: | 75% white/ 19% black/ 6% other
Other:
Attrition/Drop-out (not available for endpoint measurement): | Overall
Adherence:
Contamination:
Response Rates (e.g. for surveys): | Response rate was 62%
STATISTICAL ANALYSES: | Describe: Descriptive analyses, logistic regression and examination of confounders
ASSESSMENT OF EXPOSURES AND POTENTIAL CONFOUNDERS: | Yes
OUTCOME ASSESSMENT: | Outcome Measures: primary outcome was proportion of persons up to date with CRC screening Survey asked about individuals completion of CRC screening, whether even had and when tests were conducted Claims data on CRC screening, including FOBT (within 1 year), FS (5 years), colonoscopy (10 years) or BE (5 years), including most recent data for each type. Indication for the procedure was not specified.
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | NA
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | NA
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Outcomes: • Of 4,020 average-risk members identified, claims data indicated that 1,066 (27%) had recent colorectal cancer screening. Among the 1,269 average risk members with no evidence of screening by claims data who returned surveys, 498 (39%) reported being up-to-date with screening. • Combining claims data and survey data: • Prevalence of CRC screening, combining claims data plus self-reported data (and not including nonresponders to the survey): 47% • Prevalence of CRC screening, combining claims data plus self-reported data (assuming nonresponders were screened at the same rate as average-risk responders): 59%
QUALITY RATING: | Fair
Quality Assessment-Internal Validity for Observational Studies
| | | | | | Yes | | | | No | | | | Other (CD, NR, NA)
Were the groups similar at baseline regarding the most important prognostic indicators? | | | | | | | | | | | | | | NA
Were the drop-out or response rates acceptable (≤20%)? [If between 20% and 60%, check other and explain.] | | | | | | x | | | | | | | | 62% response rate
Were the differential drop-out or response rates acceptable (≤15%)? | | | | | | | | | | | | | | Not known
Were intervention/exposure measures valid, reliable, and equally applied? | | | | | | | | | | | | | | NA
Were the outcome assessors blinded to the intervention or exposure status of subjects? | | | | | | | | | | | | | | NA
Were outcome measures valid, reliable, and equally applied? | | | | | | x | | | | | | | | However, screening vs. diagnostic procedures were not distinguished
Does the analysis control for baseline differences? | | | | | | | | | | | | | | NA
Were important potential confounding and modifying variables taken into account in the design and analysis (e.g., through matching, stratification, or statistical adjustment)? | | | | | | | | | | | | | | NA
Were the statistical methods used to assess the abstracted outcomes appropriate? | | | | | | x
Quality Rating (Good, Fair, or Poor): Fair
STUDY: Data sources for measuring colorectal endoscopy use among Medicare enrollees Evaluation of claims, medical records, and self-report for measuring fecal occult blood testing among Medicare enrollees in fee for service | Authors, ref ID: Schenck 105–106 Year of publication: 2007 and 2008 Dates of data collection: 1998–2002 Trial name:
OBJECTIVE OR AIM: | Comparison of different data sources used for measuring CRC testing
DESIGN: | Setting: Study design: Observational Duration (mean followup): Brief Overall study size (N enrolled/N analyzed): 936 eligible 561 analyzed
| [underlined: Overall]
Sample size: | 561
Describe intervention: NA | endoscopy and FOBT
RECRUITMENT: (population-based, clinic-based, volunteer, other) | Population – NC Medicare patients from 10 different counties
INCLUSION CRITERIA: | North Carolina Medicare enrollees, African American or white, in fee for service Medicare, between ages 55 and 80 without history of CRC, who had responded to a 2002 survey.
EXCLUSION CRITERIA: | HMO coverage or gap in coverage
POPULATION CHARACTERISTICS: | [underlined: Overall]
Mean age & range (years): | 50–64 10.5% 65–74 62.7% 75–80 26.8%
Sex (% female): | 61% female
Race: | African American 23.5% White 76.5%
Attrition/Drop-out (not available for endpoint measurement): | Overall – NA
Adherence:
Contamination:
Response Rates (e.g. for surveys): | Response rate to survey not reported. Sample consisted of 1001 persons who had responded to the survey.
STATISTICAL ANALYSES: | Describe: descriptive statistics, report to record ratio to detect bias, concordance amongst sources
ASSESSMENT OF EXPOSURES AND POTENTIAL CONFOUNDERS: | No
OUTCOME ASSESSMENT: | Outcome Measures: • Sigmoidoscoy, colonoscopy and FOBT (both at home and in office) • Ever use of an endoscopic procedure measured by survey, and date of most recent (outcome of FS in last 4 years and colonscopy in last 5 years) • FOBT, distinguishing in office from home, and whether test was part of a check up or because of a problem, from survey • Medical record review (using a hierarchical algorithm to link the patient to a provider) to record date of endoscopic procedure, and whether screening or diagnostic; and dates of four most recent FOBTs • Claims (1/1998–12/2002) data using Medicare inpatient, outpatient, and physician claims. Screening and diagnostic codes were available.
RESULTS:
KQ2 - What factors influence the use of colorectal cancer screening? | Outcomes: NA
KQ3 - Which strategies are effective in increasing the appropriate use of colorectal cancer screening and followup? | Outcomes: NA
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | Outcomes: NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Outcomes: %
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | | | | | | Self report | | | | Claim | | | | Medical record
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Sigmoidoscopy | | | | | 22.8 | | | | 21.6 | | | | 15.2
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Colonoscopy | | | | | 38.5 | | | | 35.1 | | | | 34.1
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Endoscopy | | | | | 50.1 | | | | 44.9 | | | | 42.3
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | In last 5 yrs | | | | | NR | | | | NR
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | FOBT- home | | | | | | | | | | | | | 30.1
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | FOBT office | | | | | | | | | | | | | 31.4
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | FOBT in last year | | | | | 28.7 | | | | 21.2 | | | | 19.4
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | FOBT in last 2 years | | | | | 44.0 | | | | 34.2 | | | | 29.2
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Prevalence of endoscopy in the past year Overall: Survey 50.1 Administrative 44.9 Medical record review 42.3 By sociodemographic characteristics: Age 55–64; 65–74; 65–80 Survey 50.8; 52.4; 44.0 Administrative 35.6; 43.9; 50.7 Medical record review 32.2; 40.7; 50.0 All African Americans; all whites; all women, all men: Survey 40.9; 52.9; 46.8; 55.3 Administrative 41.7; 45.9; 43.6; 47.0 Medical record review 42.4; 42.2; 42.7; 41.6 Less than high school; high school diploma; more than high school: Survey 28.7; 46.9; 59.8 Administrative 39.4; 45.9; 45.8 Medical record review 38.3; 41.8; 43.6 Prevalence of FOBT in the past year Overall: Survey 28.7 Administrative 21.2 Medical record review: 19.4 By sociodemographic characteristics: Age 55–64; 65–74; 65–80 Survey 35.2; 27.9; 28.4 Administrative 19.3; 21.0; 23.6 Medical record review: 19.3; 19.8; 19.6 All African Americans; all whites; all women, all men Survey 32.0; 27.8; 30.6; 25.9 Administrative 18.8; 22.4; 25.5; 15.3 Medical record review: 12.5; 21.9; 21.7; 16.7 Less than high school; high school diploma; more than high school Survey 26.6; 26.0; 31.6 Administrative 20.2; 20.4; 22.8 Medical record review: 19.1; 16.3; 22.4 Measures of concordance for endoscopy use Administrative to medical record review Agreement: 95 (93–97) Kappa: 0.89 (0.81–0.98) Self-report to medical record review Agreement: 70 (66–73) Kappa: 0.39 (0.31–0.47) Self-report to administrative Agreement: 70 (66–74) Kappa: 0.40 (0.32–0.49) Agreement regarding test type (FS or colonoscopy) Claims to medical record review: 93 (88–97) Self-report to medical record review: 82 (75–89) Self-report to claims: 77 (70–85) Agreement regarding test purpose (screening or diagnostic): Administrative to medical record review: 52 (43–61) Self-report to medical record review: 65 (55–74) Self-report to administrative: 29 (20–36) Measures of concordance for FOBT Administrative to medical record review Agreement: 82 (79–85) Self-report to medical record review Agreement: 70 (66–74) Self-report to administrative Agreement: 67 (63–71) Sensitivity analyses included: excluding claims of FOBT on day of medical visit; including all medical record review of FOBTs (likely including in-office, single card FOBTs with digital rectal exams); did not appreciably change the measures
QUALITY RATING: | Good
Quality Assessment-Internal Validity for Observational Studies
| | | | | | Yes | | | | No | | | | Other (CD, NR, NA)
Were the groups similar at baseline regarding the most important prognostic indicators? | | | | | | | | | | | | | | NA
Were the drop-out or response rates acceptable (≤20%)? [If between 20% and 60%, check other and explain.] | | | | | | | | | | | | | | Survey response not recorded; possibility that non respondents to survey would be different in some way to alter agreement between a survey response and medical records/chart review
Were the differential drop-out or response rates acceptable (≤15%)? | | | | | | | | | | | | | | NA
Were intervention/exposure measures valid, reliable, and equally applied? | | | | | | | | | | | | | | NA
Were the outcome assessors blinded to the intervention or exposure status of subjects? | | | | | | | | | | | | | | NA
Were outcome measures valid, reliable, and equally applied? | | | | | | x
Does the analysis control for baseline differences? | | | | | | | | | | | | | | NA
Were important potential confounding and modifying variables taken into account in the design and analysis (e.g., through matching, stratification, or statistical adjustment)? | | | | | | | | | | | | | | NA
Were the statistical methods used to assess the abstracted outcomes appropriate? | | | | | | x
Quality Rating (Good, Fair, or Poor): Good
STUDY: | Authors, ref ID: Schneider EC, et al.107 Year: 2008 Trial Name:
RESEARCH OBJECTIVE OR AIM: | Evaluate quality measures by describing a field test of the colorectal cancer screening measure included in the Health Plan Employer Data and Information Set of the National Committee for Quality Assurance –
DESIGN: | Setting: 5 geographically dispersed healthcare plans that enrolled 189,193 considered eligible for CRC screening Study design: Observational Duration (mean follow-up): Overall study size (N enrolled/N analyzed): 1000 plus an additional random sample of 400 enrollees from the original health care plan cohort (3000 enrollees)
INTERVENTIONS: | NA
Sample size:
Describe intervention:
RECRUITMENT: (population-based, clinic-based, volunteer, other) | Each of the 5 enrolled health plans identified all enrollees > 51 y/o, sent this to RAND Corp for further analysis. Research staff at RAND Corp. randomly selected 1000 enrollees (200 per plan) who lacked evidence of CRC screening (based on administrative data). Then, medical record abstractors looked for evidence of CRC screening in these pts. Health plan also surveyed patients via mail. During a 6 week period, nonrespondents received 3 survey mailings + a reminder postcard and a final overnight mailing. Response rate was 48.1% (range 37.8% – 57.5%
INCLUSION CRITERIA: | > or = 51 y/o continuously enrolled for at least 2 years in one of the 5 health plans
EXCLUSION CRITERIA: | NR
POPULATION CHARACTERISTICS: | Survey respondents older, longer enrollment Survey respondents more likely than non respondents to have evidence of CRC screening
Mean age & range (years):
Sex (% female):
Ethnicity:
Other:
OUTCOME ASSESSMENT: | | | | | | Plan A | | Plan B | | Plan C | | Plan D | | Plan E
OUTCOME ASSESSMENT: | Age of plan, y | | | | | 53 | | 19 | | 17 | | 17 | | 17
OUTCOME ASSESSMENT: | Submitted cohort aged 51–80 and enrolled continuously for 2 years | | | | | 65,241 | | 68,659 | | 28,564 | | 3,561 | | 23,168
OUTCOME ASSESSMENT: | Age, mean, y | | | | | 64.2 | | 60.9 | | 59.7 | | 58.8 | | 57.4
OUTCOME ASSESSMENT: | Female, % | | | | | 54.1% | | 53.0 | | 51.4 | | 52.8 | | 51.4
OUTCOME ASSESSMENT: | Enrollment, mo | | | | | 73.3 | | NA | | 69.1 | | 83.1 | | 46.8
OUTCOME ASSESSMENT: | Survey rspndts | | | | | N=1250
OUTCOME ASSESSMENT: | Age, mean, y | | | | | 65.9 | | 60.4 | | 60.9 | | 59.4 | | 56.8
OUTCOME ASSESSMENT: | Female, % | | | | | 58.9 | | 51.7 | | 50.2 | | 54.7 | | 51.3
OUTCOME ASSESSMENT: | Enrollment, mo | | | | | 76.5 | | NA | | 75.5 | | 86.4 | | 48.3
OUTCOME ASSESSMENT: | Survey nonrespondents | | | | | N=1349
OUTCOME ASSESSMENT: | Age, mean, y | | | | | 64.6 | | 60.3 | | 59.9 | | 58.8 | | 56.7
OUTCOME ASSESSMENT: | Female, % | | | | | 54.2 | | 50.7 | | 52.0 | | 51.8 | | 49.3
OUTCOME ASSESSMENT: | Enrollment, | | | | | 81.8 | | NA | | 72.0 | | 82.6 | | 48.5
OUTCOME ASSESSMENT: | The authors defined, for each data source (administrative, medical record, and survey results), the data elements needed to implement all of the measure specifications. The authors developed a list of outpatient diagnosis codes that represent a prior diagnosis of colorectal cancer, CPT codes related to an acceptable screening procedure, and historical CPT codes used within the previous 10 years. For the medical record method, the authors designed an abstraction tool to collect data on screening tests, clinical risk factors for colorectal cancer, and evidence of limited life expectancy and trained experienced nurses from each health care plan during a pilot test of the abstraction protocol using a common set of records. For the enrollee survey, the authors developed a sequence of questions (based on the Behavioral Risk Factor Surveillance System) that addressed each of the screening tests, the time frames in which they occurred, and a measure of risk status based on report of a family history of colorectal cancer. Data from all sources (administrative, survey, and medical record) were linked at the enrollee level to create a single analytic file. For each of the 4 colorectal screening tests, the authors compared across health care plans the percentage of sampled enrollees identified as screened based on administrative data and the percentage based on survey data. The authors could not determine the percentage screened by each test under the hybrid method because medical record abstractors were instructed to stop after identifying the occurrence of 1 of the tests. For the single measure that combined all tests, the authors calculated colorectal cancer screening performance scores based on administrative data only, survey data only, and combined administrative and medical record data (the hybrid method), weighing the medical record sample to represent the population from which they were drawn (unscreened based on administrative data).. Among the survey respondents, the authors assessed agreement of the sampled enrollees’ screening status according to the survey data and the hybrid data. The authors compared the rate of screening among survey respondents and nonrespondents using the hybrid estimation procedure.
RESULTS:
KQ4 - What are the current and projected capacities to deliver colorectal cancer screening and surveillance at the population level? | NA
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Compared with survey non-respondents, respondents were older (60.4 vs. 59.4 years; P_.001) and had longer enrollment (73.3 vs. 67.6 months; P = .001), but the 2 groups had similar percentages of female participants (53.3% vs. 51.1%; P = .28). Survey respondents were more likely than non-respondents to have evidence of CRC screening (62.7% vs. 46.5%; p<0.001) The percentage of enrollees having specific tests varied between the administrative and survey data methods. In health care plans A and E, the percentages of enrollees screened by FOBT according to the 2 methods were similar; in health care plan B, the percentage based on survey data was nearly twice that based on administrative data; and in health care plan C, the percentage based on administrative data exceeded that based on survey data. For the procedural tests (flexible sigmoidoscopy, doublecontrast barium enema, and colonoscopy), the rates based on survey data were 2 to 3 times higher than the rates based on administrative data.
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Method | | | | | Plan A | | Plan B | | Plan C | | Plan D | | Plan E
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | FOBT
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Administrative | | | | | 23.6 | | 15.0 | | 31.1 | | NA | | 24.7
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Survey | | | | | 25.4 | | 26.3 | | 20.5 | | 21.8 | | 25.1
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Flex Sig
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Administrative | | | | | 14.2 | | 17.9 | | 18.4 | | 15.3 | | 15.4
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Survey | | | | | 29.7 | | 39.6 | | 33.9 | | 33.6 | | 30.6
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | COLON
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Administrative | | | | | 12.8 | | 12.1 | | 9.4 | | 10.5 | | 14.2
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Survey | | | | | 19.9 | | 39.0 | | 33.6 | | 33.7 | | 40.7
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Using the single measure of screening (based on any 1 of the 4 tests), the percentage of enrollees with evidence of colorectal cancer screening varied substantially depending on the data sources used. For 4 of the 5 health care plans, the hybrid method produced a higher screening rate than the administrative data method. The difference ranged from 0 (health care plan A) to 14.9 (health care plan B) percentage points. For all 5 health care plans, the survey data method produced a higher calculated screening rate than the other 2 methods.
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Method | | | | | Plan A | | Plan B | | Plan C | | Plan D | | Plan E
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Administrative | | | | | 41.5 (41.1–41.9) | | 38.6 (38.2–38.9) | | 47.1 (46.5–47.6) | | 27.3 (25.8–28.7) | | 44.4 (43.8–45.1)
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Survey | | | | | 53.2 (42.1–64.4) | | 69.7 (60.3–79.2) | | 55.0 (41.1–68.8) | | 62.1 (53.8–70.4) | | 66.2 (57.1–75.2)
KQ5 - What are the effective approaches for monitoring the use and quality of colorectal cancer screening? | Hybrid | | | | | 41.5 (41.1–41.9) | | 53.5 (48.5–56.8) | | 52.6 (48.3–56.8) | | 38.8 (34.3–43.4) | | 45.6 (44.0–47.2)
ANALYSIS:
ARE GROUPS COMPARABLE AT BASELINE:
ASCERTAINMENT METHODS ADEQUATE AND EQUALLY APPLIED:
STATISTICAL ANALYIS ADEQUATE:
ATTRITION: | NA
Dropout (not available for endpoint measurement):
Adherence in control group:
Contamination in control group:
Differential dropouts:
QUALITY RATING: | Fair
Quality Assessment-Internal Validity for Observational Studies
| | | | | | Yes | | | | No | | | | Other (CD, NR, NA)
Were the groups similar at baseline regarding the most important prognostic indicators?
Were the drop-out or response rates acceptable (≤ 20%)? [If between 20% and 60%, check other and explain.] | | | | | | | | | | | | | | RR varied among plans from 38% to 58%
Were the differential drop-out or response rates acceptable (≤ 15%)?
Were intervention/exposure measures valid, reliable, and equally applied? | | | | | | X
Were the outcome assessors blinded to the intervention or exposure status of subjects?
Were outcome measures valid, reliable, and equally applied? | | | | | | X | | | | | | | | Questions Based on BRFSS
Does the analysis control for baseline differences?
Were important potential confounding and modifying variables taken into account in the design and analysis (e.g., through matching, stratification, or statistical adjustment)?
Were the statistical methods used to assess the abstracted outcomes appropriate? | | | | | | | | | | | | | | Very specific purpose to this study to compare results of 3 different methods of estimating overall screening rates. Hence outcomes not directly comparable to other studies.
Quality Rating (Good, Fair, or Poor): Fair

## References

1 Afable-Munsuz A, Liang SY, Ponce NA, et al. Acculturation and colorectal cancer screening among older Latino adults: differential associations by national origin. J Gen Intern Med. Aug. 2009;24(8):963-70. [pmid: 19472016].
2 Ananthakrishnan AN, Schellhase KG, Sparapani RA, et al. Disparities in colon cancer screening in the Medicare population. Arch Intern Med. Feb 12. 2007;167(3):258-64. [pmid: 17296881].
3 Ata A, Elzey JD, Insaf TZ, et al. Colorectal cancer prevention: adherence patterns and correlates of tests done for screening purposes within United States populations. Cancer Detect Prev. 2006;30(2):134-43. [pmid: 16638628].
4 Atlas SJ, Grant RW, Ferris TG, et al. Patient-physician connectedness and quality of primary care. Ann Intern Med. Mar 3. 2009;150(5):325-35. [pmid: 19258560].
5 Berkowitz Z, Hawkins NA, Peipins LA, et al. Beliefs, risk perceptions, and gaps in knowledge as barriers to colorectal cancer screening in older adults. J Am Geriatr Soc. Feb. 2008;56(2):307-14. [pmid: 18070002].
6 Cardarelli R, Thomas JE. Having a personal health care provider and receipt of colorectal cancer testing. Ann Fam Med. Jan‐Feb. 2009;7(1):5-10. [pmid: 19139443].
7 Cairns CP, Viswanath K. Communication and colorectal cancer screening among the uninsured: data from the Health Information National Trends Survey (United States). Cancer Causes Control. Nov. 2006;17(9):1115-25. [pmid: 17006717].
8 Carcaise-Edinboro P, Bradley CJ. Influence of patient-provider communication on colorectal cancer screening. Med Care. Jul. 2008;46(7):738-45. [pmid: 18580394].
9 Carlos RC, Fendrick AM, Ellis J, et al. Can breast and cervical cancer screening visits be used to enhance colorectal cancer screening?. J Am Coll Radiol. Oct. 2004;1(10):769-76. [pmid: 17411698].
10 Carlos RC, Fendrick AM, Patterson SK, et al. Associations in breast and colon cancer screening behavior in women. Acad Radiol. Apr. 2005;12(4):451-8. [pmid: 15831418].
11 Christman LK, Abdulla R, Jacobsen PB, et al. Colorectal cancer screening among a sample of community health center attendees. J Health Care Poor Underserved. May. 2004;15(2):281-93. [pmid: 15253379].
12 Coughlin SS, Thompson T. Physician recommendation for colorectal cancer screening by race, ethnicity, and health insurance status among men and women in the United States, 2000. Health Promot Pract. Oct. 2005;6(4):369-78. [pmid: 16210678].
13 Diaz JA, Roberts MB, Goldman RE, et al. Effect of language on colorectal cancer screening among Latinos and non-Latinos. Cancer Epidemiol Biomarkers Prev. Aug. 2008;17(8):2169-73. [pmid: 18708410].
14 Etzioni DA, Ponce NA, Babey SH, et al. A population-based study of colorectal cancer test use: results from the 2001 California Health Interview Survey. Cancer. Dec 1. 2004;101(11):2523-32. [pmid: 15505783].
15 Fenton JJ, Cai Y, Weiss NS, et al. Delivery of cancer screening: how important is the preventive health examination?. Arch Intern Med. Mar 26. 2007;167(6):580-5. [pmid: 17389289].
16 Ferrante JM, Ohman-Strickland P, Hudson SV, et al. Colorectal cancer screening among obese versus non-obese patients in primary care practices. Cancer Detect Prev. 2006;30(5):459-65. [pmid: 17067753].
17 Fisher DA, Jeffreys A, Coffman CJ, et al. Barriers to full colon evaluation for a positive fecal occult blood test. Cancer Epidemiol Biomarkers Prev. Jun. 2006;15(6):1232-5. [pmid: 16775188].
18 Fox SA, Heritage J, Stockdale SE, et al. Cancer screening adherence: does physician-patient communication matter?. Patient Educ Couns. May. 2009;75(2):178-84. [pmid: 19250793].
19 Garman KS, Jeffreys A, Coffman C, et al. Colorectal cancer screening, comorbidity, and follow-up in elderly patients. Am J Med Sci. Oct. 2006;332(4):159-63. [pmid: 17031239].
20 Gilbert A, Kanarek N. Colorectal cancer screening: physician recommendation is influential advice to Marylanders. Prev Med. Aug. 2005;41(2):367-79. [pmid: 15917034].
21 Goel MS, Wee CC, McCarthy EP, et al. Racial and ethnic disparities in cancer screening: the importance of foreign birth as a barrier to care. J Gen Intern Med. Dec. 2003;18(12):1028-35. [pmid: 14687262].
22 Gupta S, Tong L, Allison JE, et al. Screening for colorectal cancer in a safety-net health care system: access to care is critical and has implications for screening policy. Cancer Epidemiol Biomarkers Prev. Sep. 2009;18(9):2373-9. [pmid: 19745221].
23 Heo M, Allison DB, Fontaine KR. Overweight, obesity, and colorectal cancer screening: disparity between men and women. BMC Public Health. Nov 8. 2004;4:53. [pmid: 15533259].
24 Honda K, Kagawa-Singer M. Cognitive mediators linking social support networks to colorectal cancer screening adherence. J Behav Med. Oct. 2006;29(5):449-60. [pmid: 16958004].
25 Hudson SV, Ohman-Strickland P, Cunningham R, et al. The effects of teamwork and system support on colorectal cancer screening in primary care practices. Cancer Detect Prev. 2007;31(5):417-23. [pmid: 18031947].
26 Janz NK, Wren PA, Schottenfeld D, et al. Colorectal cancer screening attitudes and behavior: a population-based study. Prev Med. Dec. 2003;37(6 Pt 1):627-34. [pmid: 14636796].
27 Jerant AF, Arellanes RE, Franks P. Factors associated with Hispanic/non-Hispanic white colorectal cancer screening disparities. J Gen Intern Med. Aug. 2008;23(8):1241-5. [pmid: 18500503].
28 Jerant AF, Fenton JJ, Franks P. Determinants of racial/ethnic colorectal cancer screening disparities. Arch Intern Med. Jun 23. 2008;168(12):1317-24. [pmid: 18574089].
29 Katz ML, James AS, Pignone MP, et al. Colorectal cancer screening among African American church members: a qualitative and quantitative study of patient-provider communication. BMC Public Health. Dec 15. 2004;4:62. [pmid: 15601463].
30 Klabunde CN, Vernon SW, Nadel MR, et al. Barriers to colorectal cancer screening: a comparison of reports from primary care physicians and average-risk adults. Med Care. Sep. 2005;43(9):939-44. [pmid: 16116360].
31 Koroukian SM, Litaker D, Dor A, et al. Use of preventive services by Medicare fee-for‐service beneficiaries: does spillover from managed care matter?. Med Care. May. 2005;43(5):445-52. [pmid: 15838408].
32 Koroukian SM, Xu F, Dor A, et al. Colorectal cancer screening in the elderly population: disparities by dual Medicare-Medicaid enrollment status. Health Serv Res. Dec. 2006;41(6):2136-54. [pmid: 17116113].
33 Lemon S, Zapka J, Puleo E, et al. Colorectal cancer screening participation: comparisons with mammography and prostate-specific antigen screening. Am J Public Health. Aug. 2001;91(8):1264-72. [pmid: 11499116].
34 Levy BT, Dawson J, Hartz AJ, et al. Colorectal cancer testing among patients cared for by Iowa family physicians. Am J Prev Med. Sep. 2006;31(3):193-201. [pmid: 16905029].
35 Ling BS, Klein WM, Dang Q. Relationship of communication and information measures to colorectal cancer screening utilization: results from HINTS. J Health Commun. 2006;11(Suppl 1):181-90. [pmid: 16641083].
36 Matthews BA, Nattinger AB, Venkatesan T, et al. Colorectal cancer screening among midwestern community-based residents: indicators of success. J Community Health. Apr. 2007;32(2):103-20. [pmid: 17571524].
37 McQueen A, Vernon SW, Meissner HI, et al. Are there gender differences in colorectal cancer test use prevalence and correlates?. Cancer Epidemiol Biomarkers Prev. Apr. 2006;15(4):782-91. [pmid: 16614124].
38 Messina CR, Lane DS, Colson RC. Colorectal cancer screening among users of county health centers and users of private physician practices. Public Health Rep. Jul–Aug. 2009;124(4):568-78. [pmid: 19618794].
39 Muus KJ, Baker-Demaray T, McDonald LR, et al. Body mass index and cancer screening in older American Indian and Alaska Native men. J Rural Health. Winter. 2009;25(1):104-8. [pmid: 19166569].
40 Nguyen BH, McPhee SJ, Stewart SL, et al. Colorectal cancer screening in Vietnamese Americans. J Cancer Educ. Jan‐Mar. 2008;23(1):37-45. [pmid: 18444045].
41 O'Malley AS, Forrest CB, Mandelblatt J. Adherence of low-income women to cancer screening recommendations. J Gen Intern Med. Feb. 2002;17(2):144-54. [pmid: 11841530].
42 O'Malley AS, Forrest CB, Feng S, et al. Disparities despite coverage: gaps in colorectal cancer screening among Medicare beneficiaries. Arch Intern Med. Oct 10. 2005;165(18):2129-35. [pmid: 16217003].
43 Peterson NB, Murff HJ, Ness RM, et al. Colorectal cancer screening among men and women in the United States. J Womens Health (Larchmt). Jan–Feb. 2007;16(1):57-65. [pmid: 17324097].
44 Pham HH, Schrag D, Hargraves JL, et al. Delivery of preventive services to older adults by primary care physicians. JAMA. Jul 27. 2005;294(4):473-81. [pmid: 16046654].
45 Rosen AB, Schneider EC. Colorectal cancer screening disparities related to obesity and gender. J Gen Intern Med. Apr. 2004;19(4):332-8. [pmid: 15061742].
46 Schenck AP, Klabunde CN, Davis WW. Racial differences in colorectal cancer test use by Medicare consumers. Am J Prev Med. Apr. 2006;30(4):320-6. [pmid: 16530619].
47 Schneider EC, Rosenthal M, Gatsonis CG, et al. Is the type of Medicare insurance associated with colorectal cancer screening prevalence and selection of screening strategy?. Med Care. Sep. 2008;46(9 Suppl 1):S84-90. [pmid: 18725838].
48 Schootman M, Jeffe DB, Baker EA, et al. Effect of area poverty rate on cancer screening across US communities. J Epidemiol Community Health. Mar. 2006;60(3):202-7. [pmid: 16476748].
49 Schumacher MC, Slattery ML, Lanier AP, et al. Prevalence and predictors of cancer screening among American Indian and Alaska native people: the EARTH study. Cancer Causes Control. Sep. 2008;19(7):725-37. [pmid: 18307048].
50 Seeff LC, Nadel MR, Klabunde CN, et al. Patterns and predictors of colorectal cancer test use in the adult U.S. population. Cancer. May 15. 2004;100(10):2093-103. [pmid: 15139050].
51 Shah M, Zhu K, Potter J. Hispanic acculturation and utilization of colorectal cancer screening in the United States. Cancer Detect Prev. 2006;30(3):306-12. [pmid: 16872756].
52 Shapiro JA, Seeff LC, Thompson TD, et al. Colorectal cancer test use from the 2005 National Health Interview Survey. Cancer Epidemiol Biomarkers Prev. Jul. 2008;17(7):1623-30. [pmid: 18628413].
53 Shih YC, Zhao L, Elting LS. Does Medicare coverage of colonoscopy reduce racial/ethnic disparities in cancer screening among the elderly?. Health Aff (Millwood). Jul–Aug. 2006;25(4):1153-62. [pmid: 16835198].
54 Shih YC, Elting LS, Levin B. Disparities in colorectal screening between US-born and foreign-born populations: evidence from the 2000 National Health Interview Survey. J Cancer Educ. Jan–Mar. 2008;23(1):18-25. [pmid: 18444042].
55 Sun WY, Basch CE, Wolf RL, et al. Factors associated with colorectal cancer screening among Chinese-Americans. Prev Med. Aug. 2004;39(2):323-9. [pmid: 15226041].
56 Thompson B, Coronado G, Chen L, et al. Celebremos la salud! a community randomized trial of cancer prevention (United States). Cancer Causes Control. Jun. 2006;17(5):733-46. [pmid: 16633921].
57 Thompson B, Coronado G, Neuhouser M, et al. Colorectal carcinoma screening among Hispanics and non-Hispanic whites in a rural setting. Cancer. Jun. 15. 2005;103(12):2491-8. [pmid: 15880744].
58 Thompson B, Coronado GD, Solomon CC, et al. Cancer prevention behaviors and socioeconomic status among Hispanics and non-Hispanic whites in a rural population in the United States. Cancer Causes Control. Oct. 2002;13(8):719-28. [pmid: 12420950].
59 Thorpe LE, Mostashari F, Hajat A, et al. Colon cancer screening practices in New York City, 2003: results of a large random-digit dialed telephone survey. Cancer. Sep 1. 2005;104(5):1075-82. [pmid: 16044401].
60 Trivers KF, Shaw KM, Sabatino SA, et al. Trends in colorectal cancer screening disparities in people aged 50–64 years, 2000–2005. Am J Prev Med. Sep. 2008;35(3):185-93. [pmid: 18617355].
61 Walsh JM, Kaplan CP, Nguyen B, et al. Barriers to colorectal cancer screening in Latino and Vietnamese Americans. Compared with non-Latino white Americans. J Gen Intern Med. Feb. 2004;19(2):156-66. [pmid: 15009795].
62 Wee CC, McCarthy EP, Phillips RS. Factors associated with colon cancer screening: the role of patient factors and physician counseling. Prev Med. Jul. 2005;41(1):23-9. [pmid: 15916989].
63 Wong ST, Gildengorin G, Nguyen T, et al. Disparities in colorectal cancer screening rates among Asian Americans and non‐ Latino whites. Cancer. Dec 15. 2005;104(12 Suppl):2940-7. [pmid: 16276538].
64 Yano EM, Soban LM, Parkerton PH, et al. Primary care practice organization influences colorectal cancer screening performance. Health Serv Res. Jun. 2007;42(3 Pt 1):1130-49. [pmid: 17489907].
65 Yip MP, Tu SP, Chun A, et al. Participation in colorectal cancer screening among Chinese Americans. Asian Pac J Cancer Prev. Oct–Dec. 2006;7(4):645-50. [pmid: 17250445].
66 Young WF, McGloin J, Zittleman L, et al. Predictors of colorectal screening in rural Colorado: testing to prevent colon cancer in the high plains research network. The Journal of rural health : official journal of the American Rural Health Association and the National Rural Health Care Association. 2007;(3):238-45.
67 Zapka JG, Puleo E, Vickers-Lahti M, et al. Healthcare system factors and colorectal cancer screening. Am J Prev Med. Jul. 2002;23(1):28-35. [pmid: 12093420].
68 Ayanian JZ, Sequist TD, Zaslavsky AM, et al. Physician reminders to promote surveillance colonoscopy for colorectal adenomas: a randomized controlled trial. J Gen Intern Med. Jun. 2008;23(6):762-7. [pmid: 18386103].
69 Braun KL, Fong M, Kaanoi ME, et al. Testing a culturally appropriate, theory-based intervention to improve colorectal cancer screening among Native Hawaiians. Prev Med. Jun. 2005;40(6):619-27. [pmid: 15850857].
70 Campbell MK, James A, Hudson MA, et al. Improving multiple behaviors for colorectal cancer prevention among african american church members. Health Psychol. Sep. 2004;23(5):492-502. [pmid: 15367069].
71 Church TR, Yeazel MW, Jones RM, et al. A randomized trial of direct mailing of fecal occult blood tests to increase colorectal cancer screening. J Natl Cancer Inst. May 19. 2004;96(10):770-80. [pmid: 15150305].
72 Costanza ME, Luckmann R, Stoddard AM, et al. Using tailored telephone counseling to accelerate the adoption of colorectal cancer screening. Cancer Detect Prev. 2007;31(3):191-8. [pmid: 17646058].
73 Denberg TD, Coombes JM, Byers TE, et al. Effect of a mailed brochure on appointment-keeping for screening colonoscopy: a randomized trial. Ann Intern Med. Dec 19. 2006;145(12):895-900. [pmid: 17179058].
74 Dietrich AJ, Tobin JN, Cassells A, et al. Telephone care management to improve cancer screening among low-income women: a randomized, controlled trial. Ann Intern Med. Apr 18. 2006;144(8):563-71. [pmid: 16618953].
75 Dietrich AJ, Tobin JN, Cassells A, et al. Translation of an efficacious cancer-screening intervention to women enrolled in a Medicaid managed care organization. Ann Fam Med. Jul–Aug. 2007;5(4):320-7. [pmid: 17664498].
76 Dolan JG, Frisina S. Randomized controlled trial of a patient decision aid for colorectal cancer screening. Med Decis Making. Mar–Apr. 2002;22(2):125-39. [pmid: 11958495].
77 Jandorf L, Gutierrez Y, Lopez J, et al. Use of a patient navigator to increase colorectal cancer screening in an urban neighborhood health clinic. J Urban Health. Jun. 2005;82(2):216-24. [pmid: 15888638].
78 Ling BS, Schoen RE, Trauth JM, et al. Physicians encouraging colorectal screening: a randomized controlled trial of enhanced office and patient management on compliance with colorectal cancer screening. Arch Intern Med. Jan 12. 2009;169(1):47-55. [pmid: 19139323].
79 Myers RE, Sifri R, Hyslop T, et al. A randomized controlled trial of the impact of targeted and tailored interventions on colorectal cancer screening. Cancer. Nov 1. 2007;110(9):2083-91. [pmid: 17893869].
80 Pignone M, Harris R, Kinsinger L. Videotape-based decision aid for colon cancer screening. A randomized, controlled trial. Ann Intern Med. Nov 21. 2000;133(10):761-9. [pmid: 11085838].
81 Potter MB, Phengrasamy L, Hudes ES, et al. Offering annual fecal occult blood tests at annual flu shot clinics increases colorectal cancer screening rates. Ann Fam Med. Jan–Feb. 2009;7(1):17-23. [pmid: 19139445].
82 Roetzheim RG, Christman LK, Jacobsen PB, et al. A randomized controlled trial to increase cancer screening among attendees of community health centers. Ann Fam Med. Jul–Aug. 2004;2(4):294-300. [pmid: 15335126].
83 Ruffin MTt, Fetters MD, Jimbo M. Preference-based electronic decision aid to promote colorectal cancer screening: results of a randomized controlled trial. Prev Med. Oct. 2007;45(4):267-73. [pmid: 17689600].
84 Sequist TD, Zaslavsky AM, Marshall R, et al. Patient and physician reminders to promote colorectal cancer screening: a randomized controlled trial. Arch Intern Med. Feb 23. 2009;169(4):364-71. [pmid: 19237720].
85 Stokamer CL, Tenner CT, Chaudhuri J, et al. Randomized controlled trial of the impact of intensive patient education on compliance with fecal occult blood testing. J Gen Intern Med. Mar. 2005;20(3):278-82. [pmid: 15836533].
86 Tu SP, Taylor V, Yasui Y, et al. Promoting culturally appropriate colorectal cancer screening through a health educator: a randomized controlled trial. Cancer. Sep 1. 2006;107(5):959-66. [pmid: 16865681].
87 Zapka JG, Lemon SC, Puleo E, et al. Patient education for colon cancer screening: a randomized trial of a video mailed before a physical examination. Ann Intern Med. Nov 2. 2004;141(9):683-92. [pmid: 15520425].
88 Ballew C, Lloyd BG, Miller SH. Capacity for colorectal cancer screening by colonoscopy, Montana, 2008. Am J Prev Med. Apr. 2009;36(4):329-32. [pmid: 19285198].
89 Benuzillo JG, Jacobs ET, Hoffman RM, et al. Rural-urban differences in colorectal cancer screening capacity in Arizona. J Community Health. 2009. Sep. 2.
90 Brown ML, Klabunde CN, Mysliwiec P. Current capacity for endoscopic colorectal cancer screening in the United States: data from the National Cancer Institute Survey of Colorectal Cancer Screening Practices. Am J Med. Aug 1. 2003;115(2):129-33. [pmid: 12893399].
91 Butterly L, Olenec C, Goodrich M, et al. Colonoscopy demand and capacity in New Hampshire. Am J Prev Med. Jan. 2007;32(1):25-31. [pmid: 17184962].
92 Hoffman RM, Stone SN, Herman C, et al. New Mexico's capacity for increasing the prevalence of colorectal cancer screening with screening colonoscopies. Prev Chronic Dis. Jan. 2005;2(1):A07.
93 Hur C, Gazelle GS, Zalis ME, et al. An analysis of the potential impact of computed tomographic colonography (virtual colonoscopy) on colonoscopy demand. Gastroenterology. Nov. 2004;127(5):1312-21. [pmid: 15521000].
94 Ladabaum U, Song K. Projected national impact of colorectal cancer screening on clinical and economic outcomes and health services demand. Gastroenterology. Oct. 2005;129(4):1151-62. [pmid: 16230069].
95 Pickhardt PJ, Hassan C, Laghi A, et al. Is there sufficient MDCT capacity to provide colorectal cancer screening with CT colonography for the U.S. population?. AJR Am J Roentgenol. Apr. 2008;190(4):1044-9. [pmid: 18356453].
96 Robertson RH, Burkhardt JH, Powell MP, et al. Trends in colon cancer screening procedures in the US Medicare and Tricare populations: 1999–2001. Prev Med. Jun. 2006;42(6):460-2. [pmid: 16563479].
97 Seeff LC, Manninen DL, Dong FB, et al. Is there endoscopic capacity to provide colorectal cancer screening to the unscreened population in the United States?. Gastroenterology. Dec. 2004;127(6):1661-9. [pmid: 15578502].
98 Seeff LC, Richards TB, Shapiro JA, et al. How many endoscopies are performed for colorectal cancer screening? Results from CDC's survey of endoscopic capacity. Gastroenterology. Dec. 2004;127(6):1670-7. [pmid: 15578503].
99 Vijan S, Inadomi J, Hayward RA, et al. Projections of demand and capacity for colonoscopy related to increasing rates of colorectal cancer screening in the United States. Aliment Pharmacol Ther. Sep 1. 2004;20(5):507-15. [pmid: 15339322].
100 El-Serag HB, Petersen L, Hampel H, et al. The use of screening colonoscopy for patients cared for by the Department of Veterans Affairs. Arch Intern Med. Nov 13. 2006;166(20):2202-8. [pmid: 17101937].
101 Fiscella K, Holt K, Meldrum S, et al. Disparities in preventive procedures: comparisons of self-report and Medicare claims data. BMC Health Serv Res. 2006;6:122. [pmid: 17010195].
102 Hall HI, Van Den Eeden SK, Tolsma DD, et al. Testing for prostate and colorectal cancer: comparison of self-report and medical record audit. Prev Med. Jul. 2004;39(1):27-35. [pmid: 15207983].
103 Haque R, Chiu V, Mehta KR, et al. An automated data algorithm to distinguish screening and diagnostic colorectal cancer endoscopy exams. J Natl Cancer Inst Monogr. 2005(35):116-8.
104 Pignone M, Scott TL, Schild LA, et al. Yield of claims data and surveys for determining colon cancer screening among health plan members. Cancer Epidemiol Biomarkers Prev. Mar. 2009;18(3):726-31. [pmid: 19273480].
105 Schenck AP, Klabunde CN, Warren JL, et al. Evaluation of claims, medical records, and self-report for measuring fecal occult blood testing among Medicare enrollees in fee for service. Cancer Epidemiol Biomarkers Prev. Apr. 2008;17(4):799-804. [pmid: 18381471].
106 Schenck AP, Klabunde CN, Warren JL, et al. Data sources for measuring colorectal endoscopy use among Medicare enrollees. Cancer Epidemiol Biomarkers Prev. Oct. 2007;16(10):2118-27. [pmid: 17932360].
107 Schneider EC, Nadel MR, Zaslavsky AM, et al. Assessment of the scientific soundness of clinical performance measures: a field test of the National Committee for Quality Assurance's colorectal cancer screening measure. Arch Intern Med. Apr 28. 2008;168(8):876-82. [pmid: 18443264].