# Sample Data Abstraction Forms

GENERAL INFO | | | PUBLICATION TYPE
Reviewer initials | Ref ID | Author, Year | Not original research (e.g., review, letter, editorial) | Published as abstract only (or conference proceeding, poster)

POPULATION | OUTCOMES | SETTING | INTERVENTIONS
Wrong population--High risk population (diagnosis of other illness, e.g., cancer, FAP, HNPCC, UC, Crohns)--Refer to study population exclusion criteria box from table | Wrong outcome--refer to study outcomes exclusion box from table | Not U.S. | Wrong intervention--Not colonocsopy, Sigmoidoscopy, CTC, FIT, gFOBT, or DNA stool

| DESIGN | | OTHER | | BACKGROUND
Not about screening | Exprimental (RCT or non-randomized controlled trial) N < 30 | Observational N < 100 | Does not address a KQ | Other--specify | Exclude but save for background | Systematic review

INCLUDE? | KEY QUESTIONS (CHECK ALL THAT APPLY)
Article should be included If article is to be included, proceed; if not STOP here | KQ1: What are the recent trends in the use and quality of CRC screening? | KQ2: What factors influence the use of CRC screening? | KQ3: Which strategies are effective in increasing the appropriate use of CRC screening and followup?

ALL THAT APPLY) | Comments, if necessary
KQ4: What are the current and projected capacities to deliver CRC screening and surveillance at the population level? | KQ5: What are the effective approaches for monitoring the use and quality of CRC screening?