# Exact Search Strings

## Colorectal Cancer Search Strategy

#1 | Search “Colorectal Neoplasms” [MeSH] OR “Mass Screening”[Majr] | 154648
#2 | Search ((“Colonoscopy”[Mesh] OR “Colonography, Computed Tomographic”[Mesh])) OR “Sigmoidoscopes”[Mesh] OR “stool test” OR “fecal immunochemical testing” OR (FIT AND fecal) OR fobt OR fobt OR occult blood OR “DNA Stool” | 26681
#3 | Search “Polyps”[Mesh] AND “Biopsy”[Mesh] | 967
#4 | Search #2 OR #3 | 27451
#5 | Search #1 AND #4 | 9033
#6 | Search #1 AND #4 Limits: Publication Date from 1998, Humans, English | 4660
#7 | Search #1 AND #4 Limits: Publication Date from 1998, Humans, Review, English | 705
#8 | Search (“Randomized Controlled Trials” [MeSH] OR ”Randomized Controlled Trial” [Publication Type]) OR ”Single-Blind Method” [MeSH] OR ”Double-Blind Method” [MeSH] OR ”Random Allocation” [MeSH] | 336385
#9 | Search #6 AND #8 | 263
#10 | Search (”Case-Control Studies” [MeSH] OR ”Cohort Studies” [MeSH] OR ”Epidemiologic Studies” [MeSH] OR ”Cross-Sectional Studies” [MeSH] OR ”Organizational Case Studies” [MeSH] OR ”Cross-Over Studies” [MeSH] OR ”Follow-Up Studies” [MeSH] OR ”Seroepidemiologic Studies” [MeSH] OR ”Multicenter Studies” [MeSH] OR ”Evaluation Studies” [MeSH]) OR Longitudinal Studies OR observational studies | 1150609
#11 | Search #6 AND #10 | 1340
#12 | Search #7 OR #9 OR #11 | 2150
#13 | Search (”Colorectal Neoplasms/diagnosis” [Majr] OR ”Colorectal Neoplasms/prevention and control” [Majr]) | 29131
#14 | Search ”Mass Screening” [Majr] | 48233
#15 | Search #13 AND #14 | 2175
#16 | Search #15 NOT #12 | 1752
#17 | Search #15 NOT #12 Limits: Publication Date from 1998, Humans, English | 1019
#19 | Search ”United States” [Mesh] OR United States Limits: Publication Date from 1998, Humans, English | 676580
#20 | Search #17 AND #19 Limits: Publication Date from 1998, Humans, English | 399
#21 | Search #4 NOT #12 | 25301
#22 | Search #15 AND #21 | 1128
#23 | Search #15 AND #21 Limits: Publication Date from 1998, Humans, English | 591
#25 | Search #19 AND #23 | 211

Total PUBMED = 2265

Cochrane Reviews = 7 = 6 New

Cochrane Central Trials Registry = 138 = 38 New

Total Unduplicated Database = 2309

## Update Search Strategy (September 21^st^ 2009)

#1 | Search ”Colorectal Neoplasms” [MeSH] OR ”Mass Screening” [Majr] | 158767
#2 | Search ((”Colonoscopy” [Mesh] OR ”Colonography, Computed Tomographic” [Mesh])) OR ”Sigmoidoscopes” [Mesh] OR ”stool test” OR ”fecal immunochemical testing” OR (FIT AND fecal) OR fobt OR fobt OR occult blood OR ”DNA Stool” | 27659
#3 | Search ”Polyps” [Mesh] AND ”Biopsy” [Mesh] | 987
#4 | Search #2 OR #3 | 28442
#5 | Search #1 AND #4 | 9346
#6 | Search #1 AND #4 Limits: Entrez Date from 2009, Humans, English | 277
#7 | Search #1 AND #4 Limits: Entrez Date from 2009, Humans, Review, English | 29
#8 | Search (”Randomized Controlled Trials” [MeSH] OR ”Randomized Controlled Trial” [Publication Type]) OR ”Single-Blind Method” [MeSH] OR ”Double-Blind Method” [MeSH] OR ”Random Allocation” [MeSH] | 346335
#9 | Search #6 AND #8 | 21
#10 | Search (”Case-Control Studies” [MeSH] OR ”Cohort Studies” [MeSH] OR ”Epidemiologic Studies” [MeSH] OR ”Cross-Sectional Studies” [MeSH] OR ”Organizational Case Studies” [MeSH] OR ”Cross-Over Studies” [MeSH] OR ”Follow-Up Studies” [MeSH] OR ”Seroepidemiologic Studies” [MeSH] OR ”Multicenter Studies” [MeSH] OR ”Evaluation Studies” [MeSH]) OR Longitudinal Studies OR observational studies | 1192822
#11 | Search #6 AND #10 | 77
#12 | Search #7 OR #9 OR #11 | 118
#13 | Search (”Colorectal Neoplasms/diagnosis” [Majr] OR ”Colorectal Neoplasms/prevention and control” [Majr]) | 30104
#14 | Search ”Mass Screening” [Majr] | 49616
#15 | Search #13 AND #14 | 2272
#16 | Search #15 NOT #12 | 2250
#17 | Search #15 NOT #12 Limits: Entrez Date from 2009, Humans, English | 67
#18 | Search ”United States” [Mesh] OR United States | 2377508
#19 | Search #17 AND #18 | 20
#20 | Search #4 NOT #12 | 28324
#21 | Search #15 AND #20 | 1592
#22 | Search #15 AND #20 Limits: Entrez Date from 2009, Humans, English | 32
#23 | Search #18 AND #22 | 6

Total PUBMED = 124

Cochrane Reviews = 2 = 2 New

Cochrane Central Trials Registry = 19 = New 14

Total Unduplicated Database = 140