# Appendixes

Appendix A Exact Search Strings

Appendix B Sample Data Abstraction Forms

Appendix C Evidence Tables

Appendix D Excluded Studies

Appendix E Technical Expert Panel Members and Peer Reviewers

Appendix F Characteristics of Studies with Poor Internal Validity

Appendix G Additional Material for KQ 4