# List of Abbreviations

ACS: American Cancer Society
AHRQ: Agency for Healthcare Research and Quality
AOR: adjusted odds ratio
BRFSS: Behavioral Risk Factor Surveillance Survey
CAD: computer-aided detection
CAHPS: Consumer Assessment of Healthcare Providers and Systems
CCME: Carolina Center for Medical Excellence
CDC: Centers for Disease Control and Prevention
CHIS: California Health Interview Survey
CI: confidence interval
CONSORT: Consolidated Standards of Reporting Trials
CORI: Clinical Outcomes Research Initiative
CPT: current procedural terminology
CRC: colorectal cancer
CT: computed tomography
CTC: computed tomographic colonography
CTS: Community Tracking Study
DCBE: double contrast barium enema
DERS: Direct Endoscopic Referral System
DNA: deoxyribonucleic acid
DRE: digital rectal examination
FAP: familial adenomatous polyposis
FIT: fecal immunochemical test
FSS: fee-for-service
FFS + SUPP: fee-for-service Medicare + supplemental insurance
FIT: fecal immunochemical test
FOBT: fecal occult blood test
FS: flexible sigmoidoscopy
gFOBT: guaiac-based fecal occult blood test
G: group
GI: gastrointestinal
GI: gastroenterologist
HEDIS: Healthcare Effectiveness Data and Information Set
HINTS: Health Information National Trends Survey
HMO: health maintenance organization
HNPCC: hereditary nonpolylposis colorectal cancer
ICD: International Classification of Diseases
iFOBT: immunochemical fecal occult blood test
KQ: key question
LHA: lay health advisors
MCA: managed care activity
MCBS: Medicare Current Beneficiary Survey
MEPS: Medical Expenditure Panel Survey
MeSH: Medical Subject Heading
MMC: Medicare managed care
MMSA: metropolitan or micropolitan statistical areas
MR: magnetic resonance
MRI: magnetic resonance imaging
MSTF: Multi-Society Task Force
MSTF: Multi-Society Task Force
NCI: National Cancer Institute
NCQA: National Committee on Quality Assurance
NHIS: National Health Interview Survey
NIH: National Institutes of Health
N: number
NR: not reported
OMAR: Office of Medical Applications of Research
OR: odds ratio
PCP: primary care physician
PET: positron emission tomography
PHE: periodic health examination
PSA: prostate-specific antigen
PSAs: public service announcements
RCTs: randomized controlled trials
RDD: random digital dialing
RR: relative risk
RTC: Randomized Control Trial
RTI-UNC EPC: RTI International–University of North Carolina Evidence-based Practice Center
SES: socioeconomic status
SI: standard intervention
STROBE: STrengthening the Reporting of OBservational studies in Epidemiology
TEP: Technical Expert Panel
TFCPS: Task Force on Community Preventive Services
TI: tailored intervention
TIP: tailored intervention plus reminder phone call
US: United States
USPSTF: US Preventive Services Task Force
VA: Veterans Administration