# Evidence Tables

Evidence Table 1. Differential diagnosis and initial assessment of severity

Study | Design and Quality | Patient Population | Study Protocol | Results | | | | Notes
Chest Roentgenography
Emerman and Cydulka, 1993 | Design: Retrospective cohort | N = 685 episodes of AECB in which medical records were available and radiographs were taken (254 patients) | Interventions: N/S | Abnormal chest radiographs: 16% (109/685 episodes) | | | | Radiographs were not taken in 7.6% of otherwise eligible visits for AECB
| Dates: 1/88-7/91 | Setting: Urban public academic medical center ED | Outcome(s) of interest: Abnormal chest radiograph according to radiologist's report. Abnormal was defined as the presence of new infiltrates, pulmonary edema, pneumothorax, and new lung masses | Clinically significant abnormalities: | | | | Attempt to validate findings of Sherman, Skoney, and Ravikrishnan, 1989
| Location: Cleveland, OH | Inclusion (COPD): Computerized ED discharge diagnosis for COPD, verified by chart review | Predictors considered: Age; sex; history of CHF; history of coronary artery disease; chest pain; cough; sputum production; history of fever; rales; pedal edema; jugular venous distension; WBC count; temperature | •88 infiltrates | | | | Study population may not be representative of patients presenting with AECB, as patients suspected of having AECB but diagnosed based on CXR to have another cause for exacerbation may not later receive an ED discharge diagnosis of COPD.
| Assessment period: To time of discharge for ED or hospital | Inclusion (AcEx): ED discharge diagnosis of AcEx of COPD | (°C); presence of Sherman's high-yield criteria | • 2 new lung masses
| External validity: ^1^ 0/4 | Exclusion: No chest radiograph | Analytic methods: | • 1 pneumothorax
| COPD dx- | Smoking history:N/S | • Univariable parametric tests (Student's t- and chi square tests) | • 20 episodes of pulmonary edema
| COPD bl- | Baseline stable FEV_1_: N/S | • No multivariable analysis | Predictors of abnormal CXR:
| AECB dx- | FEV_1_ at admission: N/S | | • History of CHF
| AECB sev- | Age: 62.2 ± 8.9 | | • History of fever
| Internal validity: ^2^ Level 3 | Sex: 119 men, 135 women | | • Rales
| | Race: N/S | | • Pedal edema
| | | | • Jugular venous distension
| | | | • Presence of Sherman's high-yield criteria
| | | | Sherman's high-yield criteria (any of the following:
| | | | • WBC > 15×10^9^/L
| | | | • Total PMN leukocyte count > 8×10^9^/L
| | | | • History of CHF
| | | | • History of coronary artery disease
| | | | • Edema
| | | | • Chest pain
| | | | Sensitivity = 0.76
| | | | Specificity = 0.41
| | | | Pos pred value = 0.20
| | | | Neg pred value = 0.90
| | | | Overall accuracy = 0.47
Sherman, Skoney, and Ravikrishnan, 1989 | Design: Retrospective cohort | N = 242 patients admitted for AECB; 107 with predominant emphysema/chronic bronchitis; 135 with predominant asthma | | Abnormal chest radiographs: | | | | (1) No validation of predictors in independent group of patients.
| Dates: 12/86-11/87 | Setting: General medical ward of acute care hospital | | • Overall: 14.5% (35/242) | | | | (2) No multivariable analysis.
| Location: Royal Oak, MI | Inclusion (COPD): Computerized discharge diagnosis for COPD, verified by chart review | | • COPD: 16% (17/107) | | | | (3) Heterogeneity among causes of abnormal CXR (CHF and pneumonia) may reduce ability to identify predictors that are specific to a particular etiology of exacerbation.
| Assessment period: To time of discharge or death | Inclusion (AcEx): Required hospitalisation with principal discharge diagnosis of COPD | | • Asthma: 13% (18/135) | | | | (4) Low rate of abnormalities.
| External validity: 0/4 | Exclusion: No chest radiograph; intubation before or immediately on admission | | Clinically significant abnormalities: | | | | (5) Most predictors had missing data from a large number of subjects, limiting the ability to assess predictive power.
| COPD dx- | Smoking history: N/S | | • COPD: 8 (5 CHF, 3 pneumonia) | | | | (6) Study population may not be representative of patients presenting with AECB, as patients suspected of having AECB but diagnosed based on CXR to have another cause for exacerbation may not later receive a principal discharge diagnosis of COPD.
| COPD bl- | Baseline stable FEV_1_: N/S | | • Asthma: 4 (3 CHF, 1 pneumothorax)
| AECB dx- | FEV_1_ at admission: N/S | | Predictors of abnormal CXR:
| AECB sev- | Age: 59.3 ± 18.2 (range 18–92) | | COPD/emphysema
| Internal validity: Level 3 | COPD: 69.9 ± 8.4 | | • Elevated neutrophil count (> 8×10^9^/L)
| | Asthma: 46.6 ± 19.1 | | • Increased sputum production
| | Sex: 88 men, 154 women | | Asthmatics only
| | Race: N/S | | • CHF
| | | | All patients
| | | | • CHF
| | | | • Elevated neutrophil count (> 8×10^9^/L)
| | | | • Leukocytosis (> 15×10^9^/L)
| | | | • Edema
Tsai, Gallagher, Lombardi et al., 1993 | Design: Prospective cohort | N = 128 admissions for AcEx of obstructive airways disease (115 patients) | Interventions: N/S | Change in management based on chest radiograph: 21% (27/128) | | | | Attempt to validate findings of Aronson, Gennis, Kelly, et al., 1989, describing predictors of significant abnormalities in adult asthmatics.
| Dates: 7/91-7/92 | Setting: Urban public medical center ED | Outcome(s) of interest: Change in management based on chest radiograph result, as reported by ED attending and house officer responsible for inpatient care | Radiographic findings that led to change in management: | | | | Limited usefulness when applied to patients with AECB, as all would be classified as “complicated.” The usefulness of the other criteria in those with COPD is not described.
| Location: Cleveland, OH | Inclusion (COPD): Asthma or COPD according to ATS criteria (1987) | Predictors considered: | • 17 infiltrates
| Assessment period: To time of discharge for ED or hospital | Inclusion (AcEx): Hospitalized after failing to improve after ED therapy | “Complicated” patients defined as the presence of any of the following: | • 7 CHF
| External validity: ¼ | Exclusion: No chest radiograph | • COPD (versus asthma) | • 3 normal
| COPD dx+ | Smoking history: N/S | • History of fever (T > 100° F) | • 1 lobar collapse (intubated patient)
| COPD b- | Baseline stable FEV_1_: N/S | • History of heart disease (historical or ECG evidence of IHD or radiographic evidence of CHF or cardiomyopathy) | Classification of patients:
| AECB dx- | FEV_1_ at admission: N/S | • History of IV drug abuse | • “Complicated” 66% (84/128)
| AECB sev- | Age: 50 ± 18 (range 18–93) | • History of seizures | • “Uncomplicated” 34% (44/128)
| Internal validity: Level 3 | Sex: 54 men, 74 women | • Immunosuppression (not including chronic steroid use or diabetes) | Performance of criteria for “complicated” patients as a predictor of change in management based on chest radiograph:
| | Race: N/S | • Other pulmonary disease | Sensitivity 0.98 (95% CI; 0.88–1.0)
| | | • History of thoracic surgery | Specificity 0.43 (95% CI; 0.33–0.52)
| | | Analytic methods: | Pos pred value = 0.20
| | | • Univariable parametric tests (chi square tests) | Neg pred value = 0.90
| | | • No multivariable analysis | Overall accuracy = 0.47
Diagnosis of Deep Venous Thrombosis
Oneglia, Lombardi, Polotti, et al., 1998 | Design: Prospective cohort | N = 36 consecutive hospitalized with AcEx of COPD | Interventions: Ultrasound evaluation of lower extremities using two-dimensional and color Doppler with compression maneuver | Prevalence of DVT: 2.8% (1/36 patients), asymptomatic | | | | No reference standard
| Dates: 4/96-6/97 | Setting: Acute care hospital | Outcome(s) of interest: Presence of DVT | Location:
| Location: Italy | Inclusion (COPD): Severe COPD based on history of cigarette smoking, winter bronchitis, dyspnea progressing over several yrs; FEV_1_/FVC < 70%, PaO_2_ < 60 mm Hg | Predictors considered: None | • 1 popliteal only
| Assessment period: At time of presentation | Inclusion (AcEx): Recent increase in severity of respiratory symptoms, resulting in hospital admission | Analytic methods: None | • 0 superficial femoral vein only
| External validity: ¼ | Exclusion: Increase of FEV_1_ by more than 15% in response to inhalation of a beta agonist | | • 0 common femoral vein
| COPD dx+ | Smoking history: N/S
| COPD bl- | Baseline stable FEV_1_: N/S
| AECB dx- | FEV_1_ at admission: N/S
| AECB sev- | Age: 76.4 ± 7
| Internal validity: Level 3 | Sex: 31 men, 5 women
| | Race: N/S
Prescott, Richards, Tikoff, et al., 1981 | Design: Prospective cohort | N = 45 consecutive pts hospitalized with “decompensated” AcEx of COPD | Interventions: Ultrasound evaluation of lower extremities using Doppler with compression maneuver | Prevalence of DVT: 8.9% (4/45 patients) | | | | Small sample size and small number of DVT cases limit comparing tests, identifying predictors
| Dates: 10/76-6/78 | Setting: Veterans Affairs acute care hospital | Iodine-125-labelled fibrinogen studies (33 subjects) positive if 20% difference that persisted for 24 hours between same site on opposite legs or adjoining sites on same leg | Location:
| Location: Salt Lake City, UT; and Albuquerque, NM | Inclusion (COPD): Based on “obstruction of the airways being present on physical examination and/or spirometry” | Ascending contrast venography (39 subjects) | • 2 popliteal only
| Assessment period: At time of presentation | Inclusion (AcEx): Symptomatic worsening, including an increase in dyspnea and/or sputum production, combined with various objective changes, such as wheezing, and increasing hypoxemia or hypercarbia | Electrical IPG by cuff occlusion technique | • 0 superficial femoral vein only
| External validity: 2/4 | Exclusion: Patients with an obvious cause for their decompensation, pneumonia, left ventricular failure, tuberculosis, allergy to iodides | Outcome(s) of interest: Presence of DVT | • 2 common femoral vein
| COPD dx+ | Smoking history:98% past or present (44/45); 49% present (22/45) | Predictors considered: None | All (proximal or distal) DVT
| COPD bl- | Baseline stable FEV_1_: N/S | Analytic methods: Standard categorical methods | IPG
| AECB dx+ | FEV_1_ at admission: N/S | | Sensitivity 50% (2/4)
| AECB sev- | Age: 68.3 | | Specificity 83% (30/36)
| Internal validity: Level 3 | Sex: 45 men, 0 women | | Doppler Ultrasound
| | Race: N/S | | Sensitivity 50% (2/4)
| | | | Specificity 89% (32/36)
| | | | Proximal DVT only
| | | | IPG
| | | | Sensitivity 100% (2/2)
| | | | Specificity 84% (32/38)
| | | | Doppler Ultrasound
| | | | Sensitivity 100% (2/2)
| | | | Specificity 90% (34/38)
Schönhofer and Köhler, 1998 | Design: Prospective cohort | N = 196 consecutive patients admitted to ICU with AcEx of COPD | Interventions: Ultrasound evaluation of lower extremity using a 5 MHz electronically focused linear-array transducer (model Sonoline, Siemens, Erlangen, Germany). Veins were assessed for noncompressibility and intraluminal echogenic material, signs indicative of DVT; lower extremity veins were studied in 3 segments: (1) common femoral vein; (2) superficial femoral veins including long saphenous vein, and (3) popliteal vein | Prevalence of DVT: 11% (21/196 patients); asymptomatic in 18/21 cases | | | | Single observer, no assessment of reliability
| Dates:1/95-12/96 | Setting: Urban academic medical center respiratory ICU | Outcome(s) of interest: Presence of DVT | Location: | | | | Similar prevalence found in heterogeneous ICU populations in other studies (cited)
| Location: Germany | Inclusion (COPD): Severe COPD defined as FEV_1_ < 1 L and FEV_1_/FVC < 45% | Predictors considered: Age, hemoglobin, hematocrit, PaO_2_, pH, FEV_1_, VC, Borg scale | • 8 popliteal only | | | | No reference standard
| Assessment period: At time of presentation to ICU | Inclusion (AcEx): Clinical diagnosis | Analytic methods: | • 2 superficial femoral vein only
| External validity: 2/4 | Exclusion: Cancer, left ventricular failure, neurologic abnormalities or a history of DVT, history of PE within 6 mo or other indication for anticoagulant therapy | • Univariable nonparametric tests (Mann-Whitney U test) | • 11 common femoral vein
| COPD dx+ | Smoking history: N/S | • No multivariable analysis | None of predictors associated with DVT
| COPD bl+ | Baseline stable FEV_1_: 0.7 ± 0.2 L
| AECB dx- | FEV_1_ at admission: N/S
| AECB sev- | Age: 66.9 ± 9.1
| Internal validity: Level 3 | Sex: 110 men, 86 women
| | Race: N/S
Winter, Buckler, Bautista, et al., 1983 | Design: Prospective cohort | N = 29 consecutive hospitalized with exacerbation of COPD | Interventions: Indium-111-labelled platelet technique study to diagnose DVT of pelvis and lower extremities; scanning at 24 hours after platelet labelling | Prevalence of DVT: | | | | Small study, low number of events, little power to identify predictors of DVT
| Dates: 10/76-6/78 | Setting: Acute care hospital | All patients receive physiotherapy, O_2_, antibiotic, nebulized bronchodilator drugs, bed rest | • Any location: 45% (13/29 patients) | | | | No reference standard
| Location: Scotland, UK | Inclusion (COPD): Based on history of cigarette smoking, winter bronchitis, dyspnea progressing over several yrs, FEV_1_/FVC < 70%, PaO_2_ < 60 mm Hg | Outcome(s) of interest: Presence of DVT | • Proximal DVT: 31% (9/29 patients) | | | | Wide variation in interval between admission and scanning
| Assessment period: 3 to 18 days after admission | Inclusion (AcEx): Recent increase in severity of respiratory symptoms, resulting in hospital admission | Predictors considered: Age, spirometric indices, blood gases, percentage of average body weight, interval between admission and scanning | • All patients were asymptomatic | | | | One patient with negative scan later died and was found to have DVT and PE. Unknown whether this was a false-negative scan or a later-developing DVT
| External validity: 2/4 | Exclusion: Increase of FEV_1_ by more than 15% in response to inhalation of a beta agonist | Analytic methods: | Location:
| COPD dx+ | Smoking history: 14% current smokers (4/29) | • Univariable parametric tests | • 4 popliteal only
| COPD bl- | Baseline stable FEV_1_: N/S | • No multivariable analysis | • 0 superficial femoral vein only
| AECB dx- | FEV_1_ at admission: 0.67 L (range 0.25–1.5) | | • 9 common femoral vein
| AECB sev+ | Age: 67.2 (range 36–84) | | Predictors of DVT: None
| Internal validity: Level 3 | Sex: N/S
| | Race: N/S
Ultrasound
Lichtenstein and Mezière, 1998 | Design: Prospective cohort | N = 146 consecutive admissions to ICU; 26 had COPD | Interventions: Bedside chest ultrasound using longitudinal scans in semirecumbent or supine position. Hitachi-405 ultrasound with 3.5 MHz cardiac probe and an ADR-4000 portable unit with a 3.0 MHz cardiac probe | Classification of patients: | | | | Population was not limited to those in whom diagnosis was in doubt; spectrum bias
| Dates: 20-mo period, dates N/S | Setting: Urban academic medical center ICU | Outcome(s) of interest: Correct classification to COPD, pulmonary edema/CHF for non-respiratory pathology | • Pulmonary edema, 40 | | | | Single observer, unknown reliability, reproducibility
| Location: Paris, France | Inclusion (COPD): Clinical diagnosis | Predictors considered: Presence of multiple comet tail artifacts on ultrasound from the pleural line; multiple vertical hyperechogenic narrow-based repetition artifacts, which are distinct from the normal pattern of horizontal parallel reverberation lines | • AcEx of COPD, 26
| Assessment period: At time of presentation to ICU | Inclusion (AcEx): Clinical diagnosis | Analytic methods: | • No dyspnea, 80
| External validity: 0/4 | Exclusion: No chest radiograph | • Univariable parametric tests (chi square tests) | Performance of presence of multiple comet tail artifacts on ultrasound as a predictor of pulmonary edema versus COPD in patients admitted to ICU with dyspnea:
| COPD dx- | Smoking history: N/S | • No multivariable analysis | Sensitivity = 40/40 1.0
| COPD bl- | Baseline stable FEV_1_: N/S | | Specificity = 24/26 0.92
| AECB dx- | FEV_1_ at admission: N/S
| AECB sev- | Age: 74 (range 63–88)
| Internal validity: Level 3 | Sex: 15 men, 11 women
| | Race: N/S
Spirometric Assessment
Emerman, Connors, Lukens, et al., 1989a | Design: Prospective cohort | N = 70 patients presenting with AcEx of COPD | Interventions: None | Initial ABG: | | | | Authors note contrast with studies of asthmatics, where spirometry and ABGs are well correlated
| Dates: N/S | Setting: ED of large urban medical center | Outcome(s) of interest: Agreement between FEV_1_ measurements and ABG measurements | • pH 7.43 ± 0.05
| Location: Cleveland, OH | Inclusion (COPD): Age over 50 yrs, postbronchodilator FEV_1_ < 75% predicted or FEV_1_/FVC < 70% | Predictors considered: None | • PaCO_2_ 39.7 ± 7.6 mm Hg
| Assessment period: On arrival at ED | Inclusion (AcEx): Recent increase in severity of respiratory symptoms, resulting in presentation to ED | Analytic methods: | • PaO_2_ 63.5 ± 11.8 mm Hg
| External validity: ¾ | Exclusion: History of asthma (with onset before age 35) or unable to perform spirometry; pneumonia; decompensated CHF; pneumothorax; postbronchodilator increase in FEV_1_ > 30% | • Pearson correlation coefficients | PaCO_2_ > 45 mm Hg: 20% (14/70)
| COPD dx+ | Smoking history: 96% current or former smokers; 60.2 ± 31.4 pack-years | • Chi-square test with Yates correction | PaO_2_ < 60 mm Hg: 34% (24/70)
| COPD bl+ | Baseline stable FEV_1_: 1.37 ± 0.56 L = 57.4% ± 19.3 % predicted | | pH < 7.36: 4.3% (3/70)
| AECB dx- | FEV_1_ at admission: 0.71 ± 0.36 L = 25.7% ± 11.4% predicted | | Correlation between FEV_1_ and:
| AECB sev+ | Age: 64.0 ± 8.5 | | • PaO_2_: 0.06, p > 0.05
| Internal validity: Level 3 | Sex: 36 women, 34 men | | • PaCO_2_: -0.46 p < 0.001
| | Race: N/S | | • pH: 0.33, p < 0.01
| | | | Correlation between FEV_1_ % predicted and:
| | | | • PaO_2_: 0.06, p > 0.05
| | | | • PaCO_2_: -0.47 p < 0.001
| | | | • pH: 0.36, p < 0.01
Emerman and Cydulka 1996 | Design: Prospective cohort | N = 556 measurements from 199 patients presenting with AcEx of COPD | Interventions: PEFR and FEV_1_ measured using commercially available spirometer. PEFR and FEV_1_ measured simultaneously on each of 3 attempts and highest simultaneously obtained measures were used; FEV_1_ and PEFR analyzed as absolute values and as percent predicted normal values; measures taken before treatment, 1 hour after treatment, and before ED discharge | PEFR: 113.1 ± 51.6 L/min (26.2 ± 11.5 % predicted) | | | | Study did not use inexpensive hand held peak-flow meter that offers a less costly, easier-to-use alternative to spirometer
| Dates: N/S | Setting: ED of large urban medical center | Outcome(s) of interest: Agreement between PEFR and FEV_1_ measurements | FEV_1_ at admission: 0.85 ± 0.44 L (30.2 ± 13.6 % predicted)
| Location: Cleveland, OH | Inclusion (COPD): Age over 50 yrs, previously determined clinical diagnosis or history consistent with a diagnosis | Predictors considered: None | Correlation coefficient = absolute values of FEV_1_ vs. PEFR: 0.84 (p < 0.001)
| Assessment period: During ED treatment | Inclusion (AcEx): Recent increase in severity of respiratory symptoms, resulting in presentation to ED | Analytic methods: Pearson correlation coefficients | Percent predicted values: 0.81 (p < 0.001)
| External validity: ¼ | Exclusion: History of asthma (ATS) or unable to perform spirometry; pneumonia, decompensated CHF, history of lung cancer, or surgery | | Mean difference between % predicted for FEV_1_ and % predicted for PEFR: 4.3% ± 9.9
| COPD dx- | Smoking history: 54.5 ± 32.6 pack-yrs | | In 27% of patients, the absolute difference between % predicted for FEV_1_ and PEFR was greater than 10%.
| COPD bl- | Baseline stable FEV_1_: N/S
| AECB dx- | FEV_1_ at admission: 0.85 ± 0.44 L = 30.2 ± 13.6 % predicted
| AECB sev+ | Age: 61.4 ± 9.8
| Internal validity: Level 3 | Sex: 99 women, 100 men
| | Race: N/S
Emerman, Lukens, Effron, et al., 1994 | Design: Prospective cohort | N = 90 patients presenting with AcEx of COPD | Interventions: Hourly administration of beta-agonists; aminophylline and intravenous steroids at discretion of treating physician | Post-treatment FEV_1_ (measured): 35.7% ± 19.7% predicted normal | | | | Pretreatment estimates obtained before FEV_1_ measurement, but for posttreatment estimate; physicians were not blinded to pretreatment FEV_1_ measurement. This may explain improved accuracy of physician posttreatment FEV_1_ predictions
| Dates: N/S | Setting: ED of large urban medical center | Outcome(s) of interest: Pretreatment and posttreatment FEV_1_ (% predicted normal) measured by computerized portable pneumotachygraph-type spirometer | Correlation between observed and predicted FEV_1_: | | | | Authors conclude that physicians tend to overestimate FEV_1_, and their predictions are not sufficiently accurate to guide treatment decisions.
| Location: Cleveland, OH | Inclusion (COPD): Age over 50 yrs, postbronchodilator FEV_1_ < 75% predicted or FEV_1_/FVC < 70% (ATS 1987 criteria) | Predictors considered: Pretreatment and posttreatment estimates of FEV_1_ by treating physician; physician level of training (attending vs. resident); severity of obstruction (FEV_1_ < 30%) | Pretreatment FEV_1_:
| Assessment period: During treatment in ED | Inclusion (AcEx): Recent increase in severity of respiratory symptoms, resulting in presentation to ED | Analytic methods: | (actual): r = 0.34 (p<0.001)
| External validity: 2/4 | Exclusion: Acute asthma, pneumonia, CHF, pneumothorax, lung cancer | • Pearson correlation coefficients | (as % predicted) r = 0.42 (p<0.001)
| COPD dx+ | Smoking history: 51.9 ± 23.8 pack-yrs | • Chi-square test with Yates correction | 38% accurate
| COPD bl- | Baseline stable FEV_1_: N/S | | 48% high
| AECB dx- | FEV_1_ at admission: 30.9 ± 18.9% predicted | | 14% low
| AECB sev+ | Age: 63.0 ± 8.5 | | Posttreatment FEV_1_:
| Internal validity: Level 3 | Sex: 44 women, 46 men | | (actual): r = 0.57 (p<0.001)
| | Race: N/S | | (as % predicted): r= 0.63 (p<0.0001)
| | | | 46% were accurate
| | | | 43% high
| | | | 11% low
| | | | Predictors: Level of training: 61% of attending physician's pretreatment estimates were accurate compared with 22% of residents' estimates (p < 0.001)
Estimating Serum Theophylline Levels
Elenbaas and Payne, 1984 | Design: Prospective cohort | N = 40 patients presenting with AcEx of COPD (n=11) or asthma (n=29) and a clinical history of theophylline use within previous 12 hours | Interventions: None | Initial serum theophylline level: 12.7 ± 6.62 μg/mL | | | | Predicted serum theophylline levels calculated without knowledge of prior outpatient theophylline levels
| Dates: N/S | Setting: ED of an urban medical center | Outcome(s) of interest: Serum theophylline level, predicted using pharmacokinetic formula assuming steady state (stable dose for at least five elimination half-lives) | Subtherapeutic (<10 μg/mL): 39% (16/41) | | | | Discrepancy between data presented in text and figure could not be resolved
| Location: Kansas City, MO | Inclusion (COPD): Past history of COPD (chronic bronchitis or emphysema) or asthma | Predictors considered: Cigarette use (yes or no), body weight, type of theophylline preparation, theophylline dose, hours since last outpatient theophylline dose, interval between theophylline doses | Therapeutic (10 μg/mL -20 μg/mL) 49% | | | | Predictive model and accuracy assessment do not address difference based on diagnosis (COPD versus asthma) or age
| Assessment period: On arrival at ED | Inclusion (AcEx): Recent increase in severity of respiratory symptoms, resulting in presentation to ED | Analytic methods: | Toxic (>20 μg/mL) 12% (5/41)
| External validity: 0/4 | Exclusion: N/S | • Pearson correlation coefficients | Agreement between observed and predicted theophylline levels:
| COPD dx- | Smoking history: 33% (13/40) smoked ½ pack per day or more | • Chi-square test with Yates correction | | Observed
| COPD bl- | Baseline stable FEV_1_: N/S | | Predicted | Sub | Ther | Tox
| AECB dx- | FEV_1_ at admission: N/S | | Subtherapeutic | 12 | 3 | 1
| AECB sev- | Age: 41.5 ± 19.97 (range 17–76) | | Therapeutic | 3 | 16 | 4
| Internal validity: Level 3 | Sex: 20 women, 20 men | | Toxic | 1 | 1 | 0
| | Race: N/S | | Correlation between observed and predicted theophylline levels:
| | Age: 64.3 ± 8.1 | | r = 0.468 (p-value not reported)
| | Sex: 37 women, 42 men | | In 38% of cases (15/40), the difference between predicted and observed theophylline levels exceeded 5 μg/mL.
| | Race: N/S

1 External validity score (4 points possible): COPD dx = COPD diagnosis based on spirometry (+ = yes + 1; - = no = 0); COPD bl = baseline stable ventilatory status of population described (+ = yes = 1; - = no = 0); AECB dx = diagnosis of AECB includes at least two of the following: increased sputum purulence, increased sputum volume, increased dyspnea (+ = yes = 1; - = no = 0); AECB sev = severity of AECB at enrollment described based on at least two of the following: mental status change, work of breathing, ventilatory status (+ = yes = 1; - = no = 0).

2 Internal validity score (Levels 1–3): Level 1 = inception cohort study with ≥ 80% followup, a systematic review (with homogeneity) of inception cohort studies, or clinical prediction guide validated on a test set; Level 2 = retrospective cohort study of followup of untreated control patients in a randomized controlled trial or clinical prediction guide not validated on a test set; Level = 3 case series or poor cohort studies.

Evidence Table 2. Prognosis

Study | Design and Quality | Patient Population | Study Protocol | Results | Notes
Outpatient and ED Studies
Ball, Harris, Lowson, et al., 1995 | Design: Prospective cohort | N = 471 | Interventions: Not standardized; not described; antibiotics given to 378 pts (80%) | Relapse rate: 56/423 pts (13%) | No validation of predictors in separate grp of pts
| Dates: 11/92-3/93 | Setting: General practices | Outcome(s) of interest: | Hospitalization rate (within 28 days): 9/423 (2.1%) | Prevalence of Winnipeg criteria in study population: None or 1 symptom, 31%; 2 or more symptoms, 69%
| Location: United Kingdom | Inclusion (COPD): Age ≥ 30 yrs, clinical diagnosis of COPD | (1) Relapse = return to GP with chest problem within 28 days; | Short-term (28 days) mortality: 2/423 (0.5%)
| Assessment period: 4 wks following initial presentation | Inclusion (AcEx): Presenting with “features of AECB [acute infective exacerbation of chronic bronchitis]” | (2) hospitalization within 28 days | Predictors of relapse (univariable analysis):
| External validity: ^1^ ¼ | Exclusion: None described | Predictors considered: Duration of COPD (yrs), history of ever smoking, degree of usual airflow obstruction (none/slight, mod/sev), sputum production (a.m. only, all day), increase in airflow obstruction (none/slight, mod/sev), age, sex (male), pyrexia (> 37° C), abnormal findings on auscultation (present), Winnipeg criteria (2 or more), presence of comorbid cardiopulmonary disease, no. of previous exacerbations in the past yr (2 or fewer, 3 or 4, more than 4) | Significant predictors:
| COPD dx- | Smoking history: 82% current or past smokers | Analytic method(s): | • Presence of comorbid cardiopulmonary disease
| COPD bl- | Baseline stable FEV_1_: N/S | • Univariable logistic regression | • More than 4 previous exacerbations in the past yr
| AECB dx+ | FEV_1_ at admission: N/S | • Multivariable logistic regression | Predictors of relapse (multivariable analysis):
| AECB sev- | Age: 68 (median, range 31–94) | | Significant predictors (p < 0.05):
| Internal validity: ^2^ Level 1 | Sex: 265 men (56%), 206 women (44%) | | • Presence of comorbid cardiopulmonary disease
| | Race: N/S | | • More than 4 previous exacerbations in the past yr
| | | | Combination of predictor variables with the best predictive ability was history of cardiopulmonary disease + more than 4 previous exacerbations in previous yr (Se 75%, Sp 47%)
| | | | Predictors of hospitalization
| | | | (multivariable analysis):
| | | | • Presence of comorbid cardiopulmonary disease
| | | | • Duration of COPD
| | | | • History of smoking (ever or current)
Emerman, Effron, and Lukens, 1991 | Design: Prospective cohort | N = 83 | Interventions: All pts received hrly administration of a beta-agnonist, by hand-held nebulizer, and oxygen by nasal cannula; aminophylline given absed on initial theophylline level; steroids administered at the discretion of the treating physician | Hospitalization rate: 37/83 pts (45%) | No validation of predictors or criteria in separate grp of pts
| Dates: 10/88-3/89 | Setting: ED of a large, urban, county medical center | Outcome(s) of interest: Relapse = return to ED or admission to hospital within 48 hrs of discharge from ED | Relapse rate: 8/46 pts (17%)
| Location: Cleveland, OH | Inclusion (COPD): Clinical diagnosis of chronic bronchitis (chronic sputum production of 3 mos' duration for at least 2 yrs) and/or history of emphysema (clinical evidence of lung hyperinflation during a stable period) | Predictors considered: Age, sex, cigarette use (pack-yrs), WBC count, PaO_2_, PaCO_2_, pH, pretreatment FEV_1_, posttreatment FEV_1_, aminophylline treatment in ED, steroid treatment in ED, number of aerosol bronchodilator treatments in ED, length of treatment in ED | Predictors of relapse (univariable analysis):
| Assessment period: 48 hrs after discharge from ED | Inclusion (AcEx): ATS criteria (1987) | Analytic method(s): Univariable analysis | • Lower pretreatment FEV_1_ (0.66±0.31 vs. 0.98±0.45; p< 0.001)
| External validity: 2/4 | Exclusion: Age < 50 yrs, asthma, other acute condition (e.g., pneumonia, acute CHF, or pneumothorax) | | • Older age (65.3±8.6 vs. 60.2±8.3; p < 0.05)
| COPD dx- | Smoking history: 77% current or past users; 51.5±24.1 pack yrs | | • Female sex (27/43 women vs. 18/40 men; p < 0.05
| COPD b- | Baseline stable FEV_1_: N/S | | • Greater number of aerosol treatments in ED (2.6±1.0 vs. 1.7±0.9; p < 0.01)
| AECB dx+ | FEV_1_ at admission: 0.81 | | • Other predictors considered (see list at left) not significant
| AECB sev+ | Age: 63.0±8.8 | | Performance of proposed hospital admission criteria:
| Internal validity: Level 3 | Sex: 40 M (48%), 43 F 52%) | | • Posttreatment FEV_1_ < 40% pred normal: Se 0.96 (43/45, Sp 0.58 (22/38)
| | Race: N/S | | • Posttreatment FEV_1_ < 70% baseline FEV_1_: Se 0.83 (24/29, Sp 0.56 (14/25)
| | | | • Pretreatment FEV_1_ < 30% pred normal: Se 0.76 (34/45), Sp 0.58 (22/38)
| | | | • Less than 10% increase in FEV_1_ after treatment: Se 0.44 (20/45), Sp 0.39 (16/41)
| | | | • PaO_2_ < 60 mm Hg: Se 0.46 (16/35), Sp 0.85 (11/13)
| | | | • PaCO_2_ > 45 mm Hg: Se 0.23 (8/35), Sp 0.92 (12/13)
Fedullo, Swinburne, and McGuire-Dunn, 1986 | Design: Retrospective cohort | N = 24 | Interventions: Not standardized, not described | Hospitalization rate: 17/24 pts (71%) | No validation of predictors in separate grp of pts
| Dates: 5 wks in 1982 (precise dates N/S) | Setting: ED of general hospital | Outcome(s) of interest: Admission to hospital | Predictors of hospitalization (univariable analysis):
| Location: Rochester, NY | Inclusion (COPD): “Underlying chronic obstructive lung disease”; diagnostic criteria N/S | Predictors considered: Age, duration of breathlessness, heart rate, respiratory rate, wheezing (by auscultation); peripheral edema, body temperature, arterial pH, arterial pH < 7.30, PaCO_2_, PaO_2_, WBC count | Significant (p < 0.05) independent predictors:
| Assessment period: To time of discharge or admission to hospital | Inclusion (AcEx): Primary complaint of shortness of breath | Analytic method(s): Univariable analysis | • Body temperature (°C): Admitted pts, 37.8 ± 1.1 (SD); nonadmitted pts, 36.8 ± 0.5
| External validity: ¼ | Exclusion: N/S | | • Arterial pH: Admitted pts, 7.35 ± 0.08; nonadmitted pts, 7.44 ± 0.06
| COPD dx- | Smoking history: N/S | | • PaCO_2_ (mm Hg): Admitted pts, 50.8 ± 14.4; nonadmitted pts, 33.5 ± 13.3
| COPD bl- | Baseline stable FEV_1_: N/S | | • PaO_2_ (mm Hg): Admitted pts, 46.9 ± 17.7; nonadmitted pts, 65.8 ± 24.5
| AECB dx- | FEV_1_ at admission: N/S | | Not significant (p ≥ 0.05):
| AECB sev+ | Age: 69.4 ± 6.3 (SD) | | • Age: Admitted pts, 69.5 ± 6.1; nonadmitted pts, 69.3 ± 7.3
| Internal validity: Level 3 | Sex: N/S | | • Duration of breathlessness (days): Admitted pts, 4.2 ± 4.5; nonadmitted pts, 4.3 ± 4.8
| | Race: N/S | | • Heart rate: Admitted pts, 109.6 ± 19.2; nonadmitted pts, 99.7 ± 27.1
| | | | • Respiratory rate: Admitted pts, 32.7 ± 7.4; nonadmitted pts, 29.4 ± 8.5
| | | | • Wheezing: 65% of admitted pts vs. 57% of nonadmitted pts
| | | | • Peripheral edema: 35% of admitted pts vs. 14% of nonadmitted pts
| | | | • Arterial pH < 7.30: 29% of admitted pts vs. 0% of nonadmitted pts
| | | | • WBC count: Admitted pts, 10.6 ± 4.2 × 10^9^/L; nonadmitted pts, 8.9 ± 1.2 × 109/L
Murata, Gorby, Chick, et al., 1989 | Design: Retrospective cohort | N = 268 consecutive pts, 37% hospitalized as result of index ED visit (data from these pts not analyzed further) | Interventions: Not standardized; varying combinations of low-flow oxygen, nebulized bronchodilators, parenteral aminophylline, antibiotics, and corticosteroids | Relapse rate: 23% (pts with COPD only) | Analysis of predictors of relapse also included 94 pts with asthma and 134 pts with mixed features of asthma and COPD
| Dates: 4/85-8/87 | Setting: ED of the Albuquerque Veterans | Outcome(s) of interest: Relapse = return to ED within 14 days after discharge from ED | Predictors of relapse (univariable analysis, all pts):
| Location: Albuquerque, NM | Affairs Medical Center | Predictors considered: Time of admission to ED (daytime vs. evening vs. nighttime); day of admission (Mon, Tues, etc.); season of admission (spring, summer, etc.); LOS | Significantly increased risk of relapse:
| Assessment period: 14 days after index ED visit | Inclusion (COPD): Baseline PFTs consistent with obstructive lung disease, with < 15% improvement in FEV_1_ after inhaled bronchodilators | Analytic method(s): Univariable | • Nighttime vs. day or evening presentation (p = 0.013)
| External validity: 2/4 | Inclusion (AcEx): ED discharge diagnosis of exacerbation of COPD; pts with discharge diagnosis of shortness of breath or bronchitis also included if they had been treated with nebulized bronchodilators and their baseline FEV_1_ (within previous 3 yrs) was < 70% predicted and < 70% of FVC | | • Weekend vs. weekday presentation (34.6% vs. 26.6% p = 0.049)
| COPD dx+ | Exclusion: Left heart failure, pneumoni, pneumothorax, visit for dyspnea within 2 wks, asthma, $ 15% improvement in FEV_1_ after inhaled bronchodilators | | Did not significantly affect risk of relapse:
| COPD bl+ | Smoking history: N/S | | • Season of admission (p = N/S)
| AECB dx- | Baseline stable FEV_1_: 1.45 ± 0.67 L = 46.3% ± 20.6% predicted | | • Length of ED stay (p = N/S)
| AECB sev- | FEV_1_ at admission: N/S
| Internal validity: Level 3 | Age: N/S
| | Sex: N/S
| | Race: N/S
Murata, Gorby, Chick, et al., 1991 | Design: Retrospective cohort | N = 352 consecutive pts (269 with at least 1 ED discharge) | Interventions: Not standardized; varying combinations of low-flow oxygen, nebulized bronchodilators, IV aminophylline, parenteral adrenergic drugs, antibiotics, and corticosteroids | Hospitalization rate: 280/1157 visits = 24% (measured in pts with at least 1 ED discharge only; see note) | Hospitalization rate excludes 83 pts who were admitted on every visit during the study period; thus, total hospitalization rate is somewhat higher than figure given at left
| Dates: 3-yr period, dates N/S | Setting: ED of the Albuquerque Veterans Affairs Medical Center | Outcome(s) of interest: Relapse = return to ED within 14 days of discharge | Relapse rate: 281/877 visits = 32%
| Location: Albuquerque, NM | Inclusion (COPD): Physician diagnosis of COPD, emphysema, asthma, or bronchitis, and baseline (within previous 3 yrs) FEV_1_ < 80% predicted and < 80% of FVC both before and after inhaled bronchodilators | Predictors considered: No. of nebulizer treatments; use of parenteral adrenergic drugs; oral prednisone at entry; oral prednisone on discharge; duration of dyspnea; temperature; pulse; respiratory rate; FEV_1_ at entry; FEV_1_ at discharge; ABG (pH, PaO_2_, PaCO_2_, O_2_ sat); hematocrit; WBC count; IV corticosteroids in ED; IV aminophylline used in ED; antibiotics on discharge; new bronchodilator added on discharge; percent recovery of baseline FEV_1_; ED diagnosis asthma versus COPD; change in sputum | Predictors of relapse (univariable analysis, by visit):
| Assessment period: 14 days after index ED visit | Inclusion (AcEx): Complaint of dyspnea, cough, and/or excessive sputum production | Analytic method(s): | • Shorter duration of dyspnea (p = 0.002)
| External validity: 4/4 | Exclusion: Pneumonia, pneumothorax, PE, pleural effusion, occupational lung disease, or pulmonary fibrosis; pts with left heart failure who were not treated with bronchodilators in ED | • Multivariable linear regression | • Lower entry FEV_1_ (p = 0.027)
| COPD dx+ | Smoking history: N/S | • Univariable analysis | • Lower discharge FEV_1_ (p = 0.04)
| COPD bl+ | Baseline stable FEV_1_: 1.38 ± 0.58 L = 43.8% ± 17.4% predicted | | • Greater no. nebulized bronchodilator treatments (p = 0.009)
| AECB dx+ | Bronchodilator response (avg % change in FEV_1_): 8.0% | | • More frequent use of parenteral adrenergic drugs (p = 0.006)
| AECB sev+ | FEV_1_ at admission: 0.74 ± 0.38 | | • Less frequent use of oral prednisone on discharge (p = 0.016)
| Internal validity: Level 3 | Age: 65.8 ± 8.7 | | Predictors of relapse (univariable analysis, by pt):
| | Sex: 266 men (99%), 3 women (1%) | | • Greater bronchodilator response on baseline FEV_1_ than nonrelapsers (p = 0.047)
| | Race: N/S | | • More bronchodilator treatments in ED (p = 0.001)
| | | | • More frequent use of parenteral adrenergic drugs (p = 0.006)
| | | | Predictors of relapse (multivariable analysis): Linear regression to predict number of relapse visits per pt. Response index, number of nebulizer treatments, use of parenteral adrenergic drugs, oral prednisone on discharge were independent predictors; overall model was highly significant (p<0.001), but explained little variance in relapse number (multiple R^2^ = 0.202)
Murata, Gorby, Kapsner, et al., 1992a | Design: Retrospective cohort | N = 289 consecutive pts (218 pts with 1, 008 ED visits in training phase; 159 pts with 476 ED discharges in validation phase, including 88 pts who also were treated during training phase) | Interventions: Not standardized; not described; all treatment decisions made by attending physician on duty | TRAINING SET | Results are similar when the following possible confounders are removed from the validation set: (1) pts with multiple visits; (2) pts who also were in the training set
| Dates: Training set, 1985-1988 validation set, 1988-1990 | Setting: ED of the Albuquerque Veterans Affairs Medical Center | Outcome(s) of Interest: Relapse = pt returns to ED within 48 hrs of discharge with shortness of breath and is treated with bronchodilators | Hospitalization rate: 303/1, 008 visits = 301% | Authors attempted to discriminate between pts who ever relapsed vs. never relapsed, but this was unsuccessful.
| Location: Albuquerque, NM | Inclusion (COPD): Physician diagnosis of COPD, bronchitis, or emphysema and baseline (within previous 3 yrs) FEV_1_ < 75% predicted and < 75% of FVC both before and after inhaled bronchodilators | Predictors considered: Pt age; time of day; LOS in ED; admission rate for previous visits; relapse rate for previous visits; previous visit within 7 days; use of home oxygen or prednisone at entry; temperature; pulse; respiratory rate; no. of doses of nebulized bronchodilators; use of parenteral sympathomimetics, intravenous corticosteroids, aminophylline, antibiotics, and tapered doses of prednisone at discharge | Relapse rate: 82/705 visits = 12% | Study population overlaps substantially with population in Murata, Gorby, Kapsner, et al., 1992b
| Assessment period: 14 days after index ED visit | Inclusion (AcEx): Chief complaint of increased shortness of breath | Analytic method(s): Multivariable logistic regression | Predictors of relapse (multivariable analysis):
| External validity: 2/4 | Exclusion: Left heart failure, pleural effusion, PE, interstitial lung disease, occupational lung disease, pneumonia, pneumothorax, clinical features of asthma (onset before age 40 yrs, history of eczema, atopic dermatitis, multiple allergies or aspirin sensitivity, or minimal symptoms between episodes of respiratory decompensation), visit for dyspnea within previous 2 wks | | Increased risk of relapse:
| COPD dx+ | Smoking history: N/S | | • High relapse rate for previous visits
| COPD bl+ | Baseline stable FEV_1_: 1.26 ± 0.49 L = 40.4% ± 15.1% predicted | | • Use of aminophylline
| AECB dx- | Bronchodilator response (avg % change in FEV_1_): 17.0% ± 17.6% | | • Use of antibiotics at discharge
| AECB sev- | FEV_1_ at admission: N/S | | • No. of doses of nebulized bronchodilators
| Internal validity: Level 3 | Age: 66.8 ± 7.4 | | • Previous visit within 7 days
| | Sex: N/S | | Decreased risk of relapse:
| | Race: N/S | | • Long-term oxygen therapy
| | | | • Use of prednisone at discharge
| | | | VALIDATION SET
| | | | Relapse rate: 47/476 visits = 9.9%
| | | | High- vs. low-risk (based on prediction model) pt relapse rates: 18% (27/147) vs. 6.1% (20/329)
| | | | SE 57%
| | | | SP 72%
| | | | LR+
| | | | LR-
| | | | Predictors of relapse: All of the above predictors of relapse were validated except:
| | | | • Use of antibiotics at discharge
| | | | • Long-term oxygen therapy
Murata, Gorby, Kapsner, et al., 1992b | Design: Retrospective cohort | N = 213 consecutive pts (training), 92 (validation) | Interventions: Not standardized, not described | TRAINING SET | Study population overlaps substantially with population in Murata, Gorby, Kapsner, et al., 1992a
| Dates: Training set, 1985-1988 validation set, 1988-1990 | Setting: ED of the Albuquerque Veterans Affairs Medical Center | Outcome(s) of Interest: Relapse = hospital admission within 14 days after ED visit for COPD exacerbation | Hospitalization rate: 210/693 visits = 30%
| Location: Albuquerque, NM | Inclusion (COPD): Physician diagnosis of COPD, bronchitis, or emphysema and baseline (within previous 3 yrs) FEV_1_ < 75% predicted and < 75% of FVC both before and after inhaled bronchodilators | Predictors considered: Pt age; day of wk; time of day; baseline pre- and post-bronchodilator PFTs (FEV_1_, VC, FEV_1_/FVC ratio); bronchodilator response (change in FEV_1_, % of baseline); no. of previous visits; no. of previous admissions; no. of previous relapses (return to ED within 48 hrs of discharge); previous visit within 7 days; previous visit resulted in admission; admission rate for previous visits; relapse rate for previous visits; proportion of past discharges in which conservative therapy was used | Predictors of hospitalization (multivariable analysis):
| Assessment period: 14 days after index ED visit | Inclusion (AcEx): Chief complaint of increased shortness of breath | Analytic method(s): Multivariable logistic regression with dependent variable log odds for admission | Significant independent predictors:
| External validity: 2/4 | Exclusion: Pneumonia, pneumothorax, pleural effusion, PE, left ventricular failure, or clinical features of asthma (based on onset before age 40 yrs, history of eczema, atopic dermatitis, multiple allergies or aspirin sensitivity, or minimal symptoms between episodes of respiratory decompensation); previous visit for dyspnea within previous 2 wks | | • Admission rate for previous visits
| COPD dx+ | Smoking history: N/S | | • Relapse rate for previous visits
| COPD bl+ | Baseline stable FEV_1_: 1.25 ± 0.49 L = 40.2% ± 15.2% predicted | | • Proportion of past discharges in which conservative therapy was used
| AECB dx- | Bronchodilator response (avg % change in FEV_1_): 18.4% ± 17.2% | | • Postbronchodilator FEV_1_ (baseline) % of predicted
| AECB sev- | FEV_1_ at admission: N/S | | • Postbronchodilator FEV _1_/FVC ratio (baseline), %
| Internal validity: Level 3 | Age: 66.9 ± 6.9 | | VALIDATION SET
| | Sex: 211 men (99%), 2 women (1%) | | Hospitalization rates:
| | Race: N/S | | • Overall: 76/269 visits (28%)
| | | | • Low risk 98 (36%)
| | | | • High risk 171 (64%)
| | | | Admission rate (high- vs. low-risk):
| | | | 40% (68/171) vs. 8.2% (8/98)
| | | | RR = 4.9 (2.5 to 9.8)
| | | | Se 90%
| | | | Sp 47%
Parshall, 1999 | Design: Prospective cohort | N = 239 visits to ED; no more than 4% of visits coded as follow-up visits of any kind; repeat enrollment unlikely due to survey sampling strategy | Interventions: Not standardized, not described | Hospitalization rate: 131/239 visits (55%) | Based on data prospectively gathered in 1992 National Hospital Ambulatory Medical Care Survey (National Center for Health Statistics, 1995)
| Dates: 1992 | Setting: 437 EDs in nonfederal hospitals in the U.S. (National Hospital Ambulatory Medical Care Survey as a whole; number of EDs supplying COPD pts not specified) | Outcome(s) of Interest: Admission to hospital | Predictors of hospitalization (univariable analysis): | Also included data on pts with asthma without COPD (n = 395), CHF (n = 320), mixed asthma and COPD (n = 18), and chronic restrictive disease (n = 14)
| Location: United States (various locations) | Inclusion (COPD): Physician diagnosis | Predictors considered: Age; presence of dyspnea (defined to include pt reports of shortness of breath, labored or difficult breathing, wheezing or asthma [so described by pt], and miscellaneous breathing conditions [e.g., painful or rapid breathing]); urgency of visit (dichotomized as urgent/emergent = “pt requires immediate attention for acute illness or injury that threatens life or function; delay would be harmful to the pt” vs. nonurgent = “pt does not require attention immediately or within a few hrs”); use of IV fluids; use of bronchodilators (β-agonists or methylxanthines) | Significant independent predictors: | 17 pts included in the COPD grp (7%) were diagnosed with both COPD and CHF; 88% of these (15/17) had breathing symptoms as the primary or only reason for the ED visit
| Assessment period: Up to time of discharge or admission to hospital | Inclusion (AcEx): N/S; 78% of pts were dyspneic on presentation | Analytic method(s): | • Use of IV fluids (Se 0.70; Sp 0.82; OR 10.0, p < 0.0001); 92/111 pts receiving IV fluids admitted to hospital (83%) vs. 39/128 not receiving IV fluids (30%)
| External validity: 0/4 | Exclusion: N/S | • Univariable analysis | • Dyspnea (Se 0.83; Sp 0.28; OR 1.9, p = 0.04); 109/187 pts with dyspnea admitted (58%) vs. 22/52 w/o dyspnea (42%)
| COPD dx- | Smoking history: N/S | • Multivariable logistic regression | • Urgency of visit (Se 0.93; Sp 0.35; OR 7.4, p < 0.0001); 122/192 urgent/ emergent pts admitted (64%) vs. 9/47 nonurgent pts (19%); lack of standardization of triage categories across participating sites and the cutpoint used make interpretation of these results difficult
| COPD bl- | Baseline stable FEV_1_: N/S | | Not significant:
| AECB dx- | FEV_1_ at admission: N/S | | • Use of bronchodilators (Se 0.74; Sp 0.18; OR 0.65); 71/126 pts treated with bronchodilators were admitted (56%) vs. 60/113 not treated with bronchodilators (53%)
| AECB sev- | Age: 66.6 ± 11.9 | | • Age
| Internal validity: Level 1 | Sex: 121 men (51%), 118 women (49%) | | Predictors of hospitalization (multivariable analysis, excluded urgency):
| | Race: 91% white, 8% African-American | | • Use of IV fluids strongest predictor
| | | | • No other independent predictors
Inpatient Studies
Bone, Pierce, and Johnson, 1978 | Design: Prospective cohort | N = 50 (Dallas), 73 (Kansas) | Interventions: Not standardized; included oxygen therapy, IV aminophylline, replacement fluids, inhaled bronchodilators, postural drainage with chest percussion, and antimicrobial agents if the sputum was purulent | MV needed: | Time to greatest hypercapnea variable, 8 ± 7 hrs
| Dates: 10/72-3/74 (Dallas); Sep 9/74-12/76 (Kansas) | Setting: Respiratory intensive care units of two acute care hospitals | Dallas pts received oxygen 24% by Venturi mask (increased to 28% if hypoxemia remained severe); Kansas pats received low-flow oxygen (1 L/min) initially, subsequently adjusted to obtain PaO_2_of 50–60 mm Hg | 13/50 (26%), Dallas
| Location: Dallas, TX and Kansas City, KS | Inclusion (COPD): Clinical, not described | Outcome(s) of Interest: Need for MV (invasive) when pt became stuporous and unable to cooperate with therapy (not based on blood gas criteria) | 16/73 (22%), Kansas
| Assessment period: | Inclusion (AcEx): Clinical deterioration of steady state symptoms for hrs to days preceding admission | Predictors considered: Age, sex, baseline stable spirometry, baseline stable blood gases, and blood gases measured on hospital admission | Predictors of need for MV:
| External validity: 2/4 | Exclusion: Intubation in ED, history of tranquilizer or sedative use | Analytic method(s): Discriminant analysis | • Blood gas values (PaO_2_ , PaCO_2_, pH) on admission
| COPD dx- | Smoking history: N/S | | • Change in pH after initial oxygen therapy (p < 0.05)
| COPD bl+ | Baseline stable FEV_1_: 0.67 ± 0.27 (Dallas) | | Not predictive:
| AECB dx- | FEV_1_ at admission: N/S | | • Age
| AECB sev+ | Age: 56.5 +/- 8.3 (Dallas) | | • Sex
| Internal validity: Level 3 | Sex: 22/50 men (44%) (Dallas) | | • Baseline stable spirometry
| | Race: N/S | | • Initial response to oxygen therapy (PaO_2_ increase, PaCO_2_ increase)
| | | | Clinical prediction rule:
| | | | pH < -0.00919*PaO_2_ - 7.66
| | | | Se 10/13 = 77% Sp 34/37 = 92%
| | | | Validation (Kansas):
| | | | Se 13/16 = 81% Sp 48/57 = 84%
Burk and George, 1973 | Design: Retrospective cohort | N= 74 treated for 166 episodes | Interventions: Controlled oxygen administration, measures to decrease airway obstruction, and close monitoring; MV employed when “pts were comatose and unable to breathe or cough effectively, or when conservative management was not effective” | Hospital mortality rate: 26% | Includes data from MV using tracheostomy tube
| Dates: 1966-1970 | Setting: Veterans Affairs hospital general medical ward (1966-May 1970) and ICU (May-Dec 1970) | Outcome(s) of Interest: (1) Hospital mortality; (2) survival at 1 yr | Predictors of hospital mortality (univariable analysis): | Small sample size; poor statistical methodology further impaired statistical power
| Location: New Orleans, LA | Inclusion (COPD): Clinical diagnosis of chronic bronchitis, emphysema, or a combination of two | Predictors considered: FEV_1_ , age, etiology of acute respiratory failure (ARF) | • Use of MV vs. conservative care associated with higher hospital mortality, 42% vs. 14% (p < 0.01)
| Assessment period: 6 mos following index hospitalization | Inclusion (AcEx): Acute respiratory failure, defined as PaCO_2_ ≥ 50 mm Hg and/or PaO_2_ < 50 mm Hg, plus rapid deterioration in the clinical status of the pt | Analytic method(s): Univariable analysis, correlation coefficients (instead of survival -analysis) | • ICU vs. general medical ward associated with lower hospital mortality, 19% vs. 32%
| External validity: ¼ | Exclusion: Post-operative pts, trauma to chest | | • Etiology of ARF (respiratory infection vs, CHF), 21% (19/91) vs, 31% (18/59)
| COPD dx- | Smoking history: 100% “long-term smokers” | | Survival at 1 yr: 54%
| COPD bl- | Baseline stable FEV_1_: For 41 pts, “severe obstructive ventilatory impairment, which in most cases improved only slightly after isoproterenol” | | Predictors of 1-yr survival (univariable analysis):
| AECB dx- | FEV_1_ at admission: N/S | | • FEV_1_ not significant (r = -0.36; p = 0.08)
| AECB sev+ | Age: 64 (mean); range, 43–87 | | • Age not significant (r = -0.21; p = 0.31)
| Internal validity: Level 3 | Sex: 73 men (99%), 1 woman (1%)
| | Race: NS
Connors, Dawson, Thomas et al., 1996 | Design: Prospective cohort | N = 1,016 | Interventions: Not described | Survival data: | Etiology of exacerbation: Respiratory infection, 48%; other infection, 3%; CHF, 26%; arrhythmia, 4.8%; PE, 1.4%, pneumothorax, 1%; post-op, 1.6%; lung Ca, 3.3%
| Dates: 6/89-6/91 | Setting: Respiratory intensive care units of acute care hospitals | Outcome(s) of Interest: Survival at 180 days | • 89% survived hospital stay
| Location: Hospitals in Boston, MA; Durham, NC; Cleveland, OH; Marshfield, WI; Los Angeles, CA | Inclusion (COPD): Clinical diagnosis of COPD recorded in the chart by a physician | Predictors considered: Acute physiology score, Activities of Daily Living (ADL) score, BMI, albumin, age, heart rate, PaO _2_ /FiO_2_, Duke Activity Status Index, cor pulmonale, CHF, pH, PaCO_2_ , number of comorbid illnesses, history of heart disease, infection as cause of acute exacerbation of COPD | • 80% survived 2 mo
| Assessment period: 6 mos following index hospitalization | Inclusion (AcEx): Breathlessness, respiratory failure, or change in mental status due to COPD as main reason for admission; documentation of hypercapnia (PaCO_2_ > 50 mm Hg) within 1 wk of admission | Analytic method(s): | • 67% survived 6 mo
| External validity: ¼ | All pts met general SUPPORT study criteria, which were designed to identify people with a 20%–80% 6-mo mortality | • Univariable analysis | • 58% survived 1 yr (K-M estimate)
| COPD dx- | Exclusion: Age ≤ 18, death or discharge within 48 hrs of hospitalization, inability to speak English, acute psychiatric disorders, pregnancy, AIDS, acute burns, head trauma, other trauma | • Multivariable logistic regression analysis | • 51% survived 2 yr (K-M estimate)
| COPD bl- | Smoking history: N/S | | Lower survival in pts requiring MV (n = 348, 57% 180-d survival) or an ICU stay (n = 526, 63% 180-d survival)
| AECB dx- | Baseline stable FEV_1_: N/S | | Readmission during 6 mo after discharge: 754 readmissions involving 446 pts (50% of pts discharged)
| AECB sev+ | FEV_1_ at admission: N/S | | 180-day mortality by no. of readmissions:
| Internal validity: Level 1 | Age: 70 (median), 63–77 (IQR) | | • 0 readmissions - 21%
| | Sex: 52% male | | • 1 readmission - 27%
| | Race: 87% white; 10% black, 3% other races | | • 2 readmissions - 31%
| | | | • 3 readmissions - 36%
| | | | LOS data:
| | | | • 53% of pts spent at least 1 day in ICU
| | | | • 35% required MV
| | | | • Median LOS in hospital, 9 days (5–15)
| | | | • Median LOS in ICU, 2 days (0–6)
| | | | • Median LOS for readmissions, 8 days (5–14)
| | | | Median cost of hospital stay: $7,400 ($4,100–$16,000)
| | | | Predictors of 180-day survival (univariable analysis):
| | | | • Acute physiology score
| | | | • ADL
| | | | • BMI
| | | | • Albumin
| | | | • Age
| | | | • Heart rate
| | | | • PaO_2_/FiO_2_
| | | | • Duke Activity Status Index
| | | | • Cor pulmonale (associated with longer survival)
| | | | • CHF (associated with longer survival)
| | | | Predictors of 180-day survival (multivariable analysis):
| | | | • Acute physiology score
| | | | • BMI
| | | | • Age
| | | | • Functional status 2 wks prior to admission
| | | | • PaO_2_/FiO_2_
| | | | • CHF
| | | | • Albumin
| | | | • Cor pulmonale
| | | | Validation in separate set shows good calibration and fair discrimination (c = 0.731)
Dardes, Campo, Chiappini, et al., 1986 | Design: Prospective cohort | N = 152 consecutive pts | Interventions: All pts treated with IV aminophylline, methylprednisolone, antibiotics, and low flow oxygen; MV by tracheal intubation employed as needed | Hospital mortality rate: 15% (23/152) overall; for mechanically ventilated pts, the hospital mortality rate was 73% (11/15) | No validation of predictors in independent grp of pts
| Dates: 7/77-6/84 | Setting: Hospital Dept. of Internal Medicine | Outcome: Hospital mortality; long-term follow-up mortality | Predictors of hospital or long-term mortality (univariable analysis): | Abstract containing limited data
| Location: Rome, Italy | Inclusion (COPD): ATS diagnostic criteria | Predictors considered: Baseline stable PaO_2_ and PaCO_2_; no. of readmissions during follow-up period | • Baseline stable PaO_2_ and PaCO_2_ not significant predictors (r = 0.24) | Uncertain whether study was prospective
| Assessment period: To death or up to 7 yrs | Inclusion (AcEx): Acute respiratory failure, defined as sudden worsening of clinical conditions with hypoxemia (PaO_2_ < 50 mm Hg) and/or hypercapnia (PaCO_2_ > 50 mm Hg) | Analytic method(s): Univariable parametric tests (Student's t test) | • No. of readmissions during follow-up period not significant predictor (r = 0.35) | ARF due in most cases to acute exacerbation of bronchitis, defined as an increase in cough, dyspnea and sputum production, with a change in sputum color or volume occurring within the days prior to hospitalization
| External validity: 2/4 | Exclusion: N/S
| COPD dx+ | Smoking history: 100% had a “history of heavy cigarette use”
| COPD bl- | Baseline stable FEV_1_: N/S
| AECB dx- | FEV_1_ at admission: N/S
| AECB sev+ | Age: 69 ± 8
| Internal validity: Level 3 | Sex: 108 men (71%), 44 women (29%)
| | Race: N/S
Fuso, Antonelli Incalazi, Pistelli, et al., 1995 | Design: Retrospective cohort | N = 590 consecutive pts | Interventions: All pts treated with: (1) Oxygen via Venturi mask, adjusted to achieve oxygen saturation of at least 85% by pulse oximeter; (2) antibiotics; (3) corticosteroids; (4) aerosolized albuterol; (5) aerosolized ipratropium bromide | Inhospital mortality rate: 14% (85/590); | No validation of predictors in independent grp of pts
| Dates: 1981-1990 | Setting: Pneumology unit in university hospital | Outcome(s) of Interest: | Predictors of inhospital mortality (univariable analysis): | MV required in 130/590 cases (22%); endotracheal intubation in 37/590 (6.3%)
| Location: Rome, Italy | Inclusion (COPD): ATS diagnostic criteria | Short-term (in-hospital) mortality | • Age
| Assessment period: To death or discharge | Inclusion (AcEx): Increasing dyspnea reducing usual performance as assessed by the ADL scale, with or without changes in sputum production, blood temperature, and body weight, and occurring within the 5 days prior to hospitalization | Predictors considered: Age, alveolar-arterial oxygen gradient (PA-aO_2_) on oxygen for at least 2 hrs, need for MV, atrial fibrillation, previous myocardial infarction, ventricular arrhythmias, use of digitalis, chronic renal failure, pneumonia on roentgenogram, pulmonary edema on roentgenogram, use of diuretics | • Higher PA-aO_2_
| External validity: ¾ | Exclusion: N/S | Analytic method(s): | • Need for MV (35% mortality vs. 8.7%, p < 0.001)
| COPD dx+ | Smoking history: 100% had a “history of heavy cigarette use” | • Univariable parametric tests | • Atrial fibrillation
| COPD b- | Baseline stable FEV_1_: N/S | • Multivariable logistic regression analysis with death as dependent variable | • Previous myocardial infarction
| AECB dx+ | FEV_1_ at admission: N/S | • Goodness of fit (Hosmer-Lemeshow test) | • Ventricular arrhythmias
| AECB sev+ | Age: 67.9 ± 10.2 | | • Use of digitalis
| Internal validity: Level 2 | Sex: 464 men (79%), 126 women (21%) | | Predictors of inhospital mortality (multivariable analysis):
| | Race: N/S | | • Age
| | | | • PA-aO_2_ > 41 mm Hg
| | | | • Atrial fibrillation
| | | | • Ventricular arrhythmias
| | | | Goodness-of-fit value of 12.1 (p = 0.15) suggests that the model fits the data well
Heuser, Case, Ettinger, 1992 | Design: Retrospective cohort | N = 3050 consecutive admissions of pts age 50 yrs or older with disease of the lower respiratory tract; 813 had asthma or bronchitis | Interventions: Not described; all pts treated in ICU | Inhospital mortality rate: 6.7% (51/762 episodes of asthma or bronchitis) | Purpose was not to predict outcome for individual pts, but rather to study effect of age on adjusted mortality rates
| Dates: 7/87-12/88 | Setting: Intensive care units of 78 US hospitals | Outcome: Short-term (in-hospital) mortality | Predictors of in-hospital mortality (multivariable analysis): | No validation of predictors in independent grp of pts
| Location: United States | Inclusion (COPD): Notation on admission history or physical exam form | Predictors considered: Age; sex; primary discharge diagnosis (asthma/bronchitis was reference case); MedisGroups ASG (0–4), based on clinical and lab data at time of initial evaluation; presence of comorbid conditions (DM, angina, CHF, COPD, stroke/TIA) | • Age
| Assessment period: To death or discharge | Inclusion (AcEx): Primary discharge diagnosis code in International Classification of Diseases, Ninth Revision, Clinical Modification category indicating asthma or bronchitis | Analytic method(s): | • Comorbid COPD
| External validity: 0/4 | Exclusion: N/S | • Univariable parametric tests | • Age-comorbid COPD interaction
| COPD dx- | Smoking history: N/S | • Multivariable logistic regression analysis with death as dependent variable | • Primary diagnosis pneumonia (note asthma bronchitis was reference case)
| COPD bl- | Baseline stable FEV_1_: N/S | | • ASG 3
| AECB dx- | FEV_1_ at admission: N/S | | • ASG 4
| AECB sev- | Age: 71 (median); range, 50–103 | | The age-comorbid COPD interaction term describes the following relationship: Younger pts with a history of COPD had less chance of dying in hospital than pts without COPD; after age 76 yrs, pts with COPD had a greater chance of dying in hospital than pts without COPD.
| Internal validity: Level 2 | Sex: 1522 men (50%), 1528 women (50%)
| | Race: N/S
Jeffrey, Warren, and Flenley, 1992 | Design: Prospective cohort | N = 95 pts with 139 emergency admissions | Interventions: All pts treated according to specific guidelines: (1) Oxygen given by nasal cannulae or Venturi mask, with levels adjusted to raise PaO_2_ above 50 mm Hg; (2) if, at any time during oxygen treatment, arterial pH fell below 7.26, a continuous IV infusion of doxapram (2 mg/min) was started and continued for 24 hrs; (3) if pH ≥ 7.26 at 24 hrs, then doxapram gradually discontinued; if pH still < 7.26 at 24 hrs, or if sudden deterioration in clinical state of pt, then assisted ventilation considered; (4) other management (e.g., treatment with bronchodilators, antibiotics, or by physiotherapy) left to discretion of responsible physician | Hospital mortality rate: 12% (17/139 episodes) | Validation of predictors of hospital mortality identified in Warren, Flenley, Millar et al., 1980
| Dates: N/S | Setting: Dept. of Respiratory Medicine Unit at City Hospital, Edinburgh, UK | Outcome(s) of interest: Hospital mortality | Predictors of hospital mortality (univariable analysis): | Guidelines concerning use of doxapram “not always adhered to;” doxapram given in 27 of the 39 episodes in which its use was indicated, and in an additional 10 cases in which its use was not indicated
| Location: Edinburgh, UK | Inclusion (COPD): Diagnostic criteria N/S | Predictors considered: | Measured at admission: | Lowest pH recorded immediately before death in only 4/17 cases (24%)
| Assessment period: To time of discharge or death | Inclusion (AcEx): Acute hypercapnic respiratory failure, defined as PaO_2_ < 50 mm Hg and PaCO_2_ > 50 mm Hg on admission when breathing room air (for pts on home oxygen, PaCO_2_ > 75 mm Hg); acute exacerbation of COPD defined as increased cough, increased and purulent sputum production, or increased dyspnea | Measured at time of admission: | • High blood urea concentration (p < 0.02): median 6.9 mmol/L (2.3 to 35.9) among survivors vs. 14.6 (4.0 to 35.5) among nonsurvivors
| External validity: 2/4 | Exclusion: “Unconvincing evidence” of a history of COPD; or radiographic evidence of a pneumothorax, bronchogenic carcinoma, pulmonary edema, or segmental or lobar pneumonia; or elective admission for assessment or respite care | Age, PaO_2_(on room air), PaCO_2_ (on room air), pH (on room air), hemoglobin, WBC, urea, sodium, potassium, alkaline phosphatase, AST, ALT, BP (systolic, diastolic), pulse, RVH, JVP | • Low systolic BP (p < 0.5): median 129 mm Hg (80 to 205) among survivors vs. 119 (90 to 160) among nonsurvivors
| COPD dx- | Smoking history: 53 current smokers (56%), 34 ex-smokers (36%), 8 denied ever having smoked (8%) | Measured at any time during hospitalization: | • Low arterial pH (p < 0.05): median 45 nmol/L (31 to 96) among survivors vs. 50 (41 to 72) among nonsurvivors
| COPD bl- | Baseline stable FEV_1_: N/S | PaO_2_, PaCO_2_, lowest pH < 7.26, lowest pH < 7.28, treatment with bronchodilators, treatment with steroids | Measured throughout hospital stay:
| AECB dx+ | FEV_1_ at admission: N/S | Analytic method(s): Univariable parametric and nonparametric tests (Student's t and Wilcoxon rank sum) | • Lowest pH < 7.26 (p < 0.05): Death occurred in 10/39 episodes (26%) in which lowest pH < 7.26, compared to 7/100 episodes (7%) in which lowest pH ≥ 7.26
| AECB sev+ | Age: 63.9 | | • Lowest pH < 7.28 (p < 0.001): Best discriminator of the likelihood of death on retrospective analysis; death occurred in 13/46 episodes (28%) in which lowest pH < 7.28, compared to 4/93 episodes (4%) in which lowest pH ≥ 7.28
| Internal validity: Level 3 | Sex: 55 men (58%), 40 women (42%)
| | Race: N/S
Loukides and Polyzogopoulos, 1996 | Design: Prospective cohort | N = 597 consecutive pts hospitalized for COPD exacerbation due to respiratory infection | Interventions: Not described | Average hospital LOS: | Diabetics were found to have gram negative sputum culture growth more often than nondiabetics
| Dates: 1992-1994 | Setting: Hospital pulmonary department | Outcome(s) of interest: Length of stay (LOS) in hospital | • Overall: 8.9 days
| Location: Athens, Greece | Inclusion (COPD): N/S | Predictors considered: Diabetes mellitus (DM); insulin-dependent diabetes mellitus (IDDM); noninsulin-dependent diabetes mellitus (NIDDM) | • Pts with COPD only: 8.53 ± 1.9
| Assessment period: To death or discharge | Inclusion (AcEx): Productive cough with purulent sputum | Analytic method(s): Univariable parametric tests (paired t-test) | • Pts with COPD + DM: 10.76 ± 2.7
| External validity: 2/4 | Exclusion: N/S | | • Pts with COPD + IDDM: 15.63 ± 3.62
| COPD dx- | Smoking history: 23 pack-yrs | | (p < 0.0001 vs. COPD-only grp)
| COPD bl- | Baseline stable FEV_1_: N/S | | • Pts with COPD + NIDDM: 7.69 ± 2.6
| AECB dx+ | FEV_1_ at admission: 1.2 L
| AECB sev+ | Age: 64.4
| Internal validity: Level 3 | Sex: 568 men (95%), 29 women (5%)
| | Race: N/S
Moran, Green, Homan, et al., 1998 | Design: Retrospective case series | N = 75 pts with 100 admissions | Interventions: Not standardized; included IV aminophylline, replacement fluids, inhaled bronchodilators, postural drainage with chest percussion, and antimicrobial agents if the sputum was purulent. | Hospital LOS: 17 days (4–97) | No validation of predictors in independent grp of pts
| Dates: 6/88-9/92 | Setting: Respiratory intensive care unit of acute care teaching hospital | Outcome(s) of interest: Hospital LOS; ICU LOS; ventilation before and during ICU stay; prolonged ICU ventilation; hospital survival | ICU LOS: 5 (1–40) days | Study also assessed survival beyond discharge and found age, previous ICU admission, and plasma albumin to be predictive of survival beyond hospitalization
| Location: Australia | Inclusion (COPD): Clinical diagnosis of COPD recorded in the chart, post-bronchodilator FEV_1_ < 50% predicted, and FEV_1_/FVC < 70% | Predictors considered: | Duration of MV: 4 (0.8–30) days
| Assessment period: 6 mos following index hospitalization | Inclusion (AcEx): Cough, increased sputum, dyspnea, cyanosis, labored respiration with use of accessory muscles of inspiration | Premorbid: Previous hospital admission, steroid and bronchodilator prescription, FEV_1_ and FVC, bronchodilator responsiveness, dyspnea index, home O_2_ prescription, body weight, comorbidity (CHF, IHD, HTN), smoking history (current, former, none) | Predictors of ICU LOS:
| External validity: ¾ | Exclusion: Pneumonia (based on fever, leukocytosis, purulent sputum and radiograph opacity), asthma, left ventricular failure, restrictive lung disease, or pulmonary embolus | At admission: Previous ICU admission; admission source (ward or ED); antibiotic Rx before admission; respiratory rate; ABG (PaO_2_/FiO_2_ ratio); respiratory index (alveolar-arterial O_2_ difference normalized by PaO_2_); temperature; heart rate; mean arterial pressure; leukocyte count; plasma sodium, potassium, creatinine, urea, and albumin concentrations; chest x-ray appearance; ventilation details; ICU therapeutics; tracheostomy; use of mask CPAP; initial sputum culture; acute physiology score (APACHE II) | Univariable
| COPD dx+ | Smoking history: 39% current, 37% former, 24% never | Analytic method(s): | • Ventilation
| COPD bl+ | Baseline stable FEV_1_: 0.70 ± 0.34 liters | • Univariable parametric tests chi-square and t-tests | • Ventilation time
| AECB dx+ | FEV_1_ at admission: N/S | • Stepwise multivariable logistic regression model | • Tracheostomy
| AECB sev- | Age: 68.5 ± 7 | • Multiple regression model | Multivariable
| Internal validity: Level 3 | Sex: 48 men (64%), 27 women (36%) | | • Ventilation time
| | Race: N/S | | Predictors of hospital LOS:
| | | | Univariable
| | | | • Admission status
| | | | • Tracheostomy
| | | | Multivariable
| | | | • Tracheostomy
| | | | Predictors of incidence of ventilation:
| | | | Univariable
| | | | • None
| | | | Multivariable
| | | | • None
| | | | Predictors of prolonged ventilation:
| | | | Univariable
| | | | • Tracheostomy
| | | | Multivariable
| | | | • Tracheostomy
| | | | Predictors of hospital survival:
| | | | Univariable
| | | | • None
| | | | Multivariable
| | | | • None
Mushlin, Black, Connolly, et al., 1991 | Design: Prospective cohort | N = 83 consecutive pts hospitalized for exacerbation of chronic pulmonary disease | Interventions: Not standardized; most pts treated with IV aminophylline, corticosteroids, oxygen, and oral or IV antimicrobial agents | Hospital LOS: 8.7 days (mean); range, 1–57; median, 6 | 45% had broncho-spasm as reason for admission, while over 50% were admitted with a diagnosis of AECB
| Dates: 11/86-late 1987 | Setting: Two acute care hospitals | Outcome(s) of interest: Hospital LOS ( ≤ 4 vs. ≥ 5 days) | No. of pts requiring admission to ICU: 8/83 (10%) | No validation of predictors in independent grp of pts
| Location: Rochester, NY | Inclusion (COPD): Clinical diagnosis of COPD or restrictive pulmonary disease or asthma, age ≥ 45 yrs; or Wheezing on examination; or Two of the following: | Predictors considered: N/S | ICU LOS: 7.4 days | No specification of the number and identity of predictors considered. Only those found to be significantly associated with LOS were identified
| Assessment period: To death or discharge | • History of smoking more than 40 packs/yr of cigarettes | Analytic method(s): | Hospital survival: 96% (80/83)
| External validity: 0/4 | • Past treatment with bronchodilator medications | • Univariable parametric (chi-square and t-tests) tests | Predictors of hospital LOS (univariable analysis):
| COPD dx- | • Findings indicating COPD on physical exam, chest x-ray, ABG (hypoxemia) or PFTs | • Stepwise multivariable logistic regression model | • No history of bronchospasm
| COPD bl- | Inclusion (AcEx): Dyspnea on exertion or shortness of breath as chief complaint | | • No wheezing on physical exam
| AECB dx- | Exclusion: Stable COPD, respiratory problems due to neuromuscular disease, transferred from another hospital, terminal illness | | • PaCO_2_ level > 44 mm Hg in ED
| AECB dx- | Smoking history: N/S | | • Theophylline level > 55 μmol/L in ED
| Internal validity: | Baseline stable FEV_1_: N/S | | • Baseline grade 4 symptom activity scale
| Level 3 | FEV_1_ at admission: N/S | | • Grade 2 or 3 change in SAS
| | Age: 68 | | • More than 1 attack in past yr
| | Sex: 30 men (36%), 53 women (64%) | | • Symptoms present for more than 1 day
| | Race: 84% white | | • Comorbid illness
| | | | • Bronchitis
| | | | • Upper respiratory tract infection
| | | | • Received antibiotics on day of admission
| | | | Predictors of hospital LOS (multivariable analysis):
| | | | • PaCO_2_ level > 44 mm Hg in ED
| | | | • Symptoms present for more than 1 day
| | | | • Received antibiotics on day of admission
Portier, Defouil-loy, Muir et al., 1992 | Design: Prospective cohort | N = 322 consecutive pts hospitalized for acute respiratory failure | Interventions: Not standardized | ICU mortality: 11% (35/322) | Study mixed pts with COPD and other causes of underlying chronic respiratory insufficiency.
| Dates: 1-yr period, dates N/S | Setting: Nine medical ICUs | Outcome(s) of interest: ICU mortality | ICU LOS: 15 ± 7.7 days | Precipitating factors were bronchial infection (54%), unilateral pneumonia (15%), iatrogenic factor (5.6%), bilateral pneumonia (5.3%), pneumo-thorax (3.9%), PE (2.2%) and unknown (14%).
| Location: France | Inclusion (COPD): Clinical diagnosis of COPD or other chronic respiratory insufficiency (45% of pts had COLD) | Predictors considered: Simplified Acute Physiology Score (SAPS), age, sex, existence of previous decompensation with or without MV, number of episodes of previous ARF, precipitating cause of ARF, initial ABG levels on RA, method of transport, origin, time between arrival at the hospital and start of active management, presence of concomitant risk factors | MV required: 52% | Pts more seriously ill than those in most other studies
| Assessment period: To death or discharge | Inclusion (AcEx): Sudden worsening of respiratory function, with cyanosis, dyspnea, impaired consciousness, and signs of respiratory muscle exhaustion confirmed by blood gas levels (PaO_2_ < 6 mm Hg and/or decompensated ventilatory acidosis, while breathing room air) | Analytic method(s): | Predictors of hospital mortality (univariable analysis): | No validation of predictors in independent grp of pts
| External validity: ¼ | Exclusion: Respiratory decompensation secondary to a toxic event, surgery or trauma; concomitant malignant disease | • Univariable parametric (chi-square and t-tests) tests | • Cachexia
| COPD dx- | Smoking history: N/S | • Multivariable recursive partitioning | • Previous confinement to home
| COPD bl- | Baseline stable FEV_1_: N/S | | • Presentation in coma
| AECB dx- | FEV_1_ at admission: N/S | | • Required MV in first 24 hrs
| AECB sev+ | Age: 65.5 ± 14.5 | | • Unspecified etiology or precipitant of ARF
| Internal validity: Level 1 | Sex: 225 men (70%), 97 women (30%) | | • Reduced systolic BP
| | Race: N/S | | • Elevated serum BUN
| | | | • Reduced serum sodium
| | | | • Elevated serum phosphate
| | | | • SAPS score
| | | | Predictors of hospital mortality (multivariable analysis):
| | | | • Cachexia
| | | | • Reduced serum sodium
| | | | • Required MV in first 24 hrs
| | | | • Not COPD as underlying chronic respiratory insufficiency
| | | | • Previous confinement to home
| | | | • Presence of edema
Seneff, Wagner, Wagner, et al., 1995 | Design: Prospective cohort | N = 362 admissions | Interventions: Not described | Hospital mortality rate: 24% | Mean LOS: ICU, 7 days; hospital, 25 days
| Dates:5/88-2/90 | Setting: ICUs at 42 US hospitals | Outcome(s) of interest: (1) Hospital mortality; (2) survival at 180 days | 180-day survivial rate: | ICU mortality: 9.4%
| Location: 42 ICUs at 40 US hospitals | Inclusion (COPD): Clinical diagnosis of COPD | Predictors considered: Acute physiology score, respiratory component (includes respiratory rate, pH, PaCO_2_ and PaO_2_ or PA-aO_2_); acute physiology score, nonrespiratory component (includes Glasgow Coma Score, heart rate, mean blood pressure, temperature, hematocrit WBC count, creatinine, urine output, serum urea nitrogen, sodium, albumin, and glucose); age; treatment location; no. of pre-ICU hospital days; use of MV; ADL | Predictors of hospital mortality (multivariable):
| Assessment period: 6 mos following index hospitalization | Inclusion (AcEx): ICU admission for respiratory failure without pulmonary embolus, pulmonary edema, or pneumonia | Analytic method(s): Multivariable logistic regression analysis and Cox proportional hazards regression | Significant predictors:
| External validity: ¼ | Exclusion: Operative pts | | • Nonrespiratory APS score
| COPD dx- | Smoking history: N/S | | • Number of pre-ICU hospital days
| COPD bl- | Baseline stable FEV_1_: N/S | | Not significant:
| AECB dx- | FEV_1_ at admission: N/S | | • Respiratory APS score
| AECB sev+ | Age: 66 | | • Age
| Internal validity: Level 1 | Sex: N/S | | • Use of MV on day 1 (n =170 = 47%)
| | Race: N/S | | • ADL
| | | | Predictors of 180-day survival (multivariable):
| | | | Significant predictors:
| | | | • Nonrespiratory APS score
| | | | • Respiratory APS score
| | | | • Number of pre-ICU hospital days
| | | | • Age
| | | | Not significant:
| | | | • ADL
Vitacca, Clini, Porta et al., 1996 | Design: Retrospective cohort | N = 39 | Interventions: Not standardized; all pts received oxygen 24–28% by Venturi mask; other therapies included theophylline, antibiotics, steroids and beta agonists or both; no pts received respiratory stimulants | MV needed: 14/39 (36%) | Potential “overfit” model (14/5 outcome/candidate predictors)
| Dates: N/S | Setting: Respiratory department of acute care hospital | Outcome(s) of interest: Need for MV (invasive or noninvasive) because of rapid deterioration in neurological status or an acute onset of respiratory distress (severe hypercapnia with PaCO_2_ > 65 mm Hg, acute decrease in pH < 7.35) or a worsening in tachypnea and the presence of paradoxic abdominal breathing pattern | Predictors of need for MV (univariable analysis): | No validation of predictors or criteria in separate grp of pts
| Location: Gussago, Italy | Inclusion (COPD): Spirometric criteria, according to ATS (1987) | Predictors considered: Anthropometric data, APACHE II score, bedside spirometry, breathing pattern, respiratory mechanics, blood gases measured on hospital admission | • Reduced body weight as % IBW
| Assessment period: N/S | Inclusion (AcEx): Increased coughing, production of purulent sputum, fever, severe bronchospasm with lack of response to inhalation therapy, or increased dyspnea without infiltrate on chest x-ray | Analytic method(s): Discriminant analysis | • Higher nutritional prognostic index (NPI)
| External validity: ¾ | Exclusion: Pneumonia, severe comorbid chronic diseases, cancer, cerebrovascular accident, dilated myocardiopathy, comatose status, inability to perform bedside measurements due to need for immediate MV | | • Lower APACHE II score
| COPD dx+ | Smoking history: N/S | | • Lower PaO_2_/FiO_2_
| COPD bl- | Baseline stable FEV_1_: N/S | | • Higher PaCO_2_
| AECB dx+ | FEV_1_ at admission: 35.6% ± 15.5% predicted | | • Lower pH
| AECB sev+ | Age: 62.9 ± 7.1 | | • Lower SaO_2_
| Internal validity: Level 3 | Sex: 32 men (82%), 7 women (18%) | | • Lower FEV_1_
| | Race: N/S | | • Lower FVC
| | | | • Lower VC
| | | | • Lower FEV_1_/FVC ratio
| | | | Predictors of need for MV (multivariable analysis): Significant independent predictors:
| | | | • NPI
| | | | • FVC (% predicted)
| | | | Se 0.69 Sp 0.79
| | | | PPV 0.64 NPV 0.83
Warren, Flenley, Millar, et al., 1980 | Design: Retrospective cohort | N = 135 pts with 157 consecutive emergency admissions
| Dates: 1961-68 and 1970-76 | Setting: General medical ward of acute care hospital
| Location: Edinburgh, UK | Inclusion (COPD): N/S
| Assessment period: To time of discharge or death | Inclusion (AcEx): Acute hypercapnic respiratory failure, defined as PaO_2_ < 50 mm Hg and/or PaCO_2_ > 50 mm Hg on admission when breathing RA; purulent sputum
| External validity: 2/4 | Exclusion: N/S
| COPD dx- | Smoking history: N/S
| COPD bl- | Baseline stable FEV_1_: N/S
| AECB dx+ | Age: 63.2 yrs (range 31 to 79)
| AECB sev+ | Sex: 105 admissions for men (67%), 52 admissions for women (33%)
| Internal validity: Level 3 | Race: N/S

1 External validity score (4 points possible): COPD dx = COPD diagnosis based on spirometry (+ = yes = 1; - = no = 0); COPD bl = baseline stable ventilatory status of population described (+ = yes = 1; - = no = 0); AECB dx = diagnosis of AECB includes at least two of following: increased sputum purulence, increased sputum volume, increased dyspnea (+ = yes = 1; - = no = 0); AECB sev = severity of AECB at enrollment described based on at least two of following: mental status change, work of breathing, ventilatory status (+ = yes = 1; - = no = 0).

2 Internal validity score (Levels 1–3): Level 1 = inception cohort study with ≥ 80% followup, a systematic review (with homogeneity) of inception cohort studies, or a clinical prediction guide validated on a test set; Level 2 = retrospective cohort study or followup of untreated control patients in a randomized controlled trial or clinical prediction guide not validated on a test set; Level 3 = case series or poor quality cohort studies.

Evidence Table 3. Antibiotics

Study | Design and Quality | Patient Population | Study Protocol | Results | Notes
Anthonisen, Manfreda, Warren et al., 1987 | Design: Crossover | N = 173 pts treated for 362 exacerbations (182 with antibiotic, 180 with placebo) | Interventions: | PEFR: The rate of increase in PEFR during exacerbations was significantly faster in exacerbations treated with antibiotic than in those treated with placebo (p < 0.02). Data were reported only in graphical form. | Of the exacerbations treated with antibiotic (n = 180), 39.7% were type 1, 41.9% were type 2, and 18.4% were type 3.
| Dates: 11/81-2/85 | Setting: Outpatient study, recruitment setting N/S | Experimental: (a) trimethoprim-sulfamethoxazole PO, one tablet (160 mg/800 mg) 2 times per day for 10 days; or (b) amoxicillin PO 0.25 g, 4 times per day for 10 days; or (c) doxycycline PO initially, followed by 0.1 g per day for 10 days; pt's physician decides which antibiotic should be used | Physicians' overall clinical assessment: (a) When all exacerbations treated were analyzed, the % in which treatment was considered a success was significantly higher with antibiotic treatment (68% = 124/182 exacerbations) than with placebo treatment (55% = 99/180 exacerbations) (p < 0.01). Similarly, the % of exacerbations in which pts deteriorated was significantly higher with placebo than with antibiotic (19% vs. 10%; p < 0.05). | Corresponding numbers for exacerbations treated with placebo (n = 182) were 38.5%, 42.3%, and 19.2%, respectively (p > 0.10 vs. antibiotic).
| Location: Canada | Inclusion (COPD): Age ≥ 35 yrs; clinical diagnosis of COPD; FEV_1_ < 70% predicted and < 70% of FVC; total lung capacity > 80% predicted | Control: Placebo | When these results were broken down by exacerbation type (1, 2, or 3), both treatments showed a graduation of success rates from type-1 to type-3 exacerbations (antibiotic, 63% to 70% to 74%; placebo, 43% to 60% to 70%). Deterioration rates for type-1, type-2, and type-3 exacerbations were as follows: antibiotic, 14%, 5%, and 11%; placebo, 30.5%, 11%, and 12%. Differences between the two treatments in both success and deterioration rates were most striking for type-1 exacerbations. No p-values or other measures of statistical significance were reported for these results. | Systemic steroid therapy was used in 43% of antibiotic-treated exacerbations and 43.5% of placebo-treated exacerbations. Investigators reported that, “[i]n exacerbations treated with steroids, the success rate with antibiotic was higher (though not significantly so) than that with placebo, and these rates were similar and not significantly different from those in exacerbations not treated with steroids.”
| Assessment period: Pts followed for an average of 23.7 mos; each exacerbation assessed for 21 days | Inclusion (AcEx): Increased dyspnea, sputum volume, and sputum purulence (type-1 exacerbation); type 2 = two of the above three symptoms; type 3 = one of the above three symptoms plus at least one of the following: upper respiratory infection within past 5 days, fever without other cause, increased wheezing, increased cough, or increase in respiratory rate or heart rate by 20%; exacerbations had to be separated by at least 2 weeks to be included in the analysis | Co-interventions: Not described. Authors stated that “[a]side from the use of antibiotic or placebo, treatment regimens during exacerbations did not differ”; however, pts thought to be steroid-responsive were given prednisone 40 mg for 3 days, with dose tapering to maintenance level in 9–12 days | (b) When only the first exacerbation treated was considered (antibiotic, n = 57; placebo, n = 59), the differences in success and deterioration rates between the two treatments were not significant: Success: Antibiotic, 67%; placebo, 52% (p = 0.06).
| External validity: ^1^ 5/5 | Exclusion: Clinical diagnosis of asthma; increase in FEV_1_ to 80% predicted after inhaled bronchodilator; other serious diseases such as cancer, left ventricular failure, or stroke; other conditions likely to require antibiotic treatment such as recurrent sinusitis or urinary tract infection | Maintenance therapy (used by all pts between exacerbations): Inhaled albuterol by MDI or compressed nebulizers or both; oral theophylline; some pts with serious symptoms who were thought to be steroid-responsive received prednisone 5–10 mg per day; home oxygen therapy used for pts who fulfilled standard criteria; diuretics used to manage edema; all pts received annual flu vaccine | Deterioration: Antibiotic, 12%; placebo, 17%.
| COPD dx+ | Smoking history: 39.9 pack-yrs; 93.6% history of smoking, with 21.4% current smokers | Outcomes: | Adverse events: Reported in terms of % of exacerbations with AEs: Nausea (10% antibiotic, 8% placebo), diarrhea (5%, 3%), abdominal cramps (3%, 4%), vomiting (3%, 2%), rash (1%, 1%), other (1.5%, 6%).
| COPD bl+ | Baseline stable FEV_1_/PEFR: FEV_1_: 33.9% ± 13.7% (SD) predicted; PEFR: 227.5 L/min ± 96.1 | PEFR: Analyzed only in pts with paired exacerbations that were followed for 15–21 days (n = 64); exacerbations that deteriorated were excluded from analysis; investigators analyzed increase in PEFR using a repeated-measures ANOVA. | Dropouts: 59 patients (34%) dropped out before trial ended; 18 died, 15 did not cooperate with study protocol, 17 developed another disease or withdrew because their physicians believed the study was not in their best interest; reasons for remaining 9 withdrawals not stated; exacerbations treated by these pts were included in the efficacy analysis.
| AECB dx+ | FEV_1_/PEFR at admission: 190 L/min | Physicians' overall clinical assessment: Each exacerbation was evaluated at 21 days on the following scale: “success” = all symptoms resolved; “no resolution” = symptoms not all resolved, but no further intervention deemed necessary; and “deterioration” = symptoms worsened to the point that further intervention (hospitalization or treatment with antibiotic in unblinded fashion) was deemed necessary; exacerbations in which pts deteriorated < 72 hrs after treatment began or developed another illness were counted as “other”
| AECB sev+ | Purulent sputum at admission: Exacerbations treated with antibiotic (n = 182), 59%; exacerbations treated with placebo (n = 180), 61% | Investigators analyzed rates of results (a) for all antibiotic-treated and placebo-treated exacerbations (total and stratified by exacerbation type); (b) for the first exacerbation treated by each pt; and (c) as matched, within-pt sets for pts who treated at least two exacerbations (one with antibiotic and one with placebo); separate results were reported only for (a) and (b)
| Tx duration+ | Age: 67.3
| Internal validity: ^2^ 4/5 | Sex: 138 M, 35 F
| r, db+, dd | Race: N/S
Berry, Fry, Hindley et al., 1960 | Design: SPPG | N = 58 | Interventions: | Symptoms: For pts with mild exacerbations, the difference in severity scores between the oxytetracycline- and placebo-treated groups was not significant at any time point (p ≥ 0.05, all time points). For pts with moderate to severe exacerbations, severity scores were significantly lower with oxytetracycline at 2 and 7 days (p < 0.05, both time points). Mean scores were as follows: | Trial included only pts with exacerbations for which the treating physician judged that antibiotic treatment was not imperative.
| Dates: N/S | Setting: Outpatient trial conducted in general practices | Experimental: Oxytetracycline PO 250 mg, 4 times per day for 5 days | Mild exacerbations: | In addition to the 5 dropouts, 5 pts required supplementary treatment before the completion of the trial due to “poor progress” (1 mild placebo, 4 moderate to severe placebo); these pts were included in the efficacy analysis and were assigned a severity score of 4 for all time points after their withdrawal.
| Location: UK | Inclusion (COPD): Persistent or recurrent cough with diffuse physical signs in the chest; other disease ruled out by x-ray | Control: Placebo | (a) Oxytetracycline (n = 11): day 1, 1.00; day 2, 0.64; day 7, 0.23; day 14, 0.14
| Assessment period: 14 days from start of exacerbation | Inclusion (AcEx): Sudden worsening (during the past week), characterized by one or more of the following: increased cough, increased volume of sputum, increased purulence of sputum, increased breathlessness, fever | Co-interventions: All pts given oral vitamin B and expectorants, antispasmodics, and other treatment as indicated | (b) Placebo (n = 13): day 1, 0.96; day 2, 0.96; day 7, 0.32; day 14, 0.31
| External validity: 2/5 | Exclusion: Pts with exacerbations for which treating physician judged that antibiotic treatment was imperative | Outcomes: | Moderate to severe exacerbations:
| COPD dx- | Smoking history: N/S | Symptoms: Graded by physicians on scale of 0–3 (equal to pt's baseline, mild, moderate, severe). Investigators analyzed mean severity scores on days 1, 2, 7, and 14; these were analyzed separately for pts whose exacerbations were mild (score of 1) at onset and those whose exacerbations were moderate to severe (score of 2 or 3) at onset | (c) Oxytetracycline (n = 15): day 1, 2.03; day 2, 1.13; day 7, 0.53; day 14, 0.47
| COPD bl- | Baseline stable PEFR: N/S | | (d) Placebo (n = 14): day 1, 2.04; day 2, 1.57; day 7, 1.36; day 14, 1.00
| AECB dx+ | PEFR at admission: N/S | | Adverse events: No data reported (see “Dropouts”)
| AECB sev- | Purulent sputum at admission: 32/53 pts (60%) | | Dropouts: 5/58 (9%) were not included in the efficacy analysis, 2 due to “inadequate records” and 3 due to “possibly toxic effects” of study med (2 oxytetracycline, 1 placebo)
| Tx duration+ | Age: 40% over 65 yrs
| Internal validity: 3/5 | Sex: 31 M, 21 F, 1 not recorded
| r, db, dd | Race: N/S
Elmes, Fletcher, and Dutton, 1957 | Design: SPPG | N = 59 pts, treating a total of 146 exacerbations; results reported in terms of number of exacerbations treated | Interventions: | Duration of symptoms: The mean duration of symptoms was 11.68 days for exacerbations treated with oxytetracycline (range, 3–48; variance, 1.38), 16.86 days for those treated with placebo (range, 2–163; variance, 9.66), and 25.848 days for exacerbations that were not treated (range, 4–136; variance, 20.8). The difference between oxytetracycline and placebo was not significant (0.1 < p < 0.2), even when a logarithmic scale was used to (0.2 < p < 0.3) reduce the impact of outlying cases Oxytetracycline was significantly better than no treatment for this outcome (0.001 < p < 0.01), but placebo was not (0.1 < p < 0.2). | In 4/57 exacerbations treated with oxytetra-cycline (7%) and 9/56 treated with placebo (16%), pts who continued to produce purulent sputum after a week's course of study med were given a course of an antibiotic (a second course for pts in the oxytetracycline group), usually tetracycline. This difference in the number of exacerbations requiring supplementary antibiotic treatment was not significant (0.1 < p < 0.2).
| Dates: Pts enrolled from 11/54-11/55 and followed “during two winters” | Setting: Outpatient study, with 21 pts recruited from a “bronchitis clinic”; 67 GPs | Experimental: Oxytetracycline PO 250 mg, 4 times per day (n = 57 exacerbations). Pts instructed to take tablets for 5 days and then assess condition: If feeling “quite well again,” stop taking tablets; if not, continue taking tablets until gone (full course = 7 days); if condition worsens, consult own GP. | Work days lost: The mean number of work days lost was 4.25 for exacerbations treated with oxytetracycline (range, 0–29; variance, 0.94), 9.43 for those treated with placebo (range, 0–155; variance, 8.80), and 22.79 for exacerbations that were not treated (range, 0–136; variance, 22.3). The difference between oxytetracycline and placebo was not significant (p = 0.1), even when a logarithmic scale was used to reduce the impact of outlying cases (0.05 < p < 0.1). Both oxytetracycline (p < 0.001) and placebo (0.01 < p < 0.02) were significantly better than no treatment for this outcome. | Details of onset, symptoms, and duration of exacerbations recorded at clinic visits (once per mo in winter, less often in summer)
| Location: UK | Inclusion (COPD): Productive winter cough ≥ 3 yrs | Control 1: Placebo (n = 56 exacerbations); same instructions given as above | Adverse events: Diarrhea (19 pts oxytetracycline; 4 pts placebo); mild and brief anal pruritus (6 pts oxytetracycline)
| Assessment period: two winters; pts seen at approximately monthly intervals during winter and at 2–3-monthly intervals during summer | Inclusion (AcEx): Pts required to have history of at least two episodes of productive winter cough with purulent sputum, causing loss of time from work, in past 3 yrs. Pts instructed to start taking study med if they have “a head cold, increased difficulty in breathing, increased cough and phlegm, or any other chest symptoms which [they] think may indicate the beginning of a chest illness.” | Control 2 ( posthoc ): No treatment = tablets (of either oxytetracycline or placebo) taken for fewer than 5 days or not at all (n = 33 exacerbations) | Dropouts: No pts withdrew, though some required supplementary treatment (see “Notes”) (0.05 < p < 0.1). Both oxytetracycline (p < 0.001) and placebo (0.01 < p < 0.02) were significantly better than no treatment for this outcome.
| External validity: 2/5 | Further inclusion criteria: Age < 65; in regular employment | Cointerventions: Not standardized; majority of patients took ephedrine or choline theophyllinate by mouth, with or without a hand inhaler, using either 1% isoprenaline or the combined spray of adrenaline and atropine. A chalk and opium mixture was given to all pts to take in the event that diarrhea developed. | Adverse events: Diarrhea (19 pts oxytetracycline; 4 pts placebo); mild and brief anal pruritus (6 pts oxytetracycline)
| COPD dx- | Exclusion: No other disabling disease | Outcomes: | Dropouts: No pts withdrew, though some required supplementary treatment (see “Notes”)
| COPD bl- | Smoking history: N/S | Duration of symptoms: Defined as the number of days during which the pts had respiratory symptoms, especially cough and sputum, of greater severity than usual.
| AECB dx+ | Baseline stable PEFR: N/S | Investigators analyzed the mean duration per exacerbation.
| AECB sev- | PEFR at admission: N/S | Work days lost: Investigators analyzed the mean number of work days missed per exacerbation, based on pt reports.
| Tx duration + | Purulent sputum at admission: N/S
| Internal validity: 5/5 | Age: 54.0
| r+, db+, dd | Sex: 74 M, 14 F
| | Race: N/S
Elmes, King, Langlands et al., 1965 | Design: Matched-pairs | N = 58 (included in nonsequential analysis); 56 (included in sequential analysis); see “Dropouts” | Interventions: | PEFR: There was no significant difference between the ampicillin and placebo groups for improvement in PEFR from day 1 to day 7 (0.05 < p < 0.1). The mean increase in PEFR was 51.5 ml in the ampicillin group (n = 29) and 27.9 ml in the placebo group (n = 29). | Trial excluded pts taking corticosteroids Pts in the placebo group had significantly higher PEFR and significantly greater sputum volume at admission than pts in the ampicillin group.
| Dates: 2/63 through the winter of 1963-1964 | Setting: Inpatient study, hospitalized pts | Experimental: Ampicillin PO 1 g, 4 times per day for 3 days, then 0.5 g, 4 times per day for 4 days | Physicians' overall clinical assessment: There was no significant difference between the two treatment groups (n = 28, each group) at any of the time points measured. (No detailed data reported.) | Poor ventilatory function on admission was found to correlate with a longer stay in hospital.
| Location: Northern Ireland | Inclusion (COPD): At least a 3-yr history of productive cough for more than 3 mos in the yr | Control: Placebo | LOS in hospital: There was no significant difference between the ampicillin and placebo groups for this Outcome (p > 0.05). The mean LOS was 18.3 days in the ampicillin group (n = 29) and 18.8 days in the placebo group (n = 29).
| Assessment period: 7 days initially; pt's overall condition assessed again at discharge and at followup, 6–18 mos after discharge | Inclusion (AcEx): Current AcEx (diagnostic criteria N/S); history of at least 2 illnesses with increased sputum during last 3 yr | Co-interventions: Oral and aerosol bronchodilators; early ambulation; postural coughing exercises; digitalis, diuretics, oxygen, and respiratory stimulants when necessary to treat cardiac or respiratory failure; pts encouraged to sleep with feet elevated and without pillows | Adverse events: Reported for ampicillin only: mania (1 pt), diarrhea (1 pt), abdominal discomfort with loose stools (“several” pts); no drug rashes were noted
| External validity: 2/5 | Exclusion: Severe cardiac failure unrelated to chest disease, carcinoma of the lung, lung abscess, long-standing bronchiectasis, evidence of disseminated infection or septicemia, active tuberculosis, allergy to penicillin, use of corticosteroids | Outcomes: | Dropouts: 74 pts were enrolled in trial, and 29 pairs (58 pts) were included in the main (nonsequential) analyses. 12 of the remaining 16 could not be suitably paired. The other four were started as pairs but withdrawn: one pt in the first pair required treatment with corticosteroids, and one pt in the second pair developed mania on 3^rd^ day of treatment with ampicillin. One of the 29 pairs had been mismatched for age and were excluded from the sequential analysis (overall clinical evaluation).
| COPD dx- | Smoking history: N/S | PEFR: Investigators analyzed mean increase in PEFR from day 1 to day 7.
| COPD bl- | Baseline stable FEV_1_/PEFR: N/S | Physicians' overall clinical assessment: Using data recorded on evaluation forms, investigators made a decision about which member of each pair had responded better to treatment; assessments made at 7 days, time of discharge, and at end of followup period; results evaluated in a sequential analysis.
| AECB dx- | PEFR at admission: Ampicillin grp, 69.2 L/min; placebo grp, 89.2 L/min (0.0125 < p < 0.02) | LOS in hospital: Mean number of days
| AECB sev+ | Purulent sputum at admission: 45/58 pts (78%)
| Tx duration | Age: 63.3
| Internal validity: 5/5 | Sex: 36 M, 20 F; sex of unmatched-for-age pair included in nonsequential analysis N/S
| r+, db+, dd | Race: N/S
Fear and Edwards, 1962 | Design: SPPG | N = 62 pts, treating 119 exacerbations | Interventions: | Symptoms: There was no significant difference between the two treatment groups for this outcome (t = 1.22; p > 0.30). The mean symptom score (± SEM) in the oxytetracycline group (n = 32 pts) was +70.8 (± 21.3); in the placebo group (n = 30 pts), it was +35.3 (± 19.9). | Pts kept daily diaries of symptoms.
| Dates: 11/58-3/59 | Setting: Outpatient study; pts recruited from bronchitis clinics | Experimental: Oxytetracycline PO 500 mg, twice per day for 7 days | Duration of symptoms: There was no significant difference between the two groups for this outcome (p ≥ 0.05). The average duration of exacerbations treated with oxytetracycline (n = 58 exacerbations) was 7.5 days (range 1–35), compared with 13.5 days (range 1–48) for exacerbations treated with placebo (n = 61).
| Location: UK | Inclusion (COPD): Age > 20 yrs and < 65 yrs; winter cough and sputum for at least 3 yrs, with shortness of breath on effort; some degree of disability, such as limitation of normal activity or loss of time at work | Control: Placebo | Adverse events: No data reported
| Assessment period: 5 mos; pts assessed at monthly clinic visits | Inclusion (AcEx): Illness of sudden onset accompanied by an increase in sputum volume or purulence, and/or of dyspnea or wheezing | Co-interventions: Not described | Dropouts: None
| External validity: 2/5 | Exclusion: N/S | Outcomes:
| COPD dx- | Smoking history: N/S | Symptoms: Graded by physicians. Included the following factors:
| COPD bl- | Baseline stable FEV_1_/PEFR: N/S | (a) Purulence and volume of sputum, and degree of dyspnea and wheezing
| AECB dx+ | FEV_1_/PEFR at admission: N/S | (b) Frequency and duration of exacerbations
| AECB sev- | Purulent sputum at admission: N/S | (c) Pt's subjective evaluation of general health and response to treatment
| Tx duration+ | Age: N/S | (d) Observer's assessment based on knowledge of pt's previous record
| Internal validity: 5/5 | Sex: N/S | Item (a) scored as follows: 10–40% change = 5 points; 40–70% change = 10 points; 70–100% change = 20 points
| r+, db+, dd | Race: N/S | Items (b) through (d) scored as follows: 10–40% change = 15 points; 40–70% change = 30 points; 70–100% change = 60 points
| | | Points could be positive or negative, depending on whether improvement or deterioration noted. Total scores were calculated for each pt, and investigators analyzed group mean scores.
| | | Duration of symptoms: Mean number of days per exacerbation
Jørgensen, Coolidge, Pedersen et al., 1992 | Design: SPPG | N = 273 | Interventions: | PEFR: In both treatment groups, a slight increase in PEFR was recorded during treatment. There were no statistically significant differences between the two groups (t-test, p > 0.50). (Mean PEFR values reported only in graphical form.) | Pts taking oral steroids excluded
| Dates: 3/86-8/88 | Setting: General practices; 131 physicians participated | Experimental: Amoxicillin PO 750 mg, twice per day | Physicians' overall clinical assessment: Treatment was deemed to have been a success in 83/132 pts receiving amoxicillin (63%), and 87/136 receiving placebo (64%). There was no significant difference between the two groups for this outcome (no p-value reported). | The prognostic value of the baseline variables in predicting the outcome of the study in a single pt was evaluated by multiple regression. None of the variables was found to be significant.
| Location: Denmark | Inclusion (COPD): Age > 18 yrs; continuous cough and expectoration, present for at least 3 mos of the yr in more than 2 consecutive yrs | Control: Placebo | A subgroup analysis on the pts with complete resolution of symptoms showed a significant difference in favor of amoxicillin (25/132 pts receiving amoxicillin [19%] vs. 13/136 receiving placebo [10%]; χ2, p = 0.03).
| Assessment period: Pts treated for 7 days and evaluated on day 8 | Inclusion (AcEx): Subjective worsening due to change in sputum (increased volume, change in viscosity or color), possibly accompanied by cough or dyspnea, lasting for more than 3 days | Co-interventions: No other antibiotics permitted during trial; no antipyretics permitted during trial; other concomitant medication to be recorded by pts (investigators reported that there were no significant differences in concomitant medications between the two groups) | Symptoms: There were no significant differences between the two groups for any of the symptoms evaluated (Mann-Whitney, p > 0.40).
| External validity: 2/5 | Exclusion: Pneumonia; temperature > 38.5° C; heart rate > 100; antibiotics within the previous 7 days; pregnancy; allergy to penicillin; uncompensated heart disease, diabetes mellitus, malignant disease, or other severe disease; treatment with oral steroids (prednisone 5 mg or equipotent treatment) or immunosuppressants (i.e., azathioprine, cyclophosphamide, methotrexate); previous inclusion in the study | Outcomes: | Adverse events: Antibiotic grp (27/133 pts = 20%): Diarrhea, 13 pts; dyspesia, 3 pts; smarting pain in mouth, 3 pts; exanthema, itching, 3 pts; other, 5 pts. Placebo grp (18/137 pts = 13%): Diarrhea, 4 pts; dyspesia, 6 pts; exanthema, itching, 1 pt; other, 11 pts. There was no significant difference between the two groups in the number of AEs reported (p = 0.37) or the number of pts reporting AEs (p = 0.11).
| COPD dx- | Smoking history: 74% smokers | PEFR: Measured twice daily; investigators analyzed change in PEFR from admission (day 1) to day 8 | Dropouts: 14 total, 5 due to AEs (3 amoxicillin, 2 placebo), 5 due to deterioration (2 amoxicillin, 3 placebo), 1 due to occurrence of another (unspecified) disease (placebo), 3 did not attend evaluation visit on day 8 (treatment grps N/S). All dropouts except the 3 who did not show up for evaluation were included in efficacy and AE analyses.
| COPD bl- | Baseline stable FEV_1_/PEFR: N/S | Physicians' overall clinical assessment: Measured on day 8; “success” defined as “symptoms resolved (i.e., pt felt well)” or “symptoms diminished” (i.e., a definite improvement)”; “failure” defined as “symptoms unchanged” or “symptoms deteriorated (i.e., felt more ill).” Investigators analyzed the percentage of pts for whom treatment was deemed to be a success.
| AECB dx+ | FEV_1_/PEFR at admission: N/S | Symptoms: Following symptoms graded on 4-pt scales on day 1 and day 8: volume, viscosity, and color of sputum; dyspnea at night; cough; general well-being
| AECB sev- | Purulent sputum at admission: Overall, 89/267 pts (33%); antibiotic grp, 38/131 (29%); placebo grp, 51/136 (37.5%)
| Tx duration+ | Age: 60.1
| Internal validity: 3/5 | Sex: 115 M, 155 F
| r, db, dd | Race: N/S
Nicotra, Rivera, and Awe, 1982 | Design: SPPG | N = 40 | Interventions: | Spirometry: There were no significant differences in spirometric values (FEV_1_, FVC, and PEFR) between the two groups on day 1 or day 7 (p ≥ 0.05 for all outcomes and both time points). FVC improved significantly from day 1 (1.67 L) to day 7 (1.95 L) in the placebo group (p = 0.019). PEFR did the same (from 160 L/min to 198) in the tetracycline group (p = 0.011). Otherwise, there were no significant within-group improvements from day 1 to 7. | Corticosteroids were taken as a co-intervention by 75% of pts in the tetracycline group and 65% in the placebo group.
| Dates: N/S | Setting: Inpatient study, hospitalized pts | Experimental: Tetracycline PO 500 mg, 4 times per day for 7 days; n = 20 | Symptoms: Clinical improvement, as judged both by pts and investigators, was “marked and equal” in the two groups; no further data reported.
| Location: United States | Inclusion (COPD): Significant sputum production for at least 3 mos of the preceding 2 yrs | Control: Placebo; n = 20 | Adverse events: No data reported
| Assessment period: 7 days | Inclusion (AcEx): Increase in symptoms of dyspnea, cough, and sputum production; pt sufficiently ill to require hospitalization, but not ventilatory support (assessment made by pt's primary physician) | Co-interventions: Given at discretion of primary physician; included bronchodilators (oral, parenteral, inhaled), corticosteroids, chest physiotherapy, diuretics, and supplemental oxygen | Dropouts: None
| External validity: 4/5 | Exclusion: New or changed parenchymal lung infiltrate; temperature > 38.5° C; blood leukocyte count > 12 × 10^9^/L (unless an increase in corticosteroid dosage had occurred in the preceding 3 days); antibiotic use during the preceding 7 days; need for mv | Outcomes:
| COPD dx+ | Smoking history: 75% current smokers | Spirometry: FEV_1_, FVC, and PEFR measured on days 1 and 7
| COPD bl- | Baseline stable FEV_1_/PEFR: N/S | Symptoms: (1) Assessed by pts on days 1 and 7. Questionnaire included severity of cough and dyspnea; sputum volume, color, and consistency; weakness; and overall degree of illness during exacerbation as compared to baseline status. Scored on scale of 0–14, with higher scores indicating greater severity of illness
| AECB dx+ | FEV_1_/PEFR at admission: FEV _1_: Tetracycline (n = 20), 0.88 L ± 0.33 (SD); placebo (n = 20), 0.92 L ± 0.54; PEFR: Tetracycline, 160 L/min ± 72; placebo, 159 L/min ± 105 | (2) Assessed by an investigator on days 1 and 7. Questionnaire included presence and severity of acute and chronic illness, cyanosis, dyspnea, and physical signs including peripheral edema, rales, pulmonary consolidation, wheezing, and altered breath sounds
| AECB sev+ | Purulent sputum at admission: N/S
| Tx duration+ | Age: 56.3
| Internal validity: 4/5 | Sex: 20 M, 20 F
| r, db+, dd | Race: N/S
Petersen, Esmann, Høncke et al., 1967 | Design: SPPG | N = 19 (completed trial in placebo or antibiotic treatment group) | Interventions: | PEFR: There was no significant difference between the two groups at day 10. In the chloramphenicol-treated group, 5 pts were improved, and 4 were unchanged. In the placebo-treated group, 6 pts were improved, and 4 unchanged. Similar results were reported for vital capacity. | Trial also included physiotherapy and expectorant treatment arms not described here.
| Dates: Pts admitted 10/64-4/65 | Setting: Inpatient study conducted in hospital ward | Experimental: Chloramphenicol 0.5 g, 4 times per day for 10 days | Adverse events: No data reported | Randomization was stratified to ensure an equal distribution of “light” and “severe” cases in the various treatment groups. Severity determined according to whether pt's residual volume comprised less or more than 50% of total lung capacity.
| Location: Denmark | Inclusion (COPD): Age 45–75 yrs; history of cough and expectoration on most days during at least 3 consecutive mos in each of 2 or more successive yrs | Control: Placebo | Dropouts: 5 of the total of 43 pts originally enrolled in the study (all treatment groups) were later excluded (12%). Two developed cardiac insufficiency, 1 was found to have a bronchial carcinoma, 1 left the ward before the end of the trial, and 1 refused to cooperate with PFTs. It was not clear whether any of these pts had been randomized to treatment with chloramphenicol or placebo. | Response to treatment was not found to be correlated with sex or duration of disease.
| Assessment period: 10 days | Inclusion (AcEx): N/S | Co-interventions: Both groups received 10 ml 3.3% potassium chloride, 3 times per day. No other co-interventions described. Placebo group specifically said to have received “no other treatment”
| External validity: 2/5 | Exclusion: Severe deformities of the spine or chest; localized or generalized specific lung disease; signs of cardiac insufficiency | Outcomes:
| COPD dx- | Smoking history: N/S | PEFR: Investigators analyzed the number of pts in each group whose PEFR was improved, unchanged, or worse, relative to admission values, on day 10. “Improvement” was defined as an increase of 15% or more.
| COPD bl- | Baseline stable FEV_1_/PEFR: N/S
| AECB dx- | PEFR at admission: 6/9 pts (67%) in the chloramphenicol group and 5/10 (50%) in the placebo group had PEFRs < 240 L/min (men) or < 175 L/min (women)
| AECB sev+ | Purulent sputum at admission: 14/19 pts (74%)
| Tx duration+ | Age: 62.4
| Internal validity: 5/5 | Sex: 10 M, 9 F
| r+, db+, dd | Race: N/S
Pines, Raafat, Greenfield et al., 1972 | Design: SPPG | N = 259 | Interventions: | PEFR: There were no significant differences among the three treatments for improvement in PEFR (p ≥ 0.05). At day 12, PEFR had improved by an average of 10.7% in the tetracycline group, 12.6% in the chloramphenicol group, and 4.7% in the placebo group (no variance data reported). | Pts were required to be “moderately ill” as judged by the admitting physician, and to have failed at least one previous trial of antibiotic therapy.
| Dates: N/S | Setting: Inpatient study, hospitalized pts | Experimental 1: Tetracycline PO 500 mg, 4 times per day for 12 days | Physicians' overall clinical assessment: At days 7 and 12, a significantly higher percentage of pts treated with antibiotics had improved (“success” or “partial success”), compared to the percentage who improved with placebo (p < 0.05, both time points). By day 12, a significantly higher percentage of pts had deteriorated (gotten worse or died) with placebo (p < 0.05). There was no significant difference between the two antibiotics for these outcomes (p ≥ 0.05). The data were as follows: | “Nearly all” pts remained in hospital for up to 4 weeks after treatment.
| Location: United Kingdom | Inclusion (COPD): Age ≥ 60 yrs; history of bronchitis for ≥ 5 yrs | Experimental 2: Chloramphenicol PO 500 mg, 4 times per day for 12 days | Day 7:
| Assessment period: 12 days from start of treatment, with followup assessments for a further 28 days | Inclusion (AcEx): Definite history of exacerbation of symptoms over the past 6 weeks; persistently purulent sputum; PEFR ≤ 200 L/min | Control: Placebo | (1) Tetracycline: 60/89 pts (67%) improved; 4/89 (4%) deteriorated
| External validity: 3/5 | Additional inclusion criteria: Male sex; pt assessed as moderately ill by admitting physician; at least one failed trial of antibiotic therapy prior to entry | Co-interventions: Early ambulation, encouragement, postural drainage, physiotherapy, bronchodilators, copious water intake, steam inhalations, and treatment of respiratory or heart failure when indicated | (2) Chloramphenicol: 54/84 pts (64%) improved; 4/84 (4.8%) deteriorated
| COPD dx- | Exclusion: Asthma; eosinophilia in sputum of 10% or more; bronchiectasis or other pulmonary disease | Outcomes: | (3) Placebo: 39/86 pts (45%) improved; 15/86 (17%) deteriorated
| COPD bl- | Smoking history: N/S | PEFR: Investigators analyzed mean percentage improvement from day 1 to day 12. | Day 12:
| AECB dx+ | Baseline stable FEV_1_/PEFR: N/S | Physicians' overall clinical assessment: Conducted by study investigators. Included degree of well-being, color, and dyspnea. Pt's condition assessed on categorical scale: success, partial success, failure, worse, or dead. Investigators analyzed percentage of pts who improved (“success” or “partial success”) and percentage who deteriorated (“worse” or “dead”) at 7 and 12 days | (4) Tetracycline: 58/89 pts (65%) improved; 5/89 (5.6%) deteriorated
| AECB sev+ | PEFR at admission: Overall, 146.0 L/min; tetracycline grp, 149.3 ± 5.2 (SEM) L/min; chloramphenicol grp, 142.3 ± 5.2 L/min; placebo grp, 146.1 ± 6.3 L/min | Symptom score (including followup component): Graded by investigators. Points awarded or subtracted as follows: improvement or deterioration in clinical state (+6 to -6); improvement or deterioration in purulence of sputum (+3 to -2); diminution in quantity of sputum (+2 to +4); maintenance of mucoid sputum to 1-week (+2) and 4-week (+6) follow-up. Investigators analyzed mean scores in pts available for followup | (5) Chloramphenicol: 60/84 pts (71%) improved; 4/84 (4.8%) deteriorated
| Tx duration+ | Purulent sputum at admission: 100% purulent or “moderately purulent” | | (6) Placebo: 33/86 pts (38%) improved; 23/86 (27%) deteriorated
| Internal validity: 4/5 | Age: N/S | | Symptom score: Mean symptom scores were significantly higher (better) in the tetracycline and chloramphenicol groups than in the placebo group (ANOVA, F = 5.67, d.f. = 2227). There was no significant difference between the two antibiotic groups. Mean scores (± SEM) were as follows:
| r, db+, dd | Sex: 259 M, 0 F | | (1) Tetracycline (n = 81): 11.16 ± 0.86
| | Race: N/S | | (2) Chloramphenicol (n = 79): 11.84 ± 0.83
| | | | (3) Placebo (n = 68): 8.12 ± 0.96
| | | | Adverse events: 25/89 pts (28%) in the tetracycline group, 8/84 (9.5%) in the chloramphenicol group, and 6/86 (7%) in the placebo group. The difference between the two antibiotics was significant.
| | | | Dropouts: None
Pines, Raafat, Plucinski et al., 1968 | Design: SPPG | N = 30 | Interventions: | Physicians' overall clinical assessment: In the group who received antibiotics (n = 15), 10 pts improved, 3 were unchanged, and 2 deteriorated; 1 pt died. In the group receiving placebo (n = 15), 3 pts improved, 3 were unchanged, and 9 deteriorated; 3 pts died. The difference between the two groups was significant (p < 0.05) | Data at left are from the pilot trial, which was placebo-controlled.
| Dates: N/S | Setting: Inpatient study, hospitalized pts | Experimental: Penicillin 3 million units plus streptomycin 0.5 mg injected twice daily for 7 days; penicillin alone continued for another 7 days | Adverse events: No data reported | Pts were required to be “moderately or severely ill” as judged by the admitting physician; 8/15 pts in the antibiotic group and 7/15 in the placebo group described as “severely ill” at the start of the trial
| Location: United Kingdom | Inclusion (COPD): Age > 50 yrs; history of bronchitis for ≥ 5 yrs | Control: Placebo | Dropouts: None | Clinical deterioration closely correlated with severity of illness and less definitely correlated to a low PEFR and high PaCO_2_ on entry
| Assessment period: 14 days | Inclusion (AcEx): Definite history of exacerbation of symptoms over the past 6 weeks | Co-interventions: Early ambulation, optimistic encouragement, postural drainage, physiotherapy, bronchodilators, copious fluid intake and steam inhalations, and treatment of respiratory or heart failure when indicated
| External validity: 2/5 | Additional inclusion criteria: Male sex; pt assessed as moderately or severely ill by admitting physician | Outcomes:
| COPD dx- | Exclusion: Allergy to penicillin; asthma; known eosinophilia in sputum of 10% or more; extensive bronchiectasis; active tuberculosis; carcinoma of the lung; blood urea of 60 mg/dL or more | Physicians' overall clinical assessment: Included degree of well-being, color, and dyspnea; pts assessed on day 14 as improved, unchanged, deteriorated, or dead
| COPD bl- | Smoking history: N/S
| AECB dx- | Baseline stable FEV_1_/PEFR: N/S
| AECB sev+ | PEFR at admission: Antibiotic grp , 90 L/min; placebo grp , 85 L/min
| Tx duration+ | Purulent sputum at admission: 100%
| Internal validity: 5/5 | Age: 67.5
| r+, db+, dd | Sex: 30 M, 0 F
| | Race: N/S
Sachs, Koëter, Groenier, et al., 1995 | Design: SPPG | N = 71 | Interventions: | The three treatment regimens produced comparable improvements in PEFR and symptom scores. | 10/71 pts (14%) had asthma: 3 in the amoxicillin group, 3 in the co-trimoxazole group, and 4 in the placebo group
| Dates: 10/88-3/92 | Setting: Outpatient study conducted in 25 general practices | Experimental 1: Amoxicillin PO 500 mg, three times per day for 7 days | PEFR: In all three groups, mean % predicted PEFR values were significantly lower on day 1 of the exacerbation than at baseline (p < 0.001), but there were no significant differences among the three groups at day 1 or during the following 14 days (p ≥ 0.05). Mean % predicted values (± SD) were as follows:
| Location: Netherlands | Inclusion (COPD): Age ≥ 18 yrs; positive diagnosis of asthma (n = 10) or COPD (n = 61) made by a pulmonary physician during the previous 10 yrs | Experimental 2: Co-trimoxazole PO 960 mg, twice per day for 7 days | (1) Amoxicillin (n = 22): Day 1, 56.7% ± 20.5%; day 14, 64.9% ± 24.8%
| Assessment period: 14 days (7-day treatment plus 7-day followup); baseline measurements taken over 7 stable days prior to study, mean of 7-day baseline measurements used | Inclusion (AcEx): Sustained increase in dyspnea, with or without sputum production, despite increasing normal twice-daily inhaled therapy to 3–4 times daily | Control: Placebo | (2) Co-trimoxazole (n = 17): Day 1, 48.0% ± 18.4%; day 14, 59.3% ± 20.0%
| External validity: 4/5 | Exclusion: Daily use of oral corticosteroids or antimicrobial drugs; diabetes mellitus; alcoholism; history of pulmonary surgery or tuberculosis; severe bronchiectasis; psychiatric history | Co-interventions: Prednisolone PO, 35 mg on day 1, reduced by 5 mg daily thereafter; all pts used their normal maintenance medication (inhaled corticosteroids with or without beta-2 sympathomimetics) throughout the study | (3) Placebo (n = 16): Day 1, 49.2% ± 19.7%; day 14, 57.9% ± 20.0%
| COPD dx- | Smoking history: 41% current smokers, 28% ex-smokers; median pack-yrs (with range) = 16.5 (0.15–77) | Outcomes: | The mean daily increase in PEFR (± SD), expressed as % predicted, was 0.68% ± 1.01% in both groups receiving antibiotics, and 0.34% ± 0.84% in the placebo group (n's as above). The increase in PEFR was significant in all groups (p < 0.001), with no significant between-group differences. Mean slopes of increase in % predicted FCER (with 95% CI) were 0.58 (0.27 to 0.89) in the amoxicillin group, 0.78 (0.22 to 1.34) in the co-trimoxazole group, and 0.34 (0.00 to 0.73) in the placebo group.
| COPD bl+ | Baseline stable PEFR: Overall (n = 71), 285.3 ± 99.2 (SD) L/min. In the 3 treatment groups, mean % predicted PEFRs (± SD) were: Amoxicillin (n = 22), 66.7% ± 22.1%; co-trimoxazole (n = 17), 61.7% ± 18.0%; and placebo (n = 16), 60.8% ± 19.6%. | PEFR measured 3 times before first inhalation treatment in morning; highest of 3 values used | Symptoms (pt-graded): In all three groups, mean symptom severity scores were significantly lower on day 1 of the exacerbation than at baseline, and significantly lower on day 14 than on day 1 (p < 0.001, all comparisons). There were, however, no significant differences in the three groups, whether symptom scores were expressed as absolute values or as slopes (p ≥ 0.05). Mean symptom severity scores (± SD) were as follows:
| AECB dx+ | PEFR at admission: 233 L/min (estimated % predicted PEFR at entry) | PEFR: Mean % predicted values at baseline, day 1, and day 14; mean daily increase in PEFR over 14 days; and mean slopes of increase in % predicted FCER over 14 days | (4) Amoxicillin (n = 22): Baseline, 0.56 ± 0.46; day 1, 1.42 ± 0.70; day 14, 0.75 ± 0.68
| AECB sev+ | Purulent sputum at admission: 19/71 pts (27%) | Symptoms (pt-graded): Pts graded following symptoms daily on severity scale ranging from 0–3: wheeze or dyspnea; cough with mucus production; cough without mucus production; and awakening with dyspnea. Investigators considered all symptoms together (positive correlation found), and analyzed mean symptom severity scores at baseline, day 1, and day 14; mean slope of decrease in symptom scores over 14 days; and mean daily decrease in symptom scores over 14 days. | (5) Co-trimoxazole (n = 18): Baseline, 0.60 ± 0.49; day 1, 1.46 ± 0.66; day 14, 0.68 ± 0.60
| Tx duration+ | Age: 51.7 | | (6) Placebo (n = 17): Baseline, 0.57 ± 0.48; day 1, 1.29 ± 0.49; day 14, 0.54 ± 0.43
| Internal validity: 4/5 | Sex: 30 M, 41 F | | Mean slopes of symptom scores (with 95% CI) were -0.05 (-0.07 to -0.02) in the amoxicillin group, -0.06 (-0.08 to -0.04) in the co-trimoxazole group, and -0.06 (-0.08 to -0.04) in the placebo group (n's as above). The mean daily decrease in symptom scores (± SD) was 0.05 ± 0.05 in the groups receiving antibiotics, and 0.06 ± 0.045 in the placebo group.
| r, db+, dd | Race: N/S | | Adverse events: No data reported
| | | | Dropouts: 16 pts did not record their PEFR values (4 amoxicillin, 3 co-trimoxazole, 9 placebo), and 14 did not record symptom severity scores (4 amoxicillin, 2 co-trimoxazole, 8 placebo); no pts withdrew from the study

1 External validity score (5 points possible): COPD dx = COPD diagnosis based on spirometry (+ = yes = 1; - = no = 0); COPD bl = baseline stable ventilatory status of population described (+ = yes = 1;- = no = 0); AECB dx = diagnosis of AECB includes at least two of following: increased sputum purulence, increased sputum volume, increased dyspnea (+ = yes = 1; - = no = 0); AECB sev = severity of AECB at enrollment described based on at least two of following: mental status change, work of breathing, ventilatory status (+ = yes = 1; - = no = 0); Tx duration = outcomes assessed at 24 hours or later (+ = yes = 1; - = no = 0).

2 Internal validity score (5 points possible): Randomization: r = study described as randomized, method of randomization not described (1 point); r+ = method of randomization described and adequate (2 points); r- = method of randomization described but inadequate (0 points). Double-blinding: ndb = not double-blind (0 points); db = study described as double-blind, method of blinding not described (1 point); db+ = method of blinding described and adequate (2 points); db- = method of blinding described but inadequate (0 points). Dropouts: dd = dropouts described (1 point); dnd = dropouts not described (0 points).

Evidence Table 4. Bronchodilators

Study | Design and Quality | Patient Population | Study Protocol | Results | Notes
Anticholinergics
Backman and Hellström, 1985 | Design: SPPG | N = 40 | Interventions: | There were no significant differences between the two treatment grps for any of the outcomes measured (no between-grp p-values reported). | Two pts in the ipratropium grp who did not withdraw prematurely were unable to perform spirometry and so were not included in the FEV_1_ analysis
| Dates: N/S | Setting: Hospitalized pts FEV_1_ | Experimental: Nebulized ipratropium 0.2 mg, 3x/day | FEV_1_: Improvements were small with both interventions. In the ipratropium grp (n = 17), mean scores at 15 min (p ≤ 0.02) and 30 min (p ≤ 0.05) posttreatment were significantly higher on the 7th day than on the 1st; no significant differences were noted between the 1st and 7th day at 0, 5, 10, 60, 120, or 240 min. In the fenoterol grp (n = 20), mean scores at 60 min posttreatment were significantly higher on the 7th day than on the 1st (p ≤ 0.05); otherwise, no significant differences were observed between the 1st and 7th day.
| Location: Finland | Inclusion (COPD): Chronic bronchitis, according to criteria of the British Medical Council [no ref given] | Control: Nebulized fenoterol 0.5 mg, 3x/day | Mean pretreatment FEV_1_ scores on days 1 and 7 were:
| Assessment period: 7 days | Inclusion (AcEx): AECB (no diagnostic criteria given) | Co-interventions: Pts with signs of an acute infection (fever, pneumonic infiltration, and positive sputum bacteriology) were treated with antibiotics before the start of the trial; pts taking beta_2_-receptor stimulants (n = 16) stopped them at least 8 hrs before starting the trial; all pts received daily physical treatment; otherwise, pts continued their usual regimens, which included oral theophyllamine (n = 7), combination treatment with ephedrine and hydroxyzine (n = 4), prednisolone (n = 2), and no continuous treatment (n = 7) | (a) Ipratropium (n = 17): Day 1, 0.73 ± 0.35 (SD) L; Day 7, 0.82 ± 0.34 L
| External validity: 2/5 | Exclusion: N/S | Outcomes: | (b) Fenoterol (n = 20): Day 1, 0.93 ± 0.56 L; Day 7, 1.02 ± 0.66 L
| COPD dx- | Smoking history: N/S | FEV_1_: Measured on the 1st and 7th day immediately before and 5, 10, 15, 30, 60, 120, and 240 min after the morning study drug administration. Investigators compared mean FEV_1_ scores for identical timepoints on days 1 and 7. | Blood gases/oximetry: Investigators stated that there were no significant changes in PaO_2_ or PaCO_2_ from day 1 to day 7 in either grp, but did not report any data.
| COPD bl- | Baseline stable FEV_1_: N/S | Blood gases: Arterial PaO_2_ and PaCO_2_ measured on 1st and 7th day. Investigators analyzed change from day 1 to 7. | Adverse events: 1/19 pts (5.3%) taking ipratropium and 1/20 (5.0%) taking fenoterol complained of a “strange feeling”
| AECB dx- | FEV_1_ before treatment on day 1: Ipratropium, 0.73 ± 0.35 (SD) L; fenoterol, 0.93 ± 0.56 L (n.s.; p-value not reported) | | Dropouts: 1/40 pts (2.5%), treatment grp N/S
| AECB sev+ | Age: Range: 48–77
| Tx duration+ | Sex: 36 M, 4 F
| Internal validity: 3/5 | Race: N/S
| r, db, dd
Cydulka and Emerman, 1995 | Design: SPPG | N = 57 | Interventions: | Note: No. of pts in each treatment grp unclear | FEV_1_ results accompanied by large SDs
| Dates: 2/91-2/92 | Setting: Pts presenting to ED (urban teaching hospital) | Experimental: Single dose of aerosolized glycopyrrolate 2 mg, administered as first aerosol | FEV_1_: (a) No significant differences between mean pre- and posttreatment scores (± SD) for either grp: Glycopyrrolate grp, 0.89 ± 0.36 and 1.31 ± 0.61 (p = 0.11); placebo grp, 0.93 ± 0.42 and 1.09 ± 0.57 (p = 0.19). No between-grp results reported. | Small sample size yielded low power to detect differences in AEs between grps
| Location: United States | Inclusion (COPD): Pts with self-reported diagnosis of COPD or histories consistent with COPD, as defined by ATS | Control: Placebo | (b) Repeated-measures analysis showed glycopyrrolate significantly better than placebo for mean % change (increase) in absolute FEV_1_ values from pre- to posttreatment: Glycopyrrolate grp, 56.0% ± 56.1%; placebo grp, 19.3% ± 40.9% (p < 0.01). | Within-pt analysis found difference missed by comparison of grp means
| Assessment period: 3 hrs from administration of study med | Inclusion (AcEx): Acute respiratory distress plus cough, wheezing, or both | Co-interventions: Nebulized albuterol every hr for 3 aerosols; oxygen by nasal cannula | Percentage of pts admitted to hospital: Overall, 30/57 pts (53%) admitted; no significant differences between grps: Glycopyrrolate grp, 50% admitted vs. 57% in placebo grp (p ≥ 0.05)
| External validity: 2/5 | Exclusion: Personal history of asthma; initial FEV_1_ readings > 75% of predicted normal value; clinical or radiographic evidence of pneumothorax, pneumonia, decompensated CHF, or history of lung cancer; inability to perform spirometry; having received prehospital aerosol treatment; contraindications to study med; age < 18; pregnant; nursing mothers; prisoners | Outcomes: Spirometry performed at baseline and 1 hr after first and third aerosols | Adverse events: Glycopyrrolate + albuterol grp (27% of pts): Dry mouth, headache, hypotension, palpitations. Albuterol-alone (placebo) grp (15% of pts): Tremors, anxiety, palpitations
| COPD dx+ | Smoking history: 46 pack-yrs (n = 51 current or past smokers) | FEV_1_: (a) Mean absolute values at baseline, 1 hr, and 3 hrs | Dropouts: Not described
| COPD bl- | Baseline stable FEV_1_: N/S | (b) Mean % change in absolute value from baseline to 1 and 3 hrs
| AECB dx- | FEV_1_ at admission: Glycopyrrolate grp, 0.89 ± 0.36 (SD) L; placebo grp, 0.93 ± 0.42 L (p ≥ 0.05) | Percentage of pts admitted to hospital
| AECB sev+ | Age: 61.5
| Tx duration- | Sex: N/S
| Internal validity: 4/5 | Race: N/S
| r+, db+, dnd
Karpel, Pesin, Greenberg et al., 1990 | Design: Crossover | N = 32 | Interventions: | FEV_1_: In phase 1 of the trial, mean FEV_1_ (± SEM) improved significantly in both treatment grps from 0–90 min. For ipratropium (n = 17), scores improved 25%, from 0.62 ± 0.08 to 0.88 ± 0.11 (p < 0.01). For metaproterenol (n = 15), the improvement was 18%, from 0.69 ± 0.06 to 0.92 ± 0.09 (p < 0.01). There was no significant difference between the two grps for this outcome (p > 0.05).
| Dates: N/S | Setting: ED and pulmonary clinic | Experimental: Ipratropium, single dose of 3 puffs (54 μg) administered by MDI | For phase 2 of the trial, investigators reported only that there was no further improvement in FEV_1_ in either grp.
| Location: United States | Inclusion (COPD): Chronic bronchitis or emphysema as defined by the ATS Committee on Diagnostic Standards for Nontuberculous Respiratory Disease (1962) | Control: Metaproterenol, single dose of 3 puffs (1.95 mg) administered by MDI | Blood gases: At 30 min, there was a significant (p < 0.05) rise in PaO_2_ with ipratropium (n = 10) (5.8 ± 3.0 [SEM]), and a significant (p < 0.05) decline in PaO_2_ with metaproterenol (n = 10) (-6.2 ± 1.2). At 90 min, these changes were no longer significant.
| Assessment period: 90 min for each phase of crossover | Inclusion (AcEx): Increasing dyspnea and/or change in sputum production newly occurring in previous 24 hrs; FEV_1_ < 60% of predicted | Co-interventions: None | There were no other significant changes in PO_2_, PCO_2_, or pH during phase 1.
| External validity: 3/5 | Exclusion: Asthma; baseline PFTs which failed to show persistent airway obstruction; any acute concomitant medical problem; respiratory acidosis with pH < 7.3; need for continuous oxygen therapy; need for medications other than those included in study protocol; use of inhaled | Crossover design: Pts treated with one of the two study meds initially (phase 1), then crossed over to treatment with the other after 90 min (phase 2); no washout; no information on possible carryover effect | Percentage of pts admitted to hospital: 3/17 pts (18%) from the ipratropium-first grp, 2/15 pts (13%) from the metaproterenol-first grp.
| COPD dx+ | β-agonist or ipratropium in previous 6 hrs | Outcomes: | Adverse events: Recorded for phase 1 only. Ipratropium: Nervousness (2 pts), tremors (2), dry mouth (1), palpitations (1), headache (1). Metaproterenol: Palpitations (3 pts), nervousness (3), tremors (2), dry mouth (1), headache (1).
| COPD bl- | Smoking history: N/S | FEV_1_: Measured at entry and at 30, 60, and 90 min after administration of study med in both phases of crossover; investigators analyzed change in mean FEV_1_ from 0 to 90 min in phase 1 | Dropouts: 0
| AECB dx+ | Baseline stable FEV_1_: N/S | Blood gases: Recorded only for the first 20 pts randomized into the study; measured at entry and at 30, 60, and 90 min after administration of study med in phase 1 only; investigators analyzed mean changes in PaO_2_, PaCO_2_, and pH from 0–30 min and 0–90 min
| AECB sev+ | FEV_1_ at admission: Ipratropium first: 0.62 ± 0.08 (SEM) L; metaproterenol first: 0.69 ± 0.06 L | Percentage of pts admitted to hospital
| Tx duration- | Age: 61.6
| Internal validity: 5/5 | Sex: N/S
| r+, db+, dd | Race: N/S
Moayyedi, Congleton, Page et al., 1995 | Design: SPPG | N = 70 | Interventions: | FEV_1_: No significant differences between the two grps for mean change in FEV_1_ from day 1 to (a) day 3, (b) day 7, (c) day 14, and (d) day of discharge (p > 0.05, all time points). | No significant difference between the two grps in the mean number of days on aminophylline IV, steroids IV, or antibiotics
| Dates: N/S | Setting: Inpatient hospital | Experimental: Nebulized albuterol 5 mg + ipratropium 500 μg, 4x/day, given as a mixture | (a) Albuterol + ipratropium (n = 29), 0.05 ± 0.24 (SD); albuterol (n = 33), 0.17 ± 0.28 | No significant difference between the two grps in the average time of day at which pts admitted
| Location: United Kingdom | Inclusion (COPD): Age > 45 yrs; smoking history > 10 pack-yrs; baseline stable FEV_1_ < 65% of predicted; > 3-yr history of exertional dyspnea resulting from respiratory disease; previous diagnosis of nonasthmatic COPD | Control: Nebulized albuterol 5 mg, 4x/day | (b) Albuterol + ipratropium (n = 29), 0.15 ± 0.26; albuterol (n = 33), 0.21 ± 0.42
| Assessment period: To discharge (mean time to discharge, 11.1 days; 19 pts discharged on day 14 or later) | Inclusion (AcEx): Clinical diagnosis of AcEx of COPD (no details provided) | Co-interventions: Prescribed at discretion of attending physician; included aminophylline IV, steroids IV, and antibiotics | (c) Albuterol + ipratropium (n = 10), 0.26 ± 0.29; albuterol (n = 9), 0.06 ± 0.11
| External validity: 3/5 | Exclusion: Regular home use of nebulized bronchodilators; history suggestive of asthma; peripheral eosinophilia of > 10%; > 20% (at least 200 ml) reversibility of FEV_1_ to 400 μg of inhaled albuterol at discharge | Outcomes: | (d) Albuterol + ipratropium (n = 29), 0.15 ± 0.32; albuterol (n = 33), 0.23 ± 0.32
| COPD dx+ | Smoking history: 51.7 pack-yrs | FEV_1_: Spirometric values were measured once on days 1, 3, and 7, and then wkly and on day of discharge. All readings were taken just before the nebulizer treatment at 18.00 hrs. NB: Not measured immediately on admission - day 1 reading either from 18.00 hrs on day of admission (if pt admitted before 18.00 hrs) or 18.00 hrs on next day (if pt admitted after 18.00 hrs). Investigators analyzed mean change in FEV_1_ from day 1 to (a) day 3, (b) day 7, (c) day 14, and (d) day of discharge. | Length of stay in hospital: No significant difference between the two grps for mean no. of days in hospital: Albuterol + ipratropium (n = 29), 11.8 ± 4.4 (SD); albuterol (n = 33), 10.5 ± 4.7 (p > 0.05).
| COPD bl- | Baseline stable FEV_1_: N/S | LOS in hospital: Mean no. of days | Adverse events: Two pts withdrawn due to AEs, 1 from albuterol + ipratropium grp (wheezing) and 1 from albuterol grp (chest pain). No further data reported on AEs.
| AECB dx- | FEV_1_ on Day 1: 0.78 ± 0.41 (SD) L in the albuterol + ipratropium grp and 0.77 ± 0.34 in the albuterol grp | | Dropouts: 8/70 pts (11%) overall; 4/33 (12%) in the combination therapy grp, 4/37 (11%) in the albuterol grp.
| AECB sev+ | Age: 69.2
| Tx duration+ | Sex: N/S
| Internal validity: 4/5 | Race: N/S
| r, db+, dd
O'Driscoll, Taylor, Horsley et al., 1989 | Design: SPPG | N = 47 COPD pts and 56 asthma pts completed trial; total of 125 randomized to treatment (not broken down by diagnosis) | Interventions: | PFR: No significant difference between the two treatment grps (p = 0.55). Mean pretreatment and 1-hr PFR scores were as follows (no variance data reported): | For entire pt population, no significant differences between treatment grps in number of pts receiving aminophylline or hydrocortisone; not broken down by diagnosis.
| Dates: N/S | Setting: ED | Experimental: Nebulized albuterol 10 mg + ipratropium 0.5 mg | (a) Albuterol alone (n = 21): Pretreatment, 109 l/min; 1 hr, 134
| Location: United Kingdom | Inclusion (COPD): Criteria of ATS (1987) | Control: Nebulized albuterol 10 mg | (b) Albuterol + ipratropium (n = 26): Pretreatment, 116; 1 hr, 135
| Assessment period: 1 hr | Inclusion (AcEx): Acute airflow obstruction (no further details provided) | Co-interventions: Aminophylline IV, hydrocortisone IV administered to some pts | Adverse events: Tremor reported by 2/44 pts (4.5%) receiving albuterol alone and by 5/59 (8.5%) receiving the combined therapy (not broken down by diagnosis); no other AEs reported.
| External validity: 1/5 | Exclusion: Use of home nebulizer or nebulizer treatment en route to ED; history of heart disease or renal disease | Outcomes: | Dropouts: 22/125 pts (18%), 11 from each treatment grp (not broken down by diagnosis)
| COPD dx+ | Smoking history: N/S | Peak flow rate (PFR): Improvement from pretreatment to 1 hr
| COPD bl- | Baseline stable FEV_1_: N/S
| AECB dx- | FEV_1_ at admission: N/S
| AECB sev- | Age: 66.6 (range, 47–81) (COPD pts)
| Tx duration- | Sex: N/S
| Internal validity: 2/5 | Race: N/S
| r-, db, dd
Patrick, Dales, Stark, et al., 1990 | Design: SPPG | N = 68; of 50 pts included in analysis, 21 had admission diagnosis of asthma, 29 AcEx of COPD | Interventions: | FEV_1_: In pts with AcEx of COPD, there was no significant difference between the two treatment grps for mean change in prebronchodilator | Trial included both pts with asthma and pts with AcEx of COPD; FEV_1_ results reported separately for the two types of pts
| Dates: N/S | Setting: ED | Experimental: Ipratropium 80 μg by MDI at 0 and 2 hrs, then every 3 hrs (immediately after each albuterol treatment) | FEV_1_ from 0 to 24 hrs: Ipratropium (n = 13), 0.15 L ± 0.24 (SD); placebo (n = 16), 0.10 L ± 0.18 (no p-value reported).
| Location: Canada | Inclusion (general): | Control: Placebo | Adverse events: No data reported
| Assessment period: 24 hrs | (1) Presented at ED because of dyspnea, cough, wheeze or chest discomfort, and | Co-interventions: Nebulized albuterol at 0 and 2 hrs, then every 3 hrs; aminophylline IV by continuous infusion; methylprednisolone IV every 6 hrs; broad spectrum antibiotic (ampicillin, tetracycline, or erythromycin), dosing schedule N/S | Dropouts: 18/68 pts (27%), treatment grp and diagnosis N/S
| External validity: 1/5 | (2) FEV_1_ < 60% predicted and FEV_1_/FVC < 60% predicted, and | Outcomes:
| COPD dx- | (3) clinical diagnosis by ED physician compatible with airflow limitation requiring hospital admission but not mechanical ventilation, and | FEV_1_: Measured before and 15 min after nebulized albuterol treatment on entry and at 24 hrs. Investigators analyzed mean change in prebronchodilator FEV_1_ from 0 to 24 hrs
| COPD bl- | (4) nebulized β-agonist, aminophylline IV, and corticosteroids IV administered on admission
| AECB dx- | Inclusion (AcEx): No indication of criteria used to distinguish pts with AcEx of COPD from those with asthma
| AECB sev- | Exclusion: N/S
| Tx duration+ | Smoking history: N/S
| Internal validity: 4/5 | Baseline stable FEV_1_: N/S
| r, db+, dd | FEV_1_ at admission: COPD pts only: Ipratropium, 0.62 L ± 0.33 (SD); placebo, 0.44 L ± 0.14 (no p-value reported)
| | Age: 57.6 (all pts)
| | Sex: 23 M, 27 F (all pts)
| | Race: N/S
Rebuck, Chapman, Abboud, et al., 1987 | Design: SPPG | N = 52 with AcEx of COPD (see Notes) | Interventions: | FEV_1_: Each of the three treatment regimens produced a significant improvement in FEV_1_ from 0 to 90 min (p < 0.05). There was no significant difference among the three treatments for this outcome (p < 0.2). Mean improvement scores (± SEM) were reported in graphic form only. Pretreatment and 90-min mean FEV_1_ scores (± SD) for the three grps were: | Trial included both pts with acute asthma (n = 150) and pts with AcEx of COPD (n = 52). Most results were reported separately for the two types of pts.
| Dates: N/S | Setting: 4 EDs | Experimental: Nebulized ipratropium 0.5 mg + fenoterol 1.25 mg, single dose | Fenoterol: Pre-: 0.69 ± 0.30; 90-min: 0.88 ± 0.44 | No significant difference in the proportion of COPD pts receiving aminophylline IV and cortico-steroids IV in the three treatment grps
| Location: Canada | Inclusion (COPD): ATS criteria (1962) | Control 1: Nebulized ipratropium 0.5 mg, single dose | Ipratropium: Pre-: 0.69 ± 0.26; 90-min: 0.89 ± 0.41
| Assessment period: 90 min | Inclusion (AcEx): Age > 18 yrs; FEV_1_ < 70% of predicted | Control 2: Nebulized fenoterol 1.25 mg, single dose | Ip + Fen: Pre-: 0.63 ± 0.31; 90-min: 0.80 ± 0.40
| External validity: 2/5 | Exclusion: Complicating medical illnesses (e.g., pneumonia, pulmonary edema, acute myocardial infarction, frequent ventricular ectopic beats); pregnancy or breastfeeding; use of nebulized bronchodilator in previous 6 hrs; need for medications other than those specified in study protocol | Co-interventions: Aminophylline IV or corticosteroids IV could be used at discretion of attending physician; all other drugs proscribed | Adverse events: Pts were questioned about specific AEs. Results were not reported separately for pts with asthma and COPD. The most commonly reported AEs were dry mouth (10.6% of pts taking combination treatment, 19% taking fenoterol alone, 7.4% taking ipratropium alone); tremor (17% of pts taking combination treatment, 13% taking fenoterol alone, 2.9% taking ipratropium alone); and bad taste (8.4% overall). Eye irritation, sweating, and dizziness were each reported by < 3% of pts overall.
| COPD dx+ | Smoking history: N/S | Outcomes: | Dropouts: 1/52 pts (1.9%), from ipratropium grp
| COPD bl- | Baseline stable FEV_1_: N/S | FEV_1_: Mean change from pretreatment to 45 and 90 min
| AECB dx- | FEV1 at admission: 0.67 ± 0.29 (SD) L (28% of predicted) (COPD pts only)
| AECB sev+ | Age: 66.2 (COPD pts only)
| Tx duration- | Sex: 28 M, 23 F
| Internal validity: 5/5 | Race: N/S
| r+, db+, dd
Shrestha, O'Brien, Haddox, et al., 1991 | Design: SPPG | N = 68 | Interventions: | Percentage of pts admitted to hospital: 2/30 pts (6.7%) receiving ipratropium, 3/25 pts receiving placebo (12%); not analyzed by investigators (too few pts) | No significant differences between treatment grps in the proportion of pts receiving aminophylline and methyl-prednisolone
| Dates: 4/88-9/88 | Setting: ED | Experimental: Ipratropium by MDI; 3 puffs (54 μg) given w/in 5–10 min of initial isoetharine dose; further doses of 2 puffs (36 μg) each given at 1 and 3 hrs, just after isoetharine | Length of stay in ED: Mean length of stay significantly (p < 0.05) shorter for pts receiving ipratropium (n = 30) than for pts receiving placebo (n = 25):
| Location: United States | Inclusion (COPD): Age > 40 yrs | Control: Placebo | Ipratropium: 226 ± 102 (SD) min
| Assessment period: To discharge from ED (range, 80–530 min) | Inclusion (AcEx): Clinical diagnosis of COPD exacerbation (ATS [= ATS Committee on Diagnostic Standards for Nontuberculous Respiratory Disease], 1962); FEV_1_ ≤ 40% of predicted | Co-interventions: Nebulized isoetharine on presentation and every hr thereafter; aminophylline IV given if serum theophylline level not adequate; methylprednisolone IV administered “if there was no contraindication and if the physician thought that the pt would benefit from corticosteroid treatment” | Placebo: 317 ± 135 min
| External validity: 1/5 | Exclusion: N/S | Outcomes: Percentage of pts admitted to hospital | Adverse events: Specific AEs were not sought, and none were reported during trial
| COPD dx- | Smoking history: N/S | LOS in ED: Mean (in min) | Dropouts: 13/68 (19%) total, 8/33 (24%) in the placebo grp, 5/35 (14%) in the ipratropium grp
| COPD bl- | Baseline stable FEV_1_: N/S
| AECB dx- | FEV_1_ at admission: Ipratropium, 0.68 ± 0.27 (SD); placebo, 0.69 ± 0.25 (p > 0.05)
| AECB sev+ | Age: Ipratropium grp, 62 ± 9.3 (median ± SD); placebo grp, 63 ± 8.0
| Tx duration- | Sex: 35 M, 20 F
| Internal validity: 5/5 | Race: 33 Black, 16 White, 6 Latin American
| r+, db+, dd
Beta_2_-agonists
Backman and Hellström, 1985 | | See above, under “Anticholinergics”
Cydulka and Emerman, 1995 | | See above, under “Anticholinergics”
Emerman and Cydulka, 1997 | Design: SPPG | N = 86 | Interventions: | FEV_1_: (a) There were no significant differences in FEV_1_ scores in the two treatment grps pretreatment or at 2 hrs: | 10 pts had a history of both asthma and COPD.
| Dates:1/93-12/94 | Setting: ED | Experimental: Nebulized albuterol 2.5 mg, every 20 min | (1) Pretreatment: 6-dose grp (n = 41), 24.9% ± 11.2% (SD) predicted normal; 2-dose grp (n = 45), 24.5% ± 11.7% predicted normal (no p-value or 95% CI reported) | Investigators speculated that type II statistical error was possible.
| Location: United States | Inclusion (COPD): Age > 50 yrs; previously established diagnosis of COPD as determined by primary care physician, or history consistent with chronic bronchitis (sputum production for 3 mos/yr for ≥ 2 yrs [ATS, 1987]) | Control: Nebulized albuterol 2.5 mg, every 60 min | (2) 2 hrs: 6-dose grp (n = 41), 31.6% ± 15.7% (SD) predicted normal; 2-dose grp (n = 45), 28.9% ± 15.7% predicted normal (95% CI, -4.04 to 9.44) | Post hoc analysis showed that, in 32 pts with a pretreatment FEV_1_ < 20% of predicted, the % change in the absolute value of FEV_1_ from pretreatment to 2 hrs was significantly greater with the higher dose regimen (p < 0.05). There was still no significant difference in hospitalization rate or AE rate.
| Assessment period: 2 hrs | Inclusion (AcEx): Dyspnea (no further details provided) | Co-interventions: No other medications permitted during course of study (2 hrs) | (b) The percentage change in the absolute value of FEV_1_ from pretreatment to 2 hrs in the 6-dose grp was nearly double that in the 2-dose grp, but the difference was not statistically significant (p = 0.09; 95% CI, -2.0 to 30.2), possibly due to a type II error. Repeated-measures ANOVA confirmed that there was no significant difference between the two grps in the change in FEV_1_ over time.
| External validity: 1/5 | Exclusion: Clinical evidence of decompensated CHF or pneumonia; history of lung cancer; previous lung surgery; too ill to perform spirometry | Outcomes: | Percentage of pts admitted to hospital: 69% in both grps (31/45 for 2-dose grp; n's uncertain for 6-dose grp) (NS, 95% CI -18% to 21%)
| COPD dx- | Smoking history: 60.9 pack-yrs | FEV_1_: (a) Pre- and posttreatment mean FEV_1_ (expressed as a % of predicted normal) | Adverse events: Pts were specifically questioned about AEs associated with albuterol, including palpitations, headache, tremor, nausea, and vomiting. 45% of pts in the 6-dose grp reported such symptoms, as did 24% of pts in the 2-dose grp (11/45 for 2-dose grp; n's uncertain for 6-dose grp). This difference was significant (p < 0.05; 95% CI, 21% to 42%).
| COPD bl- | Baseline stable FEV_1_: N/S | (b) Percentage change in the absolute value of FEV_1_ from pre- to posttreatment | Dropouts: 0
| AECB dx- | FEV_1_ at admission: Experimental grp, 24.9% ± 11.2% (SD) predicted normal; control grp, 24.5% ± 11.7% predicted normal | Percentage of pts admitted to hospital
| AECB sev+ | Age: 63.9
| Tx duration- | Sex: 42 M, 44 F
| Internal validity: 4/5 | Race: N/S
| r, db+, dd
Karpel, Pesin, Greenberg, et al., 1990 | | See above, under “Anticholinergics”
Moayyedi, Congleton, Page, et al., 1995 | | See above, under “Anticholinergics”
O'Driscoll, Taylor, Horsley, et al., 1989 | | See above, under “Anticholinergics”
Perri, Giovannini, and Spada, 1985 | Design: SPPG | N = 30 | Interventions: | FEV_1_: (a) Both treatment grps improved prebronchodilatation FEV_1_ scores significantly from pre- to posttreatment. There were no significant differences between grps (p-value not reported). | Before treatment, the pre- to postbronchodilatation percentage change in FEV_1_ was 14.3 ± 8.6% for the albuterol plus beclomethasone grp (n = 15) and 17.4% ± 6.8% for the fenoterol grp (n = 15).
| Dates: N/S | Setting: N/S | Experimental: Albuterol plus beclomethasone dipropionate (fixed combination), 2 puffs (75 μg albuterol + 50 μg of beclomethasone dipropionate per puff), 3x/day | (1) Albuterol plus beclomethasone grp (n = 15), pre- and post-tx scores: 52.8 ± 12.6% (SD) predicted normal; 67.80 ± 20.20% predicted normal (p = 0.003)
| Location: Italy | Inclusion (COPD): Defined as “reversible chronic obstructive lung disease,” with degree of reversibility determined by following test: “[all pts had] at least a 15% greater forced expiratory volume in one second, FEV_1_, in relation to their CECA predicted values after 200 μg (2 puffs) of albuterol administered by aerosol” (CECA = Comunita European Carbone e Acciaco) | Control: Fenoterol, 2 puffs (200 μg/puff), 3x/day | (2) Fenoterol grp (n = 15), pre- and post-tx scores: 46.2 ± 11.2% predicted normal; 53.60 ± 16.10% predicted normal (p = 0.004)
| Assessment period: 4-wk treatment period; outcomes measured on day before and day after treatment, as well as after bronchodilatation (for a “degree of reversibility test”), which was performed after pre- and posttreatment measurements were taken | Inclusion (AcEx): “Acute exacerbations” (not defined) | Co-interventions: No other drugs active against bronchial obstruction were permitted during treatment | (b) The percentage increase in prebronchodilator FEV_1_ scores from pre- to posttreatment in the albuterol plus beclomethasone grp was almost double that in the fenoterol grp: albuterol plus beclomethasone grp, 15.0 ± 17.7% (p = 0.003, pre- to posttx); fenoterol grp, 7.4 ± 9.36% (p = 0.004, pre- to post-tx). No significant between-grp differences (no p-value reported)
| External validity: 3/5 | Exclusion: Those not meeting the reversibility test described above | Degree of Reversibility Test: Bronchodilatation, using 200 μg (2 puffs) of albuterol administered by aerosol, was performed after pre- and posttreatment FEV_1_ measurements were taken | Blood gases/oximetry: N/S
| COPD dx+ | Smoking history: N/S | Outcomes: Spirometric values were measured once on day before and once on day after treatment ended; after each of the above measurements was obtained, bronchodilatation was performed and FEV_1_ was measured again | LOS in ED or hospital: N/S
| COPD bl- | Baseline stable FEV_1_: N/S | FEV_1_: (a) Pre- and posttreatment mean FEV_1_ value before bronchodilatation (expressed as a % of predicted normal) | Adverse events: At end of trial, pts were specifically questioned about AEs. Albuterol plus beclomethasone grp: tremors, 1/15 (6.7%); insomnia, 1/15 (6.7%); fenoterol grp, tremors, 5/15 (33%), 1 of whom also had insomnia; insomnia, 1/15 (6.7%), excluding the pt who also had tremors
| AECB dx- | FEV_1_ (% predicted) at admission: Albuterol plus beclomethasone dipropionate grp, 52.8 ± 12.6 (SD); fenoterol grp, 46.2 ± 11.2 | (b) Pretreatment percentage change in mean FEV_1_ from pre- to postbronchodilatation | Dropouts: Not described
| AECB sev+ | Age: 59 yrs (pts in fenoterol grp only; age of pts in other grp N/S)
| Tx duration+ | Sex: N/S
| Internal validity: 1/5 | Race: N/S
| r, ndb, dnd
Rebuck, Chapman, Abboud, et al., 1987 | | See above, under “Anticholinergics”
Zehner, Scott, Iannolo, et al., 1995 | Design: SPPG | N = 90 (numbers with asthma and with COPD N/S) | Interventions: | PEFR: Median pretreatment PEFR scores (with interquartile range) were 75 L/min (30 to 123) in the albuterol grp (n = 40) and 75 L/min (43 to 145) in the terbutaline grp (n = 43) (p > 0.05). | Trial included pts with asthma and pts with COPD. Though no results were reported separately by diagnosis, trial was included because of unique setting/pt population.
| Dates: 6/92-11/92 | Setting: EMS ambulances | Experimental: Nebulized albuterol 2.5 mg, single dose | Similar improvements were noted in the two grps after treatment (p > 0.05). Median changes (with interquartile range) in PEFR from pretreatment to arrival at the ED were 15 L/min (0 to 70) in the albuterol grp, and 0 L/min (0 to 40) in the terbutaline grp.
| Location: United States | Inclusion: Age > 18 yrs; judged (by EMS personnel) to have respiratory distress secondary to asthma or COPD | Control: Terbutaline SC 0.25 mg, single dose | Percentage of pts admitted to hospital: Albuterol, 40% (16/40); terbutaline, 44% (19/43) (p > 0.05).
| Assessment period: Up to arrival at the ED | Exclusion: Chest pain of presumed cardiac origin; allergies to study med; refusal to give informed consent; prior SC epinephrine administration; refusal of further care; need for immediate assisted ventilation or ET intubation; or incomplete data | Co-interventions: Oxygen by mask or cannula, D5W IV | Adverse events: Pts were monitored for dysrhythmias, vomiting, pain from injection, and headache; no such AEs were observed.
| External validity: 0/5 | Smoking history: N/S | Outcomes: No results were reported separately for COPD pts. | Dropouts: 7/90 (7.8%) (treatment grp and diagnosis N/S)
| COPD dx- | Baseline stable FEV_1_: N/S | PEFR: Median change in PEFR score from pretreatment to arrival at ED
| COPD bl- | FEV_1_ at admission: N/S | Percentage of pts admitted to hospital
| AECB dx- | Age: 59.0
| AECB sev- | Sex: 42 M, 41 F
| Tx duration- | Race: N/S
| Internal validity: 5/5
| r+, db+, dd
Methylxanthines
Dolcetti, Osella, De Filippis, et al., 1988 | Design: Crossover | N = 10 | Interventions: | FEV_1_: Mean posttreatment FEV_1_ with the two interventions were not directly compared. Mean FEV_1_ with doxofylline was significantly better at 2 and 4 hrs than at baseline (p < 0.05); there was no significant difference between the mean 6-hr score and baseline (no p-value reported). Mean 2-, 4-, and 6-hr FEV_1_'s with placebo were lower than at baseline, though not significantly so (no p-values reported). | Unspecified (nonstandardized?) “further therapy” permitted during 6-hr posttreatment assessment period if pt's clinical status worsened
| Dates: N/S | Setting: N/S | Experimental: Doxofylline IV 200 mg, single dose infused over 15 min | Baseline FEV_1_'s are reported at left (under “Patient Population”). 2-, 4-, and 6-hr mean scores (± SD) were:
| Location: Italy | Inclusion (COPD): Chronic obstructive airways disease (no diagnostic criteria given) | Control: Placebo | Doxofylline (n = 10): 2 hrs, 1.49 ± 0.84; 4 hrs, 1.59 ± 0.99; 6 hrs, 1.37 ± 0.92.
| Assessment period: 6 hrs for each period of crossover | Inclusion (AcEx): Acute or subacute exacerbation of chronic airways disease (no diagnostic criteria given), with improvement of ≥ 15% following albuterol inhalation | Co-interventions: No other medication given to pts during 12 hrs preceding treatment; unspecified “further therapy” permitted during 6-hr posttreatment assessment period if pt's clinical status worsened | Placebo (n = 10): 2 hrs, 1.18 ± 0.70; 4 hrs, 1.06 ± 0.54; 6 hrs, 1.17 ± 0.83.
| External validity: 1/5 | Exclusion: Severe extra-respiratory disease | Crossover design: Pts were treated with one study med on one day, then with other study med on another day, with the two treatments separated by at least 24 hrs | (b) Mean percentage increase in FEV_1_ (compared to baseline) was significantly greater with doxofylline than with placebo at 2 and 4 hrs (p < 0.05); it was unclear whether the difference between the two interventions was significant at 6 hrs (disagreement among abstract, text, table, and figure). Mean percentage changes from baseline were:
| COPD dx- | Smoking history: N/S | Outcomes: | Doxofylline: 2 hrs, +20%; 4 hrs, +31%; 6 hrs, +13% (no variance data reported).
| COPD bl- | Baseline stable FEV_1_: N/S | FEV_1_: (a) Mean FEV_1_ at baseline, 2, 4, and 6 hrs | Placebo: 2 hrs, -4.4%; 4 hrs, -14%; 6 hrs, -5% (no variance data reported).
| AECB dx- | FEV_1_ immediately prior to treatment: Before doxofylline, 1.21 ± 0.74 (SD) L; before placebo, 1.23 ± 0.67 L (n.s.) | (b) Mean percentage increase in FEV_1_ from baseline (immediately pretreatment during each period of crossover) at 2, 4, and 6 hrs | Adverse events: No AEs were reported
| AECB sev+ | Age: 58 (range: 26–79) | | Dropouts: Not described
| Tx duration- | Sex: 8 M, 2 F
| Internal validity: 2/5 | Race: N/S
| r, db, dnd
Rice, Leatherman, Duane, et al., 1987 | Design: SPPG | N = 30 | Interventions: | FEV_1_: In both treatment grps, pre- and postbronchodilator FEV_1_ scores improved significantly over time (p < 0.05, all comparisons), but there were no significant differences between the two grps for this outcome (p < 0.6). Mean changes in FEV_1_ (± SEM) were reported only in graphical form.
| Dates: N/S | Setting: VA hospital; pts admitted to hospital from ED or walk-in clinic | Experimental: Aminophylline IV; loading dose of 0–6 mg/kg given, depending on theophylline use over previous 12–24 hrs; maintenance dose adjusted to achieve serum theophylline level of 72–94 μmol/L (abstract has 72–83 μmol/L) | Blood gases: (a) Mean increases in PaO_2_ (± SEM) were 14 ± 4 mm Hg with placebo (n = 13) and 13 ± 5 mm Hg with aminophylline (n = 15). The difference between these mean increases, 2 mm Hg (95% CI, -8 to 11 mm Hg), was not statistically significant (p > 0.6).
| Location: United States | Inclusion (COPD): Previous diagnosis of COPD based on FEV_1_ more than 2 SD below the predicted value and FEV_1_/FVC < 60% | Control: Placebo | (b) Mean reductions in PaCO_2_ (± SEM) were 4 ± 3 mm Hg with placebo (n = 13) and 9 ± 3 mm Hg with aminophylline (n = 15). The difference between these mean reductions, 5 mm Hg (95% CI, -4 to 13), was not statistically significant (p > 0.2).
| Assessment period: 72 hrs | Inclusion (AcEx): Worsening of dyspnea within previous several days, usually associated with increased cough and sputum, sufficiently severe to require hospital admission | Co-interventions: Nebulized metaproterenol every 4 hrs (abstract has every 6 hrs); methylprednisolone IV every 6 hrs; ampicillin PO or IV every 6 hrs (tetracycline PO every 6 hrs or trimethoprim-sulfamethoxazole PO every 12 hrs substituted in pts with a history of penicillin allergy); supplemental oxygen as needed | Adverse events: Pts were questioned about specific adverse events which might be attributable to treatment. 1/13 pts receiving placebo (7.7%) reported AEs, as did 7/15 receiving aminophylline (47%) (0.05 < p < 0.10). Significantly more pts in the aminophylline grp reported nausea or vomiting (6/15 pts vs. 0/13 pts taking placebo, p < 0.05). One pt in each grp reported tremor.
| External validity: 4/5 | Exclusion: Clinical diagnosis of asthma; readily reversible episodes of wheezing and dyspnea separated by asymptomatic intervals; bronchodilator response of a > 30% increase in FEV_1_ shown by previous spirometry; suspected left ventricular failure or pneumonia; need for immediate MV | Outcomes: | Dropouts: 2/30 pts (6.7%), 1 from each treatment grp
| COPD dx+ | Smoking history: N/S | FEV_1_: Readings taken 2x/day, morning and afternoon, before and 30 min after metaproterenol; baseline value postbronchodilator (see left, “FEV_1_ at admission”). Investigators analyzed mean change (from baseline) in pre- and postbronchodilator FEV_1_ for morning and afternoon timepoints on days 1, 2, and 3
| COPD bl- | Baseline stable FEV_1_: N/S | Blood gases: (a) Mean increases in PaO_2_ from 0 to 72 hrs
| AECB dx+ | FEV_1_ at admission: Because many pts were treated with nebulized metaproterenol in the admissions area before entry into the study, the initial post-bronchodilator readings were used as baseline values. Aminophylline grp, 0.60 ± 0.51 (SEM) L; placebo grp, 0.56 ± 0.97 L (p > 0.05). | (b) Mean reductions in PaCO_2_ from 0 to 72 hrs
| AECB sev+ | Age: 65.1
| Tx duration+ | Sex: 27 M, 1 F
| Internal validity: 5/5 | Race:N/S
| r+, db+, dd
Seidenfeld, Jones, Moss, et al., 1984 | Design: SPPG | N = 52 | Interventions: | FEV_1_: No significant difference between the two grps for percentage change in FEV_1_ from 0 to 2 hrs (p > 0.05). | 9 pts were seen on two occasions, but none was seen within one mo of the initial visit.
| Dates: N/S, but pts recruited over 6-mo period | Setting: ED | Experimental: Aminophylline IV, 5.6 mg/kg (or 2.8 mg/kg if pt had received theophylline in previous 6 hrs), administered over 1 hr | (a) Aminophylline (n =22): 27% ± 57% (SD) | No significant differences were seen in % change in FEV_1_ from 0 to 2 hrs when subtherapeutic
| Location: United States | Inclusion (COPD): Chronic bronchitis, as defined by ATS (1962) | Control: Placebo | (b) Placebo (n = 30): 22% ± 24% | (≤ 10 μg/ml) and therapeutic (> 10 μg/ml) theophylline grps were compared.
| Assessment period: 2 hrs | Inclusion (AcEx): Exacerbation of COPD or bronchospastic episode (no further details provided) | Co-interventions: Nebulized metaproterenol at admission and 1 hr; oxygen by Venturi mask | Adverse events: Limited data reported. No significant AEs were encountered in the 15 pts with theophylline levels over 20 μg/ml. No episodes of hypoventilation occurred.
| External validity: 1/5 | Exclusion: Temperature > 37.5 degrees C; need for direct hospital admission for any reason; cardiac rhythm disturbance; acute pneumonia; acute heart failure | Outcomes: | Dropouts: N/S
| COPD dx- | Smoking history: N/S | FEV_1_: Percentage change from entry to 2 hrs
| COPD bl- | Baseline stable FEV_1_: N/S
| AECB dx- | FEV_1_ at admission: Aminophylline grp, 0.7 ± 0.3 (SD) L; placebo grp, 0.9 ± 0.5 L
| AECB sev+ | Age: 62.6
| Tx duration- | Sex: 52 M, 0 F
| Internal validity: 4/5 | Race: N/S
| r+, db+, dnd
Wrenn, Slovis, Murphy, et al., 1991 | Design: SPPG | N = 143 (numbers of pts with asthma and COPD N/S) | Interventions: | Percentage of pts admitted to hospital: 7% of pts receiving aminophylline vs. 26% receiving placebo (p = 0.07) (n's N/S). | Trial included pts with asthma and pts with COPD; limited results reported separately for COPD pts
| Dates: N/S | Setting: ED | Experimental: Aminophylline IV, loading dose of 5.6 mg/kg over 20 min, followed by constant infusion of 0.9 mg/kg/hr | Adverse events: (Reported only for entire pt population.) No significant differences between the two grps in incidence of AEs. Aminophylline: Tremor, 23%; nausea, 9%; anxiety, 9%; palpitations or arrhythmia, 6%; seizure, 0%. Placebo: Tremor, 18%; anxiety, 8%; palpitations or arrhythmia, 5%; nausea, 3%; seizure, 1.5%.
| Location: United States | Inclusion (COPD): Age > 16 yrs; asthma (age < 45 yrs; smoking history < 20 pack-yrs; and duration of disease < 20 yrs or onset of asthma in childhood); or COPD (age > 45 yrs, smoking history ≥ 20 pack-yrs; and duration of disease > 20 yrs or onset of disease after age 45) | Control: Placebo | Dropouts: 10/143 (7.0%), treatment grp and diagnosis N/S
| Assessment period: To time of discharge from ED (either home or to hospital) | Inclusion (AcEx): Asthma exacerbation or wheezing | Co-interventions: Nebulized metaproterenol every 15–20 min for 3 treatments, then every 30–60 min as needed; methylprednisolone IV
| External validity: 1/5 | Exclusion: Use of theophylline-containing product in previous 24 hrs; history of adverse reaction to theophylline; contraindication to other study med; insulin-dependent diabetes; possible myocardial ischemia; or pulmonary edema | Outcomes: Only those efficacy outcomes for which results were reported separately for pts with asthma and those with COPD are described.
| COPD dx- | Smoking history: N/S | Percentage of pts admitted to hospital: Decision to admit made by noninvestigator using preexisting guidelines (history of recent relapse, failure to clear after 6 hrs of treatment, pt-reported inability to attain preexacerbation status, respiratory failure, inability to walk 100 feet w/o exacerbating symptoms or signs)
| COPD bl- | Baseline stable FEV_1_: N/S
| AECB dx- | FEV_1_ at admission: Median FEV_1_ (COPD pts only): Aminophylline, 0.7 L (interquartile range, 0.5–0.9); placebo, 0.7 L (0.4–1.1) (p > 0.2)
| AECB sev+ | Age: N/S
| Tx duration- | Sex: 60% M, 40% F (COPD pts)
| Internal validity: 3/5 | Race: N/S
| r, db, dd
Combining Bronchodilators
Lloberes, Ramis, Montserrat, et al., 1988 | Design: Crossover | N = ? (see “Notes” column) | Interventions: | FEV_1_: (a) There were no significant differences in baseline FEV_1_ values among the three drugs (no p-values reported). All three agents improved significantly from baseline to the maximal treatment effect achieved at end of phase 1 of each protocol (no p-values reported), but there were no significant differences between the increases achieved by ipratropium, albuterol, or aminophylline alone (no p-values reported). Absolute and percentage change increases in FEV_1_ from pre-tx to the maximal effect (“post” tx) were as follows (no p-values given for any comparisons): | Low quality score (0)
| Dates: N/S | Setting: Hospitalized pts drawn from outpatient clinic where they received regular bronchodilator treatment (including beta_2_-adrenergics and oral theophylline) | Crossover Design: After the initial AcEx phase had been stabilized, bronchodilator treatment was withheld for 24 hrs (washout); pts (n = 13) then completed 3 crossover periods (protocols), 1 per day, with 2 phases per period. During phase 1, pts took an initial treatment every 30 min until a bronchodilatation phase was reached; during phase 2, pts were randomized to 1 of 2 different treatments for 45 min. Time between protocols was not specified. | (1) Albuterol (n = 13): pre-tx, 0.66; maximal effect (“post” tx), absolute increase (not value), 0.146 ± 0.102 (SEM) L (% increase, 22% ± 5%) | Not clear how many pts entered trial or if those selected (n = 13) were chosen randomly; during phase 2 of each protocol, however, pts were randomized to receive 2 different treatments during each protocol
| Location: Spain | Inclusion (COPD): Chronic bronchitis, emphysema, or both, and evidence of severe airflow obstruction, with FEV_1_ < 1 L (determined by clinical diagnosis) | Description of Protocols: | (2) Ipratropium (n = 13): pre-tx, 0.66; maximal effect, absolute increase, 0.167 ± 0.72 L (% increase, 25% ± 4.43%) | Not clear whether order of protocols was randomized
| Assessment period: 4 days; 3-day treatment period after an initial 24-hr washout period; 3 crossover periods (protocols), with 2 different treatment phases in each period (see “crossover design”) | Inclusion (AcEx): “Acute exacerbation,” defined as “an increase of symptoms (breathlessness and mucus secretion) and gasometric deterioration, attributed to a bronchial infection” | Protocol A: Inhaled albuterol 200 μg (2 puffs), administered every 30 min until bronchodilatation plateau reached (n = 13); then pts randomized to receive either ipratropium bromide 40 mg (n = 5), using an MDI, or a loading dose of aminophylline IV (n = 8), 5.6 mg/kg in 30 min followed by a continuous infusion of 0.9 mg/kg-hr; both treatments assessed at 45 min | (3) Aminophylline (n = 13): pre-tx, 0.64; maximal effect, absolute increase, 0.105 ± 0.97 L (% increase, 16% ± 3.32%)
| External validity: 4/5 | Exclusion: Episodic attacks of wheezing indicative of bronchial asthma; lung function reversibility of > 15% after inhalation of 2 puffs of albuterol while clinically stable | Protocol B: Inhaled ipratropium bromide 40 μg (n = 13), administered every 30 min, using an MDI, until bronchodilatation plateau reached; then pts randomized to receive either a single dose of albuterol (amount and route of administration N/S) (n = 7) or aminophylline IV (n = 6), administered as described above; both treatments assessed at 45 min | (b) All three agents improved from the plateau reached after the first drug to the end of treatment with the second drug, but none of the increments were statistically significant (no p-values reported). No between-grp results were reported for this outcome. The percentage (and absolute) increases from the first to the second treatment(s) were:
| COPD dx+ | Smoking history: N/S | Protocol C: Aminophylline IV (n = 13), administered using loading dose of 5.6 mg/kg in 30 min followed by a continuous infusion of 0.9 mg/kg-hr; administered every 30 min until bronchodilatation plateau reached; then pts randomized to receive either a single dose of albuterol (amount and route of administration N/S) (n = 5) or a single dose of ipratropium (amount and route of administration N/S) (n = 8); both treatments assessed at 45 min | (1) Albuterol first: ipratropium (n = 5), 0% (0 L); aminophylline (n = 8), 3% ± 1.4% (0.065 ± 0.11 L)
| COPD bl+ | Baseline stable FEV_1_: 0.82 ± 0.19 (SD) L (range, 0.54–1.1) | Co-interventions: Corticosteroids and antibiotics were permitted | (2) Ipratropium first: albuterol (n = 7), 6.3% ± 2.6% (0.053 ± 0.066 L); aminophylline (n = 6), 3.4% ± 2.6% (0.029 ± 0.065 L)
| AECB dx+ | FEV_1_ at admission: 0.64 ± 0.11 (SD) L (range, 0.35–1.01) | Outcomes: Forced spirometric measurements (by Vitalograph) were taken on each of 3 days before initial study drug was administered and at 45 min after 2nd study drug was administered | (3) Aminophylline first: albuterol (n = 5), 8.63% ± 1.78% (0.06 ± 0.03 L); ipratropium (n = 6), 6.1% ± 2.82% (0.046 ± 0.06 L)
| AECB sev+ | Age: 65 (range, 50–75) | FEV_1_: (a) Absolute (mean ± SEM) and percentage pre- to posttreatment changes in baseline FEV_1_ for each protocol; 3-way ANOVA used to analyze changes among the 3 protocols | Adverse events: No data provided on AEs
| Tx duration- | Sex: N/S | (b) Absolute and percentage changes in FEV_1_ after second drug was administered, compared with maximal bronchodilatation FEV_1_ obtained with the first treatment (for each protocol); paired t-test used to analyze changes from first to second drug | Dropouts: Not described
| Internal validity: 0/5 | Race: N/S
| nr, ndb, dnd

1 External validity score (5 points possible): COPD dx = COPD diagnosis based on spirometry (+ = yes = 1; - = no = 0); COPD bl = baseline stable ventilatory status of population described (+ = yes = 1; - = no = 0); AECB dx = diagnosis of AECB includes at least two of following: increased sputum purulence, increased sputum volume, increased dyspnea (+ = yes = 1; - = no = 0); AECB sev = severity of AECB at enrollment described based on at least two of following: mental status change, work of breathing, ventilatory status (+ = yes = 1; - = no = 0); Tx duration = outcomes assessed at 24 hours or later (+ = yes = 1; - = no = 0).

2 Internal validity score (5 points possible): Randomization: r = study described as randomized, method of randomization not described (1 point); r+ = method of randomization described and adequate (2 points); r- = method of randomization described but inadequate (0 points). Double-blinding: ndb = not double-blind (0 points); db = study described as double-blind, method of blinding not described (1 point); db+ = method of blinding described and adequate (2 points); db- = method of blinding described but inadequate (0 points). Dropouts: dd = dropouts described (1 point); dnd = dropouts not described (0 points).

Evidence Table 5. Corticosteroids

Study | Design and Quality | Patient Population | Study Protocol | Results | Notes
Albert, Martin, and Lewis, 1980 | Design: SPPG | N = 44 | Interventions: | FEV_1_: (a) Mean % change in both pre- and postbronchodilator FEV_1_ significantly greater in the steroid grp than in the placebo grp at all timepoints (p < 0.001) (means reported only in graphical form). | Predictors of ≥ 40% improvement in pre- or postbronchodilator FEV_1_ by 72 hrs:
| Dates: 10/76-3/78 | Setting: Hospitalized pts (VA hospital) | Experimental: Methylprednisolone IV, 0.5 mg/kg, every 6 hrs | (b) ≥ 40% improvement in prebronchodilator FEV_1_ scores: Steroid grp, 12/22 pts (55%) vs. placebo grp, 3/21 pts (14%) (p < 0.01). | No correlation found with baseline stable spirometry, spirometry on admission, presence of CHF, weight loss during study, bronchodilator responsiveness, or eosinophil counts
| Location: United States | Inclusion (COPD): “Chronic bronchitis” defined as cough and sputum production during most days for ≥ 3 mos/yr during the preceding 2 yrs; “chronic airflow obstruction” defined as baseline stable FEV_1_ ≤ 60% of predicted value or ≤ 60% of baseline stable FVC | Control: Placebo | (c) ≥ 40% improvement in postbronchodilator FEV_1_ scores: Steroid grp, 9/22 pts (41%) vs. placebo grp, 3/21 pts (14%) (p < 0.05).
| Assessment period: Treatment started w/in 4 hrs of admission to hospital; study duration was 72 hrs from administration of study med | Inclusion (AcEx): “Acute bronchitis” defined as an increase in cough and sputum production with a change in sputum color or tenacity within 5 days before episode of acute respiratory insufficiency; “acute respiratory insufficiency” defined as (1) PaO_2_ ≤ 65 mm Hg on room air, and/or (2) PaCO_2_ ≥ 50 mm Hg, with pH ≤ 7.35; or (3) PA-aO_2_ 10 mm Hg or more above baseline stable | Co-interventions: Aminophylline IV; nebulized isoproterenol every 4 hrs; ampicillin IV or tetracycline PO every 6 hrs; oxygen by nasal prongs | Adverse events/complications: Steroid grp (3 pts): death due to cardiorespiratory arrest at 30 hrs (1 pt); psychosis beginning on day 3 (1 pt); upper GI bleed on day 2 (1 pt, who died of progressive respiratory failure 9 days after treatment suspended). Placebo grp (3 pts): Dermatitis (1 pt); pneumonia developing on day 2 (1 pt); upper GI bleed (1 pt).
| External validity:^1^ 4/5 | Exclusion: Personal or family history of asthma; increase in baseline stable FEV_1_ of 30% or more after inhaled bronchodilator; history of eczema or allergic rhinitis; lobar or segmental consolidation on chest x-ray; treatment with steroids in preceding 30 days | Outcomes: Spirometry performed before and 15 min after bronchodilation, 3x/day | Dropouts: Steroid grp, 2/22 pts (9.1%); placebo grp, 2/22 pts (9.1%).
| COPD dx+ | Smoking history: 80 pack-yrs | FEV_1_: (a) Mean % change in pre- and postbronchodilator FEV_1_ from baseline (admission) to 12, 18, 24, 30, 36, 42, 48, 54, 60, 66, and 72 hrs
| COPD bl- | Baseline stable FEV_1_: N/S | (b) Number of pts with ≥ 40% improvement in prebronchodilator FEV_1_ by 72 hrs
| AECB dx+ | FEV_1_ at admission: | (c) Number of pts with ≥ 40% improvement in postbronchodilator FEV_1_ by 72 hrs
| AECB sev+ | Prebronchodilator: Steroid grp, 0.60 ± 0.24 L (SD); placebo grp, 0.68 ± 0.27 L (p > 0.1). Postbronchodilator: Steroid grp, 0.67 ± 0.24 L; placebo grp, 0.72 ± 0.31 L (p > 0.5)
| Tx duration+ | Age: 61.5
| Internal validity:^2^ 5/5 | Sex: 44 M, 0 F
| r+, db+, dd | Race: N/S
Bullard, Liaw, Tsai et al., 1996 | Design: SPPG | N =138 | Interventions: | FEV_1_: (a) Mean improvement from 0–6 hrs was statistically significant in the steroid grp (n = 60) (p < 0.05), but not in the placebo grp (n = 53) (p > 0.05). The two grps were not directly compared. | Pts with asthma were explicitly not excluded
| Dates: | Setting: ED | Experimental: Hydrocortisone IV 100 mg, administered w/in 15 min of admission to ED | Steroids: 0.14 (95% CI, 0.07–0.22) | Initial serum theophylline levels significantly higher in the placebo grp (10.4 μg/dL vs. 6.39 μg/dL)
| 3/93-8/93; | Inclusion (COPD): Age > 40 yrs; evidence of chronic airflow obstruction (no further details provided) | Control: Placebo | Placebo: 0.02 (0.08–0.12) | Both grps averaged 2 fenoterol nebulizations over first 6 hrs
| 11/93-2/94 | Inclusion (AcEx): Dyspnea plus FEV_1_ < 60% of predicted value and FEV_1_/FVC ratio < 60% | Co-interventions: Aminophylline IV; nebulized fenoterol and ipratropium initially; nebulized fenoterol repeated hrly, as required; oxygen | (b) No significant difference between the two grps in the number of pts with > 40% improvement in FEV_1_ from 0–6 hrs (p > 0.05): | Data collected after admission to hospital not usable due to violations of treatment protocol
| Location: Taiwan | Exclusion: Associated pneumothorax; radiological or clinical evidence of pneumonia; intubation w/in first 2 hrs; need to be hospitalized for another condition; known or suspected current use of steroids | Outcomes: | Steroids: 17/60 (28%)
| Assessment period: 6 hrs | Smoking history: N/S | FEV_1_: (a) Mean improvement from baseline (admission) to 15 min, 1 hr, and 6 hrs | Placebo: 8/53 (15%)
| External validity: 1/5 | Baseline stable FEV_1_: N/S | (b) Number of pts with > 40% improvement in FEV_1_ from 0–6 hrs | Percentage of pts admitted to hospital: 44/60 receiving steroids (73%) and 42/53 (79%) receiving (not analyzed)
| COPD dx- | FEV_1_ at admission: | Percentage of pts admitted to hospital after 6 hrs | Adverse events: No data reported
| COPD bl- | Steroid grp: 0.52 ± 0.05 L (SEM) (26% of predicted value); placebo grp: 0.55 ± 0.06 L (27% of predicted value) | | Dropouts: 25 (18%) pts, treatment grps N/S; 4 of these 25 pts refused to continue after initial assessment for unspecified reasons; the remaining 21 were excluded, post-randomization, on the basis of the inclusion/exclusion criteria
| AECB dx- | Age: 65.99
| AECB sev+ | Sex: 97 M, 16 F
| Tx duration- | Race: N/S
| Internal validity: 4/5
| r, db+, dd
Davies, Angus, and Calverley, 1999 | Design: SPPG | N =56 | Interventions: All treatment initiated within 3 hrs of presentation to the ED | FEV_1_: (a) By time of discharge, the mean % predicted prebronchodilator FEV_1_ (with 95% CI) had risen from 27.4 (22.5 to 32.3) to 38.4 (32.9 to 43.9) in the steroid-treated grp (n = 28; p < 0.0001), and from 21.4 (16.5 to 26.3) to 31.0 (26.3 to 35.7) in the placebo-treated grp (n = 22; p < 0.0001). | Mean daily increase in postbronchodilator FEV_1_ from admission to day 5 was significantly (p = 0.039) greater in the steroid grp (90 mL) than in the placebo grp (30 mL).
| Dates: N/S | Setting: Pts presented to ED of a university hospital and were admitted for treatment | Experimental: Prednisolone PO 30 mg, once per day for 14 days | (b) Mean % predicted postbronchodilator FEV_1_ scores (with 95% CI) rose from 28.2 (23.5 to 32.9) to 41.5 (35.8 to 47.2) in the steroid-treated grp (n = 28; p < 0.0001), and from 25.7 (21.0 to 30.4) to 32.2 (27.3 to 37.1) in the placebo-treated grp (n = 22; p < 0.0001). | By day 5, pts in the steroid grp had increased postbronchodilator FEV_1_ to 92% of discharge values, compared with 85% in the placebo grp (p < 0.041).
| Location: United Kingdom | Inclusion (COPD): Diagnosis of COPD; age 40–80 yrs; history of cigarette smoking | Control: Placebo | (c) Changes in pre- and postbronchodilator absolute FEV_1_ from admission to time of discharge were significantly greater in the steroid-treated grp than in the placebo-treated grp (precise values could not be read off graph; no p-value reported).
| Assessment period: To time of discharge, with followup visit 6 wks after discharge | ≥ 20 pack-yrs; physiological evidence of airflow limitation with initial FEV_1_ < 70% predicted and FEV_1_/FVC < 75% | Co-interventions: Nebulized albuterol and ipratropium every 6 hrs; controlled oxygen therapy; antibiotics (PO or IV) given at the judgment of admitting physician; pts receiving inhaled corticosteroid therapy before randomization continued this therapy during trial | (d) At the 6-wk followup visit, there was no significant difference between the two grps for % predicted postbronchodilator FEV_1_ (no p-value reported): Steroid grp (n = 27), 39.6 (95% CI, 32.5 to 46.7); placebo grp (n = 20), 33.2 (27.9 to 38.5).
| External validity: 4/5 | Inclusion (AcEx): History of increased breathlessness and at least two of the following for 24 hrs or more: increased cough frequency or severity, increased sputum volume or purulence, increased wheeze | Outcomes: Spirometry performed before and 15 min after bronchodilation, once per day | LOS in hospital: Median LOS was significantly (p = 0.027) shorter among pts treated with steroids (7 days; n = 29) than among pts treated with placebo (9 days; n = 27).
| COPD dx+ | Exclusion: Personal or family history of asthma or atopy; uncontrolled left-ventricular failure; clinical or radiological evidence of pneumonia; use of oral corticosteroids within 1 mo of presentation at ED; arterial blood pH on admission < 7.26 | FEV_1_: (a) Change in mean % predicted pre-bronchodilator FEV_1_ from baseline (admission) to time of discharge | Adverse events: Transient glycosuria (6 pts in steroid grp), heartburn (3 pts in steroid grp, 2 in placebo grp)
| COPD bl- | Smoking history: 55.0 pack-yrs | (b) Change in mean % predicted post-bronchodilator FEV_1_ from baseline (admission) to time of discharge | Dropouts: Before discharge: Steroid grp, 1/29 (3.4%); placebo grp, 5/27 (19%) (reasons for withdrawal N/S, but no deaths). Before 6-wk follow-up: Steroid grp, 1/29 (3.4%) (died); placebo grp, 2/27 (7.4%) (1 died, 1 lost to followup).
| AECB dx+ | Baseline stable FEV_1_: N/S | (c) Change in absolute pre- and postbronchodilator FEV_1_ from baseline (admission) to time of discharge
| AECB sev+ | FEV_1_ at admission: | (d) % predicted postbronchodilator FEV_1_ at 6 wks
| Tx duration+ | Prebronchodilator: Steroid grp (n = 28), 0.66 L ± 0.05 (SEM) = 27.4 ± 2.4 (SEM) % predicted; placebo grp (n = 22), 0.58 L ± 0.07 = 21.4 ± 2.5% predicted. | LOS in hospital: Median LOS (in days)
| Internal validity: 5/5 | Postbronchodilator: Steroid grp, 0.70 L ± 0.01 = 28.2 ± 2.4% predicted; placebo grp, 0.70 L ± 0.07 = 25.7 ± 2.4% predicted
| r+, db+, dd | Age: 67.3
| | Sex: 34 M, 16 F
| | Race: N/S
Emerman, Connors, Lukens et al., 1989b | Design: SPPG | N =100 | Interventions: | FEV_1_: No significant difference between the two grps in % improvement from pre- to posttreatment (p ≥ 0.05): | Subpopulations in which steroids improved FEV_1_ significantly compared with placebo: None identified; investigators examined pts with
| Dates: 10/86-11/87 | Setting: ED | Experimental: Methylprednisolone IV 100 mg, administered w/in 30 min of admission to ED | Steroid grp (n = 52): | (1) eosinophil count > 500 × 10^9^/ L;
| Location: United States | Inclusion (COPD): Age ≥ 50 yrs; clinical history of emphysema or chronic bronchitis (ATS, 1987) | Control: Placebo | Pre-tx: 29% ± 2% (SEM) predicted | (2) > 15% reduction in FEV_1_ after inhaled isoproterenol on baseline testing;
| Assessment period: 4–5 hrs (treatment terminated after 5 hrly nebulizer treatments or earlier, if pt free of wheezing and no longer dyspneic) | Inclusion (AcEx): Acute respiratory distress; FEV_1_< 70% of predicted normal or FEV_1_/FVC < 60% | Co-interventions: Aminophylline IV; nebulized isoetharine every hr for up to 5 treatments; oxygen by nasal cannula | Post-tx: 38% ± 2% predicted | (3) baseline stable postbronchodilator FEV_1_ < 60% normal or < simultaneously obtained FVC
| External validity: 3/5 | Exclusion: History of asthma; onset of episodes of respiratory distress before age 35; oral or IV steroids in previous mo; pneumonia, acute CHF, or other conditions requiring admission to hospital | Outcomes: | Percent improvement: 37 ± 6
| COPD dx+ | Smoking history: 59.2 pack-yrs | FEV_1_: Mean % improvement in FEV_1_ (expressed as a % of predicted normal) from pre- to posttreatment | Placebo grp (n = 44):
| COPD bl+ | Baseline stable FEV_1_: 59.7% predicted normal | Percentage of pts admitted to hospital | Pre-tx: 26% ± 2% predicted
| AECB dx- | FEV_1_ at admission: Steroid grp: 29% ± 2% (SEM) predicted normal; placebo grp: 26% ± 2% predicted normal | LOS in ED: Mean (in hrs) | Post-tx: 35% ± 2% predicted
| AECB sev+ | Age: 64.0 | | Percent improvement: 43 ± 10
| Tx duration- | Sex: 50 M, 46 F | | Percentage of pts admitted to hospital:
| Internal validity: 4/5 | Race: N/S | | No significant difference between the two grps (p ≥ 0.05):
| r, db+, dd | | | Steroid grp, 17/52 (33%)
| | | | Placebo grp, 13/44 (30%)
| | | | LOS in ED: No significant difference between the two grps (p ≥ 0.05):
| | | | Steroid: 4.5 ± 0.1 (SEM) hrs (range, 3–7)
| | | | Placebo: 4.4 ± 0.1 hrs (range, 2.5–6)
| | | | Adverse events: No data reported
| | | | Dropouts: 4 pts “lost to followup”; their initial treatment grp N/S
| Design: SPPG | N =271 | Interventions: | For all outcomes described below, results for the grps receiving short and long courses of glucocorticoids were equivalent; as a consequence, investigators combined these two grps into a single active treatment grp for comparison with placebo. | Trial methods also described in Erbland, Deupree, and Niewoehner, 1998
| Dates: 11/94-10/96 | Setting: 25 VA medical centers; hospitalized pts | Experimental: Placebo | Treatment failure: We considered primarily 30-day results. At 30 days, glucocorticoids significantly reduced the rate of first treatment failure (37/160 [23%] vs. 37/111 [33%], p = 0.04). Rates for specific causes of treatment failure were as follows:
| Location: United States | Inclusion (COPD): Primary diagnosis of COPD exacerbation by primary ward physician (based on clinical records, history, and physical exam); age ≥ 50 yrs; smoking history ≥ 30 pack-yrs | Control 1: Methylprednisolone IV 125 mg every 6 hrs for 72 hrs, followed by 8 wks of prednisone PO in a tapering schedule (long course) | Intensification of therapy:
| Assessment period: 72 hrs initially, with 6-mo followup | Inclusion (AcEx): Primary diagnosis of COPD exacerbation by primary ward physician (based on clinical records, history, and physical exam); FEV_1_≤ 1.5 L or inability to perform spirometry due to dyspnea | Control 2: Methylprednisolone IV 125 mg every 6 hrs for 72 hrs, followed by 12 days of prednisone PO in a tapering schedule (short course) | Placebo: 26/111 (23%)
| External validity: 2/5 | Exclusion: Primary diagnosis of asthma exacerbation by primary ward physician; use of systemic corticosteroids in previous 30 days; coexisting pneumonia, pulmonary edema, lung cancer, or unstable atherosclerotic heart disease; any other medical condition making survival for 1 yr unlikely; unwillingness to forgo theophylline for duration of study; past enrollment in this study or current enrollment in any other VA cooperative trial; current enrollment in any non-VA clinical trial involving pulmonary therapy; incompetence to give informed consent | Co-interventions: Standardized for entire 6 mos of trial: | Short course: 13/80 (16%)
| COPD dx- | Smoking history: 75.3 pack-yrs | (a) Inhaled β-agonist with an intermediate duration of action, at least 4x/day (or the equivalent) | Long course: 13/80 (16%)
| COPD bl- | Baseline stable FEV_1_: N/S | (b) Inhaled ipratropium, at least two puffs 4x/day from an MDI or 4 treatments per day from a compressor nebulizer | Readmission for COPD:
| AECB dx- | FEV_1_ at admission: Overall, 0.77 L; placebo (n = 101), 0.75 ± 0.27 (SD) L; short course (n = 73), 0.77 ± 0.29 L; long course (n = 72), 0.79 ± 0.29 L | (c) Inhaled corticosteroid, 8 puffs/day of beclomethasone or triamcinolone, or 4 puffs/day of flunisolide, to begin after 3 days of hospitalization | Placebo: 5/111 (4.5%)
| AECB sev+ | Age: 67.7 | (d) Antibiotic: Any agent suitable for treatment of acute bronchitis, for at least 7 days starting on the day of admission. Additional courses prescribed as needed. | Short course: 4/80 (5.0%)
| Tx duration+ | Sex: 268 M, 3 F | (e) Prohibited medications: theophylline, high-dose inhaled corticosteroids (> doses described above), open-label systemic corticosteroids | Long course: 2/80 (2.5%)
| Internal validity: 4/5 | Race: 83% white | Outcomes: | Intubation:
| r, db+, dd | | Treatment failure (primary outcome): Defined as any one of the following: | Placebo: 3/111 (2.7%)
| | | • Death from any cause | Short course: 2/80 (2.5%)
| | | • Intubation & MV | Long course: 1/80 (1.3%)
| | | • Hospital readmission for COPD | Death:
| | | • Physician-directed intensification of drug treatment to include prohibited meds described above | Placebo: 3/111 (2.7%)
| | | Investigators analyzed rates of first treatment failure at 30, 90, and 182 days | Short course: 0/80 (0%)
| | | LOS in hospital during initial admission and after initial admission | Long course: 2/80 (2.5%)
| | | FEV_1_: Measured at entry; on days 1, 2, and 3; and at followup visits during wks 2, 8, and 26 | Treatment failure rates were still significantly lower with glucocorticoids at 90 days (37% vs. 48%; p = 0.04), but not at 182 days (51% vs. 54%; p = 0.58).
| | | Mortality: Deaths from all causes measured over entire 6-mo followup period | Length of hospitalization: The average initial hospitalization stay was significantly longer in the placebo grp than in the glucocorticoid grps (9.7 vs. 8.5 days; p = 0.03). There was no significant difference between placebo and active grps in the average number of days spent in the hospital due to COPD after the initial hospitalization (2.0 vs. 1.9 days; p = 0.98).
| | | | FEV_1_: Mean posttreatment FEV_1_ scores were reported only graphically and could not be read off the graph. There was no significant difference between the active and placebo grps in initial FEV_1_ scores (no p-value reported). FEV_1_ scores were significantly better in pts treated with glucocorticoids on days 1, 2, and 3 (p < 0.05, all timepoints); there were no significant differences between active and placebo grps at 2, 8, or 26 wks (p ≥ 0.05, all timepoints).
| | | | Mortality: 11/111 pts receiving placebo (10%) and 13/160 pts receiving glucocortisoids (8.1%) died during the trial (p = 0.61). 13 deaths were attributed by investigators to COPD, 7 in the placebo grp, and 6 in the glucocorticoid grps.
| | | | Complications/adverse events: Pts were tested for complications and questioned about possible adverse events at every visit. The percentage of pts with hyperglycemia was significantly higher in the combined glucocorticoid grps (15%) than in the placebo grp (4%) (p = 0.002). There were no significant differences between the active and placebo grps for secondary infection (19% vs. 17%), hypertension (6% vs. 4%), psychiatric disorder (4% vs. 3%), or GI bleeding (2% vs. 5%). Significantly more pts in the active treatment grps reported “other” adverse events (24% vs. 14%; p = 0.04).
| | | | Dropouts: 10/111 placebo pts (9%), 10/80 short-course pts (13%), and 5/80 long-course pts (6.3%) discontinued study drugs for reasons other than those listed under “treatment failure”; complete followup data were available for 19 of these 25 pts.
Thompson, Nielson, Carvalho, et al., 1996 | Design: SPPG | N =27 (enrolled in study and had acute exacerbation during study period) | Interventions: | FEV_1_: (a) The mean slope of the FEV_1_ response was significantly better (p = 0.006) in the prednisone grp (n = 13) than in the placebo grp (n = 14): | Significantly more pts in the placebo grp were using inhaled triamcinolone (7 vs. 1, p = 0.03)
| Dates: 5/91-4/92 | Setting: Outpatients recruited from VA hospital by two methods: (a) screen of all pulmonary function test reports (n = 11 pts); (b) referral by attending physician in ED (n = 16 pts) | Experimental: Prednisone PO, 9-day tapering course: 60 mg, 40 mg, 20 mg for 3 days each | Steroid: (0.05 L/day [95% CI, 0.02 to 0.09]) | Predictors of significantly better FEV_1_ slope with prednisone: None identified. Investigators considered: day 1 eosinophil count and WBC; baseline IgE level, FEV_1_, bronchodilator response, and albumin level; and smoking history
| Location: United States | Inclusion (COPD): (1) History of cigarette smoking ≥ 20 pack-yr; and (2) chronic airflow obstruction (baseline stable FEV_1_ at 15 min after metaproterenol of ≤ 60% of predicted value or FEV_1_/FVC < 65%); and (3) clinical diagnosis of chronic bronchitis or emphysema as defined by ATS (1987) | Control: Placebo (vitamin B6) | Placebo: (0.00 L/day [-0.01 to 0.02])
| Assessment period: 9-day course of treatment; most outcomes measured pre-treatment (day 1) and at 3 and 10 days; treatment failure measured through 14 days | Inclusion (AcEx): (1) Subjective worsening of chronic baseline dyspnea or cough for > 24 hrs, necessitating a hospital visit; and (2) ≥ 25% increase in inhaled β-adrenoceptor agonist use for > 24 hrs or increase in sputum production of > ¼ c/day over baseline and/or purulence (> 25 neutrophils per low-power field) | Co-interventions: Pts instructed to increase β-adrenoceptor agonist dose to 4 puffs of MDI every 4 hrs or single nebulized dose every 4 hrs; ipratropium, inhaled corticosteroids, and theophylline continued unaltered if usually used; pts with clinical evidence of infective bronchitis (sputum with > 25 neutrophils and < 10 squamous epithelial cells per low-power field and a predominant organism on Gram's stain) received antibiotic therapy | (b) % change in FEV_1_ from day 1 to 3: Prednisone (n = 13) not quite significantly better than placebo (n = 14) (17.7% vs. -1.6%, p = 0.05) (no variance data reported)
| External validity: 5/5 | Exclusion: Family or personal history of asthma; history of atopy, allergic rhinitis, nasal polyposis, or pulmonary disease other than COPD; positive skin test for one or more common allergens; use of systemic corticosteroids in previous mo; CHF; pneumonia; fever ≥ 38.5° C; acidemia; hospital admission for any reason; inability to return for followup | Outcomes: | (c) % change in FEV_1_ from day 1 to 10: Prednisone (n = 13) significantly better than placebo (n = 13 [stet]) (36.9% vs. 1.0%, p = 0.01) (no variance data reported)
| COPD dx+ | Smoking history: 65.2 pack-yrs | FEV_1_: (a) Mean slope of the best-fit line through FEV_1_ values for days 1, 3, and 10 | Percentage of pts admitted to hospital: 2/14 pts taking placebo (14%) required hospital admission within 14 days of starting study med vs. 0/13 pts taking prednisone (not analyzed)
| COPD bl+ | Baseline stable FEV_1_: 1.30 ± 0.58 (SD) | (b) % change from day 1 to day 3 | LOS in ED or hospital: Not reported
| AECB dx+ | FEV_1_ at admission: Steroid grp: 1.04 ± 0.36 (SD); placebo grp: 0.90 ± 0.26 (p > 0.05) | (c) % change from day 1 to day 10 | Adverse events: No data reported
| AECB sev+ | Age: 67.8 | Percentage of pts admitted to hospital | Dropouts: 0
| Tx duration+ | Sex: 26 M, 1 F
| Internal validity: 3/5 | Race: N/S
| r+, db-, dd

1 External validity score (5 points possible): COPD dx = COPD diagnosis based on spirometry (+ = yes = 1; - = no = 0); COPD bl = baseline stable ventilatory status of population described (+ = yes = 1; - = no = 0); AECB dx = diagnosis of AECB includes at least two of following: increased sputum purulence, increased sputum volume, increased dyspnea (+ = yes = 1; - = no = 0); AECB sev = severity of AECB at enrollment described based on at least two of following: mental status change, work of breathing, ventilatory status (+ = yes = 1; - = no = 0); Tx duration = outcomes assessed at 24 hours or later (+ = yes = 1; - = no = 0).

2 Internal validity score (5 points possible): Randomization: r = study described as randomized, method of randomization not described (1 point); r+ = method of randomization described and adequate (2 points); r- = method of randomization described but inadequate (0 points). Double-blinding: ndb = not double-blind (0 points); db = study described as double-blind, method of blinding not described (1 point); db+ = method of blinding described and adequate (2 points); db-= method of blinding described but inadequate (0 points). Dropouts: dd = dropouts described (1 point); dnd = dropouts not described (0 points).

Evidence Table 6. Mucolytics

Study | Design and Quality | Patient Population | Study Protocol | Results | Notes
Aylward, 1973 | Design: SPPG | N = 30 | Interventions: | FEV_1_: No significant difference between grps for improvements in mean FEV_1_ (% predicted) scores from pre- to posttreatment (p-value not reported). Pre- and posttreatment means (± SEM): S-carboxymethylcysteine grp (n = 15), 34.7 ± 5.2% predicted and 41.8 ± 3.8% predicted; bromhexine grp (n = 13), 32.0 ± 3.6% predicted and 37.3 ± 3.2% predicted (no within-grp results provided) | 14/20 men (70%) previous coal miners with minimal radiological pneumo-coniosis
| Dates: N/S | Setting: Outpatients | Experimental: S-carboxymethylcysteine administered as a 5% w/v syrup PO, 750 mg, 3x/day for 10 days | Subjective symptom scores: Both treatments significantly improved ease of expectoration from pre- to posttreatment (Day 10), expressed as “mean percentage of baseline score”: S-carboxymethylcysteine grp, 45% (p < 0.05); bromhexine grp, 56% (p < 0.05). No significant difference between grps (no p-value given)
| Location: Wales | Inclusion (COPD): “Chronic bronchitis” | Control: Bromhexine administered as a syrup (4 mg/5 mL) PO, 16 mg, 3x/day for 10 days | Adverse events: S-carboxymethylcysteine grp, (1 pt): transient epigastric discomfort; bromhexine grp (1 pt): severe nausea and vomiting
| Assessment period: 10 days | (see “Notes”) | Co-interventions: Bronchodilator therapy (not described) continued at constant dosage for 10 days; cough suppressants and expectorants discontinued for 4 days prior to and during trial | Dropouts: S-carboxymethylcysteine grp, 0/15; bromhexine grp, 2/13 pts (15%)
| External validity: ^1^ 3/5 | Inclusion (AcEx): “Acute exacerbation” and also “expectorating macroscopically mucoid sputum” | Outcomes: Spirometry performed at beginning and end of trial
| COPD dx- | Exclusion: History of peptic ulceration; intestinal or colonic disease; severe renal, hepatic, or myocardial disease | FEV_1_ (% predicted): Difference in mean FEV_1_ (% predicted) scores from baseline (admission) to 10 days
| COPD bl-AECB dx+ | Smoking history: 5/20 men non-smokers for ≥ 4 yrs; 15/20 men, 10 women current smokers; all pts previous heavy smokers | Subjective symptom scores: Mean % improvement from baseline to 5 and 10 days in “ease of expectoration”
| AECB sev+ | Baseline stable FEV_1_: N/S
| Tx duration+ | FEV_1_ (% predicted) at admission: S-carboxymethylcysteine grp, 34.7 ± 5.2 (± SEM); bromhexine (control) grp, 32.0 ± 3.6 (no significant between-grp differences, p-value not reported)
| Internal validity:^2^ 4/5 | Age: 56.2 (range: 39–72)
| r, db+, dd | Sex: 20 M, 10 F
| | Race: N/S
Finiguerra, Conti, Figura, et al., 1982 | Design: SPPG | N = 40 | Interventions: | FEV_1_: Results provided only as p-values. Both grps improved from pre- to posttreatment (p < 0.01, both cases). No significant difference between grps at post-treatment (p-value not provided) | Low quality score (1)
| Dates: N/S | Setting: Inpatients | Experimental: Domiodol 180 mg/day PO; “given together” with amoxicillin (not clear if 1 pill or 2) and taken “at regular intervals” | Subjective symptom scores: (See “Notes” column at right.) Both grps reduced “difficulty in expectoration” scores significantly from pre- to posttreatment (Day 1 to Day 10). Av. pre- to posttreatment scores: domiodol grp (n = 10), 2.25 to 0.4 (p < 0.01) (t-value = 13.71); no-domiodol grp (n = 10), 2.05 to 0.95 (p < 0.01) (t-value = 7.329). Domiodol grp significantly better at reducing this outcome than no-domiodol grp (p < 0.01) (t-value= 3.602) | Unspecified no. of pts had chronic asthmatic bronchitis
| Location: Italy | Inclusion (COPD): Chronic bronchitis (diagnostic criteria N/S) | Control: No domiodol | Adverse events: None observed in either grp | For “subjective symptom score,” not clear if value for day 1 (pretreatment score) is from baseline or treatment period
| Assessment period: 3-day baseline (washout) period, followed by 10-day treatment period | Inclusion (AcEx): Acute infectious-phase chronic bronchitis (sometimes with bronchospasms), ascertained by clinical-anamnestic and radiological criteria; pts with “best ability to collaborate” | Co-interventions: Amoxicillin 1,500 mg/day PO; digitalis, diuretic therapy, and theophylline for bronchial spasms permitted; steroids excluded | Dropouts: N/S
| External validity: 1/5 | Exclusion: As many pts as possible with chronic asthmatic bronchitis | Outcomes: Spirometry performed before (on 3rd day of baseline period) and after treatment (on 10th day of treatment period)
| COPD dx- | Smoking history: N/S | FEV_1_: Change in FEV_1_ from pre- to post-treatment
| COPD bl- | Baseline stable FEV_1_: N/S | Subjective symptom scores: Reduction from pre- to posttreatment in scores for “every day difficulty of expectoration,” recorded daily by pt using 4-point rating scale (0 = absence of symptom, 3 = maximal intensity)
| AECB dx- | FEV_1_ at admission: N/S
| AECB sev- | Age: 53.3 (range: 32–78)
| Tx duration+ | Sex: 27 M, 13 F
| Internal validity: 1/5 | Race: N/S
| r, ndb, dnd
Fumagalli, Balzarotti, Banfi, et al., 1988 | Design: SPPG | N = 30 | Interventions: | FEV_1_: Mean FEV_1_ scores (± SE) improved from baseline to posttreatment in both grps, but improvement was significant only in the erdostein grp. For erdostein (n = 14), scores improved 17%, from 1.20 ± 0.15 to 1.41 ± 0.15 L (p < 0.05). For ambroxol (n = 15), the improvement was 11%, from 1.35 ± 0.22 to 1.50 ± 0.22 L (n.s.; p-value not reported). There were no significant differences between the two grps for this outcome (p-value not reported). | 6/30 pts (20%) had asthmatic exacerbation of bronchitis; 1/30 pts (3.3%) had “recidivant broncho-pneumo-pathy”; stratified results not reported
| Dates: N/S | Setting: Hospitalized pts | Experimental: Erdostein 300 mg PO, 2x/day | Subjective symptom scores: Erdostein reduced the mean score for sputum adhesivity significantly from baseline to posttreatment. The score improved 88.5% in this grp, from 1.9 ± 0.3 to 0.2 ± 0.2 L (p < 0.01). Ambroxol also reduced the mean score significantly over the same period, with the score improving 60.0%, from 2.0 ± 0.2 to 0.8 ± 0.3 L (p < 0.01). There were no significant differences between the two grps for this outcome (p-value not reported). | Sputum adhesivity diminished rapidly, with both grps showing significant improvements by day 3
| Location: Italy | Inclusion (COPD): Chronic bronchitis with cough, purulent excreatum, and difficulty in expectoration (determined by “clinical signs and symptoms”) | Control: Ambroxol 30 mg PO, 2x/day | Adverse events: No AEs reported by pts, and no pts withdrawn because of AEs. Blood tests indicated good tolerability of both drugs, though “some” pts (unspecified no.) on ambroxol had significant increases in SGPT (values slightly exceeding normal limits; significance level not reported) and in triglycerides (values still within normal range)
| Assessment period: 7 days | Inclusion (AcEx): “Acute” or “exacerbated” symptoms in addition to above diagnosis | Co-interventions: Antibiotics permitted during trial (all pts took them); other drugs such as theophyllinic or antihypertensive agents taken by pts before the trial also permitted during trial; mucolytics excluded | Dropouts: Erdosteine grp, 1/15 pts (6.7%); ambroxol grp, 0/15 pts
| External validity: 2/5 | Exclusion: Radiologically confirmed signs of pleural or parenchymal involvement; treatment with antibiotics or mucolytics in 7 days before start of trial; history of smoking in 3 mos before start of trial; ascertained or presumed pregnancy; history of hypersensitivity to either drug | Outcomes:
| COPD dx- | Smoking history: No history of smoking in 3 mos before start of trial; history prior to that not specified | FEV_1_: Change in mean FEV_1_ score from baseline (day 1) to days 3 and 7
| COPD bl- | Baseline stable FEV_1_: N/S | Subjective symptom scores: Change in mean score from baseline to days 3 and 7 for decrease in “sputum adhesivity” (as measure of expectoration ease); sputum adhesity recorded on days 1, 3, and 7 by pt using rating scale from 0–3, where 0 = “no difficulty in expectoration” and 3 = “always difficult expectoration”
| AECB dx- | FEV_1_ at admission: Erdostein grp, 1.20 ± 0.15 (SE) L; ambroxol grp, 1.35 ± 0.22 L (no significant difference between grps; p-value not reported)
| AECB sev+ | Age: 64 (range, 22–79)
| Tx duration+ | Sex: 16 M, 14 F
| Internal validity: 3/5 | Race: N/S
| r, db, dd
Langlands, 1970 | Design: SPPG | N = 31 | Interventions: | FEV_1_: Both grps improved mean FEV_1_ score (L) from pre- to posttreatment, though statistical significance of improvements not reported and neither grp significantly better than other (no variance data or p-values given). Mean pre- and posttreatment FEV_1_ scores: Bromhexine grp (n = 11), 0.65 and 0.66; placebo grp (n = 14), 0.74 and 0.87 | Efficacy data for FEV_1_ not available for 2 pts (in addition to the 3 dropouts) on bromhexine
| Dates: N/S | Setting: Inpatients | Experimental: Bromhexine 8 mg PO, 3x/day | Subjective symptom scores: For pre- to postimprovement in ease of expectoration (where “improvement” was not defined), 9/11 pts (82%) and 4/14 pts (29%) improved in bromhexine and placebo grps, respectively. Investigators did not report whether either treatment was significantly better (no p-values given)
| Location: Ireland | Inclusion (COPD): Chronic bronchitis, with mucoid sputum | Control: Placebo | Adverse events/complications: Bromhexine grp (2 pts): nausea, after which treatment was discontinued, followed by death 3 days later due to respiratory and cardiac failure (1 pt); severe, wheezy bronchitis, followed by sudden death on Day 8 (1 pt). Placebo grp, no AEs reported
| Assessment period: 14 days | Inclusion (AcEx): “Exacerbations of chronic bronchitis,” as defined by Medical Research Council (1965) | Co-interventions: Usual treatment, except for cough suppressants and expectorants | Dropouts: Bromhexine grp, 3/16 pts (19%) (2 due to death); placebo grp, 1/15 pts (6.7%)
| External validity: 2/5 | Exclusion: N/S | Outcomes: Spirometry performed once before trial, 2x/wk (for 2 wks) during trial, and on 2nd day after trial ended
| COPD dx- | Smoking history: N/S | FEV_1_: Mean change in FEV_1_ from pre-treatment to wk 1 (2 measurements), wk 2 (2 measurements), and posttreatment (with mean of last 3/5 measurements being recorded on each occasion)
| COPD bl- | Baseline stable FEV_1_: N/S | Subjective symptom scores: Defined as “improvement in ease of expectoration,” measured by asking pts at end of trial if they thought expectoration had improved (cutoff threshold for “improvement” not defined)
| AECB dx- | FEV_1_ at admission: Bromhexine grp, 0.65 L; placebo grp, 0.74 L (no variances or p-values reported)
| AECB sev+ | Age: N/S
| Tx duration+ | Sex: 22 M, 5 F
| Internal validity: 5/5 | Race: N/S
| r+, db+, dd
Peralta, Poderoso, Corazza, et al., 1987 | Design: SPPG | N = 24 | Interventions: | FEV_1_: No changes observed between grps in FEV_1_ scores (no means, variances, or p-values reported for within- or between-grp results) | Not explicitly stated whether “difficulty in expectoration” determined by physician or pt
| Dates: N/S | Setting: N/S | Experimental: Ambroxol 30 mg + amoxicillin 500 mg PO, 1 capsule every 8 hrs for 24 hrs (3x/day) | Subjective symptom scores: Ambroxol grp (n = 10) reduced expectoration difficulty from pre- to posttreatment (day 10) significantly better (and faster) than did amoxicillin-alone grp (n = 13) (p < 0.01). Pre- and post-treatment mean scores: Ambroxol grp, 2.80 and 0.20; amoxicillin-alone grp, 2.61 and 0.92 (no variance data given). No within-grp results given
| Location: Argentina | Inclusion (COPD): “Chronic bronchitis,” as determined by “standard clinical criteria” ; 2 pts also had pulmonary TB; 1 also had bronchial asthma | Control: Amoxicillin 500 mg PO, 1 capsule every 8 hrs for 24 hrs (3x/day) | Adverse events: No AEs observed in any pts; not clear whether pts or physicians recorded AEs
| Assessment period: 10 days from administration of study med | Inclusion (AcEx): Defined as “intercurrent infection” which caused “worsening of dyspnea and cough, presence of fever and malaise, and purulent sputum” | Co-interventions: Fenoterol, inhaled; other (unspecified) bronchodilator drugs “concomitantly administered” during treatment | Dropouts: 1 (grp N/S)
| External validity: 2/5 | Exclusion: N/S | Outcomes: Spirometry performed after washout period and before inhalation of 2 puffs of fenoterol
| COPD dx- | Smoking history: N/S | FEV_1_: No information on type of results sought (no. of pts improved, etc.)
| COPD bl- | Baseline stable FEV_1_: N/S | Subjective symptom scores: Reduction of “difficulty in expectoration,” obtained using rating scale from 0–3, where 0 = absence of symptoms and 3 = maximal intensity (scale from Finiguerra, Conti, Figura, et al. [1982])
| AECB dx+ | FEV_1_ at admission: N/S
| AECB sev- | Age: 60.0 (range: 47–82)
| Tx duration+ | Sex: 18 M, 5 F
| Internal validity: 3/5 | Race: N/S
| r, db, dd
Petersen, Esmann, Høncke, et al., 1967 | Design: SPPG | N = 43 | Interventions: | FVC: | Low quality score (1) Before trial started, pts divided into 2 grps based on whether residual volume was < 50% or > 50% of total lung capacity; pts from each subgrp then randomized to treatment grps
| Dates: 10/64-5/65 | Setting: Hospitalized pts | During 10-day study, pts were “kept in bed”; during 28-day study, pts were sometimes ambulatory | (a) Results provided only in graphical form (no p-values reported)
| Location: Denmark | Inclusion (COPD): Chronic bronchitis, defined as “story of cough and expectoration on most days during at least 3 consecutive mos in each of 2 or more successive yrs” | Experimental (1): Potassium iodide PO, 10 mL of 3.3% solution, 3x/day for 10 days | (b) No significant difference between any grps for achieving > 15% improvement in FVC from baseline to 10 or 28 days (no p-values reported)
| Assessment period: 2 study periods: | Inclusion (AcEx): AcEx (not defined) | Experimental (2): Physiotherapy, daily for 28 days; therapy, individualized for each pt based on clinical examination, consisted of “instruction in how to cough properly, diaphragmatic and abdominal breathing exercises, exercises to foster a correlation of the costal and abdominal breathing, and a correction of existing abnormal ‘level’ of respiration, postural abnormalities of local dysfunction of the thoracic cage”; also included were “exercises to train the respiratory muscles and teach the corrected breathing movements”; some pts also received “postural drainage combined with tapottement, squeezing and expansion training” | Baseline FVC data not reported as exact scores or grp means, but as “number of pts with FVC < 70%.” Baseline numbers: physiotherapy grp, 4/10 pts (40%); potassium iodide grp, 5/9 (56%); chloramphenicol grp, 4/9 (44%); placebo grp, 3/10 (30%)
| 10 days, all grps; after 10 days, placebo and physiotherapy grps only continued for additional 18 days (28 days total) | Exclusion: Age < 45 or > 75; severe deformities of spine or chest; localized or generalized specific lung disease; signs of cardiac insufficiency | Experimental (3): Chloramphenicol PO, 0.5 g, 4x/day for 10 days | No. of pts achieving > 15% improvement from baseline to 10 days: Physiotherapy grp, 2/10 pts (20%); potassium iodide grp, 4/9 pts (44%); chloramphenicol grp, 4/9 pts (44%); placebo grp, 3/10 pts (30%) (no p-values reported)
| External validity: of 5 | Smoking history: N/S | Control: Placebo for 10 days; no “sham” physiotherapy | No. of pts achieving > 15% improvement in FVC from baseline to 28 days: Physiotherapy grp, 0/10 pts; placebo grp, 2/8 pts (25%) (no p-values reported)
| COPD dx | Baseline stable FEV_1_: N/S | Co-interventions: None | Subjective symptom scores: “Ease of expectoration” improved in almost all pts (number of pts or amt of improvement not reported)
| COPD bl | FEV_1_ at admission: N/S | Outcomes: Spirometry performed (on supine pts) on days 0, 3, 6, and 10 (and day 28 for 2nd study); then repeated on days 3, 6, and 10 (and on day 28 for 2nd study) | Adverse events: Of pts withdrawn from trial after treatment started, 2 had cardiac insufficiency and 1 had bronchial carcinoma (both from unspecified treatment grps)
| AECB dx | Age: 64 | FVC: | During 28-day study, placebo grp (2 pts): sudden deterioration and death from chronic cor pulmonale after 24 days (1 pt); signs of pyloric stenosis in pt with preexisting duodenal ulcer (1 pt)
| AECB sev | Sex: 27 M, 16 F | (a) Pre- to posttreatment (days 10 and 28) variation of FVC as % of calculated normal values | Dropouts: 10-day study: 5/43 pts (12%), 1 each from potassium iodide and chloramphenicol grps; not clear from which grp(s) the other 3 were withdrawn
| Tx duration | Race: N/S | (b) No. of pts with > 15% change from baseline to 10 (and 28) days | 28-day study: Physiotherapy grp, 0/10; placebo grp, 2/8 (25%)
| Internal validity: 1/5 | | Subjective symptom scores: Termed “ease of expectoration,” and obtained from pt subjectively after treatment terminated
| r-, ndb, dd

1 External validity score (5 points possible): COPD dx = COPD diagnosis based on spirometry (+ = yes = 1; - = no = 0); COPD bl = baseline stable ventilatory status of population described (+ = yes = 1; - = no = 0); AECB dx = diagnosis of AECB includes at least two of following: increased sputum purulence, increased sputum volume, increased dyspnea (+ = yes = 1; - = no = 0); AECB sev = severity of AECB at enrollment described based on at least two of following: mental status change, work of breathing, ventilatory status (+ = yes = 1; - = no = 0); Tx duration = outcomes assessed at 24 hours or later (+ = yes = 1; - = no = 0).

2 Internal validity score (5 points possible): Randomization: r = study described as randomized, method of randomization not described (1 point); r+ = method of randomization described and adequate (2 points); r- = method of randomization described but inadequate (0 points). Double-blinding: ndb = not double-blind (0 points); db = study described as double-blind, method of blinding not described (1 point); db+ = method of blinding described and adequate (2 points); db-= method of blinding described but inadequate (0 points). Dropouts: dd = dropouts described (1 point); dnd = dropouts not described (0 points).

Evidence Table 7. Physical therapy

Study | Design and Quality | Patient Population | Study Protocol | Results | Notes
Newton and Bevans, 1978 | Design: SPPG | N = 96; pts divided into 3 grps: | Interventions: | FEV_1_: No significant difference between physiotherapy + IPPV and control in any of the pt grps. Mean FEV_1_ scores (in liters, ± SD) were as follows:
| Dates: 11/77-5/78 | (1) Men with initial PaO_2_ > 60 mm Hg (Grp 1) (n = 27); | Experimental: Physiotherapy given in “a standard fashion” by “conventional methods,” 3x/day for 10–15 min, depending on pt tolerance; plus adjunctive IPPV, 3x/day for about 15 min, using 4 ml nebulized saline | Grp 1:
| Location: United Kingdom | (2) Men with initial PaO_2_ ≤ 60 mm Hg (Grp 2) (n = 36); | Control: No physiotherapy or IPPV | (1) Physio (n = 13): Admission, 0.8 ± 0.4; discharge, 1.2 ± 0.6; change, 0.4 (no SD)
| Assessment period: From admission to discharge from hospital | (3) Women (Grp 3) (n = 16) | Co-interventions: Tetracycline PO, 4x/day or ampicillin PO, 4x/day (if pt sensitive to tetracycline or had blood urea concentration | (2) Control (n = 14): Admission, 0.8 ± 0.4; discharge, 1.5 ± 0.8; change, 0.7 (no SD) (t = 1.77 physio vs. control)
| External validity: ^1^ 3/5 | Setting: Hospitalized pts | > 8 mmol/L [48 mg/dL]); any appropriate antibiotic for consolidation; albuterol inhalation, every 6 hrs; frusemide, PO then IV, as necessary to achieve diuresis; 24% oxygen by Ventimask (for all pts with hypoxia); pts taking diuretics or steroids on admission continued them | Grp 2:
| COPD dx- | Inclusion (COPD): Age | Outcomes: | (3) Physio (n = 19): Admission, 0.8 ± 0.3; discharge, 1.1 ± 0.5; change, 0.3 (no SD)
| COPD dx- | ≥ 45 yrs; chronic bronchitis (diagnostic criteria N/S) | FEV_1_: Mean change in FEV_1_ from admission to discharge | (4) Control (n = 17): Admission, 0.6 ± 0.3; discharge, 1.0 ± 0.6; change, 0.4 (no SD) (t = 1.2 physio vs. control)
| AECB dx+ | Inclusion (AcEx): Increase in cough, phlegm, or breathlessness for > 24 hrs | LOS: Mean number of days | Grp 3:
| AECB sev+ | Exclusion: Renal, hepatic, or cardiac failure (other than cor pulmonale); malignant disease; tuberculosis; bronchial asthma or bronchiectasis; unstable angina; myocardial infarction within previous mo; anemia with a hemoglobin concentration under 11 g/dL; simple bronchitis with mucus hypersecretion but no airflow obstruction (FEV_1_ < 50% predicted and FEV_1_/FVC <70% predicted); or mental or physical state suggesting inability to cooperate in the trial | | (5) Physio (n = 8): Admission, 0.5 ± 0.3; discharge, 0.8 ± 0.3; change, 0.3 (no SD)
| Tx duration+ | Smoking history: 49.2 yrs | | (6) Control (n = 8): Admission, 0.5 ± 0.3; discharge, 0.7 ± 0.3; change, 0.2 (no SD) (t = 0.37 physio vs. control)
| Internal validity:^2^ 3/5 | Baseline stable FEV_1_: N/S | | LOS in ED or hospital: No significant difference between physiotherapy + IPPV and control in any of the pt grps. Mean LOS (in days, ± SD) were as follows (no p-values reported):
| r+, ndb, dd | FEV_1_ at admission: Grp 1: Physio, 0.8 liters ± 0.4 (SD); control, 0.8 ± 0.4; Grp 2: Physio, 0.8 ± 0.3; control, 0.6 ± 0.3; Grp 3: Physio, 0.5 ± 0.3; control, 0.5 ± 0.3. | | (1) Grp 1: Physio (n = 13), 8.1 ± 3.3; control (n = 14), 7.9 ± 1.8
| | Age: 67.7 | | (2) Grp 2: Physio (n = 19), 9.3 ± 3.2; control (n = 17), 9.1 ± 2.6
| | Sex: 63 M, 16 F | | (3) Grp 3: Physio (n = 8), 11.6 ± 7.6; control (n = 8), 10.4 ± 3.6
| | Race: N/S | | Adverse events: No information provided
| | | | Dropouts: 17/96 pts during the hospital stay (18%): 5 due to misdiagnosis (treatment grp N/S), 7 due to complicating diseases (treatment grp N/S), 1 mechanically ventilated (control grp 3), 4 died (one pt each from physiotherapy grp 2 and 3, and control grp 2 and 3)
Petersen, Esmann, Høncke, et al., 1967 | Design: SPPG | N =43 | Interventions: | FVC: | Low quality score (1)
| Dates: 10/64-5/65 | Setting: Hospitalized pts | During 10-day study, pts were “kept in bed”; during 28-day study, pts were sometimes ambulatory | (a) Results provided only in graphical form (no p-values reported) | Before trial started, pts divided into 2 grps based on whether residual volume was < 50% or > 50% of total lung capacity; pts from each subgrp then randomized to treatment grps
| Location: Denmark | Inclusion (COPD): Chronic bronchitis, defined as “story of cough and expectoration on most days during at least 3 consecutive mos in each of 2 or more successive yrs” | Experimental (1): Physiotherapy, daily for 28 days; therapy, individualized for each pt based on clinical examination, consisted of “instruction in how to cough properly, diaphragmatic and abdominal breathing exercises, exercises to foster a correlation of the costal and abdominal breathing, and a correction of existing abnormal ‘level’ of respiration, postural abnormalities of local dysfunction of the thoracic cage” also included were “exercises to train the respiratory muscles and teach the corrected breathing movements” some pts also received “postural drainage combined with tapottement, squeezing, and expansion training” | (b) No significant difference between any grps for achieving > 15% improvement in FVC from baseline to 10 or 28 days (no p-values reported)
| Assessment period: 2 study periods: 10 days, all grps; after 10 days, placebo and physiotherapy grps only continued for additional 18 days (28 days total) | Inclusion (AcEx): AcEx (not defined) | Experimental (2): Potassium iodide PO, 10 mL of 3.3% solution, 3x/day for 10 days | Baseline FVC data not reported as exact scores or grp means, but as “number of pts with FVC < 70%. ”Baseline numbers: physiotherapy grp, 4/10 pts (40%); potassium iodide grp, 5/9 (56%); chloramphenicol grp, 4/9 (44%); placebo grp, 3/10 (30%)
| External validity: 2 of 5 | Exclusion: Age <45 or > 75; severe deformities of spine or chest; localized or generalized specific lung disease; signs of cardiac insufficiency | Experimental (3): Chloramphenicol PO, 0.5 g, 4x/day for 10 days | No. of pts achieving > 15% improvement from baseline to 10 days: Physiotherapy grp, 2/10 pts (20%); potassium iodide grp, 4/9 pts (44%); chloramphenicol grp, 4/9 pts (44%); placebo grp, 3/10 pts (30%) (no p-values reported)
| COPD dx- | Smoking history: N/S | Control: Placebo for 10 days; no “sham” physiotherapy | No. of pts achieving > 15% improvement in FVC from baseline to 28 days: Physiotherapy grp, 0/10 pts; placebo grp, 2/8 pts (25%) (no p-values reported)
| COPD bl- | Baseline stable FEV_1_: N/S | Co-interventions: None | Subjective symptom scores: “Ease of expectoration” improved in almost all pts (number of pts or amt of improvement not reported)
| AECB dx- | FEV_1_ at admission: N/S | Outcomes: Spirometry performed (on supine pts) on days 0, 3, 6, and 10 (and day 28 for 2nd study); then repeated on days 3, 6, and 10 (and on day 28 for 2nd study) | Adverse events: Of pts withdrawn from trial after treatment started, 2 had cardiac insufficiency and 1 had bronchial carcinoma (both from unspecified treatment grps)
| AECB sev+ | Age: 64 | FVC: | During 28-day study, placebo grp (2 pts): sudden deterioration and death from chronic cor pulmonale after 24 days (1 pt); signs of pyloric stenosis in pt with pre-existing duodenal ulcer (1 pt)
| Tx duration+ | Sex: 27 M, 16 F | (a) Pre- to posttreatment (days 10 and 28) variation of FVC as % of calculated normal values | Dropouts: 10-day study: 5/43 pts (12%), 1 each from potassium iodide and chloramphenicol grps; not clear from which grp(s) the other 3 were withdrawn 28-day study: Physiotherapy grp, 0/10; placebo grp, 2/8 (25%)
| Internal validity: 1/5 | Race: N/S | (b) No. of pts with > 15% change from baseline to 10 (and 28) days
| r-, bdb, dd | | Subjective symptom scores: Termed “ease of expectoration,” and obtained from pt subjectively after treatment terminated
Wollmer, Ursing, Midgren, et al., 1985 | Design: Crossover | N =10 | Interventions: | FEV_1_: Chest percussion therapy (n = 10) resulted in a significant reduction in FEV_1_ value from pre- to posttreatment (p < 0.01), but therapy without chest percussion (in the same pts in this crossover trial) did not (no p-value reported). Pretreatment FEV_1_ (% predicted) (mean ± SD), all pts: 42 ± 16% of predicted value. Posttreatment % change from baseline FEV_1_: chest percussion, -7.3 ± 6.5% (p < 0.01); no chest percussion, -0.5 ± 8.0% (no p-value reported) | Low quality score (1)
| Dates: N/S | Setting: Inpatients | Experimental: Manual chest percussion, administered during postural drainage period, 2x/day for 1 day | There was a small, but not significant, period effect. Between-grp results not reported
| Location: Sweden | Inclusion (COPD): Long history of chronic bronchitis | Control: No manual chest percussion | Adverse events: No AE data provided
| Assessment period: Before study initiated, pts treated “a few days” for acute exacerbation; pts randomized to receive chest percussion on 1 of 2 consecutive days | Inclusion (AcEx): Pts recovering from AcEx | Co-interventions: Postural drainage for 5 min in each of 3 positions (supine, right and left decubitus); “instructed coughing,” consisting of taking 4 deep breaths, then coughing by “huffing” (a sequence of rapid exhalations with open glottis) until no further sputum expectorated; bronchodilator drugs; beta-agonists; terbutaline inhaled before each study; some pts took steroids | Dropouts: Not described
| External validity:2/5 | Exclusion: N/S | Outcomes:Spirometry performed 15 min after inhalation of terbutaline and at end of each study
| | Smoking history: N/S | FEV_1_: Mean % change in posttreatment FEV_1_ score from baseline value
| COPD dx- | Baseline stable FEV_1_: N/S
| COPD bl- | FEV_1_ (% predicted) at admission:
| AECB dx- | 42 ± 16% of predicted value
| AECB sev+ | Age: 71.6
| Tx duration+ | Sex: 6 M, 4 F
| Internal validity: 1/5 | Race: N/S
| r, ndb, dnd

1 External validity score (5 points possible): COPD dx = COPD diagnosis based on spirometry (+ = yes = 1; - = no = 0); COPD bl = baseline stable ventilatory status of population described (+ = yes = 1; - = no = 0); AECB dx = diagnosis of AECB includes at least two of following: increased sputum purulence, increased sputum volume, increased dyspnea (+ = yes = 1; - = no = 0); AECB sev = severity of AECB at enrollment described based on at least two of following: mental status change, work of breathing, ventilatory status (+ = yes = 1; - = no = 0); Tx duration = outcomes assessed at 24 hours or later (+ = yes = 1; - = no = 0).

2 Internal validity score (5 points possible): Randomization: r = study described as randomized, method of randomization not described (1 point); r+ = method of randomization described and adequate (2 points); r- = method of randomization described but inadequate (0 points). Double-blinding: ndb = not double-blind (0 points); db = study described as double-blind, method of blinding not described (1 point); db+ = method of blinding described and adequate (2 points); db-= method of blinding described but inadequate (0 points). Dropouts: dd = dropouts described (1 point); dnd = dropouts not described (0 points).

Evidence Table 8. Noninvasive Positive Pressure Ventilation

Study | Design and Quality | Patient Population | Study Protocol | Results | Notes
Angus, Ahmed, Fenwick, et al., 1996 | Design: SPPG | N = 17 (completed trial) | Interventions: | Blood gases/oximetry: | Not clear how many pts randomized to treatment and how many dropped out
| Dates: N/S | Setting: Pts admitted to respiratory ward of hospital | Note: After 4 hrs of study treatment, pts in either group who were deteriorating were given the alternate treatment | (a) Mean change in PaO_2_ in NIPPV grp (n = 9) significantly better at 4 hrs than in doxapram grp (n = 8) (p < 0.05). From pre- to posttreatment, mean values for PaO_2_ in NIPPV grp improved significantly from 44 (3) mm Hg (SE) to 61 (4) mm Hg (p < 0.05); for doxapram grp, these values also improved significantly from a pretreatment mean of 42 (3) mm Hg, but this significance was not maintained at 4 hrs (4-hr means reported only in graphical form)
| Location: United Kingdom | Inclusion (COPD): COPD (diagnostic criteria N/S) | Experimental: NIPPV; administered by pressure-cycled machine, with ventilation pressure set at 14–18 cm H2O; oxygen-enriched (1–3 L/min) air administered using nasal pillows or a tight-fitting nasal mask for 4 hrs | (b) Between-grp comparisons for mean change in PaCO_2_ at 4 hrs not reported. Mean values for NIPPV grp reduced significantly from pre- to posttreatment from 76 (3) mm Hg to 65 (4) mm Hg (p < 0.05); for doxapram grp, pre-treatment mean of 76 (6) mm Hg did not improve during treatment (means reported only in graphical form)
| Assessment period: Pts not improving with conventional treatment were randomized to receive NIPPV or doxapram within 1 hr of admission to hospital; blood gases assessed for 4 hrs, mortality for 24 hrs | Inclusion (AcEx): Pts with AcExs and type 2 respiratory failure, defined as “PaO_2_ < 60 mm Hg and PaCO_2_ > 50 mm Hg” whose arterial blood gas values were “static or deteriorating” after 1 hr of conventional treatment | Control: Doxapram IV for 4 hrs, using following protocol: 4 mg/min for 15 min, 3 mg/min for 30 min, 2 mg/min for 60 min, and 1.5 mg/min as maintenance dose | Percentage of pts who died: 3/8 pts in doxapram grp (38%) died after 4 hrs but within first 24 hrs; consequently, protocol was adjusted so that pts in either grp who were worsening would receive the alternate treatment; none of the 9 NIPPV pts died
| External validity: ^1^ 3/5 | Exclusion: N/S | Co-interventions: Oxygen by nasal cannulae; steroids; antibiotics; and nebulized or IV bronchodilators | Adverse events: NIPPV “tolerated” in all pts, but “doxapram was added in 1 because of drowsiness at 4 hrs”; no AE results reported for doxapram grp
| COPD dx- | Smoking history: N/S | Outcomes: | Dropouts: N/S
| COPD bl+ | Baseline stable FEV_1_: NIPPV grp, 0.76 ± 0.02 (SEM) L; doxapram grp, 0.77 ± 0.09 L; not clear if FEV_1_ scores are for disease condition at admission or when stable | Blood gases/oximetry: Before pts randomized to treatment, ABG tensions measured on admission and after 1 hr of conventional treatment; then measured every hr for 3 hrs; analyzed: (a) mean change in PaO_2_ from baseline to 4 hrs; (b) mean change in PaCO_2_ from baseline to 4 hrs
| AECB dx- | FEV_1_ at admission: See “baseline stable FEV_1_” | Percentage of pts who died
| AECB sev+ | Age: 63.0
| Tx duration+ | Sex: 9 M, 8 F
| Internal validity:^2^ | Race: N/S
| 1/5; r, ndb, dnd
Barbé, Togores, Rubí, et al., 1996 | Design: SPPG | N = 24 | Interventions: | Peak flow rate: Within-grp improvement from baseline (24 hrs) was significant only at time of discharge (p < 0.05, both grps). There were no significant differences between the two grps at any time point (p ≥ 0,05). Mean peak flow rates (L/min) (± SEM) were: | Different baseline time points/data used for peak flow (24 hrs) and blood gas (ED) outcomes.
| Dates: N/S | Setting: Pts presented to ED, were admitted to hospital, and were then (within 12–48 hrs) transferred to a respiratory ward outside the intensive care setting | Experimental: NIVS with BiPAP® applied through a nasal mask; BiPAP® administered in two daytime sessions of 3 hrs each for the first 3 days of hospitalization in respiratory ward | (a) BiPAP® grp (n = 10): Baseline (24 hrs), 176 ± 22; 80 hrs, 166 ± 27; discharge, 247 ± 35. | BiPAP® given during daytime hrs only
| Location: Spain | Inclusion (COPD): COPD (diagnostic criteria N/S) | Control: No NIVS | (b) Control grp (n = 10): Baseline, 146 ± 22; 80 hrs, 178 ± 25; discharge, 203 ± 18.
| Assessment period: 80 hrs; many outcomes also measured at discharge | Inclusion (AcEx): Severe respiratory failure with respiratory acidosis (diagnostic criteria N/S) | Co-interventions: Standard treatment = aerosolized albuterol, 4x/day (tapered individually after first 3 days); prednisolone IV, 3x/day (tapered individually after first 3 days); oxygen by Venturi mask | Blood gases:
| External validity: 3/5 | Exclusion: Clinical or radiological evidence of bacterial pneumonia, pleural effusion, left ventricular failure, or nasal deformities | Outcomes: | (a) PaO_2_: Improved significantly in both grps from baseline (ED) to 72 hrs, 80 hrs, and time of discharge (p < 0.001 for all comparisons vs. baseline). There were no significant differences between the two grps (p ≥ 0.05). (Means reported only graphically.)
| COPD dx- | Smoking history: 68 pack-yrs | NB: 24-hr outcomes represent results from time of admission to respiratory ward, before start of experimental treatment | (b) PaCO_2_: Decreased significantly in both grps from baseline (ED) to time of discharge (p < 0.05 for each comparison). There were no significant differences between the two grps (p ≥ 0.05). (Means reported only graphically.)
| COPD bl+ | Baseline stable FEV_1_: 33% ± 2% (SEM) predicted at discharge | Peak flow rate: Means reported for baseline (24 hrs), 30 hrs, 72 hrs, 80 hrs, and time of discharge. Investigators analyzed improvement from baseline within each grp and compared the two grps in a two-way ANOVA, followed by a post hoc contrast analysis. | (c) pH: Improved significantly in both grps from baseline (ED) to every time point from 24 hrs on (p < 0.001 for all comparisons).
| AECB dx- | FEV_1_ at admission: N/S | Blood gases: PaO_2_, PaCO_2_, pH, PA-aO_2_. Means reported (graphically) for baseline (ED), 24 hrs, 30 hrs, 72 hrs, 80 hrs, and time of discharge. Investigators analyzed improvement from baseline within each grp and compared the two grps in a two-way ANOVA, followed by a post hoc contrast analysis. | There were no significant differences between the two grps (p ≥ 0.05). (Means reported only graphically.)
| AECB sev+ | Age: 68 | LOS in hospital: Mean number of days | (d) PA-aO2: Did not significantly improve in either treatment grp.
| Tx duration+ | Sex: 24 M, 0 F | Percentage of pts intubated | LOS in hospital: No significant difference between the two grps: BiPAP® (n = 10), 10.6 ± 0.9 (SEM) days; control (n = 10), 11.3 ± 1.3 days
| Internal validity: | Race:N/S | | Percentage of pts intubated: No pts were intubated in either treatment grp.
| 2/5 r, ndb, dd | | | Adverse events: 4/14 pts in the BiPAP® grp (29%) could not tolerate the treatment, 3 due to claustrophobia, 1 due to anxiety. No information was provided on AEs in the control grp.
| | | | Dropouts: The 4 BiPAP® pts were the only pts prematurely withdrawn/ excluded from the analysis (17%)
Boix, Tejeda, Álvarez, et al., 1996 | Design: Crossover | N = 20 | Interventions: | Blood gases: | Low quality score (0)
| Dates: N/S | Setting: Inpatients at 2 hospitals | Experimental: EHFOV (Hayek oscillator); settings established by protocol | (1) The two modes of ventilation produced closely similar blood gas results (p > 0.5 for all outcomes; n = 20 for all data). | No significant differences between baseline and “pause” (washout) values for any of the major outcome variables (p > 0.05)
| Location: Spain | Inclusion (COPD): COPD according to ATS criteria (1987) | Control: NIPPV; settings established by protocol | (a) pH: Baseline, 7.37 ± 0.06 (SD); post-HFOV, 7.40 ± 0.03 (p < 0.001 vs. baseline); post-NPPV, 7.41 ± 0.05
| Assessment period: 3 hrs, divided into four 45-min periods (see “crossover design”) | Inclusion (AcEx): Increased cough, purulent sputum production, recent and rapid worsening of dyspnea with paradoxical abdominal motion or thoracoabdominal asynchronism, PaO_2_ < 60 mm Hg, PaCO_2_ > 50 mm Hg on room air, and/or severe pulmonary obstruction | Co-interventions: “Standard treatment,” including oxygen by nasal cannula, bronchodilators (aminophylline, β2-andrenoceptor agonists), corticosteroids, antibiotics (amoxicillin with clavulanic acid), and chest physiotherapy | (b) (p < 0.05 vs. baseline).
| External validity: 3/5 | Exclusion: Need for endotracheal intubation and MV, history of cardiovascular disease, evidence of pneumonia | Crossover design: During the 24–48 hrs after admission, each pt completed a 3-hr study session divided into four 45-min periods: baseline, first ventilatory mode, weaning of ventilation (pause), second ventilatory mode. | (c) PaCO_2_ (mm Hg): Baseline, 64.4 ± 12.0 (SD); post-HFOV, 56.4 ± 9.5 (p < 0.001 vs. baseline); post-NPPV, 56.5 ± 11.6 (p < 0.001 vs. baseline).
| COPD dx+ | Smoking history: N/S | Outcomes: | (d) PaO_2_ (mm Hg): Baseline, 52.9 ± 19.1(SD); post-HFOV, 51.1 ± 22.3; post-NPPV, 52.5 ± 8.2.
| COPD bl- | Baseline stable FEV_1_: N/S | Blood gases: Measured at 45 min during each phase of the crossover. Investigators reported mean pH, PaCO_2_, and PaO_2_ at baseline, during the pause in the crossover (washout), and posttreatment and analyzed change from baseline to posttreatment for each mode of ventilation. Period 1 and 2 data were not reported separately. | (2) Differences in the decrease in PaCO_2_ attained with the two modes of ventilation were < 5 mm Hg in 13 pts, 5–10 mm Hg in 6 pts, and > 10 mm Hg in 1 pt (not analyzed)
| AECB dx+ | FEV_1_ at admission: 30.5% ± 5.2% (SD) predicted | Investigators also reported the number of pts in whom the difference in the decrease (from baseline) in PaCO_2_ attained with the two modes of ventilation was < 5 mm Hg, 5–10 mm Hg, and > 10 mm Hg. | Percentage of pts intubated: No pts required intubation.
| AECB sev+ | Age: 63.3 | | Adverse events/complications: Investigators reported that “[n]o complications were observed during the study.”
| Tx duration- | Sex: 17 M, 3 F | | Dropouts: Not described
| Internal validity: 0/5 | Race: N/S
| r-, ndb, dnd
Bott, Carroll, Conway, et al., 1993 | Design: SPPG | N = 60 (see “Note” at right) | Interventions: | Blood gases/oximetry: Mean difference in change in PaCO_2_ significantly lower (by 9 mm Hg) in NIPPV grp (n = 26) than in control grp (n = 30) (95% CI, 3.4 to 15; p < 0.01). Baseline and 1-hr mean PaCO_2_ scores: NIPPV grp, 65 mm Hg and 54 mm Hg; control grp, 65 mm Hg and 64 mm Hg (no variance data provided). No within-grp p-values provided | Exact n's for each hospital unclear: “approximately 10 in each [treatment] grp” for all hospitals
| Dates: N/S | Setting: Pts admitted to hospital (study conducted at 3 hospitals) | Experimental: NIPPV; volume-cycled, administered by silicone nasal mask; provided 1–2 L/min of oxygen for ≤ 16 hrs/day (including all night, but excluding periods of eating, drinking, moving around); treatment duration reduced as pt improved | LOS in ED or hospital: NIPPV grp, 9 (1–22) days (median) vs. control grp, 9 (1–39) days (median) | Pts in 1 hospital significantly less acidotic at baseline than those in other 2 hospitals (p < 0.05) 4/30 pts in NIPPV grp (13%) vs. 13/30 in control grp (43%) received doxapram
| Location: United Kingdom | Inclusion (COPD): “Chronic obstructive airways disease,” not defined; age ≤ 80 yrs | Control: No NIPPV | Percentage of pts intubated: NIPPV grp, 0; control grp, 2/30 (6.7%)
| Assessment period: Treatment in NIPPV pts started as soon as possible after admission; study duration was 7 days | Inclusion (AcEx): Pts with acute ventilatory failure due to “acute exacerbations,” defined as (1) PaO_2_ < 56 mm Hg and (2) PaCO_2_ > 45 mm Hg | Co-interventions: Nonstandardized conventional treatment, defined as “that deemed appropriate by the clinicians responsible: oxygen at 24–28%; inhaled bronchodilators; and all, or a combination of, antibiotics, diuretics, respiratory stimulants, IV or oral corticosteroids, and bronchodilators” | Percentage of pts who died within 30 days: Using “intent-to-treat” analysis, no significant differences found between grps: NIPPV grp, 3/30 pts (10%) vs. 9/30 pts in control grp (30%) died within 30 days (relative risk = 0.33; CI, 0.10 to 1.11;p = 0.106)
| External validity: 2/5 | Exclusion: Use of NIPPV at home; severe disease not attributable to chronic respiratory disease; severe psychiatric disease | Outcomes: | Adverse events: N/S
| COPD dx- | Smoking history: N/S | Blood gases/oximetry: ABGs measured on admission, after 1 hr on allocated treatment, on day 3, and on day 7, while pt was breathing room air (except at 1 hr after admission when pt was using either oxygen or NIPPV) | Dropouts: NIPPV grp, 4/30 (13%); control grp, 10/30 (33%)
| COPD bl- | Baseline stable FEV_1_: N/S | (a) Mean difference in change in PaCO_2_ from baseline to 1 hr
| AECB dx- | FEV_1_ at admission: N/S | LOS in hospital: Median no. of days
| AECB sev+ | Age: N/S | Percentage of pts intubated
| Tx duration+ | Sex: N/S | Percentage of pts who died within 30 days
| Internal validity: 2/5 | Race: N/S
| r, ndb, dd
Brochard, Mancebo, Wysocki, et al., 1995 | Design: SPPG | N = 85 | Interventions: | Blood gases: There were no significant differences in blood gas levels between the two grps at admission. P-values are for 1 hr vs. baseline; no posttreatment between-grp comparisons were reported. All results are mean ± SD. | 3 pts in the standard-treatment grp and 1 in the NIV grp were intubated before 1-hr blood samples were drawn and were not included in the 1-hr blood gas results.
| Dates: 9/90-11/91 | Setting: 5 hospital ICUs | Experimental: Noninvasive, pressure-support ventilation (ARM 25 machine, with face mask) for at least 6 hrs/day (duration determined on basis of clinical criteria and ABGs by physician in charge) | (a) PaO_2_ (mm Hg): Standard treatment: Pretreatment, (n = 42), 39 ± 12; 1 hr (n = 39), 58 ± 24 (p = 0.01). NIV: Pretreatment (n = 43), 41 ± 10; 1 hr (n = 42), 66 ± 17 (p = 0.01). | Investigators formulated specific criteria for intubation to be used in both treatment grps. In NIV grp, if two minor criteria present after withdrawal of ventilation, then ventilation could be reintroduced
| Location: France (3 sites), Italy (1 site), and Spain (1 site) | Inclusion (COPD): Known COPD or high probability of COPD (on basis of clinical history, physical exam, and chest film), with respiratory acidosis and elevated bicarbonate level | Control: No NIV | (b) PaCO_2_ (mm Hg): Standard treatment: Pre-treatment, (n = 42), 67 ± 16; 1 hr (n = 39), 72 ± 18 (p = 0.003). NIV: Pretreatment (n = 43), 70 ± 12; 1 hr (n = 42), 68 ± 13 (p = 0.17). | If criteria persisted, then intubation performed
| Assessment period: Pts followed from admission until discharge from hospital | Inclusion (AcEx): Exacerbation of dyspnea lasting < 2 wks and at least two of the following: respiratory rate > 30 breaths/min; PaO_2_ < 45 mm Hg; arterial pH < 7.35 after breathing room air for at least 10 min | Co-interventions: “Standard treatment”: (1) oxygen by nasal prongs, with maximal flow rate of 5 L/min, to achieve arterial oxygen saturation > 90%; and (2) medications, including heparin SC, antibiotics, and bronchodilators (terbutaline SC, aerosolized and IV albuterol, and corticosteroids or IV aminophylline or both), with the correction of electrolyte abnormalities | (c) pH: Standard treatment: Pretreatment, (n = 42), 7.28 ± 0.11; 1 hr (n = 39), 7.26 ± 0.11 (p = 0.01). NIV: Pretreatment (n = 43), 7.27 ± 0.10; 1 hr (n = 42), 7.31 ± 0.09 (p < 0.001).
| External validity: 2/5 | Exclusion: Respiratory rate < 12 breaths/min; need for immediate intubation; tracheotomy or endotracheal intubation performed before admission; use of sedative drugs in previous 12 hrs; CNS disorder unrelated to hypercapnic encephalopathy or hypoxemia; cardiac arrest w/in previous 5 days; cardiogenic pulmonary edema; kyphoscoliosis as the cause of chronic respiratory failure or a neuromuscular disorder; upper airway obstruction or asthma; clear cause of decompensation requiring specific treatment; facial deformity; enrollment in other investigative protocols; refusal to undergo intubation | Outcomes: | Percentage of pts intubated:
| COPD dx- | Smoking history: N/S | Blood gases: PaO_2_, PaCO_2_, and pH measured pretreatment, at 1, 3, and 12 hrs, and once per day thereafter. Results reported for 0 and 1 hr only | (a) Over the entire hospital stay: 31/42 pts (74%) in the standard-treatment grp vs. 11/43 (26%) in the NIV grp (p < 0.001). Results were consistent across the 5 sites.
| COPD bl- | Baseline stable FEV_1_: N/S | Percentage of pts intubated: Reported (a) for the entire hospital stay and separately for (b) the first hr and (c) first 12 hrs | (b) During the first hr of treatment: 17/42 pts (41%) in the standard treatment grp vs. 3/43 (7.0%) in the NIV grp (not analyzed)
| AECB dx- | FEV_1_ at admission: N/S | LOS in hospital: (a) Mean LOS (in days) (b) No. of surviving pts with hospital stay > 4 wks | (c) During the first 12 hrs of treatment: 23/42 pts (55%) in the standard treatment grp vs. 9/43 (21%) in the NIV grp (not analyzed)
| AECB sev+ | Age: 70.0 | Mortality: No. of deaths during hospital stay | LOS in hospital:
| Tx duration+ | Sex: N/S | | (a) Mean LOS (± SD) significantly longer in grp receiving standard treatment (35 ± 33 days) than in grp receiving NIV (23 ± 17) (p = 0.02).
| Internal validity: 3/5 | Race: N/S | | (b) Number of surviving pts with hospital stays of > 4 wks: 14/30 (47%) in the standard treatment grp vs. 7/39 (18%) in the NIV grp (p = 0.004).
| r+, ndb, dd | | | Mortality: Deaths in hospital: 12/42 (29%) in standard treatment grp, 4/43 (9.3%) in NIV grp (p = 0.02). After adjustment for intubation, there was no significant difference between the two grps.
| | | | Adverse events: Investigators described complications and events leading to death. The proportion of pts reporting one or more complications was significantly (p = 0.001) higher in the standard treatment grp (20/42 = 48%) than in the NIVgrp (7/43 = 16%). Pneumonia developed in 7/42 pts (17%) in the standard treatment grp, compared with 2/43 (4.7%) in NIV grp. Multiple pneumothoraxes were reported by 1 (2.3%) and 0 pts in the standard treatment and ventilation grps, respectively, and facial skin necrosis by 0 and 1 (2.3%) of pts.
| | | | Dropouts: None apart from pts who died
Girault, Chevron, Richard, et al., 1997 | Design: Crossover | N = 15 | Interventions: | Investigators stated that “[n]o evidence was found for any carryover (interaction) or period effects so all the results presented are for the nonparametric treatment effects.” | Low quality score (1)
| Dates: N/S | Setting: Hospital ICU | Experimental: NIV in assist-control AC mode with nasal mask; settings adjusted according to clinical tolerance of pt | Blood gases/oximetry: | AcExs were related to bronchial infection in 14 cases and to pneumonia in 1.
| Location: France | Inclusion (COPD): Known COPD or a high probability of COPD on the basis of clinical history, physical exam, chest radiography, and/or previous PFT data | Control: NIV in spontaneous breathing SB mode with nasal mask, supplemented with inspired oxygen; ventilator settings adjusted according to clinical tolerance of pt | (a) PaO_2_: AC-mode NIV (n = 15) significantly improved PaO_2_ compared with baseline values (p < 0.001); SB-mode NIV (n = 15) did not (p ≥ 0.05). Posttreatment mean PaO_2_ values were significantly better with AC-mode ventilation than with SB-mode (p = 0.02). Mean baseline and posttreatment PaO_2_ values (± SD) were as follows:
| Assessment period: 2 consecutive treatment periods of at least 30 min each, both during first 48 hrs after admission to ICU | Inclusion (AcEx): Hypercapnic ARF requiring NIV, with at least 3 of the following: tachypnea > 25/min or bradypnea ≤ 12/min; PaO_2_ ≤ 60 mm Hg in ambient air; PaCO_2_ ≥ 49 mm Hg in ambient air or worsening with a low nasal oxygen flow (≤ 3 L/min); respiratory acidosis (pH ≤ 7.35); a normal level of consciousness or moderate signs of respiratory encephalopathy (drowsiness, confusion, flapping tremor) | Co-interventions: None described | Baseline: 63 ± 22 mm Hg
| External validity: 1/5 | Exclusion: Failure to tolerate NIV during first few hrs after admission; need for immediate endotracheal intubation; contraindication to insertion of an esophageal tube | Crossover design: Pt used NIV in one mode (AC or SB) for “a minimal duration of 30 min,” then crossed over to the other (no “washout”) | Post-AC: 100 ± 16 mm Hg
| COPD dx- | Smoking history: N/S | Outcomes: | Post-SB: 88 ± 12 mm Hg
| COPD bl- | Baseline stable FEV_1_: N/S | Blood gases: Investigators analyzed (a) mean change in PaO_2_, PaCO_2_, and pH from baseline to posttreatment; (b) mean posttreatment PaO_2_, PaCO_2_, and pH; and (c) median posttreatment differences between AC and SB ventilation for PaO_2_, PaCO_2_, and pH. | The median difference (with range) in posttreatment PaO_2_ between AC- and SB-mode ventilation was
| AECB dx- | FEV_1_ at admission: 29.20% ± 10.43% (SD) predicted | | 8.5 (-19 to 48) mm Hg.
| AECB sev+ | Age: 64.5 | | (b) PaCO_2_: AC-mode NIV (n = 15) significantly improved PaCO_2_ compared with baseline values (p = 0.001); SB-mode NIV (n = 15) did not (p ≥ 0.05). Posttreatment mean PaCO_2_ values were significantly better with AC-mode ventilation than with SB-mode (p < 0.001). Mean baseline and posttreatment PaCO_2_ values (± SD) were as follows:
| Tx duration- | Sex: 12 M, 3 F | | Baseline: 71 ± 12 mm Hg
| Internal validity: 1/5 | Race: N/S | | Post-AC: 55 ± 10 mm Hg
| r, ndb, dnd | | | Post-SB: 64 ± 10 mm Hg
| | | | The median difference (with range) in posttreatment PaCO_2_ between AC- and SB-mode ventilation was -6 (-26 to 2) mm Hg.
| | | | (c) pH: AC-mode NIV (n = 15) significantly improved pH compared with baseline values (p = 0.0009); SB-mode NIV (n = 15) did not (p ≥ 0.05). Posttreatment mean pH values were significantly better with AC-mode ventilation than with SB-mode (p < 0.001). Mean baseline and posttreatment pH values (± SD) were as follows:
| | | | Baseline: 7.32 ± 0.03
| | | | Post-AC: 7.40 ± 0.07
| | | | Post-SB: 7.35 ± 0.05
| | | | The median difference (with range) in posttreatment pH between AC- and SB-mode ventilation was 0.03 (0 to 0.19).
| | | | Percentage of pts intubated: None of the 15 pts required intubation.
| | | | Adverse events: “Respiratory comfort” (measured by pts on a 100-mm VAS) was significantly better with SB-mode ventilation than with AC-mode (p < 0.05). No other data on adverse events were reported.
| | | | Dropouts: Not described
Kramer, Meyer, Meharg, et al., 1995 | Design: SPPG | N = 23 (COPD pts) | Interventions: | Percentage of pts intubated:8/12 pts (67%) in the standard treatment grp vs. 1/11 (9.1%) in the NPPV grp (p = 0.017). | Trial also included 2 pts with CHF, 4 with pneumonia, 1 with asthma, and 1 with a PE Intubation was deemed necessary if progressive clinical deterioration occurred, as manifested by worsening mental status, dyspnea or tachypnea, development of hypotension (systolic BP < 90 mm Hg), rise in PaCO_2_ of 5–10 mm Hg, or fall in pH of 0.05–0.1 units. Pt's primary care physician made decision to intubate using these criteria
| Dates: 10/92-6/93 | Setting: 2 hospitals. Pts either presented with ARF or developed ARF during hospitalization. All pts monitored in an ICU or step-down unit. | Experimental: NPPV administered using a BiPAP® ventilatory assist system (Respironics) with a nasal mask. Pts encouraged to use NPPV for as long as tolerated, aiming for at least 8 hrs per day. Weaning attempted no sooner than 6 hrs after initiation once clinical stability attained | LOS in hospital: No significant difference between the two grps (p > 0.05): 17.3 + 3.0 (SEM) days for standard treatment grp (n = 12), 14.9 ± 3.3 for NPPV grp (n = 11) | Control pts who declined intubation were offered NPPV if they deteriorated sufficiently to warrant intubation. Such pts were considered to have needed intubation for the purposes of the analysis.
| Location: United States | Inclusion (COPD): N/S | Control: No NPPV | Adverse events: Investigators reported data on complications of treatment in all pts. 6/16 pts (38%) in the NPPV grp had problems with the mask (skin ulcerations, air leakage through the mouth, intolerance). 3/16 (19%) had worsening gas exchange requiring intubation. One intubated pt each in the control grp (5/15 = 33%) had hypotension, nosocomial pneumonia, tension pneumothorax, inspiratory stridor after self-extubation, and myopathy after prolonged steroid administration.
| Assessment period: 72 hrs for most outcomes | Inclusion (AcEx): Respiratory distress, as evidenced by moderate to severe dyspnea, accessory muscle use, or abdominal paradox; and ARF, as evidenced by pH < 7.35, PaCO_2_ > 45 mm Hg, and respiratory rate > 24 breaths/ min | Co-interventions: Standard treatment = all treatments and interventions that would have been administered had the pt not been entered into the study. For COPD pts, these might include corticosteroids, frequent respiratory treatments, supplemental oxygen, antibiotics, and, if necessary, endotracheal intubation. Treatments determined by pt's primary care physician. | Dropouts: None apart from those pts who died (in all pts, 2/15 in the standard treatment grp and 1/16 in the NPPV grp)
| External validity: 2/5 | Exclusion: Respiratory arrest or need for immediate intubation; hypotension (systolic BP < 90 mm Hg); uncontrolled arrhythmias; upper airway obstruction or facial trauma; inability to clear secretions; inability to cooperate or fit mask | Outcomes:
| COPD dx- | Smoking history: N/S | Only those outcomes for which results were reported separately for pts with COPD are considered here.
| COPD bl- | Baseline stable FEV_1_: N/S | Percentage of pts intubated: Measured over 72 hrs
| AECB dx- | FEV_1_ at admission: N/S | LOS in hospital: Mean number of days
| AECB sev+ | Age: 68.5 (all pts)
| Tx duration+ | Sex: 18 M, 13 F (all pts)
| Internal validity: 2/5 | Race: N/S
| r, ndb, dd
Meecham Jones, Paul, Grahame-Clarke, et al., 1994 | Design: Crossover | N = 12 | Interventions: | Blood gases: | Low quality score (1)
| Dates: N/S | Setting: Hospitalized pts | Experimental: Pressure-cycled NIPPV, administered via the BiPAP® ventilatory support system, using a nasal mask | (a) PaO_2_: Pressure-cycled NIPPV, CPAP, and volume-cycled NIPPV all produced significant improvements in PaO_2_; there was no significant difference in the three modes (repeated measures ANOVA). Pressure-cycled NIPPV + EPAP did not result in a significant improvement. Mean changes in PaO_2_ from pre- to posttreatment (with 95% CI) were (n = 12): Pressure-cycled NIPPV, +2.50 (1.06 to 3.95); pressure-cycled NIPPV + EPAP, +0.82 (-0.78 to 2.23); CPAP, +1.35 (0.10 to 2.79); volume-cycled NIPPV, +2.34 (1.34 to 3.38). | 7 pts had used NIPPV during previous hospital admissions, and 2 were established on domiciliary NIPPV
| Location: United Kingdom | Inclusion (COPD): Diagnosis made “on clinical grounds” (diagnostic criteria N/S) | Control 1: Pressure-cycled NIPPV + EPAP, administered via the BiPAP® ventilatory support system, using a nasal mask | (b) PaCO_2_: None of the ventilator modes produced significant improvements in mean PaCO_2_. Mean changes in PaCO_2_ from pre- to posttreatment (with 95% CI) were (n = 12): Pressure-cycled NIPPV, -0.29 (-0.59 to 0.01); pressure-cycled NIPPV + EPAP, -0.24 (-1.02 to 0.54); CPAP, +0.25 (-0.18 to 0.68); volume-cycled NIPPV, +0.04 (-0.51 to 0.60). | Across all forms of ventilation, pts with higher initial PaCO_2_ levels tended to rise further with treatment, while those with lower starting levels tended to fall (p < 0.02).
| Assessment period: Four 1-hr treatment periods, with at least 1 hr in between | Inclusion (AcEx): Diagnosis made “on clinical grounds” (diagnostic criteria N/S); no focal consolidation on chest radiography; deterioration in spirometry and ABGs | Control 2: CPAP, administered via the BiPAP® ventilatory support system, using a nasal mask | LOS in hospital: 11 days (range: 5–22)
| External validity: 1/5 | Exclusion: N/S | Control 3: Volume-cycled NIPPV, administered via the BromptonPAC ventilator, using a nasal mask | Percentage of pts intubated: No pts were intubated
| COPD dx- | Smoking history: N/S | Co-interventions: All pts entered the trial within 16 hrs of admission to hospital; during pretrial period, oxygen therapy and “other appropriate treatments” were instituted; oxygen therapy was continued for the duration of the trial; 4 pts already established on doxapram IV continued it throughout the trial; all pts were treated during the trial with antibiotics, corticosteroids, and nebulized bronchodilators | Adverse events: 3 pts experienced “great difficulty” in tolerating pressure-cycled NIPPV + EPAP. No further data reported on AEs
| COPD bl- | Baseline stable FEV_1_: N/S | Crossover design: Each pt underwent 4 periods of ventilation for 1 hr each; at least 1 hr elapsed between different treatment periods; during 1-hr “washout,” blood gas levels “returned to a stable baseline” | Dropouts: Not described
| AECB dx- | FEV_1_ at admission: | Outcomes:
| AECB sev+ | 0.59 L ± 0.13 (SD) | Blood gases: Mean changes in PaO_2_ and PaCO_2_ from immediately pretreatment to 1 hr (immediately posttreatment)
| Tx duration- | Age: Median 69 (range: 49–76) | LOS in hospital: Median no. of days
| Internal validity: 1/5 | Sex: 11 M, 1 F | Percentage of pts intubated
| r, ndb, dnd | Race: N/S
Vitacca, Rubini, Foglio, et al., 1993 | Design: SPPG | N = 29 | Interventions: | FEV_1_: NPSV (n = ?): Preventilation, 0.34 ± 0.11 (SD) L; withdrawal, 0.71 ± 0.21 L; NIPPV (n = ?): Preventilation, 0.32 ± 0.13 L; withdrawal, 0.68 ± 0.21 L (p < 0.001). | Acute diagnoses at time of admission to ICU were infectious relapse (20 pts), pneumonia (7 pts), and PE (2 pts).
| Dates: N/S | Setting: Pts admitted from hospital rehabilitation unit to 2 respiratory intermediate ICUs | Experimental: NPSV by facial mask; ventilation titrated to pt | Blood gases: There were no significant differences between the two grps for any of the following outcomes (p ≥ 0.05):
| Location: Italy | Inclusion (COPD): COLD, according to ATS criteria (1987) | Control: NIPPV in assist-control mode by facial mask; ventilation settings established by protocol | (a) pH: NPSV (n = 14), baseline, 7.29 ± 0.03 (SD?); withdrawal, 7.35 ± 0.02; NIPPV (n = 10), baseline, 7.25 ± 0.09; withdrawal, 7.40 ± 0.04.
| Assessment period: To time of discharge from hospital | Inclusion (AcEx): Acute hypercanic respiratory failure (not defined); NIV instituted when pts met the following criteria: rapid deterioration in neurological status (Glasgow Coma Scale ≤ 9), acute onset of severe hypercapnia (PaCO_2_ > 65 mm Hg), acute decrease in pH (< 7.35), tachypnea and /or abdominal paradox. | Both types of NIV were prescribed continuously, but were stopped for 15–30 min when pts had to expectorate, drink, or rest NIV was withdrawn when pt either: | (b) PaCO_2_: NPSV (n = 14), baseline, 77 ± 11 (SD?) mm Hg; withdrawal, 61 ± 5; NIPPV (n = 10), baseline, 87 ± 20; withdrawal, 57 ± 10.
| External validity: 4/5 | Exclusion: N/S | (1) reached levels of pH > 7.35 in spontaneous breathing w/o further neurological worsening for at least 24 hrs (successful therapy) or | (c) PaO_2_/FiO2: NPSV (n = 14), baseline, 1.95 ± 0.69 (SD?); withdrawal, 2.41 ± 0.62; NIPPV (n = 10), baseline, 1.65 ± 0.36; withdrawal, 2.23 ± 0.46.
| COPD dx+ | Smoking history: N/S | (2) needed endotracheal intubation (unsuccessful therapy) | Percentage of pts intubated: 2/16 pts (13%) in the NPSV grp and 3/13 (23%) in the NIPPV grp (n.s. [p ≥ 0.05])
| COPD bl+ | Baseline stable FEV_1_: 0.71 ± 0.25 (SD) L | Co-interventions: Standard IV medical therapy (aminophylline, steroids, and β2 agonists) and oxygen therapy | Mortality: 4/29 pts (14%), all intubated, died during the study (ventilation grp N/S).
| AECB dx- | FEV_1_ at admission: NPSV grp, 0.36 ± 0.13 (SD) L; NIPPV grp, 0.48 ± 0.21 L | Outcomes: | Adverse events: A significantly larger number of pts reported AEs with NIPPV than with NPSV (p < 0.01). NIPPV: nose abrasion (4 pts), bad sleeping (2), nose pain (1), gastric distension (1), mask leakage (1), claustrophobia (1). NPSV: nose abrasion (2 pts), nose pain (1), rhinitis (1).
| AECB sev+ | Age: 62 | FEV_1_: Measured only in pts able to perform spirometry (n = ?). Investigators analyzed improvement from baseline to time of withdrawal of ventilation. | Dropouts: None, apart from pts who died
| Tx duration+ | Sex: 18 M, 11 F | Blood gases: Measured only in pts who were not intubated. Investigators analyzed improvement from baseline to time of withdrawal of ventilation (note that pH > 7.35 required for withdrawal).
| Internal validity: 2/5 | Race: N/S | Percentage of pts intubated
| r, ndb, dd | | Mortality

1 External validity score (5 points possible): COPD dx = COPD diagnosis based on spirometry (+ = yes = 1; - = no = 0); COPD bl = baseline stable ventilatory status of population described (+ = yes = 1; - = no = 0); AECB dx = diagnosis of AECB includes at least two of following: increased sputum purulence, increased sputum volume, increased dyspnea (+ = yes = 1; - = no = 0); AECB sev = severity of AECB at enrollment described based on at least two of following: mental status change, work of breathing, ventilatory status (+ = yes = 1; - = no = 0); Tx duration = outcomes assessed at 24 hours or later (+ = yes = 1; - = no = 0).

2 Internal validity score (5 points possible): Randomization: r = study described as randomized, method of randomization not described (1 point); r+ = method of randomization described and adequate (2 points); r- = method of randomization described but inadequate (0 points). Double-blinding: ndb = not double-blind (0 points); db = study described as double double-blind, method of blinding not described (1 point); db+ = method of blinding described and adequate (2 points); db! = method of blinding described but inadequate (0 points). Dropouts: dd = dropouts described (1 point); dnd = dropouts not described (0 points).