# Abbreviations Used in Evidence Tables

ABG | arterial blood gas
AcEx | acute exacerbation
AC | assist-control
ADL | Activities of Daily Living
ADR | Advanced Diagnostic Research
AE | adverse effect
AECB | acute exacerbation of chronic bronchitis
AIDS | acquired immunodeficiency syndrome
ALT | alanine transaminase
Amt | amount
a.m. | ante meridiem (morning)
ANOVA | analysis of variance
APACHE | Acute Physiology and Chronic Health Evaluation
APS | Acute Physiology Score
ARF | acute respiratory failure
ARM | (A type of pressure support ventilation from TAEMA, Antony, France)
ASG | admitting severity group
AST | aspartate aminotransferase
ATS | American Thoracic Society
BiPAP^®^ | bilevel positive airway pressure (abbreviation for a trademarked machine of Respironics of Pittsburgh, PA, that provides a form of pressure support ventilation)
BMI | body mass index
BP | blood pressure
Btwn | between
BUN | blood urea nitrogen
C | Celsius
CECA | Comunita European Carbone e Acciaco
CHF | congestive heart failure
CNS | central nervous system
COLD | chronic obstructive lung disease
COPD | chronic obstructive pulmonary disease
CPAP | continuous positive airway pressure
CXR | chest x-ray
d | day
DM | diabetes mellitus
DVT | deep venous thrombosis
ECG | electrocardiogram
ED | emergency department
EHFOV | external high-frequency oscillatory ventilation
EMS | emergency medical service
EPAP | expiratory positive airway pressure
F | female or Fahrenheit
FEFR | forced expiratory flow rate
FEV_1_ | forced expiratory volume in 1 second
FiO_2_ | fraction of inspired oxygen
FVC | forced vital capacity
GI | gastrointestinal
GP | general practitioner
Grp | group
HG | mercury
hr | hour
HTN | hypertension
IBW | ideal body weight
ICU | intensive care unit
IDDM | insulin-dependent diabetes mellitus
IgE | immunoglobulin, class E
IHD | ischemic heart disease
IPAP | inspiratory positive airway pressure
IPG | impedance plethysmography
IPPV | intermittent positive pressure ventilation
IV | intravenous
JVP | jugular venous pressure
K-M | Kaplan-Meier
kPa | kilopascal
L | liter
LOS | length of stay
LR | low risk
M | male
MDI | metered-dose inhaler
mg | milligram>
MHz | megahertz
min | minute
ml or mL | milliliter
mm | millimeter
mo | month
Mod | moderate
Multi | multivariable
MV | mechanical ventilation or multivariable analysis
n | number of subjects in group (of total population)
N | number of subjects in total population
N/S | not specified
NCHS | National Center for Health Statistics
Neg | negative
NIDDM | non-insulin-dependent diabetes mellitus
NIPPV | nasal intermittent positive pressure ventilation
NIV | noninvasive ventilation
NIVS | noninvasive ventilatory support
NNPV | noninvasive negative pressure ventilation
NPI | nutritional prognostic index
NPPV | noninvasive positive pressure ventilation
NPSV | noninvasive pressure support ventilation
NPV | negative predictive value
O_2_ | oxygen
p | probability
PCO_2_ | partial pressure of carbon dioxide
PaCO_2_ | partial pressure of carbon dioxide, arterial
PO_2_ | partial pressure of oxygen
PaO_2_ | partial pressure of oxygen, arterial
PA- aO_2_ | alveolar-arterial difference in partial pressure of oxygen
PAP | positive airway pressure
PE | pulmonary embolism
PEFR | peak expiratory flow rate
PFR | peak flow rate
PFT | pulmonary function test
pH | hydrogen ion concentration
PMN | polymorphonuclear
PO | per os (orally)
Pos | positive
PPV | positive predictive value
Pred | predictive
Pt | patient
R | correlation coefficient
RA | room air
RVH | right ventricular hypertrophy
Rx | prescription
SaO_2_ | oxygen saturation, arterial
SAPS | Simplified Acute Physiology Score
Sat | saturation
SB | spontaneous breathing
SC | subcutaneous
SCCOPE | Systemic Corticosteroids in Chronic Obstructive Pulmonary Disease Exacerbations
SD | standard deviation
Se | sensitivity
Sev | severe
SEM | standard error of the mean
SGPT | serum glutamic-pyruvic transaminase
Sp | specificity
SPPG | single-period parallel group
SUPPORT | Study to Understand Prognoses and Preferences for Outcomes and Risks of Treatments
T | temperature
TB | tuberculosis
TIA | transient ischemic attack
Tx | treatment
U or Uni | univariable
VAS | visual analogue scale
VC | vital capacity
w/v | weight per volume
WBC | white blood cell (count)
wk | week
yr | year
μg | microgram
μmol | micromole