# Bibliography

Aalto E, Havu M, Kotaniemi J, et al. Comparison of terbutaline Turbuhaler and albuterol chlorofluorocarbon (CFC) inhaler in middle-aged and elderly patients with obstructive lung disease. Ann Allergy. 1992;69(1):33-6. [pmid: 1626757].
Abou-Shala N, MacIntyre N. Emergent management of acute asthma. Med Clin North Am. 1996;80(4):677-99. [pmid: 8691921].
Ahmed A H, Fenwick L, Angus R M, et al. Nasal ventilation vs. doxapram in the treatment of type II respiratory failure complicating chronic airflow obstruction [abstract]. Thorax. 1992;1:858.
Aitchison W R, Grant I W, Gould J C. Treatment of acute exacerbations in chronic bronchitis. Br J Clin Pract. 1968;22:343-5. [pmid: 4885704].
Albert R K, Martin T R, Lewis S W. Controlled clinical trial of methylprednisolone in patients with chronic bronchitis and acute respiratory insufficiency. Ann Intern Med. 1980;92:753-8. [pmid: 6770731].
Aliperta A, Bellissimo U, Turco D, et al. Normalization of bronchial exocrine pathology after endobronchial treatment with ambroxol. Int J Tissue React. 1986;8(2):167-74. [pmid: 2939036].
Allegra L, Bonsignore G, Cresci F, et al. Classification of respiratory functional impairment in chronic obstructive pulmonary disease. Respiration. 1984;45(3):175-84. [pmid: 6431570].
Allegra L, Cordaro C I, Grassi C. Prevention of acute exacerbations of chronic obstructive bronchitis with carbocysteine lysine salt monohydrate: a multicenter, double-blind, placebo-controlled trial. Respiration. 1996;63:174-80. [pmid: 8739489].
Allegra L, Grassi C, Grossi E, et al. Ruolo degli antibiotici nel trattamento delle riacutizza della bronchite cronica. Ital J Chest Dis. 1991;45:138-48.
Allen M B, Pugh J, Wilson R S. Nebuhaler or nebulizer for high dose bronchodilator therapy in chronic bronchitis: a comparison. Br J Dis Chest. 1988;82(4):368-73. [pmid: 3076792].
Ambrosino N, Foglio K, Rubini F, et al. Non-invasive mechanical ventilation in acute respiratory failure due to chronic obstructive pulmonary disease: correlates for success. Thorax. 1995;50(7):755-7. [pmid: 7570410].
Ambrosino N, Montagna T, Nava S, et al. Short term effect of intermittent negative pressure ventilation in COPD patients with respiratory failure. Eur Respir J. 1990;3(5):502-8. [pmid: 2376246].
Ambrosino N, Nava S, Bertone P, et al. Physiologic evaluation of pressure support ventilation by nasal mask in patients with stable COPD. Chest. 1992;101(2):385-91. [pmid: 1735260].
Ambrosino N, Nava S, Torbicki A, et al. Haemodynamic effects of pressure support and PEEP ventilation by nasal route in patients with stable chronic obstructive pulmonary disease. Thorax. 1993;48(5):523-8. [pmid: 8322240].
Ambrosino N, Vitacca M, Polese G, et al. Short-term effects of nasal proportional assist ventilation in patients with chronic hypercapnic respiratory insufficiency. Eur Respir J. 1997;10(12):2829-34. [pmid: 9493669].
American Thoracic Society. Lung function testing: selection of reference values and interpretative strategies. Am Rev Respir Dis. 1991;144(5):1202-18. [pmid: 1952453].
American Thoracic Society. Standards for the diagnosis and care of patients with chronic obstructive pulmonary disease. Am J Respir Crit Care Med. 1995;152(5 Pt 2):S77-121. [pmid: 7582322].
Amoateng-Adjepong Y, Del Mundo J, Manthous C A. Accuracy of an infrared tympanic thermometer. Chest. 1999;115(4):1002-5. [pmid: 10208200].
Anderson G. A clinical trial of a mucolytic agent—acetylcysteine—in chronic bronchitis. Br J Dis Chest. 1966;60(2):101-3. [pmid: 5956148].
Andrivet P, Richard G, Viau F, et al. Treatment of respiratory failure using minitracheotomy and intratracheal oxygenation in selected patients with chronic lung disease. Intensive Care Med. 1996;22(12):1323-7. [pmid: 8986480].
Angus R M, Ahmed A A, Fenwick L J, et al. Comparison of the acute effects on gas exchange of nasal ventilation and doxapram in exacerbations of chronic obstructive pulmonary disease [published erratum appears in Thorax 1997 Feb;52(2):204]. Thorax. 1996;51(10):1048-50. [pmid: 8977608].
Anonymous. Definition and classification of chronic bronchitis for clinical and epidemiological purposes. A report to the Medical Research Council by their Committee on the Aetiology of Chronic Bronchitis. Lancet;1965;1(7389);775–9.
Anonymous. Acute adverse reactions to prednisone in relation to dosage. Clin Pharmacol Ther 1972;13(5):694–8.
Anonymous. When should respiratory muscles be exercised? Chest 1983;84(1):76–84.
Anonymous. Standards for the diagnosis and care of patients with chronic obstructive pulmonary disease (COPD) and asthma. [This official statement of the American Thoracic Society was adopted by the ATS Board of Directors, November 1986.] Am Rev Respir Dis 1987;136(1):225–44.
Anonymous. Prevention of chronic bronchitis exacerbations with ambroxol (mucosolvan retard). An open, long-term, multicenter study in 5,635 patients. Respiration 1989;55(Suppl 1):84–96.
Anonymous. Standardization of Spirometry, 1994 Update. American Thoracic Society. Am J Respir Crit Care Med 1995;152(3):1107–36.
Anthonisen N R. Chronic obstructive pulmonary disease. CMAJ. 1988;138(6):503-10. [pmid: 3278783]. [pmcid: 1267696].
Anthonisen N R, Connett J E, Kiley J P, et al. Effects of smoking intervention and the use of an inhaled anticholinergic bronchodilator on the rate of decline of FEV_1_ The Lung Health Study. JAMA. 1994;272(19):1497-505. [pmid: 7966841].
Anthonisen N R, Manfreda J, Warren C P, et al. Antibiotic therapy in exacerbations of chronic obstructive pulmonary disease. Ann Intern Med. 1987;106(2):196-204. [pmid: 3492164].
Anthonisen N R, Wright E C, Hodgkin J E. Prognosis in chronic obstructive pulmonary disease. Am Rev Respir Dis. 1986;133(1):14-20. [pmid: 3510578].
Anthonisen P, Riis P, Søgaard Andersen T. The value of lung physiotherapy in the treatment of acute exacerbations in chronic bronchitis. Acta Med Scand. 1964;175:715-9. [pmid: 14171977].
Antonelli Incalzi R, Fuso L, De Rosa M, et al. Co-morbidity contributes to predict mortality of patients with chronic obstructive pulmonary disease. Eur Respir J. 1997;10(12):2794-800. [pmid: 9493663].
Appendini L, Patessio A, Zanaboni S, et al. Physiologic effects of positive end-expiratory pressure and mask pressure support during exacerbations of chronic obstructive pulmonary disease. Am J Respir Crit Care Med. 1994;149(5):1069-76. [pmid: 8173743].
Appendini L, Zanaboni S, Patessio A, et al. Respiratory mechanics and respiratory muscle performance in CO_2_ retainers during non-invasive mechanical ventilation. Monaldi Arch Chest Dis. 1993;48(5):506-8. [pmid: 8312914].
Arbab O A, Wiggins J, Ayres J G, et al. The use of parenteral aminophylline in patients taking slow release theophylline preparations: an observation of clinical practice. Br J Dis Chest. 1985;79(2):161-71. [pmid: 3986120].
Armstrong ML. Double-blind crossover trial of bromhexine (Bisolvon) in the treatment of chronic bronchitis. Med J Aust 1976;1(17):612, 614–5, 617.
Aronson S, Gennis P, Kelly D, et al. The value of routine admission chest radiographs in adult asthmatics. Ann Emerg Med. 1989;18(11):1206-8. [pmid: 2817563].
Ashutosh K, Bajaj R, Cho C D, et al. Use of serum theophylline level as a guide to optimum therapy in patients with chronic obstructive lung disease. J Clin Pharmacol. 1990;30(4):324-9. [pmid: 2160479].
Aubier M, Murciano D, Milic-Emili J, et al. Effects of the administration of O_2_ on ventilation and blood gases in patients with chronic obstructive pulmonary disease during acute respiratory failure. Am Rev Respir Dis. 1980;122(5):747-54. [pmid: 6778278].
Aubier M, Murciano D, Viires N, et al. Effects of digoxin on diaphragmatic strength generation in patients with chronic obstructive pulmonary disease during acute respiratory failure. Am Rev Respir Dis. 1987;135(3):544-8. [pmid: 3826880].
Aylward M. A between-patient, double-blind comparison of S-carboxymethylcysteine and bromhexine in chronic obstructive bronchitis. Curr Med Res Opin. 1973;1(4):219-27. [pmid: 4589629].
Aylward M. An assessment of S-carboxymethylcysteine in the treatment of chronic bronchitis. Curr Med Res Opin. 1974;2(7):387-94. [pmid: 4615884].
Aylward M, Bater P A, Davies D E, et al. Clinical therapeutic evaluation of methylcysteine hydrochloride in patients with chronic obstructive bronchitis: a balanced double-blind trial with placebo control. Curr Med Res Opin. 1978;5(6):461-71. [pmid: 350498].
Aylward M, Maddock J, Dewland P. Clinical evaluation of acetylcysteine in the treatment of patients with chronic obstructive bronchitis: a balanced double-blind trial with placebo control. Eur J Respir Dis. 1980;111(Suppl):81-9.
Bach J R. A historical perspective on the use of noninvasive ventilatory support alternatives. Respir Care Clin N Am. 1996;2(2):161-81. [pmid: 9390877].
Bach J R, Alba A S. Management of chronic alveolar hypoventilation by nasal ventilation. Chest. 1990;97(1):52-7. [pmid: 2104793].
Bach J R, Rajaraman R, Ballanger F, et al. Neuromuscular ventilatory insufficiency: effect of home mechanical ventilator use vs oxygen therapy on pneumonia and hospitalization rates. Am J Phys Med Rehabil. 1998;77(1):8-19. [pmid: 9482374].
Backman R, Hellström P. Fenoterol and ipratropium bromide for treatment of patients with chronic bronchitis. Curr Ther Res. 1985;38:135-40.
Baigorri F, de Monte A, Blanch L, et al. Hemodynamic responses to external counterbalancing of auto-positive end-expiratory pressure in mechanically ventilated patients with chronic obstructive pulmonary disease. Crit Care Med. 1994;22(11):1782-91. [pmid: 7956282].
Balbi B, Bason C, Balleari E, et al. Increased bronchoalveolar granulocytes and granulocyte/macrophage colony-stimulating factor during exacerbations of chronic bronchitis. Eur Respir J. 1997;10:846-50. [pmid: 9150323].
Ball C, Sackett DL, Phillips B, et al. Levels of evidence and grades of recommendations [nonprint data]. From Internet website: http://cebm.jr2.ox.ac.uk/docs/levels.html. September 18, 1998.
Ball P. Epidemiology and treatment of chronic bronchitis and its exacerbations. Chest. 1995;108(2 Suppl):43S-52S. [pmid: 7634925].
Ball P, Harris J M, Lowson D, et al. Acute infective exacerbations of chronic bronchitis. QJM. 1995;88(1):61-8. [pmid: 7894990].
Balter M S, Hyland R H, Low D E, et al. Recommendations on the management of chronic bronchitis: a practical guide for Canadian physicians. Can Med Assoc J. 1994;151(10 Suppl):5-20.
Barbé F, Togores B, Rubí M, et al. Noninvasive ventilatory support does not facilitate recovery from acute respiratory failure in chronic obstructive pulmonary disease. Eur Respir J. 1996;9(6):1240-5. [pmid: 8804944].
Barbera J A, Reyes A, Roca J, et al. Effect of intravenously administered aminophylline on ventilation/perfusion inequality during recovery from exacerbations of chronic obstructive pulmonary disease. Am Rev Respir Dis. 1992;145(6):1328-33. [pmid: 1595998].
Barbera J A, Roca J, Ferrer A, et al. Mechanisms of worsening gas exchange during acute exacerbations of chronic obstructive pulmonary disease. Eur Respir J. 1997;10(6):1285-91. [pmid: 9192930].
Barnes P J. New therapies for chronic obstructive pulmonary disease. Thorax. 1998;53(2):137-47. [pmid: 9624300].
Bauer L A, Blouin R A. Influence of age on theophylline clearance in patients with chronic obstructive pulmonary disease. Clin Pharmacokinet. 1981;6(6):469-74. [pmid: 7318306].
Bauman J H, Kimelblatt B J, Caraccio T R, et al. Cimetidine-theophylline interaction: report of four patients. Ann Allergy. 1982;48(2):100-2. [pmid: 6121526].
Beachey W D, Olson D E. Quantifying ventilatory reserve to predict respiratory failure in exacerbations of COPD. Chest. 1990;97(5):1086-91. [pmid: 2331901].
Beaty C D, Grayston J T, Wang S P, et al. Chlamydia pneumoniae, strain TWAR, infection in patients with chronic obstructive pulmonary disease. Am Rev Respir Dis. 1991;144(6):1408-10. [pmid: 1741558].
Becker C B, Gordon J M. Iodinated glycerol and thyroid dysfunction. Four cases and a review of the literature. Chest. 1993;103(1):188-92. [pmid: 8417876].
Bell D, McNicol M W, Riordan J F, et al. Non-invasive mechanical ventilation for acute respiratory failure. Br Med J. 1990;300(6729):944. [pmid: 2337729].
Belman M J, Botnick W C, Shin J W. Inhaled bronchodilators reduce dynamic hyperinflation during exercise in patients with chronic obstructive pulmonary disease. Am J Respir Crit Care Med. 1996;153(3):967-75. [pmid: 8630581].
Belman M J, Sieck G C, Mazar A. Aminophylline and its influence on ventilatory endurance in humans. Am Rev Respir Dis. 1985;131(2):226-9. [pmid: 3970454].
Belman M J, Soo Hoo G W, Kuei J H, et al. Efficacy of positive vs negative pressure ventilation in unloading the respiratory muscles. Chest. 1990;98(4):850-6. [pmid: 2119950].
Benhamou D, Girault C, Faure C, et al. Nasal mask ventilation in acute respiratory failure. Experience in elderly patients. Chest. 1992;102(3):912-7. [pmid: 1516421].
Bennion Pedley J. Treatment of acute exacerbations of chronic bronchitis in general practice. Br J Clin Pract. 1969;23:280-3. [pmid: 4892350].
Berend N, Webster J, Marlin G E. Salbutamol by pressure-packed aerosol and by intermittent positive pressure ventilation in chronic obstructive bronchitis. Br J Dis Chest. 1978;72(2):122-4. [pmid: 348225].
Berlowitz D R, Ash A S, Hickey E C, et al. Profiling outcomes of ambulatory care: casemix affects perceived performance. Med Care. 1998;36(6):928-33. [pmid: 9630133].
Bernocchi D, Castiglioni C L. Guide to therapy with theophylline for the treatment of obstructive lung disease. J Int Med Res. 1988;16(1):1-18. [pmid: 3280361].
Berry D G, Fry J, Hindley C P, et al. Exacerbations of chronic bronchitis: treatment with oxytetracycline. Lancet. 1960;1:137-9. [pmid: 13799872].
Berry R B, Shinto R A, Wong F H, et al. Nebulizer vs spacer for bronchodilator delivery in patients hospitalized for acute exacerbations of COPD. Chest. 1989;96:1241-6. [pmid: 2582828].
Beydon L, Cinotti L, Rekik N, et al. Changes in the distribution of ventilation and perfusion associated with separation from mechanical ventilation in patients with obstructive pulmonary disease. Anesthesiology. 1991;75(5):730-8. [pmid: 1952197].
Bigi R, Camerone G, Corradetti C, et al. Effect of combined use of intravenous salbutamol and aminophylline on cardiac rhythm in chronic obstructive lung disease. Respiration. 1987;51(2):119-26. [pmid: 3589176].
Bisetti A, Mancini C. Mucolytic activity of erdosteine double blind clinical trial vs placebo. Archivio Di Medicina Int. 1995;47:89-97.
Bittar G, Friedman H S. The arrhythmogenicity of theophylline. A multivariate analysis of clinical determinants. Chest. 1991;99(6):1415-20. [pmid: 2036824].
Blasi F, Legnani D, Lombardo V M, et al. Chlamydia pneumoniae infection in acute exacerbations of COPD. Eur Respir J. 1993;6(1):19-22. [pmid: 8425589].
Bleecker E R, Britt E J. Acute bronchodilating effects of ipratropium bromide and theophylline in chronic obstructive pulmonary disease. Am J Med. 1991;91(4A):24S-7S. [pmid: 1835291].
Bodenhamer J, Bergstrom R, Brown D, et al. Frequently nebulized beta-agonists for asthma: effects on serum electrolytes. Ann Emerg Med. 1992;21(11):1337-42. [pmid: 1416329].
Boix J H, Tejeda M, Álvarez F, et al. Comparison of nasal positive-pressure ventilation to external high- frequency oscillatory ventilation in severe COPD. Respir Care. 1996;41(3):187-90.
Bone R C, Pierce A K, Johnson R L Jr. Controlled oxygen administration in acute respiratory failure in chronic obstructive pulmonary disease: a reappraisal. Am J Med. 1978;65(6):896-902. [pmid: 742628].
Bonmarchand G, Chevron V, Chopin C, et al. Increased initial flow rate reduces inspiratory work of breathing during pressure support ventilation in patients with exacerbation of chronic obstructive pulmonary disease. Intensive Care Med. 1996;22(11):1147-54. [pmid: 9120105].
Bott J, Carroll M P, Conway J H, et al. Randomised controlled trial of nasal ventilation in acute ventilatory failure due to chronic obstructive airways disease. Lancet. 1993;341(8860):1555-7. [pmid: 8099639].
Bouachour G, Guiraud M P, Gouello J P, et al. Gastric intramucosal pH: an indicator of weaning outcome from mechanical ventilation in COPD patients. Eur Respir J. 1996;9(9):1868-73. [pmid: 8880104].
Bourbeau J, Rouleau M Y, Boucher S. Randomised controlled trial of inhaled corticosteroids in patients with chronic obstructive pulmonary disease. Thorax. 1998;53(6):477-82. [pmid: 9713447].
Boye N P, Gaustad P. Double-blind comparative study of ofloxacin (Hoe 280) and trimethoprim-sulfamethoxazole in the treatment of patients with acute exacerbations of chronic bronchitis and chronic obstructive lung disease. Infection. 1991;19(Suppl 7):S388-90. [pmid: 1804789].
Braga P C, Allegra L, Rampoldi C, et al. Long-lasting effects on rheology and clearance of bronchial mucus after short-term administration of high doses of carbocysteine-lysine to patients with chronic bronchitis. Respiration. 1990;57(6):353-8. [pmid: 2099568].
Braga P C, Bossi R, Allegra L. Rheological modifications of mucus in chronic bronchitic patients after treatment with stepronine-lysine salt. Drugs Exp Clin Res. 1987;13(11):707-10. [pmid: 3443046].
Braga P C, Moretti M, Piacenza A, et al. Effects of seaprose on the rheology of bronchial mucus in patients with chronic bronchitis. A double-blind study vs placebo. Int J Clin Pharmacol Res. 1993;13(3):179-85. [pmid: 8225701].
Braghiroli A, Sacco C, Erbetta M, et al. Overnight urinary uric acid: creatinine ratio for detection of sleep hypoxemia. Validation study in chronic obstructive pulmonary disease and obstructive sleep apnea before and after treatment with nasal continuous positive airway pressure. Am Rev Respir Dis. 1993;148(1):173-8. [pmid: 8317794].
Braun S R, Dixon R M, Keim N L, et al. Predictive clinical value of nutritional assessment factors in COPD. Chest. 1984;85(3):353-7. [pmid: 6697791].
Braunwald E, editor. Heart disease: a textbook of cardiovascular medicine. 4th edition. Philadelphia: Saunders; 1992.
Brinkman G L, Block D L. The prognosis in chronic bronchitis. JAMA. 1966;197(1):1-7. [pmid: 5952532].
British Thoracic Society Research Committee. Oral N-acetylcysteine and exacerbation rates in patients with chronic bronchitis and severe airways obstruction. British Thoracic Society Research Committee. Thorax. 1985;40:832-5. [pmid: 2866607].
Brochard L, Isabey D, Piquet J, et al. Reversal of acute exacerbations of chronic obstructive lung disease by inspiratory assistance with a face mask. N Engl J Med. 1990;323(22):1523-30. [pmid: 2122253].
Brochard L, Mancebo J, Wysocki M, et al. Noninvasive ventilation for acute exacerbations of chronic obstructive pulmonary disease. N Engl J Med. 1995;333(13):817-22. [pmid: 7651472].
Broseghini C, Brandolese R, Poggi R, et al. Respiratory mechanics during the first day of mechanical ventilation in patients with pulmonary edema and chronic airway obstruction. Am Rev Respir Dis. 1988;138(2):355-61. [pmid: 3195835].
Brown E L, Jenkins B A. A case of respiratory failure complicated by acute hypophosphataemia. Anaesthesia. 1980;35(1):42-5. [pmid: 7396111].
Brown J S, Meecham Jones D J, Mikelsons C, et al. Using nasal intermittent positive pressure ventilation on a general respiratory ward. J R Coll Physicians Lond. 1998;32(3):219-24. [pmid: 9670147].
Bullard M J, Liaw S J, Tsai Y H, et al. Early corticosteroid use in acute exacerbations of chronic airflow obstruction. Am J Emerg Med. 1996;14:139-43. [pmid: 8924134].
Burgi W, Burgi H, Landis E. Studies on the soluble proteins of bronchial secretion in patients with chronic obstructive bronchitis during mucolytic treatment. Med Thorac. 1967;24(6):379-83. [pmid: 5595359].
Burk R H, George R B. Acute respiratory failure in chronic obstructive pulmonary disease. Immediate and long-term prognosis. Arch Intern Med. 1973;132(6):865-8. [pmid: 4757258].
Burns R, Nichols L O. Factors predicting readmission of older general medicine patients. J Gen Intern Med. 1991;6(5):389-93. [pmid: 1744751].
Burrows B, Earle R H. Prediction of survival in patients with chronic airway obstruction. Am Rev Respir Dis. 1969;99(6):865-71. [pmid: 5787601].
Buscho R O, Saxtan D, Shultz P S, et al. Infections with viruses and Mycoplasma pneumoniae during exacerbations of chronic bronchitis. J Infect Dis. 1978;137(4):377-83. [pmid: 206630].
Calandre E P, Perez de la Cruz A J, Morales A M, et al. Monitoring aminophylline therapy using Jusko's dosage guidelines. Intensive Care Med. 1983;9(2):79-81. [pmid: 6853832].
Campbell A H, O'Connell J M, Wilson F. The effect of chest physiotherapy upon the FEV_1_ in chronic bronchitis. Med J Aust. 1975;1(2):33-5. [pmid: 1128356].
Capewell S, Reynolds S, Shuttleworth D, et al. Purpura and dermal thinning associated with high dose inhaled corticosteroids. BMJ. 1990;300(6739):1548-51. [pmid: 2372620]. [pmcid: 1663083].
Carlone S, Angelici E, Palange P, et al. Effects of fenoterol on oxygen transport in patients with chronic airflow obstruction. Chest. 1988;93(4):790-4. [pmid: 3349836].
Carrey Z, Gottfried S B, Levy R D. Ventilatory muscle support in respiratory failure with nasal positive pressure ventilation. Chest. 1990;97(1):150-8. [pmid: 2403893].
Carter C J. The natural history and epidemiology of venous thrombosis. Prog Cardiovasc Dis. 1994;36(6):423-38. [pmid: 8184096].
Casali L, Rampulla C, Rossi A. Double-blind clinical trial of domiodol vs S-carboxymethylcysteine in chronic obstructive lung disease. Int J Clin Pharmacol Ther Toxicol. 1982;20(11):554-7. [pmid: 6757153].
Castiglioni C L, Gramolini C. Effect of long-term treatment with sobrerol on the exacerbations of chronic bronchitis. Respiration. 1986;50:202-17. [pmid: 3541091].
Cazzola M, Imperatore F, Salzillo A, et al. Cardiac effects of formoterol and salmeterol in patients suffering from COPD with preexisting cardiac arrhythmias and hypoxemia. Chest. 1998;114(2):411-5. [pmid: 9726723].
Celli B R. Standards for the optimal management of COPD: a summary. Chest. 1998;113(4 Suppl):283S-7S. [pmid: 9552019].
Chan C K, Loke J, Snyder P E, et al. Oral terbutaline augments cardiac performance in chronic obstructive pulmonary disease. Am J Med Sci. 1988;296(1):33-8. [pmid: 3044105].
Chan J K, Leung R C, Lai C K. Non-invasive ventilation in the management of respiratory failure. Respirology. 1997;2(3):173-8. [pmid: 9400678].
Chapman K R. The role of anticholinergic bronchodilators in adult asthma and chronic obstructive pulmonary disease. Lung. 1990;168(Suppl):295-303. [pmid: 2143551].
Chapman KR. Diagnostic dilemmas in obstructive airway disease. Hosp Pract (Off Ed) 1993;28(2A):71–8, 81–8, 91.
Charoenratanakul S, Borrirukwanit K, Lekuthai S, et al. Is driving oxygen flow rate clinically important for nebulizer therapy in patients with COPD?. J Med Assoc Thai. 1995;78(12):670-6. [pmid: 8868011].
Chevrolet J C, Jolliet P, Abajo B, et al. Nasal positive pressure ventilation in patients with acute respiratory failure. Difficult and time-consuming procedure for nurses. Chest. 1991;100(3):775-82. [pmid: 1889272].
Chopin C, Fesard P, Mangalaboyi J, et al. Use of capnography in diagnosis of pulmonary embolism during acute respiratory failure of chronic obstructive pulmonary disease [published erratum appears in Crit Care Med 1991 Mar;19(3):450–1]. Crit Care Med. 1990;18(4):353-7. [pmid: 2107999].
Ciaccia A. Pidotimod activity against chronic bronchitis exacerbations. Arzneimittelforschung. 1994;44(12A):1516-20. [pmid: 7857355].
Clini E, Vitacca M, Foglio K, et al. Long-term home care programmes may reduce hospital admissions in COPD with chronic hypercapnia. Eur Respir J. 1996;9(8):1605-10. [pmid: 8866580].
Cochrane Controlled Trials Register [database on CDROM]. 1998 Issue 4. In: The Cochrane Library. London: BMJ Publishing Group. Updated quarterly. Available from: BMJ Publishing Group, London, United Kingdom.
Condie R. An assessment in general practice of bromhexine in the treatment of chronic bronchitis. Practitioner. 1971;207(241):672-6. [pmid: 4944130].
Confalonieri M, Aiolfi S, Gandola L, et al. Severe exacerbations of chronic obstructive pulmonary disease treated with BiPAP by nasal mask. Respiration. 1994;61(6):310-6. [pmid: 7824810].
Confalonieri M, Aiolfi S, Parigi P, et al. Added BIPAP versus conventional therapy in acute respiratory failure due to exacerbation of COPD [abstract]. Am J Respir Crit Care Med. 1995;151:A838.
Confalonieri M, Gazzaniga P, Gandola L, et al. Haemodynamic response during initiation of non-invasive positive pressure ventilation in COPD patients with acute ventilatory failure. Respir Med. 1998;92(2):331-7. [pmid: 9616534].
Confalonieri M, Parigi P, Scartabellati A, et al. Noninvasive mechanical ventilation improves the immediate and long-term outcome of COPD patients with acute respiratory failure. Eur Respir J. 1996;9(3):422-30. [pmid: 8729999].
Connors A F Jr, Dawson N V, Thomas C, et al. Outcomes following acute exacerbation of severe chronic obstructive lung disease. The SUPPORT investigators (Study to Understand Prognoses and Preferences for Outcomes and Risks of Treatments). Am J Respir Crit Care Med. 1996;154(4 Pt 1):959-67. [pmid: 8887592].
Conti G, Bufi M, Rocco M, et al. Auto-PEEP and dynamic hyperinflation in COPD patients during controlled mechanical ventilation and high frequency jet ventilation. Intensive Care Med. 1990;16(2):81-4. [pmid: 2185290].
Conway J H, Hitchcock R A, Godfrey R C, et al. Nasal intermittent positive pressure ventilation in acute exacerbations of chronic obstructive pulmonary disease—a preliminary study. Respir Med. 1993;87(5):387-94. [pmid: 8209060].
Coon W W. Epidemiology of venous thromboembolism. Ann Surg. 1977;186(2):149-64. [pmid: 329779]. [pmcid: 1396699].
Corbetta L, Ballerin L, Putinati S, et al. Efficacy of noninvasive positive pressure ventilation by facial and nasal mask in hypercapnic acute respiratory failure: experience in a respiratory ward under usual care. Monaldi Arch Chest Dis. 1997;52(5):421-8. [pmid: 9510659].
Corrado A, Bruscoli G, De Paola E, et al. Respiratory muscle insufficiency in acute respiratory failure of subjects with severe COPD: treatment with intermittent negative pressure ventilation. Eur Respir J. 1990;3(6):644-8. [pmid: 2379575].
Corrado A, Bruscoli G, Messori A, et al. Iron lung treatment of subjects with COPD in acute respiratory failure. Evaluation of short- and long-term prognosis. Chest. 1992;101(3):692-6. [pmid: 1541134].
Corrado A, De Paola E, Gorini M, et al. Intermittent negative pressure ventilation in the treatment of hypoxic hypercapnic coma in chronic respiratory insufficiency. Thorax. 1996;51(11):1077-82. [pmid: 8958888].
Corrado A, De Paola E, Messori A, et al. The effect of intermittent negative pressure ventilation and long-term oxygen therapy for patients with COPD. A 4-year study. Chest. 1994;105(1):95-9. [pmid: 8275794].
Corrado A, Gorini M, Ginanni R, et al. Negative pressure ventilation versus conventional mechanical ventilation in the treatment of acute respiratory failure in COPD patients. Eur Respir J. 1998;12(3):519-25. [pmid: 9762773].
Costello R, Deegan P, Fitzpatrick M, et al. Reversible hypercapnia in chronic obstructive pulmonary disease: a distinct pattern of respiratory failure with a favorable prognosis. Am J Med. 1997;102(3):239-44. [pmid: 9217591].
Criner G J, Kreimer D T, Tomaselli M, et al. Financial implications of noninvasive positive pressure ventilation (NPPV). Chest. 1995;108(2):475-81. [pmid: 7634887].
Criner G J, Travaline J M, Brennan K J, et al. Efficacy of a new full face mask for noninvasive positive pressure ventilation. Chest. 1994;106(4):1109-15. [pmid: 7924481].
Cusack B J, Crowley J J, Mercer G D, et al. Theophylline clearance in patients with severe chronic obstructive pulmonary disease receiving supplemental oxygen and the effect of acute hypoxemia. Am Rev Respir Dis. 1986;133(6):1110-4. [pmid: 3717762].
Cydulka R K, Emerman C L. Effects of combined treatment with glycopyrrolate and albuterol in acute exacerbation of chronic obstructive pulmonary disease. Ann Emerg Med. 1995;25(4):470-3. [pmid: 7710150].
Cydulka R K, McFadden E R Jr, Emerman C L, et al. Patterns of hospitalization in elderly patients with asthma and chronic obstructive pulmonary disease. Am J Respir Crit Care Med. 1997;156(6):1807-12. [pmid: 9412559].
Dallari R, Barozzi G, Pinelli G, et al. Predictors of survival in subjects with chronic obstructive pulmonary disease treated with long-term oxygen therapy. Respiration. 1994;61(1):8-13. [pmid: 8177977].
Daly WJ. COPD. Assessing functional status. Hosp Pract (Off Ed) 1985;20(3A):73–7, 82–5, 89–93.
Dambrosio M, Cinnella G, Brienza N, et al. Effects of positive end-expiratory pressure on right ventricular function in COPD patients during acute ventilatory failure. Intensive Care Med. 1996;22(9):923-32. [pmid: 8905427].
Dardes N, Campo S, Chiappini M G, et al. Prognosis of COPD patients after an episode of acute respiratory failure. Eur J Respir Dis. 1986;146(Suppl):377-81.
Daskalopoulou E, Tsara V, Fekete K, et al. Treatment of acute respiratory failure in COPD patients with positive airway pressure via nasal mask (NPPV) [abstract]. Chest. 1993;103(3 Suppl):271S.
Davies L, Angus R M, Calverley P M A. Oral corticosteroids in patients admitted to hospital with exacerbations of chronic obstructive pulmonary disease: a prospective randomised controlled trial. Lancet. 1999;354:456-60. [pmid: 10465169].
De Castro T A, Cacanindin D V. Clinical trial on Ambroxol in acute and chronic bronchitis. Philipp J Intern Med. 1988;26(6):363-7.
de Lucas P, Tarançon C, Puente L, et al. Nasal continuous positive airway pressure in patients with COPD in acute respiratory failure. A study of the immediate effects. Chest. 1993;104(6):1694-7. [pmid: 8252944].
Dechant KL, Noble S. Erdosteine. Drugs 1996;52(6):875–81; discussion 882.
Decramer M, Lacquet L M, Fagard R, et al. Corticosteroids contribute to muscle weakness in chronic airflow obstruction. Am J Respir Crit Care Med. 1994;150(1):11-6. [pmid: 8025735].
Dejaegher P, Demedts M, Rochette F, et al. Effects of 40 mcg and 400 mcg of ipratropium bromide in obstructive lung disease. Acta Clin Belg. 1984;39(3):136-40. [pmid: 6237539].
Dev D, Wallace E, Sankaran R, et al. Value of C-reactive protein measurements in exacerbations of chronic obstructive pulmonary disease. Respir Med. 1998;92(4):664-7. [pmid: 9659534].
DeVito A J. Dyspnea during hospitalizations for acute phase of illness as recalled by patients with chronic obstructive pulmonary disease. Heart Lung J Crit Care. 1990;19(2):186-91.
Diaz O, Iglesia R, Ferrer M, et al. Effects of noninvasive ventilation on pulmonary gas exchange and hemodynamics during acute hypercapnic exacerbations of chronic obstructive pulmonary disease. Am J Respir Crit Care Med. 1997;156(6):1840-5. [pmid: 9412564].
Dickens G R, McCoy R A, West R, et al. Effect of nebulized albuterol on serum potassium and cardiac rhythm in patients with asthma or chronic obstructive pulmonary disease. Pharmacotherapy. 1994;14(6):729-33. [pmid: 7885977].
Dines D E, Clagett O T, Payne W S. Spontaneous pneumothorax in emphysema. Mayo Clin Proc. 1970;45(7):481-7. [pmid: 5434102].
Dirksen H, Hermansen F, Groth S, et al. Mucociliary clearance in early simple chronic bronchitis. Eur J Respir Dis. 1987;153(Suppl):145-9.
Dolcetti A, Osella D, De Filippis G, et al. Comparison of intravenously administered doxofylline and placebo for the treatment of severe acute airways obstruction. J Int Med Res. 1988;16:264-9. [pmid: 3169372].
Dorinsky P M, Reisner C, Ferguson G T, et al. The combination of ipatropium and albuterol optimizes pulmonary function reversibility testing in patients with COPD. Chest. 1999;115(4):966-71. [pmid: 10208193].
Dottorini M, Baglioni S, Eslami A, et al. N-CPAP in patients with COPD in acute respiratory failure. Chest. 1995;107(2):585-7. [pmid: 7842809].
Edwards G F, Steel A E, Scott J K, et al. S-carboxymethylcysteine in the fluidification of sputum and treatment of chronic airway obstruction. Chest. 1976;70(4):506-13. [pmid: 789027].
Elenbaas R M, Payne V W. Prediction of serum theophylline levels. Ann Emerg Med. 1984;13(2):92-6. [pmid: 6691624].
Eller J, Ede A, Schaberg T, et al. Infective exacerbations of chronic bronchitis: relation between bacteriologic etiology and lung function. Chest. 1998;113(6):1542-8. [pmid: 9631791].
Elliott M W, Mulvey D A, Moxham J, et al. Domiciliary nocturnal nasal intermittent positive pressure ventilation in COPD: mechanisms underlying changes in arterial blood gas tensions. Eur Respir J. 1991;4(9):1044-52. [pmid: 1756837].
Elliott M W, Mulvey D A, Moxham J, et al. Inspiratory muscle effort during nasal intermittent positive pressure ventilation in patients with chronic obstructive airways disease. Anaesthesia. 1993;48(1):8-13. [pmid: 8434761].
Elliott M W, Simonds A K. Nocturnal assisted ventilation using bilevel positive airway pressure: the effect of expiratory positive airway pressure. Eur Respir J. 1995;8(3):436-40. [pmid: 7789490].
Elliott M W, Simonds A K, Carroll M P, et al. Domiciliary nocturnal nasal intermittent positive pressure ventilation in hypercapnic respiratory failure due to chronic obstructive lung disease: effects on sleep and quality of life. Thorax. 1992;47(5):342-8. [pmid: 1609376].
Elliott M W, Steven M H, Phillips G D, et al. Non-invasive mechanical ventilation for acute respiratory failure. BMJ. 1990;300(6721):358-60. [pmid: 2106984]. [pmcid: 1662116].
Elmes P C, Fletcher C M, Dutton A A. Prophylactic use of oxytetracycline for exacerbations of chronic bronchitis. Br Med J. 1957;2:1272-5. [pmid: 13479695].
Elmes PC, King TK, Langlands JH, et al. Value of ampicillin in the hospital treatment of exacerbations of chronic bronchitis. Br Med J 1965;(5467):904–8.
EMBASE [database online]. New York (NY): Elsevier Science Secondary Publishing Division; 1974–1999. Updated weekly. Available from: Elsevier Science Secondary Publishing Division, New York, NY; DIALOG Information Services, Inc., Palo Alto, CA.
Emerman C L, Connors A F, Lukens T W, et al. Relationship between arterial blood gases and spirometry in acute exacerbations of chronic obstructive pulmonary disease. Ann Emerg Med. 1989;18(5):523-7. [pmid: 2497664].
Emerman C L, Connors A F, Lukens T W, et al. A randomized controlled trial of methylprednisolone in the emergency treatment of acute exacerbations of COPD. Chest. 1989;95(3):563-7. [pmid: 2920584].
Emerman C L, Connors A F, Lukens T W, et al. Theophylline concentrations in patients with acute exacerbation of COPD. Am J Emerg Med. 1990;8(4):289-92. [pmid: 2363749].
Emerman C L, Cydulka R K. Evaluation of high-yield criteria for chest radiography in acute exacerbation of chronic obstructive pulmonary disease. Ann Emerg Med. 1993;22(4):680-4. [pmid: 8457095].
Emerman C L, Cydulka R K. Use of peak expiratory flow rate in emergency department evaluation of acute exacerbation of chronic obstructive pulmonary disease. Ann Emerg Med. 1996;27(2):159-63. [pmid: 8629745].
Emerman C L, Cydulka R K. Effect of different albuterol dosing regimens in the treatment of acute exacerbation of chronic obstructive pulmonary disease. Ann Emerg Med. 1997;29(4):474-8. [pmid: 9095007].
Emerman C L, Devlin C, Connors A F. Risk of toxicity in patients with elevated theophylline levels. Ann Emerg Med. 1990;19(6):643-8. [pmid: 2344081].
Emerman C L, Effron D, Lukens T W. Spirometric criteria for hospital admission of patients with acute exacerbation of COPD. Chest. 1991;99(3):595-9. [pmid: 1995214].
Emerman C L, Lukens T W, Effron D. Physician estimation of FEV_1_ in acute exacerbation of COPD. Chest. 1994;105(6):1709-12. [pmid: 7911418].
Emerman C L, Woodruff P G, Cydulka R K, et al. Prospective multicenter study of relapse following treatment for acute asthma among adults presenting to the emergency department. Chest. 1999;115(4):919-27. [pmid: 10208187].
Emery C F, Schein R L, Hauck E R, et al. Psychological and cognitive outcomes of a randomized trial of exercise among patients with chronic obstructive pulmonary disease. Health Psychol. 1998;17(3):232-40. [pmid: 9619472].
Emirgil C, Sobol B J. Long-term course of chronic obstructive pulmonary disease. A new view of the mode of functional deterioration. Am J Med. 1971;51(4):504-12. [pmid: 5155771].
Erbland M L, Deupree R H, Niewoehner D E. Systemic corticosteroids in chronic obstructive pulmonary disease exacerbations (SCCOPE): rationale and design of an equivalence trial. Control Clin Trials. 1998;19(4):404-17. [pmid: 9683314].
Esteban A, Cerda E, De La Cal M A, et al. Hemodynamic effects of oxygen therapy in patients with acute exacerbations of chronic obstructive pulmonary disease. Chest. 1993;104(2):471-5. [pmid: 8339636].
Fagon J Y, Chastre J, Trouillet J L, et al. Characterization of distal bronchial microflora during acute exacerbation of chronic bronchitis. Use of the protected specimen brush technique in 54 mechanically ventilated patients. Am Rev Respir Dis. 1990;142(5):1004-8. [pmid: 2240819].
Fairshter R D. Pharmacologic management of chronic obstructive pulmonary disease. Compr Ther. 1984;10(3):12-9. [pmid: 6713810].
Fazio F, Lafortuna C L. Beclomethasone dipropionate does not affect mucociliary clearance in patients with chronic obstructive lung disease. Respiration. 1986;50(1):62-5. [pmid: 3726286].
Fear E C, Edwards G. Antibiotic regimes in chronic bronchitis. Br J Dis Chest. 1962;56:153-62. [pmid: 13944632].
Fedullo A J, Swinburne A J, McGuire-Dunn C. Complaints of breathlessness in the emergency department. The experience at a community hospital. N Y State J Med. 1986;86(1):4-6. [pmid: 3456515].
Fein A M. Lung volume reduction surgery: answering the crucial questions. Chest. 1998;113(4 Suppl):277S-82S. [pmid: 9552018].
Feldman R, Williams M H Jr. Acute ventilatory failure. New York J Med. 1963;63:3355.
Ferguson G T, Cherniack R M. Management of chronic obstructive pulmonary disease. N Engl J Med. 1993;328(14):1017-22. [pmid: 8450855].
Fernandez A, Lazaro A, Garcia A, et al. Bronchodilators in patients with chronic obstructive pulmonary disease on mechanical ventilation. Utilization of metered-dose inhalers. Am Rev Respir Dis. 1990;141(1):164-8. [pmid: 2136979].
Fernandez A, Muñoz J, de la Calle B, et al. Comparison of one versus two bronchodilators in ventilated COPD patients. Intensive Care Med. 1994;20:199-202. [pmid: 8014286].
Fernandez R, Blanch L, Valles J, et al. Pressure support ventilation via face mask in acute respiratory failure in hypercapnic COPD patients. Intensive Care Med. 1993;19(8):456-61. [pmid: 8294628].
Fiaccadori E, Coffrini E, Fracchia C, et al. Hypophosphatemia and phosphorus depletion in respiratory and peripheral muscles of patients with respiratory failure due to COPD. Chest. 1994;105(5):1392-8. [pmid: 8181325].
Finiguerra M, Conti P, Figura I, et al. Clinical study on the effects of an antibiotic and mucolytic association (amoxicillin and domiodol) in hypersecretory chronic bronchopulmonary diseases. Curr Ther Res. 1982;31(Jun Sec 1):895-905.
Foglio C, Vitacca M, Quadri A, et al. Acute exacerbations in severe COLD patients. Treatment using positive pressure ventilation by nasal mask. Chest. 1992;101(6):1533-8. [pmid: 1600770].
Foglio K, Clini E, Vitacca M. Different modes of noninvasive intermittent positive pressure ventilation (IPPV) in acute exacerbations of COLD patients. Monaldi Arch Chest Dis. 1994;49(6):556-7. [pmid: 7711716].
Folgering H, Rooyackers J. Pulmonary rehabilitation in chronic obstructive pulmonary disease. Eur Respir J. 1998;11(3):520-3. [pmid: 9596095].
Fourrier F, Chopin C, Durocher A, et al. Intravenous nitroglycerin in acute respiratory failure of patients with chronic obstructive lung disease, secondary pulmonary hypertension and cor pulmonale. Intensive Care Med. 1982;8(2):85-8. [pmid: 6804553].
France A J, Prescott R J, Biernacki W, et al. Does right ventricular function predict survival in patients with chronic obstructive lung disease?. Thorax. 1988;43(8):621-6. [pmid: 3175974].
Franco M, Mancini C. Controlled clinical study of erdosteine in chronic bronchitis patients. Archivio Di Medicina Interna. 1995;47:101-11.
Franklin C, Samuel J, Hu T C. Life-threatening hypotension associated with emergency intubation and the initiation of mechanical ventilation. Am J Emerg Med. 1994;12(4):425-8. [pmid: 8031425].
Freiberg D B, Sullivan C E, Young I H. The effect of nasal continuous positive airway pressure on intrapulmonary gas exchange in acute exacerbations of chronic obstructive pulmonary disease. Monaldi Arch Chest Dis. 1993;48(5):447-8. [pmid: 8312900].
Fried T R, Van D C, Tinetti M E, et al. Older persons' preferences for site of treatment in acute illness. J Gen Intern Med. 1998;13(8):522-7. [pmid: 9734788]. [pmcid: 1496998].
Friedman M, Serby C W, Menjoge S S, et al. Pharmacoeconomic evaluation of a combination of ipratropium plus albuterol compared with ipratropium alone and albuterol alone in COPD. Chest. 1999;115(3):635-41. [pmid: 10084468].
Fromm R E Jr, Varon J. Acute exacerbations of obstructive lung disease. What to do when immediate care is crucial. Postgrad Med. 1994;95(8):101-6. [pmid: 7911236].
Fuleihan F J, Feisal K A, Malouf N N. Effect of corticosteroids on pulmonary function in chronic bronchitis with airway obstruction. Am Rev Respir Dis. 1967;96(4):678-84. [pmid: 6057607].
Fumagalli G, Balzarotti C, Banfi P, et al. Erdosteine: a new molecule with mucolytic activity. Clinical and instrumental evaluation in patients with acute and exacerbated chronic bronchitis. Ital J Chest Dis. 1988;42:299-308.
Fuso L, Antonelli Incalzi R, Pistelli R, et al. Predicting mortality of patients hospitalized for acutely exacerbated chronic obstructive pulmonary disease. Am J Med. 1995;98(3):272-7. [pmid: 7872344].
Gacouin A, Desrues B, Lena H, et al. Long-term nasal intermittent positive pressure ventilation (NIPPV) in sixteen consecutive patients with bronchiectasis: a retrospective study. Eur Respir J. 1996;9(6):1246-50. [pmid: 8804945].
Gallefoss F, Bakke P S, Kjærsgaard P. Quality of life assessment after patient education in a randomized controlled study on asthma and chronic obstructive pulmonary disease. Am J Respir Crit Care Med. 1999;159:812-7. [pmid: 10051255].
Gay P C, Hubmayr R D, Stroetz R W. Efficacy of nocturnal nasal ventilation in stable, severe chronic obstructive pulmonary disease during a 3-month controlled trial. Mayo Clin Proc. 1996;71(6):533-42. [pmid: 8642881].
Gay P C, Patel A M, Viggiano R W, et al. Nocturnal nasal ventilation for treatment of patients with hypercapnic respiratory failure. Mayo Clin Proc. 1991;66(7):695-703. [pmid: 1906563].
Gent M, Knowlson P A, Rime F J. Effect of bromhexine on ventilatory capacity in patients with a variety of chest diseases. Lancet. 1969;2(7630):1094-6. [pmid: 4186992].
George R B, Herbert S J, Shames J M, et al. Pneumothorax complicating pulmonary emphysema. JAMA. 1975;234(4):389-93. [pmid: 1174369].
Georgopoulos D, Giannouli E, Patakas D. Effects of extrinsic positive end-expiratory pressure on mechanically ventilated patients with chronic obstructive pulmonary disease and dynamic hyperinflation. Intensive Care Med. 1993;19:197-203. [pmid: 8366227].
Georgopoulos D, Mitrouska I, Markopoulou K, et al. Effects of breathing patterns on mechanically ventilated patients with chronic obstructive pulmonary disease and dynamic hyperinflation. Intensive Care Med. 1995;21(11):880-6. [pmid: 8636519].
Geraci J M, Ashton C M, Kuykendall D H, et al. In-hospital complications among survivors of admission for congestive heart failure, chronic obstructive pulmonary disease, or diabetes mellitus. J Gen Intern Med. 1995;10(6):307-14. [pmid: 7562121].
Gerbeaux P, Boussuges A, Torro D, et al. Heliox in the treatment of obstructive hypoventilation [letter]. Am J Emerg Med. 1998;16(2):215-6. [pmid: 9517708].
Gerbert B, Stone G, Stulbarg M, et al. Agreement among physician assessment methods. Searching for the truth among fallible methods. Med Care. 1988;26(6):519-35. [pmid: 3379984].
Germouty J. Double-blind comparison of tulobuterol and salbutamol in chronic obstructive pulmonary disease. Clin Ther. 1986;8(5):546-53. [pmid: 2876775].
Geurian K, Branam C. Iodine poisoning secondary to long-term iodinated glycerol therapy. Arch Intern Med. 1994;154(10):1153-6. [pmid: 8185427].
Gibson P G, Wlodarczyk J H, Wilson A J, et al. Severe exacerbation of chronic obstructive airways disease: health resource use in general practice and hospital. J Qual Clin Pract. 1998;18(2):125-33. [pmid: 9631350].
Gift A G, Wood R M, Cahill C A. Depression, somatization and steroid use in chronic obstructive pulmonary disease. Int J Nurs Stud. 1989;26(3):281-6. [pmid: 2767912].
Gillespie D J, Marsh H M, Divertie M B, et al. Clinical outcome of respiratory failure in patients requiring prolonged (greater than 24 hours) mechanical ventilation. Chest. 1986;90(3):364-9. [pmid: 3743148].
Girault C, Chevron V, Richard J C, et al. Physiological effects and optimisation of nasal assist-control ventilation for patients with chronic obstructive pulmonary disease in respiratory failure. Thorax. 1997;52:690-6. [pmid: 9337827].
Girault C, Richard J C, Chevron V, et al. Comparative physiologic effects of noninvasive assist-control and pressure support ventilation in acute hypercapnic respiratory failure. Chest. 1997;111:1639-48. [pmid: 9187187].
Goldberg P, Reissmann H, Maltais F, et al. Efficacy of noninvasive CPAP in COPD with acute respiratory failure. Eur Respir J. 1995;8(11):1894-900. [pmid: 8620959].
Gorecka D, Gorzelak K, Sliwinski P, et al. Effect of long-term oxygen therapy on survival in patients with chronic obstructive pulmonary disease with moderate hypoxaemia. Thorax. 1997;52(8):674-9. [pmid: 9337824].
Gottlieb L S, Balchum O J. Course of chronic obstructive pulmonary disease following first onset of respiratory failure. Chest. 1973;63(1):5-8. [pmid: 4684116].
Grambau G R, Johnson C E, Conlon P F, et al. Reliability of theophylline clearance in determining maintenance intravenous aminophylline therapy. J Clin Pharmacol. 1985;25(5):381-3. [pmid: 4031115].
Gravil J H, Al-Rawas O A, Cotton M M, et al. Home treatment of exacerbations of chronic obstructive pulmonary disease by an acute respiratory assessment service. Lancet. 1998;351(9119):1853-5. [pmid: 9652670].
Groeneveld K, van Alphen L, Eijk P P, et al. Endogenous and exogenous reinfections by Haemophilus influenzae in patients with chronic obstructive pulmonary disease: the effect of antibiotic treatment on persistence. J Infect Dis. 1990;161(3):512-7. [pmid: 2313130].
Gross N J, Bankwala Z. Effects of an anticholinergic bronchodilator on arterial blood gases of hypoxemic patients with chronic obstructive pulmonary disease. Comparison with a beta-adrenergic agent. Am Rev Respir Dis. 1987;136(5):1091-4. [pmid: 3118746].
Grossbach I. The COPD patient in acute respiratory failure. Crit Care Nurse. 1994;14(6):32-8. [pmid: 7712798].
Grossman R, Mukherjee J, Vaughan D, et al. A 1-year community-based health economic study of ciprofloxacin vs usual antibiotic treatment in acute exacerbations of chronic bronchitis: the Canadian Ciprofloxacin Health Economic Study Group. Chest. 1998;113(1):131-41. [pmid: 9440580].
Grossman RF. Acute exacerbations of chronic bronchitis. Hosp Pract (Off Ed) 1997;32(10):85–9, 92–4.
Grossman R F. Guidelines for the treatment of acute exacerbations of chronic bronchitis. Chest. 1997;112(6 Suppl):310S-3S. [pmid: 9400894].
Grossman R F. The value of antibiotics and the outcomes of antibiotic therapy in exacerbations of COPD. Chest. 1998;113(4 Suppl):249S-55S. [pmid: 9552014].
Guerin C, Coussa M L, Eissa N T, et al. Lung and chest wall mechanics in mechanically ventilated COPD patients. J Appl Physiol. 1993;74(4):1570-80. [pmid: 8514671].
Guerin C, LeMasson S, de Varax R, et al. Small airway closure and positive end-expiratory pressure in mechanically ventilated patients with chronic obstructive pulmonary disease. Am J Respir Crit Care Med. 1997;155(6):1949-56. [pmid: 9196101].
Guglielmo L, Leone R, Moretti U, et al. Antibiotic prescribing patterns in Italian hospital inpatients with pneumonia, chronic obstructive pulmonary disease, and urinary tract infections. Ann Pharmacother. 1993;27(1):18-22. [pmid: 8431612].
Guite H F, Dundas R, Burney P G J. Risk factors for death from asthma, chronic obstructive pulmonary disease, and cardiovascular disease after a hospital admission for asthma. Thorax. 1999;54:301-7. [pmid: 10092690].
Gulsvik A. Mortality in and prevalence of chronic obstructive pulmonary disease in different parts of Europe. Monaldi Arch Chest Dis. 1999;54(2):160-2. [pmid: 10394832].
Gulsvik A, Refvem O K. A scoring system on respiratory symptoms. Eur Respir J. 1988;1(5):428-32. [pmid: 3169213].
Gürsel G, Türktas H, Gökçora N, et al. Comparison of sputum and serum eosinophil cationic protein (ECP) levels in nonatopic asthma and chronic obstructive pulmonary disease. J Asthma. 1997;34(4):313-9. [pmid: 9250255].
Guyatt G H, Townsend M, Kazim F, et al. A controlled trial of ambroxol in chronic bronchitis. Chest. 1987;92(4):618-20. [pmid: 3308343].
Guyatt G H, Townsend M, Nogradi S, et al. Acute response to bronchodilator. An imperfect guide for bronchodilator therapy in chronic airflow limitation. Arch Intern Med. 1988;148:1949-52. [pmid: 3046537].
Hall I P, Woodhead M A, Johnston I D. Effect of high-dose salbutamol on cardiac rhythm in severe chronic airflow obstruction: a controlled study. Respiration. 1994;61(4):214-8. [pmid: 7973107].
Hallas J, Davidsen O, Grodum E, et al. Drug-related illness as a cause of admission to a department of respiratory medicine. Respiration. 1992;59(1):30-4. [pmid: 1579716].
Haluszka J, Chartrand D A, Grassino A E, et al. Intrinsic PEEP and arterial PCO2 in stable patients with chronic obstructive pulmonary disease. Am Rev Respir Dis. 1990;141(5 Pt 1):1194-7. [pmid: 2111105].
Hansen N C G, Skriver A, Brorsen-Riis L, et al. Orally administered N-acetylcysteine may improve general well-being in patients with mild chronic bronchitis. Respir Med. 1994;88(7):531-5. [pmid: 7972979].
Hasselblad V, Eddy DM. FAST*PRO: Software for meta-analysis by the confidence profile method [computer program]. Version 1.8. Boston: Academic Press, Inc.; 1992. 1 computer disk: 3.5 in. Accompanied by: 1 guide. System Requirements: IBM PC, or compatible; 640 K RAM; graphics card (CGA, EGA, VGA, or Hercules); DOS.
Hawker F, Breen D, Torzillo P, et al. Randomized prospective trial of noninvasive positive pressure ventilation in acute respiratory failure. Am J Respir Crit Care Med. 1996;153(3):1188-9. [pmid: 8630567].
Heffner J E, Feinstein D, Barbieri C. Methodologic standards for diagnostic test research in pulmonary medicine. Chest. 1998;114(3):877-85. [pmid: 9743180].
Herala M, Stalenheim G, Boman G. Effects of positive expiratory pressure (PEP), continuous positive airway pressure (CPAP) and hyperventilation in COPD patients with chronic hypercapnea. Ups J Med Sci. 1995;100(3):223-32. [pmid: 8808185].
Herlitz J, Rosenfelt M, Bang A, et al. Prognosis among patients with out-of-hospital cardiac arrest judged as being caused by deterioration of obstructive pulmonary disease. Resuscitation. 1996;32(3):177-84. [pmid: 8923578].
Heuser M D, Case L D, Ettinger W H. Mortality in intensive care patients with respiratory disease: is age important?. Arch Intern Med. 1992;152(8):1683-8. [pmid: 1497402].
Higgins M W, Keller J B. Trends in COPD morbidity and mortality in Tecumseh, Michigan. Am Rev Respir Dis. 1989;140(3 Pt 2):S42-8. [pmid: 2782759].
Hilbert G, Gruson D, Gbikpi-Benissan G, et al. Sequential use of noninvasive pressure support ventilation for acute exacerbations of COPD. Intensive Care Med. 1997;23(9):955-61. [pmid: 9347367].
Hilbert G, Gruson D, Portel L, et al. Noninvasive pressure support ventilation in COPD patients with postextubation hypercapnic respiratory insufficiency. Eur Respir J. 1998;11(6):1349-53. [pmid: 9657578].
Hillberg R E, Johnson D C. Noninvasive ventilation. N Engl J Med. 1997;337(24):1746-52. [pmid: 9392701].
Hodgkin J E. Prognosis in chronic obstructive pulmonary disease. Clin Chest Med. 1990;11(3):555-69. [pmid: 2205443].
Hodson M E, Madden B P, Steven M H, et al. Non-invasive mechanical ventilation for cystic fibrosis patients—a potential bridge to transplantation. Eur Respir J. 1991;4(5):524-7. [pmid: 1936222].
Holleman D R Jr, Simel D L, Goldberg J S. Diagnosis of obstructive airways disease from the clinical examination. J Gen Intern Med. 1993;8(2):63-8. [pmid: 8441077].
Hopkins E J, Pye A M, Solomon M, et al. The treatment of exacerbations of chronic bronchitis in general practice. J Coll Gen Pract. 1962;5:59-64. [pmid: 14448798].
Hsu C Y, Lin C C. Oxygen therapy without respirator in chronic lung diseases complicated with acute respiratory failure. Taiwan I Hsueh Hui Tsa Chih. 1982;81(12):1530-42. [pmid: 6963339].
Hudgel D W, Martin R J, Capehart M, et al. Contribution of hypoventilation to sleep oxygen desaturation in chronic obstructive pulmonary disease. J Appl Physiol. 1983;55(3):669-77. [pmid: 6629905].
Hudson L D. Survival data in patients with acute and chronic lung disease requiring mechanical ventilation. Am Rev Respir Dis. 1989;140(2 II Suppl):S19-S24. [pmid: 2669584].
Huseby J S, Bennett S W, Hagensee M E. Hyperthyroidism induced by iodinated glycerol. Am Rev Respir Dis. 1991;144(6):1403. [pmid: 1741556].
Ikeda A, Nishimura K, Izumi T. Pharmacological treatment in acute exacerbations of chronic obstructive pulmonary disease. Drugs Aging. 1998;12(2):129-37. [pmid: 9509291].
Imsand C, Feihl F, Perret C, et al. Regulation of inspiratory neuromuscular output during synchronized intermittent mechanical ventilation. Anesthesiology. 1994;80(1):13-22. [pmid: 8291702].
Jacobs M H, Senior R M, Kessler G. Clinical experience with theophylline. Relationships between dosage, serum concentration, and toxicity. JAMA. 1976;235(18):1983-6. [pmid: 946508].
Jadad A R, Moore R A, Carroll D, et al. Assessing the quality of reports of randomized clinical trials: is blinding necessary?. Control Clin Trials. 1996;17(1):1-12. [pmid: 8721797].
Jager E G. Double-blind, placebo-controlled clinical evaluation of guaimesal in outpatients. Clin Ther. 1989;11:341-62. [pmid: 2663163].
Jeffrey A A, Warren P M, Flenley D C. Acute hypercapnic respiratory failure in patients with chronic obstructive lung disease: risk factors and use of guidelines for management. Thorax. 1992;47(1):34-40. [pmid: 1539142].
Jones D J M, Paul E A, Grahame-Clarke C, et al. Nasal ventilation in acute exacerbations of chronic obstructive pulmonary disease: effect of ventilator mode on arterial blood gas tensions. Thorax. 1994;49(12):1222-4. [pmid: 7878556].
Jones P W, Baveystock C M, Littlejohns P. Relationship between general health measured with the Sickness Impact Profile and respiratory symptoms, physiological measures, and mood in patients with chronic airflow limitation. Am Rev Respir Dis. 1989;140(6):1538-43. [pmid: 2604285].
Jones S E, Packham S, Hebden M, et al. Domiciliary nocturnal intermittent positive pressure ventilation in patients with respiratory failure due to severe COPD: long-term follow up and effect on survival. Thorax. 1998;53(6):495-8. [pmid: 9713450].
Jørgensen A F, Coolidge J, Pedersen P A, et al. Amoxicillin in treatment of acute uncomplicated exacerbations of chronic bronchitis. A double-blind, placebo-controlled multicentre study in general practice. Scand J Prim Health Care. 1992;10(1):7-11. [pmid: 1589668].
Jounieaux V, Duran A, Levi-Valensi P. Synchronized intermittent mandatory ventilation with and without pressure support ventilation in weaning patients with COPD from mechanical ventilation [published erratum appears in Chest 1994 Sep;106(3):984]. Chest. 1994;105(4):1204-10. [pmid: 8162750].
Kaelin R M, Assimacopoulos A, Chevrolet J C. Failure to predict six-month survival of patients with COPD requiring mechanical ventilation by analysis of simple indices. A prospective study. Chest. 1987;92(6):971-8. [pmid: 3677842].
Karpel J P. Bronchodilator responses to anticholinergic and beta-adrenergic agents in acute and stable COPD. Chest. 1991;99(4):871-6. [pmid: 1672634].
Karpel J P, Pesin J, Greenberg D, et al. A comparison of the effects of ipratropium bromide and metaproterenol sulfate in acute exacerbations of COPD. Chest. 1990;98(4):835-9. [pmid: 2145136].
Keenan S P, Kernerman P D, Cook D J, et al. Effect of noninvasive positive pressure ventilation on mortality in patients admitted with acute respiratory failure: a meta-analysis. Crit Care Med. 1997;25(10):1685-92. [pmid: 9377883].
Keilty S E, Ponte J, Fleming T A, et al. Effect of inspiratory pressure support on exercise tolerance and breathlessness in patients with severe stable chronic obstructive pulmonary disease. Thorax. 1994;49(10):990-4. [pmid: 7974316].
Kerstjens H A, Brand P L, Postma D S. Risk factors for accelerated decline among patients with chronic obstructive pulmonary disease. Am J Respir Crit Care Med. 1996;154(6 Pt 2):S266-72. [pmid: 8970399].
Kessler R, Faller M, Fourgaut G, et al. Predictive factors of hospitalization for acute exacerbation in a series of 64 patients with chronic obstructive pulmonary disease. Am J Respir Crit Care Med. 1999;159:158-64. [pmid: 9872834].
Kettel L J, Diener C F, Morse J O, et al. Treatment of acute respiratory acidosis in chronic obstructive lung disease. JAMA. 1971;217(11):1503-8. [pmid: 5109747].
Khokhar N. Cardiac arrhythmias associated with acute respiratory failure in chronic obstructive pulmonary disease. Mil Med. 1981;146(12):856-8. [pmid: 6799857].
Kirsten D K, Taube C, Lehnigk B, et al. Exercise training improves recovery in patients with COPD after an acute exacerbation. Respir Med. 1998;92(10):1191-8. [pmid: 9926148].
Kisch G L, Paloucek F P. Metered-dose inhalers and nebulizers in the acute setting. Ann Pharmacother. 1992;26(1):92-5. [pmid: 1351411].
Kjer J, Christensen F, Ryskjaer S, et al. Respirophonographical measurements into the effect of bromhexine in the treatment of chronic bronchitis. Curr Ther Res Clin Exp. 1971;13(7):434-43. [pmid: 5000296].
Klein G, Ruhle K H, Matthys H. Long-term oxygen therapy vs. IPPB therapy in patients with COLD and respiratory insufficiency: survival and pulmonary hemodynamics. Eur J Respir Dis. 1986;146(Suppl):409-15.
Knobl P N, Burghuber O C. Intravenous therapy of chronic obstructive pulmonary disease with sodium glycinate theophylline monitored by a new bed side theophylline assay. Acta Med Austriaca. 1992;19(4):114-7. [pmid: 1290320].
Kok-Jensen A. Simple electrocardiographic features of importance for prognosis in severe chronic bronchial obstruction. Scand J Respir Dis. 1975;56(5):273-84. [pmid: 1209201].
Krachman S L, Quaranta A J, Berger T J, et al. Effects of noninvasive positive pressure ventilation on gas exchange and sleep in COPD patients. Chest. 1997;112(3):623-8. [pmid: 9315793].
Kramer N, Meyer T J, Meharg J, et al. Randomized, prospective trial of noninvasive positive pressure ventilation in acute respiratory failure. Am J Respir Crit Care Med. 1995;151(6):1799-806. [pmid: 7767523].
Kramer N R, Fine M D, McRae R G, et al. Unusual complication of nasal CPAP: subcutaneous emphysema following facial trauma. Sleep. 1997;20(10):895-7. [pmid: 9415951].
Kuhl D A, Agiri O A, Mauro L S. Beta-agonists in the treatment of acute exacerbation of chronic obstructive pulmonary disease. Ann Pharmacother. 1994;28(12):1379-88. [pmid: 7696730].
Lal S, McGhie D, Kerfoot P. A comparison of pivmecillinam/pivampicillin and co-trimoxazole in hospitalized patients with acute exacerbations of chronic bronchitis. J Antimicrob Chemother. 1984;14(2):179-84. [pmid: 6334071].
Lamy M E, Pouthier-Simon F, Debacker-Willame E. Respiratory viral infections in hospital patients with chronic bronchitis. Observations during periods of exacerbation and quiescence. Chest. 1973;63(3):336-41. [pmid: 4347906].
Langan C, Clecner B, Cazzola C M, et al. Short-course cefuroxime axetil therapy in the treatment of acute exacerbations of chronic bronchitis. Int J Clin Pract. 1998;52(5):289-97. [pmid: 9796558].
Langlands J H. Double-blind clinical trial of bromhexine as a mucolytic drug in chronic bronchitis. Lancet. 1970;1(7644):448-50. [pmid: 4189753].
Lau A H, O'Connor T, Lam G, et al. Rapid estimation of total body clearance of theophylline in patients receiving intravenous aminophylline infusion. Int J Clin Pharmacol Ther Toxicol. 1986;24(1):12-5. [pmid: 3957483].
Leeman M, Lejeune P, Melot C, et al. Reduction in pulmonary hypertension and in airway resistances by enoximone (MDL 17,043) in decompensated COPD. Chest. 1987;91(5):662-6. [pmid: 2952467].
Leger P, Bedicam J M, Cornette A, et al. Nasal intermittent positive pressure ventilation. Long-term follow-up in patients with severe chronic respiratory insufficiency. Chest. 1994;105(1):100-5. [pmid: 8275718].
Legler F, Jansen W. [Double-blind long-term study on a combination of tetracycline, theophylline, doxylamine succinate, etafedrine, phenylephedrine and guaifenesine in chronic bronchitis (author's translation)]. Arzneimittelforschung. 1977;27:883-8. [pmid: 326265].
Lesser B A, Leeper K V Jr, Stein P D, et al. The diagnosis of acute pulmonary embolism in patients with chronic obstructive pulmonary disease. Chest. 1992;102(1):17-22. [pmid: 1623748].
Lichtenstein D, Mezière G. A lung ultrasound sign allowing bedside distinction between pulmonary edema and COPD: the comet-tail artifact. Intensive Care Med. 1998;24(12):1331-4. [pmid: 9885889].
Lien T C, Wang J H, Wu T C. Short-term effects of nasal pressure support ventilation in acute exacerbation of hypercapnic COPD. Chung Hua I Hsueh Tsa Chih (Taipei). 1996;57(5):335-42. [pmid: 8768381].
Lim S, MacRae K D, Seed W A, et al. The value of forced expiratory volume in 1 s in screening subjects with stable COPD for PaO2 < 7.3 kPa qualifying for long-term oxygen therapyA prospective study. Respir Med. 1998;92(9):1122-6. [pmid: 9926166].
Lim T K. Treatment of severe exacerbation of chronic obstructive pulmonary disease with mask-applied continuous positive airway pressure. Respirology. 1996;1(3):189-93. [pmid: 9424395].
Lim T K, Tan W C. Acute carbon dioxide narcosis during inhalational therapy with oxygen powered nebulizers in patients with chronic airflow limitation. Ann Acad Med Singapore. 1985;14(3):439-41. [pmid: 4073810].
Limauro J, Mahler D A, Olmstead E M, et al. Responses to inhaled bronchodilator in patients with acute airflow obstruction. Respir Care. 1995;40(8):815-9.
Limthongkul S, Wongthim S, Udompanich V, et al. Spontaneous pneumothorax in chronic obstructive pulmonary disease. J Med Assoc Thai. 1992;75(4):204-12. [pmid: 1402443].
Lin C C. Comparison between nocturnal nasal positive pressure ventilation combined with oxygen therapy and oxygen monotherapy in patients with severe COPD. Am J Respir Crit Care Med. 1996;154(2 Pt 1):353-8. [pmid: 8756806].
Lloberes P, Ramis L, Montserrat J M, et al. Effect of three different bronchodilators during an exacerbation of chronic obstructive pulmonary disease. Eur Respir J. 1988;1:536-9. [pmid: 2971565].
Lopez-Vidriero M T, Charman J, Keal E, et al. Sputum viscosity: correlation with chemical and clinical features in chronic bronchitis. Thorax. 1973;28(4):401-8. [pmid: 4741442].
Loukides S, Polyzogopoulos D. The effect of diabetes mellitus on the outcome of patients with chronic obstructive pulmonary disease exacerbated due to respiratory infections. Respiration. 1996;63(3):170-3. [pmid: 8739488].
MacIntyre N R. Efficacy assessment criteria based on risk and cost. Respir Care. 1995;40(9):968-70. [pmid: 10152241].
MacIntyre N R, Cheng K C, McConnell R. Applied PEEP during pressure support reduces the inspiratory threshold load of intrinsic PEEP. Chest. 1997;111(1):188-93. [pmid: 8996015].
Maesen F P, Davies B I, Brouwers J, et al. Erythromycin and bromhexine in acute exacerbations of chronic bronchitis. A study on sputum penetration and clinical effectiveness. Eur J Respir Dis. 1982;63:325-9. [pmid: 6981522].
Maestrelli P, Saetta M, Di S A, et al. Comparison of leukocyte counts in sputum, bronchial biopsies, and bronchoalveolar lavage. Am J Respir Crit Care Med. 1995;152(6 I):1926-31. [pmid: 8520757].
Maguire G P, Newman T, DeLorenzo L J, et al. Comparison of a hand-held nebulizer with a metered dose inhaler-spacer combination in acute obstructive pulmonary disease. Chest. 1991;100:1300-5. [pmid: 1935285].
Mahler D A. Pulmonary rehabilitation. Chest. 1998;113(4 Suppl):263S-8S. [pmid: 9552016].
Mahler D A, Donohue J F, Barbee R A, et al. Efficacy of salmeterol xinafoate in the treatment of COPD. Chest. 1999;115(4):957-65. [pmid: 10208192].
Malmberg L P, Hedman J, Sovijärvi A R. Accuracy and repeatability of a pocket turbine spirometer: comparison with a rolling seal flow-volume spirometer. Clin Physiol. 1993;13:89-98. [pmid: 8435980].
Maloney F P, Fernandez E, Hudgel D W. Postural drainage effect after bronchodilator inhalation in patients with chronic airway obstruction. Arch Phys Med Rehabil. 1981;62(9):452-5. [pmid: 7283688].
Mandelberg A, Chen E, Noviski N, et al. Nebulized wet aerosol treatment in emergency department—is it essential? Comparison with large spacer device for metered-dose inhaler. Chest. 1997;112:1501-5. [pmid: 9404745].
Manresa F, Blavia R, Martin R, et al. Antibiotics for exacerbations of chronic bronchitis [letter]. Lancet. 1987;2:394-5. [pmid: 2886848].
Marangoni S, Vitacca M, Quadri A, et al. Non-invasive haemodynamic effects of two nasal positive pressure ventilation modalities in stable chronic obstructive lung disease patients. Respiration. 1997;64(2):138-44. [pmid: 9097349].
Marchioni C F, Polu J M, Taytard A, et al. Evaluation of efficacy and safety of erdosteine in patients affected by chronic bronchitis during an infective exacerbation phase and receiving amoxycillin as basic treatment (ECOBES, European Chronic Obstructive Bronchitis Erdosteine Study). Int J Clin Pharmacol Ther. 1995;33(11):612-8. [pmid: 8688986].
Marino W. Intermittent volume cycled mechanical ventilation via nasal mask in patients with respiratory failure due to COPD. Chest. 1991;99(3):681-4. [pmid: 1899822].
Martin T R, Lewis S W, Albert R K. The prognosis of patients with chronic obstructive pulmonary disease after hospitalization for acute respiratory failure. Chest. 1982;82(3):310-4. [pmid: 7105857].
Mathers J A Jr, Cooper K, Glauser F. Office management of COPD. Geriatrics. 1981;36(1):103-11. [pmid: 7450501].
Matts S G. A comparative trial of bromhexine HCl and oxytetracycline in acute and chronic bronchitis. Br J Clin Pract. 1974;28:403-5. [pmid: 4617590].
Maziak W, Loukides S, Culpitt S, et al. Exhaled nitric oxide in chronic obstructive pulmonary disease. Am J Respir Crit Care Med. 1998;157(3 Pt 1):998-1002. [pmid: 9517624].
Mbuyamba P. Clinical trial with CO-1177: a preliminary report. Int J Clin Pharmacol Res. 1986;6(2):119-21. [pmid: 3522442].
McCaig L F. National Hospital Ambulatory Medical Care Survey: 1992 emergency department summary. Advance Data. 1994;245:1-12. [pmid: 10132568].
McNally E, Fitzpatrick M, Bourke S, et al. Reversible hypercapnia in acute exacerbations of chronic obstructive pulmonary disease (COPD). Eur Respir J. 1993;6(9):1353-6. [pmid: 8287954].
McNamara R M, Cionni D J. Utility of the peak expiratory flow rate in the differentiation of acute dyspnea. Cardiac vs pulmonary origin. Chest. 1992;101(1):129-32. [pmid: 1729059].
Medical Research Council Working Party. Long term domiciliary oxygen therapy in chronic hypoxic cor pulmonale complicating chronic bronchitis and emphysema. Report of the Medical Research Council Working Party. Lancet. 1981;1(8222):681-6. [pmid: 6110912].
Medici T C, von Graevenitz A, Shang H, et al. Gram stain and culture of morning and 24 h sputum in the diagnosis of bacterial exacerbation of chronic bronchitis: a dogma disputed. Eur Respir J. 1988;1:923-8. [pmid: 2465180].
MEDLINE [database online]. Bethesda (MD): National Library of Medicine; 1985-. Updated weekly. Available from: National Library of Medicine; BRS Information Technologies, McLean VA; DIALOG Information Services, Inc., Palo Alto, CA; Ovid Technologies, Inc., New York, NY.
Meduri G U. Noninvasive positive-pressure ventilation in patients with acute respiratory failure. Clin Chest Med. 1996;17(3):513-53. [pmid: 8875010].
Meduri G U, Abou-Shala N, Fox R C, et al. Noninvasive face mask mechanical ventilation in patients with acute hypercapnic respiratory failure. Chest. 1991;100(2):445-54. [pmid: 1864119].
Meduri G U, Conoscenti C C, Menashe P, et al. Noninvasive face mask ventilation in patients with acute respiratory failure. Chest. 1989;95(4):865-70. [pmid: 2924616].
Meduri G U, Fox R C, Abou-Shala N, et al. Noninvasive mechanical ventilation via face mask in patients with acute respiratory failure who refused endotracheal intubation. Crit Care Med. 1994;22(10):1584-90. [pmid: 7924369].
Meduri G U, Turner R E, Abou-Shala N, et al. Noninvasive positive pressure ventilation via face mask. First-line intervention in patients with acute hypercapnic and hypoxemic respiratory failure. Chest. 1996;109(1):179-93. [pmid: 8549183].
Meecham Jones D J, Paul E A, Grahame-Clarke C, et al. Nasal ventilation in acute exacerbations of chronic obstructive pulmonary disease: effect of ventilator mode on arterial blood gas tensions. Thorax. 1994;49(12):1222-4. [pmid: 7878556].
Meecham Jones D J, Paul E A, Jones P W, et al. Nasal pressure support ventilation plus oxygen compared with oxygen therapy alone in hypercapnic COPD. Am J Respir Crit Care Med. 1995;152(2):538-44. [pmid: 7633704].
Meecham Jones D J, Wedzicha J A. Comparison of pressure and volume preset nasal ventilator systems in stable chronic respiratory failure. Eur Respir J. 1993;6(7):1060-4. [pmid: 8370432].
Melbye H, Aasebø U, Straume B. Symptomatic effect of inhaled fenoterol in acute bronchitis: a placebo-controlled double-blind study. Fam Pract. 1991;8(3):216-22. [pmid: 1959720].
Menzies R, Gibbons W, Goldberg P. Determinants of weaning and survival among patients with COPD who require mechanical ventilation for acute respiratory failure. Chest. 1989;95(2):398-405. [pmid: 2914493].
Meyerovitz M F, Mannting F, Polak J F, et al. Frequency of pulmonary embolism in patients with low-probability lung scan and negative lower extremity venous ultrasound. Chest. 1999;115(4):980-2. [pmid: 10208195].
Mezzanotte W S, Tangel D J, Fox A M, et al. Nocturnal nasal continuous positive airway pressure in patients with chronic obstructive pulmonary disease. Influence on waking respiratory muscle function. Chest. 1994;106(4):1100-8. [pmid: 7924480].
Milvio C, Di T G, Mader R. Treatment of bronchial hypersecretion in acute and chronic bronchopneumopathies. Acta Ther. 1981;7:243-60.
Minette A. Clinical effects of mucolytics associated with bronchodilators in treating exacerbation of chronic bronchitis in coal miners. Rev Inst Hyg Mines (Hasselt). 1982;37(2):112-9. [pmid: 6129691].
Miravitlles M, Espinosa C, Fernandez-Laso E, et al. Relationship between bacterial flora in sputum and functional impairment in patients with acute exacerbations of COPD. Chest. 1999;116:40-6. [pmid: 10424501].
Miro A M, Shivaram U, Hertig I. Continuous positive airway pressure in COPD patients in acute hypercapnic respiratory failure. Chest. 1993;103(1):266-8. [pmid: 8417894].
Mishoe S C, Hooker L L, Griffith J A. Acute respiratory failure imposed on chronic lung disease. Respir Care. 1988;33(3):199-201.
Mitchell D M, Gildeh P, Dimond A H, et al. Value of serial peak expiratory flow measurements in assessing treatment response in chronic airflow limitation. Thorax. 1986;41(8):606-10. [pmid: 3538487].
Moayyedi P, Congleton J, Page R L, et al. Comparison of nebulised salbutamol and ipratropium bromide with salbutamol alone in the treatment of chronic obstructive pulmonary disease. Thorax. 1995;50(8):834-7. [pmid: 7570433].
Monsó E, Ruiz J, Rosell A, et al. Bacterial infection in chronic obstructive pulmonary disease. A study of stable and exacerbated outpatients using the protected specimen brush. Am J Respir Crit Care Med. 1995;152(4 I):1316-20. [pmid: 7551388].
Monto A S, Ross H W. The Tecumseh study of respiratory illness. X Relation of acute infections to smoking, lung function and chronic symptoms. Am J Epidemiol. 1978;107(1):57-64. [pmid: 623090].
Montserrat J M, Martos J A, Alarcon A, et al. Effect of negative pressure ventilation on arterial blood gas pressures and inspiratory muscle strength during an exacerbation of chronic obstructive lung disease. Thorax. 1991;46(1):6-8. [pmid: 1908138].
Moran J L, Green J V, Homan S D, et al. Acute exacerbations of chronic obstructive pulmonary disease and mechanical ventilation: a reevaluation. Crit Care Med. 1998;26(1):71-8. [pmid: 9428546].
Morgan E J, Petty T L. Summary of the National Mucolytic Study. Chest. 1990;97(2 Suppl):24S-7S. [pmid: 2404710].
Morice A H, Morris D, Lawson-Matthew P. A comparison of nebulized budesonide with oral prednisolone in the treatment of exacerbations of obstructive pulmonary disease. Clin Pharmacol Ther. 1996;60(6):675-8. [pmid: 8988070].
Morris R D, Munasinghe R L. Geographic variability in hospital admission rates for respiratory disease among the elderly in the United States. Chest. 1994;106(4):1172-81. [pmid: 7924492].
Morrison D, Ali N J, Routledge P A, et al. Bone turnover during short course prednisolone treatment in patients with chronic obstructive airways disease. Thorax. 1992;47(6):418-20. [pmid: 1496499].
Muir J F, Cuvelier A, Verin E, et al. Noninvasive mechanical ventilation and acute respiratory failure: indications and limitations. Monaldi Arch Chest Dis. 1997;52(1):56-9. [pmid: 9151523].
Murata G H, Gorby M S, Chick T W, et al. Use of emergency medical services by patients with decompensated obstructive lung disease. Ann Emerg Med. 1989;18(5):501-6. [pmid: 2719362].
Murata G H, Gorby M S, Chick T W, et al. Intravenous and oral corticosteroids for the prevention of relapse after treatment of decompensated COPD. Effect on patients with a history of multiple relapses. Chest. 1990;98(4):845-9. [pmid: 2209140].
Murata G H, Gorby M S, Chick T W, et al. Aminophylline in the outpatient management of decompensated chronic obstructive pulmonary disease. Chest. 1990;98(6):1346-50. [pmid: 2123149].
Murata G H, Gorby M S, Chick T W, et al. Treatment of decompensated chronic obstructive pulmonary disease in the emergency department—correlation between clinical features and prognosis. Ann Emerg Med. 1991;20(2):125-9. [pmid: 1996791].
Murata G H, Gorby M S, Kapsner C O, et al. A multivariate model for predicting hospital admissions for patients with decompensated chronic obstructive pulmonary disease. Arch Intern Med. 1992;152(1):82-6. [pmid: 1728933].
Murata G H, Gorby M S, Kapsner C O, et al. A multivariate model for the prediction of relapse after outpatient treatment of decompensated chronic obstructive pulmonary disease. Arch Intern Med. 1992;152(1):73-7. [pmid: 1728932].
Murata G H, Kapsner C O, Lium D J, et al. Time course of respiratory decompensation in chronic obstructive pulmonary disease: a prospective, double-blind study of peak flow changes prior to emergency department visits. Respir Med. 1998;92(7):936-41. [pmid: 10070567].
Murciano D, Aubier M, Lecocguic Y, et al. Effects of theophylline on diaphragmatic strength and fatigue in patients with chronic obstructive pulmonary disease. N Engl J Med. 1984;311(6):349-53. [pmid: 6738652].
Murciano D, Boczkowski J, Lecocguic Y, et al. Tracheal occlusion pressure: a simple index to monitor respiratory muscle fatigue during acute respiratory failure in patients with chronic obstructive pulmonary disease. Ann Intern Med. 1988;108(6):800-5. [pmid: 3369770].
Murphy D J, Cluff L E. SUPPORT: study to understand prognoses and preferences for outcomes and risks of treatments—study design. J Clin Epidemiol. 1990;43(Suppl.):1S-123S.
Murphy T F, Sethi S. Bacterial infection in chronic obstructive pulmonary disease. Am Rev Respir Dis. 1992;146(4):1067-83. [pmid: 1416398].
Mushlin A I, Black E R, Connolly C A, et al. The necessary length of hospital stay for chronic pulmonary disease. JAMA. 1991;266(1):80-3. [pmid: 1904506].
Music E, Erzen R. Role of host defense mechanisms in community-acquired respiratory tract infections (CARTI). Atemwegs-Lungenkr. 1997;23(7):364-7.
Muza S R, Silverman M T, Gilmore G C, et al. Comparison of scales used to quantitate the sense of effort to breathe in patients with chronic obstructive pulmonary disease. Am Rev Respir Dis. 1990;141(4 Pt 1):909-13. [pmid: 2327655].
Nakos G, Lachana A, Prekates A, et al. Respiratory effects of tracheal gas insufflation in spontaneously breathing COPD patients. Intensive Care Med. 1995;21(11):904-12. [pmid: 8636522].
National Heart, Lung, and Blood Institute. Morbidity and mortality: 1996 chartbook on cardiovascular, lung, and blood diseases. Bethesda (MD): U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health; 1996. p. 14.
Nava S. Rehabilitation of patients admitted to a respiratory intensive care unit. Arch Phys Med Rehabil. 1998;79(7):849-54. [pmid: 9685104].
Nava S, Ambrosino N, Bruschi C, et al. Physiological effects of flow and pressure triggering during non-invasive mechanical ventilation in patients with chronic obstructive pulmonary disease. Thorax. 1997;52(3):249-54. [pmid: 9093341].
Nava S, Ambrosino N, Clini E, et al. Noninvasive mechanical ventilation in the weaning of patients with respiratory failure due to chronic obstructive pulmonary disease. A randomized, controlled trial. Ann Intern Med. 1998;128(9):721-8. [pmid: 9556465].
Nava S, Bruschi C, Fracchia C, et al. Patient-ventilator interaction and inspiratory effort during pressure support ventilation in patients with different pathologies. Eur Respir J. 1997;10(1):177-83. [pmid: 9032512].
Nava S, Rubini F, Zanotti E, et al. Survival and prediction of successful ventilator weaning in COPD patients requiring mechanical ventilation for more than 21 days. Eur Respir J. 1994;7(9):1645-52. [pmid: 7995395].
Navin D M, Gross N J. Management of chronic obstructive pulmonary disease. Curr Opin Pulm Med. 1996;2(2):141-7. [pmid: 9363130].
Neill A M, Epton M J, Martin I R, et al. An audit of the assessment and management of patients admitted to Christchurch Hospital with chronic obstructive pulmonary disease. N Z Med J. 1994;107(986 Pt 1):365-7. [pmid: 7936461].
Newhouse M T, Nantel N P, Chambers C B, et al. Clickhaler (a novel dry powder inhaler) provides similar bronchodilation to pressurized metered-dose inhaler, even at low flow rates. Chest. 1999;115(4):952-6. [pmid: 10208191].
Newton D A, Bevans H G. Physiotherapy and intermittent positive-pressure ventilation of chronic bronchitis. Br Med J. 1978;2:1525-8. [pmid: 365289]. [pmcid: 1608821].
Nicholson D, Tiep B, Jones R, et al. Noninvasive positive-pressure ventilation in chronic obstructive pulmonary disease. Curr Opin Pulm Med. 1998;4(2):66-75. [pmid: 9612668].
Nicotra M B, Rivera M, Awe R J. Antibiotic therapy of acute exacerbations of chronic bronchitis. A controlled study using tetracycline. Ann Intern Med. 1982;97(1):18-21. [pmid: 7092002].
Niederman M S. Introduction: mechanisms and management of COPD: we can do better—it's time for a re-evaluation. Chest. 1998;113(4 Suppl):233S-4S. [pmid: 9552011].
Niewoehner D E, Erbland M L, Deupree R H, et al. Effect of systemic glucocorticoids on exacerbations of chronic obstructive pulmonary disease. New Engl J Med. 1999;340(25):1941-7. [pmid: 10379017].
Nimmo C J, Chen D N, Martinusen S M, et al. Assessment of patient acceptance and inhalation technique of a pressurized aerosol inhaler and two breath-actuated devices. Ann Pharmacother. 1993;27(78):922-7. [pmid: 8364279].
Nisar M, Earis J E, Pearson M G, et al. Acute bronchodilator trials in chronic obstructive pulmonary disease. Am Rev Respir Dis. 1992;146(3):555-9. [pmid: 1387772].
Nouvet G, Benmessaoud K. Comparative study of efficacy and safety of ciprofloxacin and cefixime in the treatment of acute exacerbations of chronic bronchitis after first-line treatment failure. French Study Group. Drugs. 1995;49(Suppl 2):423-5. [pmid: 8549386].
O'Connor B J, Towse L J, Barnes P J. Prolonged effect of tiotropium bromide on methacholine-induced bronchoconstriction in asthma. Am J Respir Crit Care Med. 1996;154(4 Pt 1):876-80. [pmid: 8887578].
O'Donnell D E, Sanii R, Giesbrecht G, et al. Effect of continuous positive airway pressure on respiratory sensation in patients with chronic obstructive pulmonary disease during submaximal exercise. Am Rev Respir Dis. 1988;138(5):1185-91. [pmid: 3059891].
O'Donnell D E, Sanii R, Younes M. Improvement in exercise endurance in patients with chronic airflow limitation using continuous positive airway pressure. Am Rev Respir Dis. 1988;138(6):1510-4. [pmid: 3059897].
O'Driscoll B R, Taylor R J, Horsley M G, et al. Nebulised salbutamol with and without ipratropium bromide in acute airflow obstruction. Lancet. 1989;1:1418-20. [pmid: 2567431].
O'Reilly J F, Shaylor J M, Fromings K M, et al. The use of the 12 minute walking test in assessing the effect of oral steroid therapy in patients with chronic airways obstruction. Br J Dis Chest. 1982;76(4):374-82. [pmid: 6758833].
Olivier K N, Bennett W D, Hohneker K W, et al. Acute safety and effects on mucociliary clearance of aerosolized uridine 5′-triphosphate +/• amiloride in normal human adults. Am J Respir Crit Care Med. 1996;154(1):217-23. [pmid: 8680683].
Olivieri D, Zavattini G, Tomasini G, et al. Ambroxol for the prevention of chronic bronchitis exacerbations: long-term multicenter trial. Protective effect of ambroxol against winter semester exacerbations: a double-blind study versus placebo. Respiration 1987;42–51.
Oneglia C, Lombardi G, Polotti R, et al. The risk of deep vein thrombosis in patients with exacerbation of severe chronic obstructive pulmonary disease: is heparin prophylaxis indicated?. J Cardiovasc Diagn Proc. 1998;15(3):205-8.
Osman I M, Godden D J, Friend J A, et al. Quality of life and hospital re-admission in patients with chronic obstructive pulmonary disease. Thorax. 1997;52(1):67-71. [pmid: 9039248].
Oswald-Mammosser M, Weitzenblum E, Quoix E, et al. Prognostic factors in COPD patients receiving long-term oxygen therapy. Importance of pulmonary artery pressure. Chest. 1995;107(5):1193-8. [pmid: 7750305].
Paganin F, Bouvet O, Chanez P, et al. Evaluation of the effects of ambroxol on the ofloxacin concentrations in bronchial tissues in COPD patients with infectious exacerbation. Biopharm Drug Dispos. 1995;16(5):393-401. [pmid: 8527688].
Pande J N, Jain B P, Gupta R G, et al. Effect of corticosteroids on pulmonary mechanics and blood gases in severe respiratory failure due to chronic bronchitis and emphysema. J Assoc Physicians India. 1972;20(4):277-82. [pmid: 5026515].
Parkes S N, Bersten A D, Holt A W, et al. Noninvasive assisted ventilation in hypercapnic respiratory failure. Anaesth Intensive Care. 1993;21(1):111-5. [pmid: 8447580].
Parr G D, Huitson A. Oral Fabrol (oral N-acetyl-cysteine) in chronic bronchitis. Br J Dis Chest. 1987;81:341-8. [pmid: 3329530].
Parshall M B. Adult emergency visits for chronic cardiorespiratory disease: does dyspnea matter?. Nurs Res. 1999;48(2):62-70. [pmid: 10190832].
Patrick D M, Dales R E, Stark R M, et al. Severe exacerbations of COPD and asthma. Importance of pulmonary artery pressure. Chest. 1990;98(2):295-7. [pmid: 2142915].
Peach H, Pathy M S. Follow-up study of disability among elderly patients discharged from hospital with exacerbations of chronic bronchitis. Thorax. 1981;36(8):585-9. [pmid: 7314032].
Pearlman R A. Variability in physician estimates of survival for acute respiratory failure in chronic obstructive pulmonary disease. Chest. 1987;91(4):515-21. [pmid: 3829743].
Pela R, Marchesani F, Agostinelli C, et al. Airways microbial flora in COPD patients in stable clinical conditions and during exacerbations: a bronchoscopic investigation. Monaldi Arch Chest Dis. 1998;53(3):262-7. [pmid: 9785808].
Pennock B E, Crawshaw L, Kaplan P D. Noninvasive nasal mask ventilation for acute respiratory failure. Institution of a new therapeutic technology for routine use. Chest. 1994;105(2):441-4. [pmid: 8306743].
Pennock B E, Kaplan P D, Carlin B W, et al. Pressure support ventilation with a simplified ventilatory support system administered with a nasal mask in patients with respiratory failure. Chest. 1991;100(5):1371-6. [pmid: 1935296].
Peralta J, Poderoso J J, Corazza C, et al. Ambroxol plus amoxicillin in the treatment of exacerbations of chronic bronchitis. Arzneimittelforschung. 1987;37:969-71. [pmid: 3675696].
Perri G, Giovannini M, Spada E. Salbutamol plus beclomethasone dipropionate (Ventolin Flogo) vs fenoterol (Dosberotec) in chronic obstructive lung disease therapeutic strategy: a 4-week clinical trial. Int J Clin Pharmacol Ther Toxicol. 1985;23(5):274-8. [pmid: 3891642].
Perrin C, El Far Y, Vandenbos F, et al. Domiciliary nasal intermittent positive pressure ventilation in severe COPD: effects on lung function and quality of life. Eur Respir J. 1997;10(12):2835-9. [pmid: 9493670].
Perry R J, Man G C, Jones R L. Effects of positive end-expiratory pressure on oscillated flow rate during high-frequency chest compression. Chest. 1998;113(4):1028-33. [pmid: 9554642].
Petersen E S, Esmann V, Høncke P, et al. A controlled study of the effect of treatment on chronic bronchitis. An evaluation using pulmonary function tests. Acta Med Scand. 1967;182(3):293-305. [pmid: 6069924].
Peto R, Speizer F E, Cochrane A L, et al. The relevance in adults of air-flow obstruction, but not of mucus hypersecretion, to mortality from chronic lung disease. Results from 20 years of prospective observation. Am Rev Respir Dis. 1983;128(3):491-500. [pmid: 6614643].
Petrof B J, Calderini E, Gottfried S B. Effect of CPAP on respiratory effort and dyspnea during exercise in severe COPD. J Appl Physiol. 1990;69(1):179-88. [pmid: 2203722].
Petrof B J, Kimoff R J, Levy R D, et al. Nasal continuous positive airway pressure facilitates respiratory muscle function during sleep in severe chronic obstructive pulmonary disease. Am Rev Respir Dis. 1991;143(5 Pt 1):928-35. [pmid: 2024845].
Petty T L. Pharmacotherapy for chronic obstructive pulmonary disease. Postgrad Med. 1986;80(2):56-66. [pmid: 3526310].
Petty T L. The National Mucolytic Study. Results of a randomized, double-blind, placebo-controlled study of iodinated glycerol in chronic obstructive bronchitis. Chest. 1990;97:75-83. [pmid: 2403903].
Petty T L. Supportive therapy in COPD. Chest. 1998;113(4 Suppl):256S-62S. [pmid: 9552015].
Petty T L, Weinmann G G. Building a national strategy for the prevention and management of and research in chronic obstructive pulmonary disease. National Heart, Lung, and Blood Institute Workshop Summary. Bethesda, Maryland, August 29–31, 1995. JAMA. 1997;277(3):246-53. [pmid: 9005275].
Phelan M C. Beclomethasone mania. Br J Psychiatry. 1989;155:871-2. [pmid: 2620226].
Piccioni P, Caria E, Bignamini E, et al. Predictors of survival in a group of patients with chronic airflow obstruction. J Clin Epidemiol. 1998;51(7):547-55. [pmid: 9674661].
Pines A, Raafat H, Greenfield J S, et al. Antibiotic regimens in moderately ill patients with purulent exacerbations of chronic bronchitis. Br J Dis Chest. 1972;66(2):107-15. [pmid: 4556292].
Pines A, Raafat H, Plucinski K, et al. Antibiotic regimens in severe and acute purulent exacerbations of chronic bronchitis. Br Med J. 1968;2:735-8. [pmid: 4872151].
Ploysongsang Y, Rashkin M C, Ranganathan V H. Serial physiologic studies of a chronic obstructive pulmonary disease patient in acute respiratory failure: clues for weaning?. Respiration. 1990;57(2):122-6. [pmid: 2236932].
Polito A, Fessler H. Heliox in respiratory failure from obstructive lung disease [letter]. N Engl J Med. 1995;332(3):192-3. [pmid: 7800021].
Polkey M I, Kyroussis D, Mills G H, et al. Inspiratory pressure support reduces slowing of inspiratory muscle relaxation rate during exhaustive treadmill walking in severe COPD. Am J Respir Crit Care Med. 1996;154(4 Pt 1):1146-50. [pmid: 8887619].
Pollack C V Jr, Fleisch K B, Dowsey K. Treatment of acute bronchospasm with beta-adrenergic agonist aerosols delivered by a nasal bilevel positive airway pressure circuit. Ann Emerg Med. 1995;26(5):552-7. [pmid: 7486361].
Pollack C V Jr, Torres M T, Alexander L. Feasibility study of the use of bilevel positive airway pressure for respiratory support in the emergency department. Ann Emerg Med. 1996;27(2):189-92. [pmid: 8629750].
Poole P J, Bagg B, Brodie S M, et al. Characteristics of patients admitted to hospital with chronic obstructive pulmonary disease. N Z Med J. 1997;1101048:272-5. [pmid: 9269290].
Poponick J M, Renston J P, Emerman C L. Successful use of nasal BiPAP in three patients previously requiring intubation and mechanical ventilation. J Emerg Med. 1997;15(6):785-8. [pmid: 9404794].
Portier F, Defouilloy C, Muir J F. Determinants of immediate survival among chronic respiratory insufficiency patients admitted to an intensive care unit for acute respiratory failure. A prospective multicenter study. The French Task Group for Acute Respiratory Failure in Chronic Respiratory insufficiency. Chest. 1992;101(1):204-10. [pmid: 1729072].
Postma D S, Burema J, Gimeno F, et al. Prognosis in severe chronic obstructive pulmonary disease. Am Rev Respir Dis. 1979;119(3):357-67. [pmid: 443616].
Postma D S, Sluiter H J. Prognosis of chronic obstructive pulmonary disease: the Dutch experience. Am Rev Respir Dis. 1989;140(3 Pt 2):S100-5. [pmid: 2782755].
Powell J R, Vozeh S, Hopewell P, et al. Theophylline disposition in acutely ill hospitalized patients. The effect of smoking, heart failure, severe airway obstruction, and pneumonia. Am Rev Respir Dis. 1978;118(2):229-38. [pmid: 697173].
Pras E, Stienlauf S, Pinkhas J, et al. Urinary retention associated with ipratropium bromide. DICP. 1991;25(9):939-40. [pmid: 1835224].
Prescott E, Bjerg A M, Andersen P K, et al. Gender difference in smoking effects on lung function and risk of hospitalization for COPD: results from a Danish longitudinal population study. Eur Respir J. 1997;10(4):822-7. [pmid: 9150319].
Prescott S M, Richards K L, Tikoff G, et al. Venous thromboembolism in decompensated chronic obstructive pulmonary disease. A prospective study. Am Rev Respir Dis. 1981;123(1):32-6. [pmid: 7458085].
Primbs K. Therapeutic activity of ambroxol theophyllinacetate in chronic obstructive pulmonary diseases. Clin Ther. 1985;7(6):733-6. [pmid: 4075364].
Rahman I, Skwarska E, MacNee W. Attenuation of oxidant/antioxidant imbalance during treatment of exacerbations of chronic obstructive pulmonary disease. Thorax. 1997;52(6):565-8. [pmid: 9227727].
Ramsdell J. Use of theophylline in the treatment of COPD. Chest. 1995;107(5 Suppl):206S-9S. [pmid: 7743828].
Ramsdell J W, Klinger N M, Ekholm B P, et al. Safety of long-term treatment with HFA albuterol. Chest. 1999;115(4):945-51. [pmid: 10208190].
Ramsdell J W, Nachtwey F J, Moser K M. Bronchial hyperreactivity in chronic obstructive bronchitis. Am Rev Respir Dis. 1982;126(5):829-32. [pmid: 7149448].
Ranieri V M, Giuliani R, Cinnella G, et al. Physiologic effects of positive end-expiratory pressure in patients with chronic obstructive pulmonary disease during acute ventilatory failure and controlled mechanical ventilation. Am Rev Respir Dis. 1993;147(1):5-13. [pmid: 8420430].
Ranieri V M, Grasso S, Mascia L, et al. Effects of proportional assist ventilation on inspiratory muscle effort in patients with chronic obstructive pulmonary disease and acute respiratory failure. Anesthesiology. 1997;86(1):79-91. [pmid: 9009943].
Rasmussen J B, Glennow C. Reduction in days of illness after long-term treatment with N-acetylcysteine controlled-release tablets in patients with chronic bronchitis. Eur Respir J. 1988;1:351-5. [pmid: 3294038].
Rebuck A S, Chapman K R, Abboud R, et al. Nebulized anticholinergic and sympathomimetic treatment of asthma and chronic obstructive airways disease in the emergency room. Am J Med. 1987;82(1):59-64. [pmid: 2879458].
Redelmeier D A, Goldstein R S, Min S T, et al. Spirometry and dyspnea in patients with COPD. When small differences mean little. Chest. 1996;109(5):1163-8. [pmid: 8625661].
Regueiro C R, Hamel M B, Davis R B, et al. A comparison of generalist and pulmonologist care for patients hospitalized with severe chronic obstructive pulmonary disease: resource intensity, hospital costs, and survival. Am J Med. 1998;105(5):366-72. [pmid: 9831419].
Rennard S I. COPD: overview of definitions, epidemiology, and factors influencing its development. Chest. 1998;113(4 Suppl):235S-41S. [pmid: 9552012].
Renston J P, DiMarco A F, Supinski G S. Respiratory muscle rest using nasal BiPAP ventilation in patients with stable severe COPD. Chest. 1994;105(4):1053-60. [pmid: 8162724].
Restrick L J, Fox N C, Braid G, et al. Comparison of nasal pressure support ventilation with nasal intermittent positive pressure ventilation in patients with nocturnal hypoventilation. Eur Respir J. 1993;6(3):364-70. [pmid: 8472827].
Restrick L J, Scott A D, Ward E M, et al. Nasal intermittent positive-pressure ventilation in weaning intubated patients with chronic respiratory disease from assisted intermittent, positive-pressure ventilation. Respir Med. 1993;87(3):199-204. [pmid: 8497699].
Rice K L, Leatherman J W, Duane P G, et al. Aminophylline for acute exacerbations of chronic obstructive pulmonary disease. A controlled trial. Ann Intern Med. 1987;107:305-9. [pmid: 3619219].
Ricevuti G, Mazzone A, Uccelli E, et al. Influence of erdosteine, a mucolytic agent, on amoxycillin penetration into sputum in patients with an infective exacerbation of chronic bronchitis. Thorax. 1988;43:585-90. [pmid: 3051508].
Riddington C J, Shipman A J. The use of sustained-release theophylline (‘Theo-dur’) for the treatment of chronic reversible obstructive lung disease in hospital practice. Br J Clin Pract. 1985;39(4):148-53. [pmid: 3893504].
Rieves R D, Bass D, Carter R R, et al. Severe COPD and acute respiratory failure Correlates for survival at the time of tracheal intubation. Chest. 1993;104(3):854-60. [pmid: 8365300].
Riise G C, Larsson S, Larsson P, et al. The intrabronchial microbial flora in chronic bronchitis patients: a target for N-acetylcysteine therapy?. Eur Respir J. 1994;7(1):94-101. [pmid: 8143838].
Rizzo A, Mirabella A, Ferrara G, et al. Theophylline pharmacokinetics in patients with mild or severe airway obstruction. Bull Eur Physiopathol Respir. 1982;18(6):811-8. [pmid: 6927536].
Roberts C M, Bugler J R, Melchor R, et al. Value of pulse oximetry in screening for long-term oxygen therapy requirement. Eur Respir J. 1993;6(4):559-62. [pmid: 8491308].
Roessingh P H, Van L A M, Lammers J W J, et al. Viral and atypical pathogens as causes of type 1 acute exacerbations of chronic bronchitis. Clin Microbiol Infect. 1997;3(5):513-4. [pmid: 11864173].
Rossi A, Santos C, Roca J, et al. Effects of PEEP on VA/Q mismatching in ventilated patients with chronic airflow obstruction. Am J Respir Crit Care Med. 1994;149(5):1077-84. [pmid: 8173744].
Rubini F, Rampulla C, Nava S. Acute effect of corticosteroids on respiratory mechanics in mechanically ventilated patients with chronic airflow obstruction and acute respiratory failure. Am J Respir Crit Care Med. 1994;149(2 Pt 1):306-10. [pmid: 8306023].
Rutter B M. The prognostic significance of psychological factors in the management of chronic bronchitis. Psychol Med. 1979;9(1):63-70. [pmid: 424490].
Ruzkowski C J, Sanowski R A, Austin J, et al. The effects of inhaled albuterol and oral theophylline on gastroesophageal reflux in patients with gastroesophageal reflux disease and obstructive lung disease. Arch Intern Med. 1992;152(4):783-5. [pmid: 1558436].
Sacchetti A D, Harris R H, Paston C, et al. Bi-level positive airway pressure support system use in acute congestive heart failure: preliminary case series. Acad Emerg Med. 1995;2(8):714-8. [pmid: 7584750].
Sachs A P, Koëter G H, Groenier K H, et al. Changes in symptoms, peak expiratory flow, and sputum flora during treatment with antibiotics of exacerbations in patients with chronic obstructive pulmonary disease in general practice. Thorax. 1995;50(7):758-63. [pmid: 7570411].
Sackett DL, Haynes RB, Tugwell P. Clinical epidemiology: a basic science for clinical medicine. Boston/Toronto: Little, Brown and Company; 1985.
Saetta M, Di Stefano A, Maestrelli P, et al. Airway eosinophilia and expression of interleukin-5 protein in asthma and in exacerbations of chronic bronchitis. Clin Exp Allergy. 1996;26(7):766-74. [pmid: 8842549].
Sahn S A, Nett L M, Petty T L. Ten year follow-up of a comprehensive rehabilitation program for severe COPD. Chest. 1980;77(2 Suppl):311-4. [pmid: 7357926].
Saint S, Bent S, Vittinghoff E, et al. Antibiotics in chronic obstructive pulmonary disease exacerbations. A meta-analysis. JAMA. 1995;273(12):957-60. [pmid: 7884956].
Sampol G, Sagales M T, Roca A, et al. Nasal continuous positive airway pressure with supplemental oxygen in coexistent sleep apnoea-hypopnoea syndrome and severe chronic obstructive pulmonary disease. Eur Respir J. 1996;9(1):111-6. [pmid: 8834343].
Sassoon C S, Lodia R, Rheeman C H, et al. Inspiratory muscle work of breathing during flow-by, demand-flow, and continuous-flow systems in patients with chronic obstructive pulmonary disease. Am Rev Respir Dis. 1992;145(5):1219-22. [pmid: 1586070].
Saudny-Unterberger H, Martin J G, Gray-Donald K. Impact of nutritional support on functional status during an acute exacerbation of chronic obstructive pulmonary disease. Am J Respir Crit Care Med. 1997;156(3 Pt 1):794-9. [pmid: 9309995].
Sauret J M, Guitart A C, Rodriguez-Frojan G, et al. Intermittent short-term negative pressure ventilation and increased oxygenation in COPD patients with severe hypercapnic respiratory failure. Chest. 1991;100(2):455-9. [pmid: 1907538].
Scarlett M D, Hanna W J. Nasal non-invasive positive pressure ventilation. A new method of ventilatory support for patients with chronic respiratory failure. West Indian Med J. 1994;43(4):143-5. [pmid: 7900380].
Schaberg T, Gialdroni-Grassi G, Huchon G, et al. An analysis of decisions by European general practitioners to admit to hospital patients with lower respiratory tract infections. Thorax. 1996;51(10):1017-22. [pmid: 8977603].
Schentag J J, Tillotson G S. Antibiotic selection and dosing for the treatment of acute exacerbations of COPD. Chest. 1997;112(6 Suppl):314S-9S. [pmid: 9400895].
Schönhofer B, Köhler D. Prevalence of deep-vein thrombosis of the leg in patients with acute exacerbation of chronic obstructive pulmonary disease. Respiration. 1998;65(3):173-7. [pmid: 9670296].
Scoggin C H. Aerosolized terbutaline sulfate in the treatment of bronchospasm. Clin Ther. 1984;6(5):603-12. [pmid: 6434183].
Seemungal T A, Donaldson G C, Paul E A, et al. Effect of exacerbation on quality of life in patients with chronic obstructive pulmonary disease. Am J Respir Crit Care Med. 1998;157(5 Pt 1):1418-22. [pmid: 9603117].
Seidenfeld J J, Jones W N, Moss R E, et al. Intravenous aminophylline in the treatment of acute bronchospastic exacerbations of chronic obstructive pulmonary disease. Ann Emerg Med. 1984;13:248-52. [pmid: 6367554].
Seneff M G, Wagner D P, Wagner R P, et al. Hospital and 1-year survival of patients admitted to intensive care units with acute exacerbation of chronic obstructive pulmonary disease. JAMA. 1995;274(23):1852-7. [pmid: 7500534].
Servera E, Peréz M, Marín J, et al. Noninvasive nasal mask ventilation beyond the ICU for an exacerbation of chronic respiratory insufficiency. Chest. 1995;108(6):1572-6. [pmid: 7497763].
Sherman S, Skoney J A, Ravikrishnan K P. Routine chest radiographs in exacerbations of chronic obstructive pulmonary disease. Diagnostic value. Arch Intern Med. 1989;149(11):2493-6. [pmid: 2818109].
Shields T W, Oilschlager G A. Spontaneous pneumothorax in patients 40 years of age and older. Ann Thorac Surg. 1966;2(3):377-83. [pmid: 5954470].
Shindo K, Hirai Y, Fukumura M, et al. Plasma levels of leukotriene E4 during clinical course of chronic obstructive pulmonary disease. Prostaglandins Leukot Essent Fatty Acids. 1997;56(3):213-7. [pmid: 9089801].
Shrestha M, O'Brien T, Haddox R, et al. Decreased duration of emergency department treatment of chronic obstructive pulmonary disease exacerbations with the addition of ipratropium bromide to beta-agonist therapy. Ann Emerg Med. 1991;20(11):1206-9. [pmid: 1835324].
Siafakas N M, Vermeire P, Pride N B, et al. Optimal assessment and management of chronic obstructive pulmonary disease (COPD). The European Respiratory Society Task Force. Eur Respir J. 1995;8(8):1398-420. [pmid: 7489808].
Simonds A K, Elliott M W. Outcome of domiciliary nasal intermittent positive pressure ventilation in restrictive and obstructive disorders. Thorax. 1995;50(6):604-9. [pmid: 7638799].
Sivasothy P, Smith I E, Shneerson J M. Mask intermittent positive pressure ventilation in chronic hypercapnic respiratory failure due to chronic obstructive pulmonary disease. Eur Respir J. 1998;11(1):34-40. [pmid: 9543267].
Skorodin M S, Tenholder M F, Yetter B, et al. Magnesium sulfate in exacerbations of chronic obstructive pulmonary disease. Arch Intern Med. 1995;155(5):496-500. [pmid: 7864705].
Slovis C M, Daniels G M, Wharton D R. Intravenous use of glycopyrrolate in acute respiratory distress due to bronchospastic pulmonary disease. Ann Emerg Med. 1987;16(8):898-900. [pmid: 3619169].
Sluiter H J, Blokzijl E J, van Dijl W, et al. Conservative and respirator treatment of acute respiratory insufficiency in patients with chronic obstructive lung disease. A reappraisal. Am Rev Respir Dis. 1972;105(6):932-43. [pmid: 4503863].
Smith R, Ellis K, Alderson P O. Role of chest radiography in predicting the extent of airway disease in patients with suspected pulmonary embolism. Radiology. 1986;159(2):391-4. [pmid: 3961171].
Smurthwaite G J, Ford P. Skin necrosis following continuous positive airway pressure with a face mask. Anaesthesia. 1993;48(2):147-8. [pmid: 8460763].
Snell J D Jr. Treatment of acute respiratory failure in chronic obstructive pulmonary disease: results without a special respiratory care unit. South Med J. 1973;66(1):153-8. [pmid: 4509620].
Soguel Schenkel N, Burdet L, de Muralt B, et al. Oxygen saturation during daily activities in chronic obstructive pulmonary disease. Eur Respir J. 1996;9(12):2584-9. [pmid: 8980973].
Soler N, Torres A, Ewig S, et al. Bronchial microbial patterns in severe exacerbations of chronic obstructive pulmonary disease (COPD) requiring mechanical ventilation. Am J Respir Crit Care Med. 1998;157(5 Pt 1):1498-505. [pmid: 9603129].
Soo Hoo G W, Santiago S, Williams A J. Nasal mechanical ventilation for hypercapnic respiratory failure in chronic obstructive pulmonary disease: determinants of success and failure. Crit Care Med. 1994;22(8):1253-61. [pmid: 8045145].
Staley H, McDade H B, Paes D. Is an objective assessment of antibiotic therapy in exacerbations of chronic bronchitis possible?. J Antimicrob Chemother. 1993;31(2):193-7. [pmid: 8463165].
Stauffer J L, Fayter N A, Graves B, et al. Survival following mechanical ventilation for acute respiratory failure in adult men. Chest. 1993;104(4):1222-9. [pmid: 8404197].
Steventon R D, Wilson R S. Facemask or mouthpiece for delivery of nebulized bronchodilator aerosols?. Br J Dis Chest. 1981;75(1):88-90. [pmid: 7259970].
Strom K. Survival of patients with chronic obstructive pulmonary disease receiving long-term domiciliary oxygen therapy. Am Rev Respir Dis. 1993;147(3):585-91. [pmid: 8442591].
Strumpf D A, Millman R P, Carlisle C C, et al. Nocturnal positive-pressure ventilation via nasal mask in patients with severe chronic obstructive pulmonary disease. Am Rev Respir Dis. 1991;144(6):1234-9. [pmid: 1741532].
Sue D Y, Oren A, Hansen J E, et al. Diffusing capacity for carbon monoxide as a predictor of gas exchange during exercise. N Engl J Med. 1987;316(21):1301-6. [pmid: 3574401].
Sukumalchantra Y, Dinakara P, Williams M H Jr. Prognosis of patients with chronic obstructive pulmonary disease after hospitalization for acute ventilatory failure: a three-year follow-up study. Am Rev Respir Dis. 1966;93(2):215-22. [pmid: 5908086].
Swinburn C R, Wakefield J M, Newman S P, et al. Evidence of prednisolone induced mood change (‘steroid euphoria’) in patients with chronic obstructive airways disease. Br J Clin Pharmacol. 1988;26(6):709-13. [pmid: 3242575].
Swinburne A J, Fedullo A J, Shayne D S. Mechanical ventilation: analysis of increasing use and patient survival. J Intensive Care Med. 1988;3(6):315-20.
Tan I K, Bhatt S B, Tam Y H, et al. Effects of PEEP on dynamic hyperinflation in patients with airflow limitation. Br J Anaesth. 1993;70(3):267-72. [pmid: 8471367].
Tandon M K, Gebski V. A controlled trial of a killed Haemophilus influenzae vaccine for prevention of acute exacerbations of chronic bronchitis. Aust N Z J Med. 1991;21(4):427-32. [pmid: 1953532].
Taylor D C, Clancy R L, Cripps A W, et al. An alteration in the host-parasite relationship in subjects with chronic bronchitis prone to recurrent episodes of acute bronchitis. Immunol Cell Biol. 1994;72(2):143-51. [pmid: 8200689].
Taylor D C, Cripps A W, Clancy R L. A possible role for lysozyme in determining acute exacerbation in chronic bronchitis. Clin Exp Immunol. 1995;102(2):406-16. [pmid: 7586699]. [pmcid: 1553411].
Taylor D C, Cripps A W, Clancy R L, et al. Biotypes of Haemophilus parainfluenzae from the respiratory secretions in chronic bronchitis. J Med Microbiol. 1992;36(4):279-82. [pmid: 1560450].
Teculescu D B, Racoveanu C, Manicatide M A. Relationships of carbon dioxide retention to ventilatory impairment and hypoxemia in chronic obstructive lung disease. Respiration. 1979;38(2):81-7. [pmid: 515533].
The COMBIVENT Inhalation Solution Study Group. Routine nebulized ipratropium and albuterol together are better than either alone in COPD. The COMBIVENT Inhalation Solution Study Group. Chest. 1997;112(6):1514-21. [pmid: 9404747].
The COPD Guidelines Group of the Standards of Care Committee of the BTS. BTS guidelines for the management of chronic obstructive pulmonary disease. Thorax. 1997;52(Suppl 5):S1-28.
The National Lung Health Education Program (NLHEP). Strategies in preserving lung health and preventing COPD and associated diseases. Chest. 1998;113(2 Suppl):123S-63S. [pmid: 9484245].
Thompson W H, Nielson C P, Carvalho P, et al. Controlled trial of oral prednisone in outpatients with acute COPD exacerbation. Am J Respir Crit Care Med. 1996;154(2 Pt 1):407-12. [pmid: 8756814].
Thorens J B, Kaelin R M, Jolliet P, et al. Influence of the quality of nursing on the duration of weaning from mechanical ventilation in patients with chronic obstructive pulmonary disease. Crit Care Med. 1995;23(11):1807-15. [pmid: 7587255].
Tiep B L. Disease management of COPD with pulmonary rehabilitation. Chest. 1997;112(6):1630-56. [pmid: 9404764].
Tognet E, Mercatello A, Polo P, et al. Treatment of acute respiratory failure with noninvasive intermittent positive-pressure ventilation in hematological patients. Clin Intens Care. 1994;5:282-8.
Trulock E P. Lung Transplantation for COPD. Chest. 1998;113(4 Suppl):269S-76S. [pmid: 9552017].
Tsai T W, Gallagher E J, Lombardi G, et al. Guidelines for the selective ordering of admission chest radiography in adult obstructive airway disease. Ann Emerg Med. 1993;22(12):1854-8. [pmid: 8239107].
Turner J R, Corkery K J, Eckman D, et al. Equivalence of continuous flow nebulizer and metered-dose inhaler with reservoir bag for treatment of acute airflow obstruction. Chest. 1988;93(3):476-81. [pmid: 3342656].
Turner M O, Patel A, Ginsburg S, et al. Bronchodilator delivery in acute airflow obstruction. A meta-analysis. Arch Intern Med. 1997;157(15):1736-44. [pmid: 9250235].
U.S. Department of Commerce, Bureau of the Census. Statistical Abstract of the United States 1997. Washington (DC): Department of Commerce; 1997.
U.S. Department of Health and Human Services. Health consequences of involuntary smoking: a report of the Surgeon General. Washington (DC): U.S. Government Printing Office; 1986. DHHS Publication No. (CDC) 87-8392.
Van Andel A E, Reisner C, Menjoge S S, et al. Analysis of inhaled corticosteroid and oral theophylline use among patients with stable COPD from 1987 to 1995. Chest. 1999;115(3):703-7. [pmid: 10084479].
van Balkom R H, van der Heijden H F, van Herwaarden C L, et al. Corticosteroid-induced myopathy of the respiratory muscles. Neth J Med. 1994;45(3):114-22. [pmid: 7969664].
van den Berg B, Aerts J G, Bogaard J M. Effect of continuous positive airway pressure (CPAP) in patients with chronic obstructive pulmonary disease (COPD) depending on intrinsic PEEP levels. Acta Anaesthesiol Scand. 1995;39(8):1097-102. [pmid: 8607317].
van den Berg B, Stam H, Bogaard J M. Effects of PEEP on respiratory mechanics in patients with COPD on mechanical ventilation. Eur Respir J. 1991;4(5):561-7. [pmid: 1936227].
van Hengstum M, Festen J, Beurskens C, et al. No effect of oral high frequency oscillation combined with forced expiration manoeuvres on tracheobronchial clearance in chronic bronchitis. Eur Respir J. 1990;3(1):14-8. [pmid: 2311725].
van Hengstum M, Festen J, Beurskens C, et al. Effect of positive expiratory pressure mask physiotherapy (PEP) versus forced expiration technique (FET/PD) on regional lung clearance in chronic bronchitics. Eur Respir J. 1991;4(6):651-4. [pmid: 1653711].
van Schayck C P, Folgering H, Harbers H, et al. Effects of allergy and age on responses to salbutamol and ipratropium bromide in moderate asthma and chronic bronchitis. Thorax. 1991;46:355-9. [pmid: 1829865].
Vaughan T R, Weber R W, Tipton W R, et al. Comparison of PEFR and FEV_1_ in patients with varying degrees of airway obstruction Effect of modest altitude. Chest. 1989;95(3):558-62. [pmid: 2920583].
Venge P, Pedersen B, Hakansson L, et al. Subcutaneous administration of hyaluronan reduces the number of infectious exacerbations in patients with chronic bronchitis. Am J Respir Crit Care Med. 1996;153(1):312-6. [pmid: 8542136].
Vestbo J, Knudsen K M, Rasmussen F V. The value of mucus hypersecretion as a predictor of mortality and hospitalization. An 11-year register based follow-up study of a random population sample of 876 men. Respir Med. 1989;83(3):207-11. [pmid: 2595038].
Vestbo J, Knudsen K M, Rasmussen F V. Predictive value of the single-breath nitrogen test for hospitalization due to respiratory disease. Lung. 1990;168(2):93-101. [pmid: 2110604].
Vestbo J, Rasmussen F V. Respiratory symptoms and FEV_1_ as predictors of hospitalization and medication in the following 12 years due to respiratory disease. Eur Respir J. 1989;2(8):710-5. [pmid: 2806492].
Vitacca M, Clini E, Bianchi L, et al. Acute effects of deep diaphragmatic breathing in COPD patients with chronic respiratory insufficiency. Eur Respir J. 1998;11(2):408-15. [pmid: 9551746].
Vitacca M, Clini E, Porta R, et al. Acute exacerbations in patients with COPD: predictors of need for mechanical ventilation. Eur Respir J. 1996;9(7):1487-93. [pmid: 8836664].
Vitacca M, Clini E, Rubini F, et al. Non-invasive mechanical ventilation in severe chronic obstructive lung disease and acute respiratory failure: short- and long-term prognosis. Intensive Care Med. 1996;22(2):94-100. [pmid: 8857115].
Vitacca M, Foglio K, Scalvini S, et al. Time course of pulmonary function before admission into ICU. A two-year retrospective study of COLD patients with hypercapnia. Chest. 1992;102(6):1737-41. [pmid: 1446481].
Vitacca M, Rubini F, Foglio K, et al. Non-invasive modalities of positive pressure ventilation improve the outcome of acute exacerbations in COLD patients. Intensive Care Med. 1993;19(8):450-5. [pmid: 8294627].
Vollmer W M, Johnson L R, McCamant L E, et al. Methodologic issues in the analysis of lung function data. J Chronic Dis. 1987;40(11):1013-23. [pmid: 3498737].
Waldhorn R E. Nocturnal nasal intermittent positive pressure ventilation with bi-level positive airway pressure (BiPAP) in respiratory failure. Chest. 1992;101(2):516-21. [pmid: 1735282].
Warren P M, Flenley D C, Millar J S, et al. Respiratory failure revisited: acute exacerbations of chronic bronchitis between 1961–68 and 1970–76. Lancet. 1980;1(8166):467-70. [pmid: 6102193].
Watson P B, Town G I, Holbrook N, et al. Evaluation of a self-management plan for chronic obstructive pulmonary disease. Eur Respir J. 1997;10:1267-71. [pmid: 9192927].
Weber E J, Levitt M A, Covington J K, et al. Effect of continuously nebulized ipratropium bromide plus albuterol on emergency department length of stay and hospital admission rates in patients with acute bronchospasm. A randomized, controlled trial. Chest. 1999;115(4):937-44. [pmid: 10208189].
Wedzicha JA. Non-invasive ventilation for exacerbations of respiratory failure in chronic obstructive pulmonary disease. Thorax 1996;S35–9.
Weill H, George R, Munsakul N, et al. Management of acute respiratory failure in chronic obstructive pulmonary disease. South Med J. 1970;63(1):90-5. [pmid: 5415808].
Weiss S M, Hudson L D. Outcome from respiratory failure. Crit Care Clin. 1994;10(1):197-215. [pmid: 8118729].
Weitzenblum E, Hirth C, Ducolone A, et al. Prognostic value of pulmonary artery pressure in chronic obstructive pulmonary disease. Thorax. 1981;36(10):752-8. [pmid: 7330793].
Whittemore A S, Perlin S A, DiCiccio Y. Chronic obstructive pulmonary disease in lifelong nonsmokers: results from NHANES. Am J Public Health. 1995;85(5):702-6. [pmid: 7733432]. [pmcid: 1615439].
Wilson R. The role of infection in COPD. Chest. 1998;113(4 Suppl):242S-8S. [pmid: 9552013].
Winter J H, Buckler P W, Bautista A P, et al. Frequency of venous thrombosis in patients with an exacerbation of chronic obstructive lung disease. Thorax. 1983;38(8):605-8. [pmid: 6612652].
Wollmer P, Ursing K, Midgren B, et al. Inefficiency of chest percussion in the physical therapy of chronic bronchitis. Eur J Respir Dis. 1985;66(4):233-9. [pmid: 4018176].
Wood-Baker R, Walters EH. The role of corticosteroids in acute exacerbations of Chronic Obstructive Pulmonary Disease (Cochrane Review). In: the Cochrane Library. Issue 4 edition. Oxford: Update Software, 1998.
Wrenn K, Slovis C M, Murphy F, et al. Aminophylline therapy for acute bronchospastic disease in the emergency room. Ann Intern Med. 1991;115(4):241-7. [pmid: 1854108].
Wu A W, Damiano A M, Lynn J, et al. Predicting future functional status for seriously ill hospitalized adults. The SUPPORT prognostic model. Ann Intern Med. 1995;122(5):342-50. [pmid: 7847645].
Wysocki M, Tric L, Wolff M A, et al. Noninvasive pressure support ventilation in patients with acute respiratory failure. Chest. 1993;103(3):907-13. [pmid: 8449090].
Wysocki M, Tric L, Wolff M A, et al. Noninvasive pressure support ventilation in patients with acute respiratory failure. A randomized comparison with conventional therapy. Chest. 1995;107(3):761-8. [pmid: 7874950].
Yang S C, Yang S P, Lee T S. Nebulized ipratropium bromide in ventilator-assisted patients with chronic bronchitis. Chest. 1994;105:1511-5. [pmid: 8181345].
Yarnell P R, Chu N S. Focal seizures and aminophylline. Neurology. 1975;25(9):819-22. [pmid: 808758].
Yohannes A M, Roomi J, Waters K, et al. Quality of life in elderly patients with COPD: measurement and predictive factors. Respir Med. 1998;92(10):1231-6. [pmid: 9926154].
Yusen R D, Haraden B M, Gage B F, et al. Criteria for outpatient management of proximal lower extremity deep venous thrombosis. Chest. 1999;115(4):972-9. [pmid: 10208194].
Zanotti E, Rubini F, Iotti G, et al. Elevated static compliance of the total respiratory system: early predictor of weaning unsuccess in severe COPD patients mechanically ventilated. Intensive Care Med. 1995;21(5):399-405. [pmid: 7665749].
Zehner W J Jr, Scott J M, Iannolo P M, et al. Terbutaline vs albuterol for out-of-hospital respiratory distress: randomized, double-blind trial. Acad Emerg Med. 1995;2(8):686-91. [pmid: 7584746].
Zema M J, Masters A P, Margouleff D. Dyspnea: the heart or the lungs? Differentiation at bedside by use of the simple Valsalva maneuver. Chest. 1984;85(1):59-64. [pmid: 6690252].
Zielinski J, MacNee W, Wedzicha J, et al. Causes of death in patients with COPD and chronic respiratory failure. Monaldi Arch Chest Dis. 1997;52(1):43-7. [pmid: 9151520].