# Introduction

## Purpose and Scope of Report

This report provides an assessment of the evidence currently available regarding acute exacerbation of chronic obstructive pulmonary disease (COPD). It covers acute exacerbation only and excludes from consideration conditions such as chronic COPD without exacerbation, asthma, cystic fibrosis, and bronchiectasis. The report describes the methodology used to search for, screen, abstract, and assess the quality of published research on this condition. It also provides the results of our analysis, conclusions, and recommendations for future research. The evidence is summarized in the attached evidence tables.

## Incidence/Prevalence

COPD is the fourth leading cause of death in the United States. Affecting 16 million people, it accounts for 13,760,000 office visits and 297,000 hospitalizations annually, at a cost of $18 billion (U.S. Department of Commerce, 1997). Causes of COPD include smoking (85–90 percent of all cases), genetic factors (alpha-1 antitrypsin deficiency), passive smoking (children), occupational exposures, air pollution, and hyperresponsive airways (U.S. Department of Health and Human Services, 1986; Whittemore, Perlin, and DiCiccio, 1995) . The prevalence of COPD is likely to increase in the near future as the population of former and current smokers ages (The National Lung Health Education Program [NLHEP], 1998).

The most important clinical feature related to COPD prevention is tobacco smoking status. Primary and secondary prevention of COPD are aimed at patient education and smoking cessation. The National Heart, Lung, and Blood Institute (NHLBI) recently called for a national agenda to concentrate on the primary prevention of COPD, emphasizing the need for smoking cessation and early detection (Petty and Weinmann, 1997). Tertiary prevention of COPD—that is, prevention of acute exacerbation in patients with COPD—includes patient education and pulmonary rehabilitation (Tiep, 1997). These issues are beyond the scope of this report.

## Natural History of Chronic Obstructive Pulmonary Disease

The natural history of moderate to severe COPD is punctuated by acute exacerbations (also known as “flares”), in which worsening symptoms of dyspnea and an increase in the amount or purulence of sputum may be accompanied by chest discomfort, fever, and other constitutional symptoms. The natural history of COPD has been well described in several long-term prospective studies, as reviewed by Anthonisen, Wright, and Hodgkin (1986). These studies agree that the degree of airways obstruction is closely related to subsequent survival. However, they provide few data on the incidence of exacerbations or of acute respiratory failure

(ARF)—a potentially life-threatening episode of hypoxemia and/or respiratory acidosis—in patients with previously stable COPD. In patients presenting with acute exacerbations of COPD, there is a wide range in frequency of previous exacerbations; patients with histories of more frequent exacerbations are at greater risk of both relapse (short-term) (Ball, Harris, Lowson, et al., 1995) and a higher frequency of exacerbations in the future (long-term) (Grossman, Mukherjee, Vaughan, et al., 1998). Furthermore, the frequency of acute exacerbation episodes is related to the baseline severity and duration of COPD (Grossman, Mukherjee, Vaughan, et al., 1998).

Acute exacerbation, particularly severe exacerbation associated with ARF, has been shown to lead to an increase in short-term mortality. The first episode of ARF is generally believed to be a hallmark of the late stage of disease (Gottlieb and Balchum, 1973), which is more often defined by forced expiratory volume in 1 second (FEV_1_) < 35 percent predicted (Table 1). However, there is controversy about whether the long-term prognosis of patients following recovery from ARF is worse than that in patients with stable COPD and similar degrees of airway obstruction (Hudson, 1989).

Table 1. Clinical staging of COPD - ATS 1995 guidelines^1^

Stage | FEV_1_
I | ≥ 50%
II | 35–49%
III | < 35%

1 Source: American Thoracic Society. Standards for the diagnosis and care of patients with chronic obstructive pulmonary disease. Am J Respir Crit Care Med 1995;152(5 Pt 2):S77–121.

ATS = American Thoracic Society; COPD = chronic obstructive pulmonary disease; FEV_1_ = forced expiratory volume in 1 second.

## Burden of Illness

Acute exacerbation of COPD is associated with an increased short-term mortality rate compared with stable COPD. The mortality rate in patients requiring intensive care unit (ICU) treatment for respiratory failure has been described as 11 to 24 percent in the hospital, and 43 to 59 percent over 1 year. In patients who were hospitalized but not admitted to the ICU, the short-term mortality rate associated with COPD exacerbation also is substantial; however, the long-term mortality rate after recovery from the acute exacerbation may not be affected (Hudson, 1989).

In patients who survive exacerbations of COPD, there is evidence of important decrements in functional status and quality of life (QOL). Functional status following exacerbation is substantially worse than preexacerbation in as many as one-third of the patients, and many remain incapacitated for several months (Peach and Pathy, 1981; Wu, Damiano, Lynn, et al., 1995). QOL in patients with acute exacerbations of COPD also is related to the frequency of exacerbations. In one study, QOL was worse in those with frequent exacerbations than in those with less frequent exacerbations, even though symptoms and physiological parameters were similar (Seemungal, Donaldson, Paul, et al., 1998).

The utilization of health care resources by patients with COPD is immense, both during hospitalization and after discharge. Frequency and length of hospitalization increase as patients grow older. The discharge rate to an independent-living facility diminishes as age increases. In 1991, 131,974 Medicare beneficiaries were hospitalized for exacerbations of COPD for a median, length of stay (LOS) of 6 days, at an average charge of $8,876 per hospitalization (Cydulka, McFadden, Emerman, et al., 1997). Readmission following hospitalization for acute exacerbation of COPD is frequent. In one study, nearly half of discharged patients were readmitted at an average of nearly two times in the 6 months after discharge (Connors, Dawson, Thomas, et al., 1996). Acute exacerbations of COPD also account for a large share of outpatient services. Dyspnea or shortness of breath was the sixth most frequent cause for emergency department (ED) visits in a 1992 study (McCaig, 1994). Patients with exacerbations of underlying COPD accounted for 15 to 25 percent of ED visits for dyspnea in various studies (Fedullo, Swinburne, and McGuire-Dunn, 1986; Parshall, 1999).

The severity of underlying (baseline) respiratory function substantially influences mortality from acute exacerbation and mortality following hospital discharge. Age, though not associated with short-term mortality in acute exacerbation, is associated with long-term outcomes. Comorbid conditions, particularly heart diseases, are common in patients with COPD and contribute substantially to the mortality of patients with acute exacerbations (Antonelli Incalzi, Fuso, De Rosa, et al., 1997)

## Disease Biology

Acute exacerbation of COPD is often thought to be caused by respiratory infections, either viral or bacterial. However, there is considerable controversy about the importance of bacterial infection. The respiratory tract of persons with COPD may be colonized by many bacteria that are usually considered pathogens in normal hosts (Murphy and Sethi, 1992). The most commonly found bacteria are Haemophilus influenzae (22 percent), Pseudomonas aeruginosa (15 percent), Streptococcus pneumoniae (10 percent), Moraxella catarrhalis (9 percent), and various nonpathogenic gram-negative bacteria (Miravitlles, Espinosa, Fernandez-Laso, et al., 1999). However, the bacteria isolated from sputum are usually determined, using clinical criteria, to not be the cause of exacerbation (Eller, Ede, Schaberg, et al., 1998).

Sputum from patients with lower FEV_1_ is more likely to grow Pseudomonas aeruginosa and Haemophilus influenzae, while patients with higher FEV_1_ are more likely to yield Streptococcus pneumoniae and nonpathogenic microorganisms.

## Pertinent Clinical Features

This section describes clinical features relating to diagnosis, clinical assessment, and treatment of acute exacerbations of COPD. The target populations and practice settings also are described.

## Diagnosis

Clinical features pertinent to diagnosis in patients with acute exacerbations of COPD include those related to the diagnosis of: underlying COPD, acute exacerbation, and other causes for respiratory decompensation. The clinical features pertinent to the diagnosis of underlying COPD are patient history (identifying risk factors and symptoms), physical examination, and laboratory studies. The pulmonary function test (PFT) is the most important diagnostic test. Typical PFT abnormalities include a decreased FEV_1_, decreased FEV_1_/forced vital capacity (FVC) ratio, and increased residual volume (RV) and total lung capacity (TLC); a decreased diffusing capacity of lung for carbon monoxide (DLCO) may be seen, particularly in emphysema. Arterial blood gases (ABGs) typically show a widened alveolar-arterial diffence in PO_2_ gradient or respiratory acidosis with hypercapnia. Chest radiographs characteristically show hyperinflation, particularly in emphysema, but they are not required for diagnosis of COPD.

The most important clinical feature in the staging of COPD is the degree of airway obstruction. Of three staging systems for chronic, stable COPD, two (European Respiratory Society and American Thoracic Society) use FEV_1_ as the sole factor (Tables 1 and 2). The British Thoracic Society (BTS) scale uses more clinical features, but the validity of this scale or of the individual clinical features has not been established (Table 3).

Table 2. Clinical staging of COPD - European Respiratory Society, 1995^1^

Stage | FEV_1_(% of predicted value)
Mild | ≥ 70%
Moderate | 50–69%
Severe | < 50%

1 Source: Adapted with publisher's permission from: Siafakas NM, Vermeire P, Pride NB, et al. Optimal assessment and management of chronic obstructive pulmonary disease (COPD). The European Respiratory Society Task Force. Eur Respir J 1995;8(8):1398–420.

COPD = chronic obstructive pulmonary disease; FEV_1_ = forced expiratory volume in 1 second.

Table 3. Clinical staging of COPD - British Thoracic Society^1^

Clinical State | Mild | Moderate | Severe
FEV_1_ | 60–80% predicted | 40–59% predicted | < 40% predicted
Cough | +/- | + | +++
Sputum | - | +/- | ++
Dyspnea | Nl/+ | +/++ | ++
Lung sounds | Nl | ↓air movement; wheezes with exertion | ↓↓air movement
| | | ++ wheezes
Other | Nl | Nl | Cyanosis
| | | Peripheral edema
| | | Polycythemia

1 Source: Adapted with publisher's permission from: The COPD Guidelines Group of the Standards of Care Committee of the BTS. BTS guidelines for the management of chronic obstructive pulmonary disease. Thorax 1997;52(Suppl):123S-63S.

BTS = British Thoracic Society; COPD = chronic obstructive pulmonary disease; FEV_1_ = forced expiratory volume in 1 second.

The diagnosis of acute exacerbation of COPD involves distinguishing the etiology of worsening respiratory symptoms. This involves a conceptual distinction between conditions that may trigger a COPD exacerbation (e.g., infection) and other conditions that may cause worsening respiratory function in patients with underlying COPD (e.g., pneumothorax or pulmonary embolus). In practice, this evaluation is based primarily on symptoms. Acute exacerbations are usually described as worsening symptoms of dyspnea and an increase in the amount or purulence of sputum, sometimes accompanied by chest discomfort, increased cough, fever, and other constitutional symptoms. Various definitions for acute exacerbation of COPD have been proposed, and most focus on the following elements: increased symptoms of dyspnea, increased sputum production, and increased sputum purulence.

The most widely cited scale for grading the severity of acute exacerbations was developed for and validated in a 1987 study on the efficacy of antibiotics in acute exacerbation of COPD (Anthonisen, Manfreda, Warren, et al., 1987). Often referred to as the “Winnipeg Criteria,” this scale combines the pertinent symptoms into three categories:

- Type-1 exacerbation. All of the following symptoms are present: increased dyspnea, sputum volume, and sputum purulence.
- Type-2 exacerbation. Two Type-1 symptoms are present.
- Type-3 exacerbation. At least one Type-1 symptom is present plus upper respiratory infection (sore throat, nasal discharge) within the past 5 days; fever without other cause; increased wheezing; increased cough; or increase in respiratory rate or heart rate by 20 percent as compared with baseline.

In the initial study, the scale was associated with response to antibiotic treatment, suggesting that the scale is valid; however, a subsequent cohort study failed to show an association with relapse after outpatient treatment (Ball, Harris, Lowson, et al., 1995).

The diagnosis of other conditions that cause worsening of respiratory function in patients with COPD, such as pneumonia, pneumothorax, and pulmonary embolus, is based on distinct clinical features related to each condition. These clinical features comprise elements of history, physical, and laboratory evaluation. Additional conditions include oversedation, uncontrolled oxygen flow, and noncompliance with medications.

## Treatment/Management

Treatment of COPD can be divided into two categories: managing the chronic airflow obstruction and managing acute exacerbations. In 1995, the American Thoracic Society (ATS) issued a consensus statement, “Standards for the Diagnosis and Care of Patients with Chronic Obstructive Pulmonary Disease” (American Thoracic Society, 1995), which serves as the current standard of care for COPD in the United States. Several other guidelines have been developed by the BTS (The COPD Guidelines Group of the Standards of Care Committee of the BTS, 1997), the European Respiratory Society (Siafakas, Vermeire, Pride, et al., 1995), and a Canadian consensus conference (Balter, Hyland, Low, et al., 1994).

The ATS statement is divided into outpatient and inpatient disease management. Outpatient management is aimed at alleviating the effects of chronic airflow obstruction through the use of inhaled bronchodilators, antiinflammatory agents, and oxygen. Treatment of acute exacerbations addresses both initial outpatient and then inpatient treatment suggestions. Outpatient management of acute exacerbations focuses on treatment of the cause (usually infection) and intensification of chronic therapy (including the addition of steroids). Inpatient management is reserved for patients who have “failed” outpatient management of the acute exacerbation. The algorithm for inpatient care starts with further increasing outpatient medications (bronchodilators), then adding steroids, antibiotics, and other therapies, such as positive pressure ventilation, if deemed necessary. The NHLBI recently endorsed the ATS consensus statement (Petty and Weinmann, 1997).

Antibiotics are commonly used for the treatment of acute exacerbation of COPD, despite controversy over the role of bacterial infection. A meta-analysis of placebo-controlled trials (Saint, Bent, Vittinghoff, et al., 1995) supports their efficacy. Selection among antibiotic agents has little empirical basis despite an enormous number of trials comparing new and traditional antimicrobial agents. Such comparator trials were designed to prove equivalence to meet regulatory requirements and generally lacked the statistical power to show superiority of one agent over another (Ball, 1995; Grossman, Mukherjee, Vaughan, et al., 1998).

Perhaps the most pertinent clinical features in determining treatment relate to whether and how aggressively to treat. Certain clinical features may direct a clinician to treat with one form of therapy versus another. For example, purulent sputum may suggest antibiotic treatment, while wheezing may dictate bronchodilator treatment. Severity of illness also may determine how aggressively an episode of acute exacerbation is treated. While a mild exacerbation might be treated with a limited change in therapy, a more severe exacerbation may receive many interventions. Furthermore, patients at significant risk for respiratory failure may be hospitalized rather than treated as outpatients.

## Noninvasive Positive Pressure Ventilation

Inpatients with severe episodes of acute exacerbation, who are in ARF, are considered candidates for NPPV. The decision to use NPPV is generally based on evidence of respiratory insufficiency and the ability of patients to cooperate.

## Target Populations

Two populations are the targets of this report. First, for questions of diagnosis, we consider patients with known diagnoses of COPD who have symptoms of acute exacerbation (i.e., increased shortness of breath, increased sputum production, or [increased] sputum purulence), and we include those who have other causes (e.g., pneumonia, congestive heart failure [CHF], pulmonary embolus, or pneumothorax) as the etiology of exacerbation of their symptoms. For questions related to prognosis and treatment, we consider patients in whom these other causes of exacerbation have been ruled out.

These target populations are consistent with the widely cited Winnipeg criteria for diagnosing and grading the severity of acute exacerbation of COPD (Anthonisen, Manfreda, Warren, et al., 1987). We presume for the purpose of this report that most cases of exacerbation are due to infection, but we will not limit the target population to those patients with infection as the suspected etiology. Because pneumonia is an acute infectious complication that is a frequent cause of exacerbation in patients with COPD, patients with pneumonia and COPD will be considered part of the target population for prognosis and treatment.

Excluded from the target populations are patients requiring mechanical ventilation (MV) at the time of presentation; patients requiring chronic MV; patients with tracheostomies, asthma, bronchiolitis obliterans with organizing pneumonia, bronchiolitis obliterans, bronchiectasis, or cystic fibrosis; and patients who are immunocompromised due to lung cancer, human immunodeficiency virus/acquired immunodeficiency syndrome (HIV/AIDS), chemotherapy, or radiation therapy.

## Practice Settings

The practice settings that this report focuses on are clinical settings for acute unscheduled urgent or emergency medical care such as urgent care centers, EDs, or hospitals. These centers can assess and observe patients during treatment over a prolonged period, and they have equipment available to deliver inhaled and intravenous (IV) treatments and, possibly, noninvasive or invasive ventilation. At the suggestion of our advisory panel, our practice settings also include office-based practices and telephone and self-care settings.