# Appendix C. Acronyms and Abbreviations Used in Report

ABG | arterial blood gas
ACCP | American College of Chest Physicians
ACP-ASIM | American College of Physicians-American Society for Internal Medicine
ACV | assist control ventilation
AHRQ | Agency for Healthcare Research and Quality
APACHE | Acute Physiology and Chronic Health Evaluation
ARF | acute respiratory failure
ASG | admitting severity group
ATS | American Thoracic Society
BMI | body mass index
BTS | British Thoracic Society
CBC | complete blood count
CCTR | Cochrane Controlled Trials Register
CHF | congestive heart failure
CI | confidence interval
CINAHL | Cumulative Index to Nursing and Allied Health
COPD | chronic obstructive pulmonary disease
CPAP | continuous positive airway pressure
CXR | chest roentgenography
dL | deciliter
DLCO | decreased diffusing capacity of lung for carbon monoxide
DVT | deep venous thrombosis
ECG | electrocardiogram
ED | emergency department
EHOV | external high-frequency oscillatory ventilation
EPAP | expiratory positive airway pressure
EPC | Evidence-based Practice Center
FEV_1_ | forced expiratory volume in 1 second
FiO_2_ | fraction of inspired oxygen
FVC | forced vital capacity
HealthSTAR | Health Services, Technology, and Research
HIV/AIDS | human immunodeficiency virus/acquired immunodeficiency syndrome
HRQL | health-related quality of life
ICU | intensive care unit
IPAP | inspiratory positive airway pressure
IV | intravenous
kg | kilogram
L | liter
LOS | length of stay
MDI | metered-dose inhaler
MeSH | Medical Subject Heading
mg | milligram
min | minute
mm Hg | millimeters of mercury
MV | mechanical ventilation
NHAMCS | National Hospital Ambulatory Care Survey
NHLBI | National Heart, Lung, and Blood Institute
NIV | noninvasive ventilation
NLHEP | National Lung Health Education Program
NNPV | noninvasive negative pressure ventilation
NPPV | noninvasive positive pressure ventilation
NPSV | nasal pressure support ventilation
O_2_ | oxygen
OR | odds ratio
p | probability
PaCO_2_ | partial pressure of carbon dioxide, arterial
PaO_2_ | partial pressure of oxygen, arterial
PA-aO_2_ | alveolar-arterial difference in partial pressure of oxygen
PCO_2_ | partial pressure of carbon dioxide
PE | pulmonary embolism
PEEP | positive end-expiratory pressure
PEFR | peak expiratory flow rate
PFT | pulmonary function test
pH | hydrogen ion concentration
PMN | polymorphonuclear
PSV | pressure-support ventilation
QOL | quality of life
r | correlation coefficient
RCT | randomized controlled trial
ROC | receiver operating characteristic (curve)
RV | residual volume
SCCOPE | Systemic Corticosteroids in Chronic Obstructive Pulmonary Disease Exacerbations
SUPPORT | Study to Understand Prognoses and Preferences for Outcomes and Risks of Treatments
TLC | total lung capacity
WBC | white blood cell (count)
μg/mL | micrograms per milliliter
μmol/L | micromoles per liter